# Results

## Overview of the RCTs of Screening

Eight main RCTs of mammography screening provide outcomes that address several key questions for this review. Trials involving over 600,000 women have been conducted in the United States, Canada, United Kingdom, and Sweden. These include the Health Insurance Plan of Greater New York (HIP) trial,74 Canadian Breast Cancer Screening Study 1 (CNBSS-1),75,76 Canadian Breast Cancer Screening Study 2 (CNBSS-2),77,78 United Kingdom Age trial,79 and four from Sweden, including the Stockholm trial,80 Malmö Mammographic Screening Trial (referred to separately as MMST I and MMST II),81 Gothenburg trial,82 and Swedish Two-County Study (referred to separately as Östergötland and Kopparberg).83 All of these trials met criteria for fair quality and were included in this report. An additional trial, the Edinburgh trial,84,85 was not included in this review because of its inadequate randomization, introducing high risk of bias and limiting any inferences.

Updates of three trials provided new data for this report,69,70,86 although only the Canadian and Age trials provided published results that were stratified by age groups.69,86 Age-stratified results for the Swedish Two-County Study were provided by the trial investigators (Dr. Lászlo Tabár personal communication).

Trials varied in their recruitment of participants, screening protocols, control groups, and sizes (Table 4). The HIP trial used direct-exposure film mammography, while all of the other trials used screen-film mammography, and none evaluated digital mammography or tomosynthesis. Five trials examined the effectiveness of screening among women between the ages of 40 and 74 years;74,80-84 two trials enrolled only women in their 40s;75,79 and one enrolled only women in their 50s.77 The four trials from Sweden and the Age trial from the United Kingdom evaluated mammography alone, and the other trials evaluated the combination of mammography and CBE. Overviews of the Swedish trials providing outcome data have also been published.87,88 The overviews addressed several important study limitations of the Swedish trials including reassessing causes of death in the Swedish Two-County Study with a blinded independent end point committee.

Table 4 Mammography Screening Trials

Trial (references) | Year trial began | Setting/population (screening, n; control, n)^*^ | Method of randomization | Comparison groups | Interval, months | Rounds, n | Views, n | Adherence, % | Duration, years | Longest followup, years | USPSTF quality rating; limitations
HIP90,95,128, 131 | 1963 | New York health plan members age 40-64 (30,239; 30,765) | Age and family size stratified pairs of women were individually randomized by drawing from a list | M + CBE vs. UC | 12 | 4 | 2 | 46 | 4 | 18 | Fair^†,‡,§^
CNBSS-1; CNBSS-2║69, 76,78 | 1980 | Self-selected participants from 15 centers in Canada age 40-49 (CNBSS-1; 25,214; 25,216) and 50-59 (CNBSS-2; 19,711; 19,694) | Individual within blocks stratified by center and 5-year age group after CBE | M + CBE vs. UC (all women prescreened with CBE and instructed in BSE); women 50-59 UC involved annual CBE; all age ≥50 offered screening after trial completed | 12 | 4-5 | 2 | 85 | 4.5 | 25 | Fair^†^
Gothenburg 82,241,242 | 1982 | All women age 39-59 born between 1923 to 1944 living in Gothenburg, Sweden (21,650; 29,961) | Cluster, based on day of birth for 1923 to 1935 cohort (18%), by individual for 1936 to 1944 cohort (82%) | M vs. UC; controls offered screening after 5 years, trial completed after approximately 7 years | 18 | 5 | 1-2 | 75 | 9 | 12 | Fair^†,‡,¶^
Stockholm80, 243 | 1981 | Residents age 40-64 from southeast greater Stockholm, Sweden (40,318; 19,943) | Individual, by day of month; ratio of screening to control group 2:1 | M vs. UC; controls screened after 5 years | 24-28 | 2 | 1 | 81 | 4.8 | 11.4 | Fair^†^
Malmö I & II 81, 244,245 | 1976- 1978 | All women age 43-69 born between 1908 to 1945 living in Malmo, Sweden (MMST I=21,088; 21,195, MMST II=9,581; 8,212) | Individual, within birth year | M vs. UC; controls offered screening after year 14 | 18-24 | 9 | 1-2 | 70 | 10+ | 11-13; 15.5 | Fair^†,‡,¶^
Swedish Two-County 83,246, 247 | 1977 | Women age 40-70 from Ostergotland and Kopparberg counties in Sweden (77,080; 55,985) | Clusters, based on geographic units; blocks designed to be demographically homogeneous | M vs. UC; controls offered screening after year 7 | 24-33 | 3 | 1 | 84 | 7 | 20; 15.5 | Fair^†^
Age║79,86 | 1991 | Women age 39-41 from 23 National Health Service breast screening units in England, Scotland, and Wales (53,884; 106,956) | Individual stratified by general practitioner group with random number generation 1991 to 1992; 1992 onwards randomization via Health Authority computer system | M vs. UC; all women offered screening at ages 50-52 | 12 | 4-6, varied by center | 2 | 57 | 9 | 13 | Fair^‡,¶^

* Numbers of participants in screening and control groups vary by publication.

† Generally effective randomization and comparable groups are assembled initially, but some question remains whether some, although not major, differences occurred in followup.

‡ Important differential loss to followup or overall high loss to followup; adherence <80%.

§ Numbers of participants in screening and control groups vary by publication.

║ New data since prior recommendation.

¶ Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination).

Abbreviations: BSE=breast self-examination; CBE=clinical breast examination; CNBSS=Canadian National Breast Screening Studies; HIP=Health Insurance Plan of New York; M=mammography; MMST=Malmö Mammographic Screening Trial; n=number; UC=usual care; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

Five trials were randomized at the individual participant level (CNBSS-1, CNBSS-2, HIP, Age, Stockholm, and Malmö); one trial used individual (82%) and cluster (18%) randomization (Gothenburg); and two trials used cluster randomization by community (Swedish Two-County). Breast cancer mortality was the main outcome measure, and all trials evaluated differences between the screening and control groups on an intention-to-screen basis. Seven studies randomized women to an invitation to screening or control group receiving “usual care” at the time the study was conducted. Usual care generally did not include screening mammography, or only at specific age thresholds.

The two Canadian trials enrolled volunteers who underwent a pre-examination with CBE before randomization to the intervention or control groups. The Swedish trials randomized women according to communities. The Age trial recruited women from general practice lists, and the HIP trial recruited women enrolled in a health insurance plan.

The Gothenburg, Stockholm, Malmö, Swedish Two-County, Age, and HIP trials included DCIS in their breast cancer case reporting, while the Canadian trials included only invasive breast cancer in the latest update. All of the trials provided information on the stage, size, or lymph node involvement of cases; however, these outcomes were reported differently across the trials using various descriptions and levels of severity.

Trials differed in their methods of accrual of breast cancer cases and deaths, influencing the analysis of outcomes. Two methods are provided in this report to help explain discrepancies between estimates (Figure 4). The long case accrual method counts all of the breast cancer cases contributing to breast cancer deaths diagnosed during the screening intervention period plus the followup period. This method has been referred to as the “followup” method of analysis by some investigators. While this method includes the most cases, it has the potential to dilute a true benefit because participants from the control group are also screened after the study intervention period ends.

Figure 4 Methods of Case Accrual in Trials

Comparison of Accrual Methods
Short case accrual (B) | Includes desths occuring among cases diagonsed during the screening intervention period (A), and in some trials, within an additional defined case accrual period. | - Includes fewer cases; - Reduces contamination of control group if screened during followup; - Can introduce bias in the absense of concurrent screening after the intervention
Long case accrual (C) | Includes deaths occuring among cases diagnosed during the screening intervention period plus the followup period (A+D). | - Includes more cases.; - Potential to dilute a true benefit because participants from the control group may be screened after the study intervention period has ended.

Figure 4 is a graphic depicting the different methods of case accrual in the trials. The figure shows that short case accrual includes deaths occurring among cases diagnosed during the screening intervention period, and for some trials, within an additional defined case accrual period. The short accrual method includes fewer cases, reduces contamination of control group if screened during followup and potentially introduces bias in the absence of concurrent screening after the intervention. The long case accrual method includes deaths among cases diagnosed during the screening intervention period plus the followup period. The long case accrual method includes more cases and has the potential to dilute a true benefit because participants from the control group may be screened after the study intervention period has ended. Additional information on case accrual in the screening trials can be found in the report on page 14.

The short case accrual method includes only deaths occurring among cases of breast cancer diagnosed during the screening intervention period, and in some trials, within an additional defined case accrual period. This has been referred to as the “evaluation method” of analysis by some investigators. This method always involves the evaluation of fewer breast cancer cases for mortality outcomes because the duration of case accrual is shorter than for the long case accrual period. This method reduces the risk of contamination in the control group after the screening phase of a trial is completed, but in the absence of concurrent screening, it can introduce bias.

The applicability of the screening trials to current populations and practice has likely decreased over time. All of the trials were conducted in the past when imaging technologies and breast cancer therapies were markedly different than today.34 Only the HIP trial enrolled women in the United States, however, this trial began 50 years ago. Only women in the Canadian and Age trials, and some women in the Malmö trial, had access to current adjuvant chemotherapies for breast cancer.

In general, women who enroll in trials and attend screening interventions differ from those who do not, underscoring the importance of intention-to-screen analysis to evaluate outcomes. Two trials (HIP, Stockholm) evaluated the differences between women randomized to the intervention group who chose to be screened (attendees) compared with those who did not. In these trials, attendees had higher risks of breast cancer and lower risks of all-cause mortality than non-attendees.89,90 In the Canadian trials that recruited volunteers from several communities, participants were more educated, had lower parity, and had overall higher risks of breast cancer compared with the general population.75,77 These findings indicate that women at higher risk of breast cancer but lower risk of all-cause mortality may choose to participate in screening. These are important differences that could influence outcomes.

## Key Question 1 What Is the Effectiveness of Routine Mammography Screening in Reducing Breast Cancer–Specific and All-Cause Mortality, and How Does It Differ by Age, Risk Factor, and Screening Interval?

### Summary

#### Randomized Trials of Screening

- Updated results from the CNBSS-1, CNBSS-2, Age, and Swedish Two-County Study trials provided breast cancer mortality outcomes with longer followup than the previous review.
- For women age 39 to 49 years, a meta-analysis of trials comparing mammography screening with nonscreening indicated a combined RR of 0.88 (95% confidence interval [CI], 0.73 to 1.003; 9 trials) using the long case accrual method; and 0.84 (95% CI, 0.70 to 1.002; 9 trials) with short case accrual. The absolute mortality reduction (deaths prevented) with screening was 4 per 10,000 women over 10 years.
- For age 50 to 59 years, the combined RR was 0.86 (95% CI, 0.68 to 0.97; 7 trials) with long case accrual; and 0.86 (95% CI, 0.69 to 1.007; 7 trials) with short case accrual. The absolute mortality reduction with screening was 5 to 8 per 10,000 women over 10 years.
- For age 60 to 69 years, the combined RR was 0.67 (95% CI, 0.54 to 0.83; 5 trials) with long case accrual; and 0.67 (95% CI 0.55 to 0.91; 5 trials) with short case accrual. The absolute mortality reduction (deaths prevented) with screening was 12 to 21 per 10,000 women over 10 years.
- Breast cancer mortality for women age 70 to 74 years was not statistically significantly different between randomized groups in the screening trials, but estimates were limited by low numbers of events from trials that had smaller sample sizes of women in this age group.
- All-cause mortality did not differ between randomized groups in meta-analyses of trials, regardless of whether trials were analyzed in combined or separate age groups.
- No RCTs evaluated breast cancer mortality or all-cause mortality outcomes on the basis of risk factors besides age.
- There are no head-to-head trials of different screening intervals and existing trials do not provide enough information to determine the specific effects of screening intervals.

#### Observational Studies

- Observational studies of the effectiveness of population-based mammography screening on breast cancer mortality reported a wide range of reductions in breast cancer death. Most studies were conducted in Europe or the United Kingdom and included women age 50 to 69 years.
- Meta-analyses from recent reviews from the EUROSCREEN Working Group indicated 25 to 31 percent mortality reduction for women invited to screening in the screening programs. This compares to 19 to 22 percent reduction for women age 50 to 69 years in the meta-analysis of screening RCTs that used intention-to screen analysis.
- The only U.S observational study of breast cancer mortality reduction is a record review that indicated no differences in breast cancer deaths between screened versus non-screened women older than age 80 years.91
- A large fair-quality study of the Mammography Screening of Young Women Cohort in Sweden indicated reduced risk for breast cancer deaths for women age 40 to 49 years invited to screening compared with women not invited (RR 0.74; 95% CI, 0.66 to 0.83).
- An observational study of Canadian women age 40 to 79 comparing screening program participants versus nonparticipants indicated reduced breast cancer mortality of 40 percent among participants.
- Two observational studies of screening intervals indicated no breast cancer mortality differences between annual and biennial screening for women 50 years or older, or between annual and triennial screening among women age 40 to 49 years.

### Evidence

#### Previous Reports

The 2002 evidence review for the USPSTF included a meta-analysis of the eight published RCTs of mammography screening and breast cancer mortality that were rated fair-quality.92,93 For all age groups combined, results of the meta-analysis indicated a RR for breast cancer mortality of 0.84 (95% credible interval [CrI], 0.77 to 0.91) for women randomly assigned to screening over 14 years of followup. For women age 40 to 49 years specifically, results indicated a RR of 0.85 (95% CrI, 0.73 to 0.99), while for women age 50 years and older, results indicated a RR of 0.78 (95% CrI, 0.70 to 0.87).

The 2009 evidence review for the USPSTF included new results from the Age trial and updated results from the Gothenburg trial in addition to the previous trials, and provided meta-analysis estimates for breast cancer mortality according to four age groups.44,94 For women age 39 to 49 years, the combined RR was 0.85 (95% CrI, 0.75 to 0.96); for 50 to 59 years, 0.86 (95% CrI, 0.75 to 0.99); for 60 to 69 years, 0.68 (95% CrI, 0.54 to 0.87); and for 70 to 74 years, 1.12 (95% CrI, 0.73 to 1.72).

Previous evidence reviews for the USPSTF did not address the effectiveness of screening in reducing all-cause mortality, or how mortality reduction differs by risk factors and screening intervals.

#### New Studies

##### Breast Cancer Mortality

RCTs with long case accrual methods. Seven RCTs provided breast cancer mortality outcomes by age using long case accrual methods. These included the Swedish Two-County (Kopparberg and Östergötland),83 Age,79 Gothenburg,82 HIP,95 and Canadian (CNBSS-1 and CNBSS-2)69 trials. The Malmö I, Malmö II, and Stockholm trials reported breast cancer mortality outcomes by age using only short case accrual.87 However, these results were included in the combined meta-analysis because they are the most inclusive results available. Quality ratings of these trials are described in previous reports. 92,93,94 Across all trials with long case accrual, the mean or median screening intervention time ranged from 3.5 to 14.6 years, case accrual time from 7.0 to 17.4 years, and followup time from 11.2 to 21.9 years.

For women age 39 to 49 years, a meta-analysis of nine RCTs using the longest case accrual available indicated a combined RR of 0.88 (95% CI, 0.73 to 1.003; I^2^=25.4%; p=0.218; Figure 5).69,82,83,86,87,95 The CIs of all nine trials crossed 1.0 as did the combined estimate.

Figure 5 Meta-Analysis of Effects of Screening Trials on Breast Cancer Mortality With Longest Case Accrual Available

* Uses short case accrual, but these are the most inclusive results available.

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study; HIP=Health Insurance Plan of Greater New York.

Figure 5 is a forest plot displaying the results of a meta-analysis of effects of screening trials on breast cancer mortality with longest case accrual available. The results of the figure are further described in the text of the report starting on page 16.

For age 50 to 59 years, a meta-analysis of seven trials using the longest case accrual available indicated a combined RR of 0.86 (95% CI, 0.68 to 0.97; I^2^=38.0%; p=0.139), consistent with a statistically significantly lower death rate in the screening group.69,82,83,87,95 Estimates from the Kopparberg83 and Stockholm87 trials indicated statistically significant differences between randomized groups favoring screening, while the CIs from the five other trials crossed 1.0.

For age 60 to 69 years, a meta-analysis of five trials using the longest case accrual available indicated a combined RR of 0.67 (95% CI, 0.54 to 0.83; I^2^=0%; p=0.739), consistent with a statistically significantly lower death rate in the screening group.83,87,95 In this age group, estimates from three Swedish trials (Kopparberg,83 Östergötland,83 and Malmö I87) indicated statistically significant differences between randomized groups favoring screening, while the CIs from the two other trials crossed 1.0. Combining results across the two age groups of women age 50 to 69 years indicated a RR of 0.78 (95% CI, 0.68 to 0.90; I^2^=41.0%; p=0.118).

Only three Swedish trials, Östergötland,83 Kopparberg,83 and Malmö I,87 provided outcomes for women age 70 to 74 years. The numbers of events in these trials were much lower than for other age groups, and none of the trials indicated statistically significant differences between randomized groups. A meta-analysis of the three trials using the longest case accrual available indicated a combined RR of 0.80 (95% CI, 0.51 to 1.28; I^2^=0%; p=0.962).

A sensitivity analysis that included results of a combined analysis of the Swedish trials (Malmö I, Malmö II, Stockholm, Östergötland, Gothenburg, Stockholm) that used a long case accrual (“followup”) method87 indicated reduced point estimates that diminished the effect of screening, although the statistical significance of the estimates did not change.

Results of the meta-analysis were used to determine absolute rates of breast cancer mortality reduction per 10,000 women screened for 10 years (Table 5). Using RRs from the long case accrual meta-analysis, the numbers of deaths reduced (prevented) included 4.1 (95% CI, -0.1 to 9.3) for age 39 to 49 years; 7.7 (95% CI, 1.6 to 17.2) for age 50 to 59 years; 21.3 (95% CI, 10.7 to 31.7) for age 60 to 69 years; and 12.5 (95% CI, -17.2 to 32.1) for age 70 to 74 years. Absolute reduction for the combined group of women age 50 to 69 was 12.5 (95% CI 5.9 to 19.5).

Table 5 Age-Specific Rates of Breast Cancer Mortality Reduction With Screening

Number of deaths prevented if 10,000 women were followed for 10 years

Age, years | Mortality rate in the control group per 100,000 person-years (95% CI)^*^ | Breast cancer mortality reduction RR (95% CI)^†^ | Deaths prevented with screening over 10 years (95% CI)
Long case accrual
39-49 | 34 (26 to 44) | 0.88 (0.73 to 1.003) | 4.1 (-0.1 to 9.3)
50-59 | 54 (50 to 58) | 0.86 (0.68 to 0.97) | 7.7 (1.6 to 17.2)
60-69 | 65 (52 to 81) | 0.67 (0.54 to 0.83) | 21.3 (10.7 to 31.7)
70-74 | 62 (48 to 80) | 0.80 (0.51 to 1.28) | 12.5 (-17.2 to 32.1)
50-69 | 58 (55 to 62) | 0.78 (0.68 to 0.90) | 12.5 (5.9 to 19.5)
Short case accrual
39-49 | 23 (16 to 32) | 0.84 (0.70 to 1.002) | 3.5 (-0.1 to 7.4)
50-59 | 31 (24 to 39) | 0.86 (0.69 to 1.007) | 4.5 (-0.2 to 9.8)
60-69 | 40 (28 to 56) | 0.67 (0.55 to 0.91) | 12.1 (3.4 to 20.7)
70-74 | 49 (36 to 64) | 0.90 (0.46 to 1.78) | 12.2 (-37.7 to 26.9)
50-69 | 32 (24 to 41) | 0.81 (0.69 to 0.95) | 6.1 (1.2 to 10.9)

* Based on trials of screening included in the meta-analysis.

† From meta-analysis of screening trials using two different methods of case accrual.

Abbreviations: CI=confidence interval; RR=relative risk.

RCTs with short case accrual methods. Meta-analysis estimates from trials with short case accrual methods differed only slightly from those with long case accrual (Figure 6). Across all trials with short case accrual, the mean or median screening intervention time ranged from 3.5 to 14.6 years, case accrual time from 5.0 to 15.5 years, and followup time from 10.7 to 25.7 years. Including the same trials as the previous analysis, but with short case accrual, the combined RR for women age 39 to 49 years was 0.84 (95% CI, 0.70 to 1.002; I^2^=35.8%; p=0.143; 9 trials).69,82,83,86,87,95 The Gothenburg trial was the only trial with statistically significant differences between groups.82

Figure 6 Meta-Analysis of Effects of Screening Trials on Breast Cancer Mortality With Short Case Accrual

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study; HIP=Health Insurance Plan of Greater New York.

Figure 6 is a forest plot displaying the results of a meta-analysis of effects of screening trials on breast cancer mortality with short case accrual. The results of the figure are further described in the text of the report starting on page 17.

Results for age 50 to 59 years indicated a RR of 0.86 (95% CI, 0.69 to 1.007; I^2^=33.9%; p=0.182; 7 trials), and only the Stockholm trial reported statistically significant differences between groups.83,87 Results for age 60 to 69 and 70 to 74 years differed slightly from the previous analysis (60 to 69 years; RR 0.67; 95% CI 0.55 to 0.91; I^2^=0%; p=0.476; 5 trials; and 70 to 74 years; RR 0.90; 95% CI, 0.46 to 1.78; I^2^=0%; p=0.923; 3 trials). Combining results across the two age groups of women age 50 to 69 years, indicated a RR of 0.81 (95% CI, 0.69 to 0.95; I^2^=43.7%; p=0.114).

Results of the meta-analysis were used to determine absolute rates of breast cancer mortality reduction per 10,000 women screened for 10 years (Table 5). Using RRs from the short case accrual meta-analysis, the numbers of deaths reduced (prevented) included 3.5 (95% CI, -0.1 to 7.4) for age 39 to 49 years, 4.5 (95% CI, -0.2 to 9.8) for age 50 to 59 years, 12.1 (95% CI, 3.4 to 20.7) for age 60 to 69 years, and 12.2 (95% CI, -37.7 to 26.9) for age 70 to 74 years. Absolute reduction for the combined group of women age 50 to 69 years was 6.1 (95% CI 1.2 to 10.9).

Observational studies. Observational studies of mammography screening provide additional information about screening effectiveness in contemporary populations and settings. However, observational studies are subject to important biases that limit their use in determining effectiveness. Most importantly, they lack comparability of comparison groups that is only attainable through randomization.

Recent comprehensive systematic reviews of observational studies summarize most of the relevant research.96-99 Included studies were designed as time-trend, incidence-based mortality, or case-control studies. Time-trend studies compare changes in breast cancer mortality among populations in relation to the introduction of screening. Incidence-based mortality studies compare mortality rates of women screened or invited to screen with women not screened or invited. To reflect the incidence of breast cancer, rather than prevalence, these studies include only breast cancer cases diagnosed during a specific time period that follows the initial screen. Case-control studies compare histories of screening between women dying of breast cancer with women not dying of breast cancer. Examples of limitations of these specific study designs include incorrect assumptions for comparison groups in time-trend studies, high risk of lead and length time bias in incidence-based mortality studies, and self-selection bias in case-control studies. Additional limitations are described in Table 6.

Table 6 Biases and Limitations of Observational Studies of Mammography Screening

Study design | Description | Limitations
Time-trend | Compares changes in breast cancer mortality among populations in relation to the introduction of screening (before/after or ecologic). | - Applicability to current populations and settings may be low.; - Mortality rates may be affected by changes in diagnosis and treatment over time.; - Analysis assumes constancy over time.; - High risk for lead-time and length-time biases depending on the choice of comparison time periods.; - Comparison groups based on age or location are not stable over time.; - Opportunistic screening in the control group may dilute mortality estimates or screening effects.
Incidence-based mortality | Compares mortality rates of women screened or invited to screen with women not screened or invited. To reflect the incidence of breast cancer, rather than prevalence, these studies include only breast cancer cases diagnosed during a specific time period that follows the initial screen. | - High risk for lead-time and length-time biases.; - Short case accrual or followup periods inadequately determine mortality effect.; - Opportunistic screening in the control group may dilute mortality estimates or screening effects.; - Self-selection bias results in important differences between women attending screening and those who do not; including social, demographic, and health factors that independently influence outcomes.; - Dependent on correct choices of comparison groups.
Case-control | Compares histories of screening between women dying of breast cancer with women not dying of breast cancer. | - Self-selection bias.; - Women who had access to screening likely had access to effective treatment.; - Retrospective data analysis is subject to recall bias and missing data.; - Lower power to detect mortality differences between groups.

Three good-quality reviews were recently conducted by the EUROSCREEN Working Group to assess the effectiveness of population-based mammography screening on breast cancer mortality (Appendix B1).96-98 Inclusion criteria included studies with original data from population-based screening programs in Europe and the United Kingdom that reported breast cancer mortality outcomes; were published in English; included women age 50 to 69 years; evaluated current screening programs; and were designed as time-trend, incidence-based mortality, or case-control studies. Studies with overlapping data or data that were updated by newer results were not included. Although quality criteria were not prespecified, the studies appeared to undergo critical review according to design-specific factors. However, individual studies were not given quality ratings. Studies included in these reviews are listed in Appendix A8.

A EUROSCREEN review evaluated 12 time-trend studies reporting changes in breast cancer mortality in relation to the introduction of screening.97 These studies described trends over time or evaluated change using regression analysis. No combined estimates of effectiveness were provided because of dissimilarities of comparisons and outcome measures. Five studies reporting outcomes as reductions per year indicated breast cancer mortality reductions of 1 to 9 percent per year for approximately 10 years after the introduction of screening (i.e., 10% to 90%).100-104 Seven studies reporting before/after changes indicated 0 to 36 percent reductions in mortality after screening was introduced compared with before screening.105-111 Three of these studies that were considered to have adequate followup reported mortality reductions ranging from 28 to 35 percent.106,107,110

Another EUROSCREEN review included 20 incidence-based mortality studies that evaluated breast cancer mortality rates in relationship to screening.96,98 The least biased studies estimated breast cancer mortality from a cohort of women not invited for screening, or from historical and current control groups; and used long case accrual periods that were the same as the study followup periods. A meta-analysis98 of these studies indicated a RR of 0.75 (95% CI, 0.69 to 0.81; p=0.23; 7 studies)34,107,112-116 for invitation to screening; and 0.62 (95% CI, 0.56 to 0.69; p=0.40; 7 studies)34,107,112-116 for actual screening.

The third EUROSCREEN review included eight case-control studies that provided odds ratios (ORs) for breast cancer mortality adjusted for self-selection bias using various methods.98 A meta-analysis of studies indicated an OR of 0.69 (95% CI, 0.57 to 0.83; p=0.005; 7 studies)117-122 for invitation to screening; and 0.52 (95% CI, 0.42 to 0.65; p=0.17; 7 studies) 117-122 for actual screening.

A good-quality systematic review conducted outside of the EUROSCREEN Working Group included time-trend, cohort, and hybrid studies (Appendix B1).99 Hybrid studies were defined as studies that identified a cohort, but used population-based data on mammography exposure. Studies were restricted to those with women age 50 to 69 years that captured over 10 years of screening experience. Several studies included in this review were also included in the EUROSCREEN reviews. Study quality was evaluated by prespecified criteria that included concepts of the USPSTF criteria and emphasized control groups, adjustment for potential confounders, and ascertainment of mortality outcomes. Of 17 studies meeting inclusion criteria and rated fair-quality, five reported RR reductions for breast cancer death of 0 to 12 percent; eight reported 13 to 33 percent; and four reported more than 33 percent, although not all results reached statistical significance.99

The results of these systematic reviews indicated a wide range of estimates of breast cancer mortality reduction with screening for women age 50 to 69 years. Meta-analyses from the EUROSCREEN reviews indicated 25 to 31 percent mortality reduction for women invited to screening in the screening programs. In comparison, the meta-analysis of screening RCTs using intention-to screen analysis for women age 50 to 69 years indicated reductions of 19 to 22 percent, as described in the previous section of this report.

Six additional studies were not included in the published systematic reviews described above because they were published in 2011 or later, included women in countries outside Europe and the United Kingdom, or focused on ages older or younger than 50 to 69 years (Table 7). The only U.S study was a record review of older women who died of breast cancer. Results indicated no differences in breast cancer deaths between screened versus non-screened women older than age 80 years.91

Table 7 Observational Studies of Screening and Mortality Not Included in Systematic Reviews

Author, year | Study design | Population; age, year; participants, n | Study years; participation rate, %; comparison | Adjusted for previous breast cancer | Reduction in breast cancer mortality | Reduction in all-cause mortality | Quality rating; limitations
Coldman et al, 2008^129^ | Time-trend | British Columbia, Canada, 4 cohorts based on date and age at first screening; 40-79; 658,151 | 1988-2005; 70%; change from annual to biennial in 1997 for age 50-79 | NR | Breast cancer deaths (mortality ratio pre vs. post); - 40-49 years: 0.67 (95% CI, 0.33 to 1.37); - ≥50 years: 1.06 (95% CI, 0.76 to 1.46) | NR | NA
Coldman et al, 2014^124^ | Incidence-based mortality | Canadian Screening Programs; 40-79; 2,796,472 | 1990-2009; 85% of Canadians; women participating in screening vs. not participating | NR | Breast cancer deaths (standardized mortality ratio); - 40-49 years: 0.56 (95% CI, 0.45 to 0.67); - 50-59 years: 0.60 (95% CI, 0.49 to 0.70); - 60-69 years: 0.58 (95% CI, 0.50 to 0.67); - 70-79 years: 0.65 (95% CI, 0.56 to 0.74) | NR | NA
Hellquist et al, 2011^123^ | Prospective cohort (Poisson distribution) | Swedish counties in Mammography Screening of Young Women cohort; 40-49; 620,620 | 1986-2005; 80-90%; invited vs. not invited to screen | Yes | Breast cancer deaths (person-years), invited vs. not; - Adjusted for invitation: 619 vs. 1,205; RR 0.74 (95% CI, 0.66 to 0.83); - Adjusted for attendance: 523 vs. 1,205; RR 0.71 (95% CI, 0.62 to 0.80); - NNS during a 10-year period to save 1 life: 1,252 (95% CI, 958 to 1,915) | NR | Fair
Hofvind et al, 2012^125^ | Time-trend | Norwegian Breast Cancer Screening Program; 55-74; N=10,478 cancer cases | Pre-screening (1984-1995) vs. biennial screening (1996-2007) | Unclear | Age standardized breast cancer mortality rate; - Pre: 20/100,000; - Post: 14/100,000 | Age standardized mortality rate; - Pre: 68/100,000 to 80/100,000; - Post: 51/100,000 | NA
Hofvind et al, 2013^126^ | Prospective cohort | Norwegian Breast Cancer Screening Program; 50-69; 699,628 | 1996-2010; 84%; screened vs. non-screened | Unclear | Breast cancer deaths (women years), nonscreened vs. screened; - Number of deaths: 392/2,055 vs. 998/13,162; - Adjusted breast cancer mortality: 1.00 vs. 0.39 (95% CI, 0.35 to 0.44); - Adjusted for self-selection bias: 1.00 vs. 0.57 (95% CI, 0.51 to 0.64) | NR | Fair^*^
Mook et al, 2011^127^ | Retrospective cohort | Netherlands; 50-69; 2,592 | 1990-2000; 70-80%; screened vs. non-screened | Yes | Breast cancer mortality, screen-detected vs. not; - Univariate HR: 0.43 (95% CI, 0.34 to 0.53, p<0.001); - Multivariate HR: 0.66 (95% CI, 0.50 to 0.86, p=0.002); - Absolute reduction in breast cancer mortality at 10 years of followup: 7% | All-cause mortality; - Univariate HR: 0.60 (95% CI, 0.51 to 0.69, p<0.001); - Multivariate HR: 0.77 (95% CI, 0.64 to 0.92, p=0.005) | Poor^*^
Parvinen et al, 2011^130^ | Retrospective cohort | Finland, national screening program registry data; 40-49; 14,765 | 1987-2003; 85%; annual vs. triennial screening | No | Breast cancer mortality (per 100,000 person- years); - Triennial: 17.9; RR (reference); - Annual: 20.3; RR 1.14 (95% CI, 0.59 to 1.27) | All-cause mortality (per 100,000 person-years); - Triennial: 192.6; RR (reference); - Annual: 230.9; RR 1.20 (95% CI, 0.99 to 1.46) | Fair^*,†^
Schonberg et al, 2009^91^ | Retrospective cohort | U.S., medical record review at community health centers; >80; 2,011 | 1994-2004; screened vs. non-screened | Yes | Breast cancer deaths: 1 vs. 2 | All-cause deaths: 12 vs. 12 | Fair^†^

* Did not maintain comparable groups (includes attrition, crossovers, adherence, contamination).

† Statistical limitations including low power to detect differences.

Abbreviations: CI=confidence interval; HR=hazard ratio; MR=mortality ratio; n=number; NA=not applicable (quality rating criteria not available for this study design); NNS=number needed to screen; NR=not reported; RR=relative risk; U.S.=United States; vs.=versus.

One study included only women in their 40s. A large fair-quality study of the Mammography Screening of Young Women Cohort in Sweden indicated reduced risk for breast cancer deaths for women age 40 to 49 years invited to screening compared with women not invited (RR 0.74; 95% CI, 0.66 to 0.83).123 The estimated NNS during a 10-year period (corresponding to about 6 mammography episodes) to save 1 life was calculated as 1252 women (95% CI, 958 to 1915 women).123

A study of over 2 million women age 40 to 79 in Canada compared screening program participants versus nonparticipants. 124 Results were expressed as standardized mortality ratios (i.e., the ratio of the observed breast cancer mortality of screening participants to province-specific breast cancer mortality based in nonparticipant incidence and survival rates). 124 Results indicated reduced breast cancer mortality of 35 to 44 percent that varied by age. Although the analysis considered the influence of self-selection bias using historical trend data for women age 35 to 39, the validity of this approach is unclear.

Additional studies provided updated data from screening programs in Norway125,126 and the Netherlands127 with results consistent with the EUROSCREEN report showing reduced mortality with screening for women age 50 to 69 years.

##### All-Cause Mortality

All included RCTs of mammography screening reported all-cause mortality outcomes. However, not all trials reported them according to age groups, and the two Canadian trials reported results by combining age groups (40 to 49 years and 50 to 59 years) as one trial. Results reflecting the longest followup times available for each trial were selected for inclusion in the meta-analysis.

For combined age groups, a meta-analysis of nine RCTs indicated a combined RR of 0.99 (95% CI, 0.97 to 1.003; I^2^=0%; p=0.577, Figure 7).69,79,87,128 Results were similar for each age group (Figure 8), including age 39 to 49 years (RR 0.99; 95% CI, 0.94 to 1.06; I^2^=0%; p=0.478; 7 trials); 50 to 59 years (RR 1.02; 95% CI, 0.94 to 1.10; I^2^=0%; p=0.588; 3 trials); 60 to 69 years (RR 0.97; 95% CI, 0.90 to 1.04; I^2^=0%; p=0.650; 2 trials); and 70 to 74 years (RR 0.98; 95% CI, 0.86 to 1.14; I^2^=72.4%; p=0.057; 2 trials).

Figure 7 Meta-Analysis of Effects of Screening Trials on All-Cause Mortality, With Combined Ages

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study; HIP=Health Insurance Plan of Greater New York.

Figure 7 is a forest plot displaying the results of a meta-analysis of the effects of screening trails on all-cause mortality for combined age groups. The results of the figure are further described in the text of the report on page 19.

Figure 8 Meta-Analysis of Effects of Screening Trials on All-Cause Mortality, Stratified by Age

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study; HIP=Health Insurance Plan of Greater New York.

Figure 8 is a forest plot displaying the results of a meta-analysis of effects of screening trials on all-cause mortality stratified by age. When the results are broken out by age groups 39 to 49, 50 to 59, 60 to 69 and 70 to 79 each group crosses 1, as do all of the individual data points indicating that there is no impact on all-cause mortality from screening. The results of the figure are further described in the text of the report on page 19.

##### Breast Cancer–Specific and All-Cause Mortality Differences by Risk Factors and Screening Intervals

Screening trials did not provide results according to risk factors other than age. No head-to-head comparisons of trials by screening intervals are available. The HIP, Age, and Canadian trials used mammography screening intervals of 12 months, and none showed age-specific mortality reductions. The Swedish Two-County trial had screening intervals ranging from 24 to 36 months that varied by age group, and reported breast cancer mortality reductions for age 50 to 69 years. However, these trials differed by many other factors (inclusion, randomization, adherence, etc.) and they did not provide enough information to determine the specific effects of screening intervals.

Observational studies provide additional information about screening intervals (Table 7). A time-trend study of 658,151 Canadian women age 40 to 79 years compared breast cancer mortality rates before and after the change from annual to biennial screening for women 50 years or older, while annual screening remain unchanged for age 40 to 49 years.129 Results indicated no significant reductions for age 40 to 49 or 50 years and older. A registry-based study in Finland indicated no breast cancer mortality differences between annual and triennial screening among women age 40 to 49 years.130

## Key Question 2 What Is the Effectiveness of Routine Mammography Screening in Reducing the Incidence of Advanced Breast Cancer and Treatment-Related Morbidity, and How Does It Differ by Age, Risk Factor, and Screening Interval?

### Summary

#### RCTs

- The RCTs of mammography screening provided several measures of intermediate breast cancer outcomes. However, most comparisons between screening and control groups using these categories provided differences between the two groups in relatively early stages of disease, rather than advanced stages.
- Combining estimates based on definitions corresponding to Stage II disease or higher (Stage II+, size ≥20 mm, 1+ positive lymph node) in a meta-analysis indicated no significant reductions in advanced disease for women age 39 to 49 or 50 years and older.
- When thresholds were defined by the most severe disease categories available from the trials (Stage III + IV disease, size ≥50 mm, 4+ positive lymph nodes), meta-analysis indicated no reductions for age 39 to 49 years (RR 0.98; 95% CI, 0.74 to 1.37); but reduced risk of advanced cancer in the screening group for age 50 years and older (RR, 0.62; 95% CI, 0.46 to 0.83).
- In a Cochrane review that included five screening RCTs, women randomized to screening were significantly more likely to have surgical therapy (mastectomies, lumpectomies) and radiation therapy, and less likely to have hormone therapy than controls. Use of chemotherapy was similar between groups.
- No RCTs evaluated the incidence of advanced breast cancer outcomes and treatment on the basis of risk factors or screening intervals.

#### Observational Studies

- Six observational studies compared advanced breast cancer outcomes between women in populations participating in screening versus nonparticipating. Of these, two studies indicated statistically significantly more Stage III and IV breast cancer among unscreened women; three reported more lymph node positive disease; and three reported more tumors greater than 20 mm in size.
- Four case series studies indicated less extensive survey, such as fewer total mastectomies and more breast conservation therapies, and less chemotherapy among women who had previously had screening mammography compared with those who did not, but these studies included women with DCIS and early stage cancer as well as advanced cancer.
- An analysis of BCSC data indicated a lower proportion of Stage III + IV disease among women age 40 to 49 years screened annually versus biennially, but not for women age 50 to 59 years.
- A second analysis of BCSC data indicated that women age 40 to 49 years with extremely dense breasts had increased risks for advanced stage cancer (IIB+) and large-size tumors (>20 mm) with biennial compared with annual screening. Differences were not significantly different for positive lymph nodes, other density categories, other age groups, or between biennial and triennial screening.

### Evidence

#### Previous Reports

Previous evidence reviews for the USPSTF did not address this question.

#### New Studies

##### Incidence of Advanced Breast Cancer

RCTs. Intermediate outcomes of screening trials can be evaluated to determine if screening reduces the risk for advanced breast cancer, thereby leading to better prognosis and potentially less aggressive treatment and morbidity. The RCTs of mammography screening provided several measures of intermediate outcomes for screening and control groups. The most commonly used measures included clinical stage (Stage 0 to IV),80,81,131,132 number of involved lymph nodes (0, 1 to 3, 4+),75,77,82,83,133 and tumor size (mm),76,78,83 although these measures varied across trials. Most comparisons between screening and control groups using these categories provided differences between the two groups in relatively early stages of disease, rather than advanced stages.

A published analysis of trials defined advanced breast cancer as Stage II disease or higher, size 20 mm or greater, or having one or more positive lymph nodes (Table 8).65 These outcomes are all consistent with Stage IIA disease (i.e., localized) or higher according to the AJCC TNM system.36 Combining estimates based on these definitions of advanced cancer in a meta-analysis produced a RR for women age 39 to 49 years of 0.90 (95% CI, 0.79 to 1.04; I^2^=23.1%; p=0.267; 5 trials),65,82,83,131 and for age 50 years and older, 0.85 (95% CI, 0.65 to 1.13; I^2^=80.5%; p=0.002; 4 trials; Figure 9),65,82,83,131 indicating no statistically significant overall differences between the screening and control groups.

Table 8 Advanced Breast Cancer Outcomes Reported in Screening Trials

Trial (reference) | Stage | +Lymph nodes, n^*^ | Size, mm^†^ | Definition of advanced cancer^‡^ | RR for advanced cancer (95% CI)^§^ | Definition of advanced cancer║ | RR for advanced cancer (95% CI)^§^
HIP131 | I, II, III, IV | NR | NR | Stage II+ | 40-64 years: 0.85 (0.69 to 1.05)^‡^ 40-49 years: 0.96 (0.69 to 1.33) 50-64 years: 0.87 (0.67 to 1.14) | Stage III-IV | 40-49 years: 0.87 (0.48 to 1.58) 50-64 years: 0.52 (0.31 to 0.88)
CNBSS-1^75,76^ | NR | 0, 1-3, 4+ | 1-9, 10-14, 15-19, 20-39, ≥40 | Size ≥20 mm 1+ lymph node | 40-49 years: 0.97 (0.74 to 1.25)^‡^ 40-49 years: 1.55 (1.13 to 2.11) | Size ≥40 mm 4+ lymph nodes | 40-49 years: 1.18 (0.67 to 2.03) 40-49 years: 2.00 (1.20 to 3.34)
CNBSS-2^77,78^ | NR | 0, 1-3, 4+ | 1-9, 10-14, 15-19, 20-39, ≥40 | Size ≥20 mm 1+ lymph node | 50-59 years: 0.84 (0.65 to 1.07)^‡^ 50-59 years: 1.09 (0.82 to 1.15) | Size ≥40 mm 4+ lymph nodes | 50-59 years: 0.75 (0.38 to 1.46) 50-59 years: 0.91 (0.55 to 1.49)
Gothenburg82 | NR | 0, 1+ | NR | 1+ lymph node | 39-59 years: 0.80 (0.61 to 1.05)^‡^ 39-49 years: 0.65 (0.44 to 0.96) 50-59 years: 1.02 (0.70 to 1.48) | NR
Stockholm80 | 0, I, II, III-IV | NR | NR | Stage II+ | 40-64 years: 0.88 (0.68 to 1.12)^‡^ | Stage III+ | 40-64 years: 1.15 (0.59 to 2.07)
Malmö81 | 0, I, II, III-IV, II-IV | NR | NR | Stage II+ | 45-70 years: 0.83 (0.68 to 1.00)^‡^ | Stage III+ | 45-70 years: 0.82 (0.56 to 1.20)
Swedish Two-County83,132 | I, II, III-IV | 0, 1+ | 1-9, 10-14, 15-19, 20-29, 30-49, ≥50 | Stage II+ | 40-74 years: 0.69 (0.61 to 0.78)^‡^ | NR
Swedish Two-County83,132 | I, II, III-IV | 0, 1+ | 1-9, 10-14, 15-19, 20-29, 30-49, ≥50 | Size ≥20 mm | 40-49 years: 0.89 (0.65 to 1.21) 50-74 years: 0.64 (0.55 to 0.73) | Size ≥50 mm | 40-49 years: 1.57 (0.63 to 3.94) 50-74 years: 0.63 (0.45 to 0.82)
Swedish Two-County83,132 | I, II, III-IV | 0, 1+ | 1-9, 10-14, 15-19, 20-29, 30-49, ≥50 | 1+ lymph node | 40-49 years: 0.85 (0.60 to 1.19) 50-74 years: 0.70 (0.60 to 0.82) | NR
Age248 | NR | 0, 1-3, 4+ | 1-9, 10-14, 15-19, 20-29, 30-49, ≥50 | Size ≥20 mm 1+ lymph node | 39-49 years: 0.88 (0.73 to 1.05)^‡^ 39-49 years: 0.89 (0.72 to 1.10) | Size ≥50 mm 4+ lymph nodes | 39-49 years: 0.85 (0.57 to 1.23) 39-49 years: 0.77 (0.53 to 1.13)

* Lymph nodes with micrometastases are classified as Stage IB, otherwise ≥1 positive lymph node is classified as Stage IIA or higher.

† Size ≥20 mm is classified as Stage IIA or higher; size ≥50 mm is classified as Stage IIB or higher.

‡ Autier, 2009^65^.

§ Screening vs. control.

║ Represents the highest category of disease reported by the trials.

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Studies; HIP=Health Insurance Plan of Greater New York; mm=millimeter; n=number; NR=not reported; RR=relative risk; vs.=versus.

Figure 9 Meta-Analysis of Effects of Screening Trials on Advanced Cancer Outcome Using a Low Threshold for Advanced Cancer

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study; HIP=Health Insurance Plan of Greater New York; mm=millimeter.

Figure 9 is a forest plot displaying the results of a meta-analysis of the effects of screening trials on advanced cancer outcomes using a low threshold for advanced cancer. The results of the figure are further described in the text of the report on page 21.

To evaluate these relationships using a higher level of disease to define advanced breast cancer, thresholds were redefined to the most severe disease categories available from the trials, recognizing that these definitions do not represent equivalent disease stages. These include Stage III + IV disease (i.e., regional + metastatic), size 50 mm or greater, or having four or more positive lymph nodes. Combining estimates based on these definitions of advanced cancer in a meta-analysis indicated no difference for women age 39 to 49 years (RR 0.98; 95% CI, 0.74 to 1.37; I^2^=0%; p=0.556; 4 trials);76,83,131,133 but reduced risk of advanced cancer in the screening group for age 50 years and older (RR, 0.62; 95% CI, 0.46 to 0.83; I^2^=0%; p=0.692; 3 trials; Figure 10).78,83,131

Figure 10 Meta-Analysis of Effects of Screening Trials on Advanced Cancer Outcome Using a Higher Threshold for Advanced Cancer

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study; HIP=Health Insurance Plan of Greater New York; mm=millimeter.

Figure 10 is a forest plot displaying results of a meta-analysis of the effects of screening trials on advanced cancer outcomes using a higher threshold for advanced cancer. The results of the figure are further described in the text of the report on page 22.

Observational studies. Although many observational studies have been published comparing characteristics of breast cancer diagnoses between screened and unscreened women, most provide comparisons between screen-detected and nonscreened-detected cases. This approach categorizes all cancer cases identified outside of a screening mammogram as nonscreen-detected, even though a woman may have had prior screening mammography. This type of comparison does not provide accurate estimates of the effectiveness of participation in a screening program compared with nonparticipation. Instead, comparisons between rates of advanced breast cancer outcomes between women in populations participating in screening versus nonparticipating would more appropriately address this Key Question.

Six case series studies compared advanced breast cancer outcomes for women who had previous mammography screening with those who did not (Table 9).134-139 These studies were based on screening populations from the Malmö trial,139 Kaiser Permanente,135 and screening programs in the United Kingdom,134 Denmark and Sweden,137 Spain,136 and Canada.138

Table 9 Observational Studies of Advanced Cancer Outcomes With Mammography Screening

Author, year | Study design | Population; age, years; participants, n | Study years; comparison | Outcome measures | Results
Breast Screening Frequency Trial Group, 2002^134^ | RCT | U.K., 5 screening units in NHS Breast Screening Programme; 50-62 years; 76,022 | 1989 to 1996; annual screening vs. no screening during study period | Size >20 mm; ≥1 positive node | Invasive: 235 vs. 208 Tumor size >20 mm: 27% (63/233) vs. 34% (69/203), p<0.05 ≥1 node positive: 34% (63/185) vs. 37% (61/166), p=0.50
Buseman et al, 2003^135^ | Case series | U.S., Kaiser Permanente; 42-49 years; 247 | 1994 to 2000; screened vs. unscreened | Stage II-IV; III-IV | - Stage II-IV: 39% (41/105) vs. 52% (74/142), p=0.06; - Stage III or IV: 4% (n=NR) vs. 9% (n=NR), p=NR
Dittus et al, 2013^141^ | Case series | U.S., BCSC data, multisite; 40-74 years; 4,432 | 1996 to 2008; 1-year vs. 2-year screening intervals | Stage; size >20 mm; node positive | OR (95% CI) for 2-year vs. 1-year interval: No statistically significant differences for stage, size, lymph node positive by weight status.
Fernández et al, 2013^136^ | Case series | Spain, breast cancer program and regular public health system; 50-69 years; 904 | 2002 to 2012; screened vs. non-screened | Node positive; ≥3 nodes positive; size >20 mm | - Cancer detection rate: 3.8/1,000 (475/123,445) vs. 9.4/1,000 (382/40,797); - Invasive: 80% (419/523) vs. 92% (373/403), p<0.001; - Lymph node positive: 75% (312/419) vs. 57% (204/373), p<0.001; - ≥3 nodes positive: 28% (28//103) vs. 42% (66.156), p<0.001; - Tumor size >20 mm: 16.5% (69/419) vs. 48.5% (181/373), p<0.001
Goel et al, 2007^142^ | Case series | U.S., Vermont Breast Cancer Surveillance System; >40 years; 1,944 | 1994 to 2002; 1-year vs. 2-year screening intervals | Advanced either Stage IIB+; size >20mm; >1 positive node | - Advanced: 21% vs. 24%, p=0.262; - No statistically significant differences by age
Hubbard et al, 2011^143^ | Case series | U.S., BCSC data, multisite; 40-59 years; 4,492 | 1996 to 2006; 1-year vs. 2-year screening intervals | Stage IIB+ | Adjusted proportion (95% CI) of cancer stage for 2-year vs 1-year intervals:; - Stage III or IV for 40-49 years: 4.8 (1.3 to 8.4); - No statistically significant differences for other stages
Jensen et al, 2003^137^ | Case series | Denmark and Sweden; 50-69 years; 2,104 | 1996 to 1997; regions with mammography screening vs. regions without | Stage III-IV; median size | - Stage III or IV: 8.8% (81/917) vs. 13.6% (162/1,187), p<0.001; - Median tumor size (mm): 18 (Malmo) and 17 (Funen) vs. 20 (Aarhus and Northern Jutland), p<0.001
Kerlikowske et al, 2013^144^ | Case series | U.S., BCSC data, multisite; 40-74 years; 11,474 | 1996 to 2008; 1-year vs. 2-year vs. 3-year screening intervals | Stage IIB-IV | Adjusted OR (95% CI) for 2-year vs. 1-year intervals:; - Stages IIB-IV in age 40-49 + extreme breast density: 1.89 (1.06 to 3.39); - Tumor size >20 mm in age 40-49 + extreme breast density: 2.39 (1.37 to 4.18); - No statistically significant differences for 50-74 years, 40-49 years without extreme density, or for any comparisons between 3-year vs. 2-year intervals
Olivotto et al, 1999^138^ | Case series | Canada, Screening Mammography Program of British Columbia; 40-89 years; 13,636 | 1989 to 1996; screening attenders vs. non-attenders | Stage III-IV; size >20 mm | - Invasive: 88% (1,712/1,946) vs. 92.3% (7,523/8,149), p<0.001; - Stage III or IV: 4.3% (84/1,946) vs. 11.9% (969/8,149), p<0.001; - Tumor size >20 mm: 24.1% (3413/1,946) vs. 38.3% (2,885/8,149), p<0.001
Olsson et al, 2009^139^ | Case series | Sweden, MMST; 45-69 years; 2478 | 1961 to 1991; invited to screen vs. not invited | Size >20 mm; node positive | - Tumor size >20 mm: 23% vs. 36%, p<0.05; - Lymph node positive: 28% vs. 36%, p<0.05
White et al, 2004^145^ | Case series | U.S., BCSC data, multisite; 40-89 years; 7,840 | 1996 to 2001; 1-year vs. 2-year screening intervals | Stage III-IV; size >20 mm | - Stage III or IV: 3% vs. 4%; - Tumor size >20 mm: 22% vs. 24%; OR (95% CI) for 2-year interval vs. 1-year interval:; - Late stage for invasive cancers only: 0.97 (0.84 to 1.13); - Tumor size >20 mm for invasive: 1.07 (0.92 to 1.24)

Abbreviations: BCSC=Breast Cancer Surveillance Consortium; BMI=body mass index; CI=confidence interval; DCIS=ductal carcinoma in situ; kq=kilogram; m=meter; MMST=Malmö Mammographic Screening Trial; N=number; NHS=National Health Service; NR=not reported; NS=not statistically significant; U.S.=United States; U.K.=United Kingdom; vs.=versus.

Two studies indicated statistically significantly more Stage III and IV breast cancer among unscreened women,137,138 three reported more lymph node positive disease,134,136,139 and three reported more tumors greater than 20 mm in size.134,136,138,139 A study of 242 women age 42 to 49 years at Kaiser Permanente found no statistically significant differences in stage between screened and nonscreened women.135

##### Treatment-Related Morbidity

Although outcomes related to treatment are reported by some of the screening trials, their interpretation and application to current practice is problematic. Treatment approaches have changed over time, are subject to local practice standards, and increasingly involve patient choices.

A Cochrane review compared treatments between randomized groups in five screening trials providing these outcomes, including the CNBSS-1, CNBSS-2, Malmö, Kopparberg, and Stockholm trials.140 In this analysis, women randomized to screening were significantly more likely to have surgical therapy, analyzed as mastectomies and lumpectomies combined (RR 1.35; 95% CI, 1.26 to 1.44; I^2^=0%; p=0.80; 5 trials) and mastectomies alone (RR 1.20; 95% CI, 1.11 to 1.30; I^2^=0%; p=0.86; 5 trials). These women were also more likely to have radiation therapy (RR 1.32; 95% CI, 1.16 to 1.50; I^2^=0%; p=0.36; 2 trials), and less likely to have hormone therapy (RR 0.73; 95% CI, 0.55 to 0.96; I^2^=78%; p=0.03; 2 trials). Use of chemotherapy was similar between groups (RR 0.96; 95% CI, 0.78 to 1.19; I^2^=71%; p=0.06; 2 trials).

Four case series studies compared breast cancer treatments for women who had previous mammography screening with those who did not, but these studies included women with DCIS and early stage cancer as well as advanced cancer (Table 10).135-138 Studies also provided information on advanced cancer outcomes described above, and were based on screening populations from Kaiser Permanente,135 and screening programs in Denmark and Sweden,137 Spain,136 and Canada.138 Results indicated statistically significantly less extensive survey, such as fewer total mastectomies and more breast conservation therapies;135-138 and less chemotherapy135,136,138 among women who had previously had screening mammography.

Table 10 Studies of Breast Cancer Treatment for Screened and Nonscreened Women

Author, year | Study design | Population; age, years; participants, n | Study years; comparison | Results
Buseman et al, 2003^135^ | Case series | U.S., Kaiser Permanente; 42-49 years; 247 | 1994 to 2000; screened vs. nonscreened | - Lumpectomy + radiation treatment: 61% (64/105) vs. 57% (81/142), NS; - Chemotherapy: 55% (58/105) vs. 61% (86/142), NS
Fernádez et al, 2013^136^ | Case series | Spain, breast cancer program and regular public health system; 50-69 years; 904 | 2002 to 2012; screened vs. nonscreened | Primary treatment:; - Conservative surgery: 83% (433/523) vs. 57% (230/403), p<0.001; - Radical surgery: 16% (84/523) vs. 41% (163/403), p<0.001; - Chemotherapy: 0.4% (2/510) vs. 0.8% (3/394), p<0.001; - Sentinel node biopsy: 73% (384/523) vs. 50% (200/403), p<0.001; Adjuvant treatment:; - Chemotherapy: 41% (211/510) vs. 72% (284/394), p<0.001; - Hormone therapy: 86% (439/510) vs. 80% (317/394), p<0.001; - Radiotherapy: 87% (444/510) vs. 75% (296/393), p<0.001
Jensen et al, 2003^137^ | Case series | Denmark and Sweden; 50-69 years; 2,104 | 1996 to 1997; regions with mammography screening vs. regions without | - Mastectomy: 61% (556/917) vs. 85% (893/1,051), p<0.001; - Lumpectomy: 32% (295/917) vs. 6.8% (72/1,051), p<0.001; - Biopsy only: 6.4% (59/917) vs. 8% (84/1,051), p<0.001
Olivotto et al, 1999^138^ | Case series | Canada, Screening Mammography Program of British Columbia; 40-89 years; 13,636 | 1989 to 1996; attenders vs. non-attenders | Definitive breast surgery:; - Total mastectomy: 35% (603/1,712) vs. 46% (3,452/7,523), p<0.001; - Breast conservation: 65% (1,109/1,712) vs. 54% (4,071/7,523), p<0.001; Adjuvant systemic therapy:; - Tamoxifen alone: 29% (493/1,712) vs. 36% (2,694/7,523), p<0.001; - Chemotherapy: 23% (392/1,712) vs. 27% (2,060/7,523), p<0.001

Abbreviations: CI=confidence interval; MMST=Malmö Mammographic Screening Trial; N=number; NR=not reported; NS=not statistically significant; OR=odds ratio; U.S.=United States; U.K.=United Kingdom; vs.=versus.

##### Differences by Risk Factors and Screening Intervals

Five observational studies compared advanced breast cancer outcomes by screening intervals (Table 9),141-145 including four studies based on BCSC data.141,143-145 A recent analysis of data from 4,492 women in the BCSC compared annual with biennial mammography screening and the adjusted proportion of cancer stage at diagnosis.143 Results indicated a lower proportion of Stage III + IV disease among women age 40 to 49 years screened annually versus biennially (10.1% vs. 14.0%; adjusted difference 4.8%; 95% CI, 1.3% to 8.4%), but not among women age 50 to 59 years.143 An older study of 7,840 women in the BCSC indicated no differences between annual and biennial screening for detecting Stage III + IV cancer or tumor size greater than 20 mm among women age 40 to 89 years.145

A separate analysis of BCSC data compared annual with biennial and triennial mammography screening and risks for advanced stage disease (Stage IIB+), large tumor size (>20 mm), and positive lymph nodes.144 Results indicated that women age 40 to 49 years with extremely dense breasts had increased risks for advanced stage cancer (OR 2.39; 95% CI, 1.06 to 3.39) and large tumors (OR 2.39; 95% CI, 1.37 to 4.18) with biennial compared with annual screening. Differences were not statistically significantly different for positive lymph nodes, other density categories, other age groups, or between biennial and triennial screening. Another BCSC study reported no statistically significant differences in stage, tumor size, or lymph node involvement for average weight, overweight, and obese women screened annually compared with biennially.141

A study based on data from the Vermont Breast Cancer Surveillance System also reported no differences in cancer stage, size, or lymph node status between women screened annually compared with biennially.142

## Key Question 3 How Does the Effectiveness of Routine Breast Cancer Screening in Reducing Breast Cancer–Specific and All-Cause Mortality Vary by Different Screening Modality?

### Summary

- RCTs of mammography with or without CBE do not compare relative mortality reduction across different modalities.
- No study of tomosynthesis, ultrasound, or MRI address this question.

## Key Question 4 How Does the Effectiveness of Routine Breast Cancer Screening in Reducing the Incidence of Advanced Breast Cancer and Treatment-Related Morbidity Vary by Different Screening Modality?

### Summary

- Cancer detection rates were higher, but there were no differences in tumor size, stage, or node status between women screened with tomosynthesis and digital mammography and with those receiving mammography alone in two case series studies.
- No other studies evaluated the effectiveness of CBE, ultrasound, or MRI in reducing the incidence of advanced breast cancer or treatment related morbidity.

### Evidence

#### Previous Reports

Previous evidence reviews for the USPSTF did not address this question.

#### New Studies

Two case series studies comparing digital mammography versus tomosynthesis and digital mammography reported detection rates by cancer stage using various categories of cancer staging (Table 11).146,147 A study of patients seen at a multisite community-based breast center in the United States evaluated diagnostic outcomes of 18,202 women receiving mammography and 10,878 receiving mammography and tomosynthesis.146 Results indicated no differences in cancer size, stage, or node status. A second case series of 12,631 women age 50 to 69 years in Norway also found no differences between groups for tumor size or node status147 but found a 27 percent adjusted increase in cancer detection rates (p=0.001) with the addition of tomography.

Table 11 Studies of Advanced Cancer Outcomes With Mammography Plus Tomosynthesis

Author, year | Study design | Population; age, years; participants, n | Study years; comparison | Outcome measures/definitions | Results
Rose et al, 2013^146^ | Case series | U.S., multisite community-based breast center; >18 years; 18,202 DM and 10,878 DM + T | 2011 to 2012; DM vs. DM+T | Cancer detection rate; positive nodes | - Cancer detection rate: 4.0 vs 5.4/1000, NS; - Positive nodes: 4 vs. 6; p=0.84
Skaane et al, 2013^147^ | Post-intervention series | Norway, Oslo screening program; 50-69; 12,631 | 2010 to 2011; DM vs. DM+T (biennial screening) | Cancer detection rate; positive nodes; size ≥20 mm | - Cancer detection rate: 6.1/1,000 vs. 8.0/1,000, (p=0.001); - Positive nodes: 9 vs. 13, NS; - Size ≥20 mm: 12 vs. 15, NS

Abbreviations: DM=digital mammography; mm= millimeter; NS=not statistically significant; T=tomosynthesis; U.S.=United States; vs.=versus.

## Key Question 5 What Are the Harms of Routine Mammography Screening, and How Do They Differ by Age, Risk Factor, and Screening Interval?

### Summary

#### False-Positive and False-Negative Mammography Results, Recommendations for Additional Imaging, and Recommendations for Biopsies

- Data from the BCSC for regularly screened women using digital mammography based on results from a single screening round indicated:
  ○ False-positive mammography rates were highest among women age 40 to 49 years (121.2 per 1,000 women; 95% CI 105.6 to 138.7) and declined with age; rates of false-negative results tended to increase with age, but were not statistically significantly different across age groups.
  ○ Rates of recommendations for additional imaging were highest among women age 40 to 49 years (124.9 per 1,000 women; 95% CI 109.3 to 142.3) and decreased with age, while rates of recommendations for biopsy did not differ between age groups.
  ○ For every case of invasive breast cancer detected by mammography screening in women age 40 to 49 years, 464 women had screening mammography, 58 were recommended for additional imaging, and 10 were recommended for biopsies. These estimates declined with age.
  ○ Results did not differ by time since last mammography screening regardless of whether broad or narrow estimates of one versus two years were used.
  ○ Family history of breast cancer, high breast density, and previous benign breast biopsy were associated with higher rates of false-positive and false-negative results and recommendations for additional imaging and biopsy across most age groups. Premenopausal status, use of menopausal hormone therapy, and lower BMI were associated with some of the outcomes for specific age groups only.
  ○ Rates for all outcomes were lowest for women with almost entirely fat breasts, and highest for women with heterogeneously dense breasts or for those in the combined category of heterogeneous and extreme density.
- Published data from the BCSC using film and digital mammography provided 10-year cumulative rates.
  ○ Rates of false-positive mammography results were 61 percent for annual and 41 percent for biennial screening, while rates of false-positive biopsy were 7 to 9 percent for annual and 5 to 6 percent for biennial screening. Women older than age 50 years had higher false-positive biopsy rates.
  ○ Rates of false-positive mammography results and biopsy were highest among women receiving annual mammography, those with heterogeneously dense or extremely dense breasts, and those either 40 to 49 years old or who used combination hormone therapy.

#### Overdiagnosis

- A meta-analysis of three RCTs, a systematic review of 13 observational studies, and 18 individual studies of overdiagnosis were identified for the current update. Studies of overdiagnosis were primarily based on screening trials, screening programs and registries, or modeled data. Studies differed by their characteristics, methods, and measures. These differences influenced their estimates of overdiagnosis, limited comparisons, and prohibited combined estimates.
- The Malmö I and Canadian National Breast Screening Study (CNBSS-1 and CNBSS-2) trials provide data with reduced bias for estimates of overdiagnosis because they did not provide screening of controls at the end of the trial, had randomized comparison groups, and followup times extended sufficiently beyond the screening period to differentiate earlier diagnosis from overdiagnosis. Combined results indicated 10.7 percent (long case accrual method) to 19.0 percent (short case accrual method) overdiagnosis for invasive cancer + DCIS.
- Data from RCTs where women in the control groups were offered screening at the end of the screening periods are susceptible to over- or underestimating overdiagnosis. Two new publications from these RCTs indicate no or minimal overdiagnosis.
- Unadjusted estimates from 13 observational studies included in the EUROSCREEN review indicated overdiagnosis rates ranging from 0 to 54 percent. For six studies that adjusted overdiagnosis estimates for breast cancer risk and lead time, rates varied from 1 to 10 percent.
- Additional observational studies not included in the EUROSCREEN review reported overdiagnosis estimates of 3 to 50 percent, with most between 14 to 25 percent.
- Although several statistical models of overdiagnosis have been published, these studies have been less acceptable to guideline development groups because of the many assumptions that were used to construct them. Models indicated estimates ranging from 0.4 to 50 percent.

#### Anxiety, Distress, and Other Psychological Responses

- Women with false-positive results were more distressed than women with normal screening results, particularly those who had biopsies, FNA, and early recall.
- Women with false-positive results had more anxiety, psychological distress, and breast cancer specific worry after screening compared with those with normal screening results in most studies. Anxiety improved over time for most women, but persisted for over 2 years for some.
- Two studies reported that women with false-positive results were less likely to return for their next mammogram; two other studies reported no differences; however, when women were given letters tailored to their last screening result they were more likely to re-attend.
- Results of studies of anxiety and depression are mixed. Some studies indicate that women with false-positive results have more anxiety and depression than those with normal screening results, particularly among non-white women, but other studies show no differences.

#### Radiation Exposure

- Models calculate the number of deaths due to radiation induced cancer using estimates for digital mammography is between 2 per 100,000 in women age 50 to 59 years screened biennially, and up to 11 per 100,000 in women ages 40 to 59 years screened annually.

#### Pain During Procedures

- Although many women may experience pain during mammography (1% to 77%), the proportion of those experiencing pain who do not attend future screening varies (11% to 46%).

### Evidence

#### False-Positive and False-Negative Mammography Results, Recommendations for Additional Imaging, and Recommendations for Biopsies

##### Previous Reports

Data from the BCSC that was based on a single screening round and included film and digital mammography indicated that false-positive mammography results were common in all age groups. The rate was highest among women age 40 to 49 years (97.8 per 1,000 women per screening round) and declined with each subsequent age decade.

The rate of false-negative mammography results was lowest among women age 40 to 49 years (1.0 per 1,000 women per screening round) and increased slightly with subsequent age decades. Rates of additional imaging were highest among women age 40 to 49 years (84.3 per 1,000 women per screening round) and decreased with age. Biopsy rates were lowest among women age 40 to 49 years (9.3 per 1,000 women per screening round) and increased with age. The BCSC data indicated that for every case of invasive breast cancer detected by mammography screening in women age 40 to 49 years, 556 women had screening mammography, 46 to 48 additional diagnostic imaging, and five to eight biopsies. These numbers declined with age for mammography and additional imaging, and only slightly for biopsies.

The cumulative risk for false-positive mammography results was reported in published studies as 21 to 49 percent after 10 mammography examinations for women in general,148-150 and up to 56 percent for women age 40 to 49.^149^ For all ages, the cumulative risk of a false-positive biopsy after 10 screening mammograms was calculated as 19 percent of all women screened.149

##### New Studies

#### BCSC Data

Differences by age. Data for regularly screened women based on results from a single screening round using digital mammography indicated that false-positive screening mammography results were common in all age groups (Table 12). The rate was highest among women age 40 to 49 years (121.2 per 1,000 women; 95% CI 105.6 to 138.7) and declined with age (p<0.001). Rates of false-negative mammography results tended to increase with age, but were not statistically significantly different across age groups, and ranged from 1.0 to 1.5 per 1,000 women.

Table 12 Age-Specific Rates of False-Positive and False-Negative Digital Mammography Results and Recommendations for Additional Imaging and Biopsies From a Single Screening Round in the BCSC

| Age, y | | | | | Difference (P-value) *
| 40-49 | 50-59 | 60-69 | 70-79 | 80-89 | Difference (P-value) *
Women screened, n | 113,770 | 127,958 | 94,507 | 50,204 | 18,752
Invasive breast cancer cases, n | 349 | 574 | 651 | 427 | 154
DCIS cases, n | 191 | 246 | 208 | 120 | 43
Outcomes, n per 1,000 women screened (95% CI)
False-positive mammography result | 121.2 (105.6, 138.7) | 93.2 (82.8, 104.7) | 80.8 (72.9, 89.4) | 69.6 (62.6, 77.3) | 65.2 (58.8, 72.2) | <0.001
False-negative mammography result | 1.0 (0.9, 1.2) | 1.1 (0.9, 1.3) | 1.2 (0.9, 1.5) | 1.5 (1.1, 1.9) | 1.3 (0.9, 1.9) | 0.32
Additional imaging recommended^†^ | 124.9 (109.3, 142.3) | 98.5 (88.0, 110.1) | 88.7 (80.6, 97.4) | 79.0 (71.9, 86.9) | 74.4 (67.4, 82.2) | <0.001
Biopsy recommended^†^ | 16.4 (13.2, 20.3) | 15.9 (12.7, 19.7) | 16.5 (14.3, 19.1) | 17.5 (15.2, 20.2) | 15.6 (13.4, 18.2) | 0.12
Screen-detected invasive cancer | 2.2 (1.8, 2.6) | 3.5 (3.1, 4.0) | 5.8 (5.3, 6.4) | 7.2 (6.4, 8.1) | 7.1 (5.9, 8.5) | <0.001
Screen-detected DCIS | 1.6 (1.3, 1.9) | 1.8 (1.5, 2.2) | 2.1 (1.7, 2.5) | 2.3 (1.7, 3.0) | 2.1 (1.5, 3.0) | 0.05

* 2-sided P-values and 95% confidence intervals from a logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† After positive mammography result.

Abbreviations: CI=confidence interval; DCIS=ductal carcinoma in situ.

In current practice, women with an initial positive mammography result are recommended for additional diagnostic imaging as a second step in the screening process. In the BCSC data, rates of recommendations for additional imaging were highest among women age 40 to 49 years (124.9 per 1,000 women; 95% CI 109.3 to 142.3) and decreased with age (p<0.001). Rates of recommendations for biopsy were not statistically significantly different across age groups, and ranged from 15.6 to 17.5 per 1,000 women.

Rates of invasive breast cancer were lowest among women aged 40 to 49 years (2.2 per 1,000 women; 95% CI 1.8 to 2.6) and increased across age groups (p<0.001). Rates of DCIS were also lowest among women aged 40 to 49 years (1.6 per 1,000 women; 95% CI 1.3 to 1.9) and increased with age (p=0.05). Women aged 70 to 79 had the highest rates of invasive cancer (7.2 per 1,000 women; 95% CI 6.4 to 8.1) and DCIS (2.3 per 1,000 women; 95% CI 1.7 to 3.0), and the yield of screening was more favorable for older women. For every case of invasive breast cancer detected by mammography screening in women aged 40 to 49 years, 464 women had mammography, 58 were recommended for additional imaging, and 10 were recommended for biopsies. In comparison, for women aged 70 to 79, for every case of invasive breast cancer detected by screening, 139 women had mammography, 11 were recommended for additional imaging, and 3 were recommended for biopsies.

Differences by time since last mammography screening. Rates of false-positives, false-negatives, and recommendations for additional imaging did not differ in comparisons of times since last mammography screening regardless of interval durations (9 to 18 versus 19 to 30 months; 11 to 14 versus 23 to 26 months) (Table 13). Biopsies were recommended at a higher rate for women aged 60 to 69 years who had their last mammogram 23 to 26 months previously compared to 11 to 14 months (18.8 versus 15.2 per 1,000 women; p=0.03).

Table 13 Rates of False-Positive and False-Negative Digital Mammography Results and Recommendations for Additional Imaging and Biopsies Based on Time Since Last Mammography Examination^*^

Outcome | Time since last exam, mo | Age, y
Outcome | Time since last exam, mo | 40-49 | | 50-59 | | 60-69 | | 70-79 | | 80-89
Comparing 9-18 vs. 19-30 months
Women screened, n | 9-18 | 79,637 | | 91,864 | | 71,324 | | 39,474 | | 14,865
Women screened, n | 19-30 | 34,133 | | 36,094 | | 23,183 | | 10,730 | | 3,887
Invasive breast cancer cases, n | 9-18 | 240 | | 391 | | 474 | | 322 | | 119
Invasive breast cancer cases, n | 19-30 | 109 | | 183 | | 177 | | 105 | | 35
DCIS cases, n | 9-18 | 126 | | 185 | | 156 | | 94 | | 32
DCIS cases, n | 19-30 | 65 | | 61 | | 52 | | 26 | | 11
Outcomes, n per 1,000 women screened (95% CI)
False-positive mammography result | 9-18 | 122.1 (105.4, 141.0) | 0.65 | 94.2 (83.3, 106.5) | 0.37 | 80.6 (72.8, 89.2) | 0.89 | 69.1 (61.9, 77.0) | 0.55 | 66.5 (60.8, 72.8) | 0.22
False-positive mammography result | 19-30 | 119.0 (103.0, 137.1) | | 90.5 (80.4, 101.8) | | 81.1 (71.4, 92.1) | | 71.6 (62.2, 82.2) | | 60.2 (49.3, 73.3)
False-negative mammography result | 9-18 | 1.1 (0.9, 1.3) | 0.14 | 1.2 (1.0, 1.4) | 0.06 | 1.3 (1.0, 1.6) | 0.26 | 1.6 (1.2, 2.1) | 0.17 | 1.4 (0.9, 2.2) | 0.27
False-negative mammography result | 19-30 | 0.8 (0.6, 1.1) | | 0.9 (0.6, 1.2) | | 0.9 (0.6, 1.5) | | 1.0 (0.5, 2.0) | | 0.8 (0.3, 2.3)
Additional imaging recommended^†^ | 9-18 | 125.6 (109.0, 144.3) | 0.74 | 99.3 (88.2, 111.7) | 0.47 | 88.2 (80.2, 96.9) | 0.59 | 78.0 (70.7, 86.1) | 0.30 | 75.3 (68.6, 82.6) | 0.46
Additional imaging recommended^†^ | 19-30 | 123.3 (107.0, 141.7) | | 96.4 (85.9, 108.0) | | 90.1 (80.1, 101.2) | | 82.8 (72.5, 94.3) | | 71.3 (59.8, 84.8)
Biopsy recommended^†^ | 9-18 | 15.6 (12.8, 19.0) | 0.11 | 15.7 (12.7, 19.3) | 0.50 | 15.9 (14.0, 18.2) | 0.10 | 17.3 (15.2, 19.6) | 0.44 | 14.9 (12.4, 17.9) | 0.25
Biopsy recommended^†^ | 19-30 | 18.2 (13.7, 24.1) | | 16.4 (12.5, 21.4) | | 18.4 (14.7, 23.0) | | 18.5 (14.6, 23.5) | | 18.3 (13.9, 24.0)
Screen-detected invasive cancer | 9-18 | 2.0 (1.6, 2.5) | 0.12 | 3.2 (2.7, 3.7) | 0.009 | 5.5 (4.9, 6.2) | 0.07 | 6.7 (5.8, 7.7) | 0.04 | 6.8 (5.4, 8.5) | 0.39
Screen-detected invasive cancer | 19-30 | 2.5 (2.1, 3.0) | | 4.3 (3.7, 5.1) | | 6.8 (5.7, 8.1) | | 8.9 (7.4, 10.8) | | 8.2 (5.8, 11.6)
Screen-detected DCIS | 9-18 | 1.5 (1.2, 1.8) | 0.18 | 1.9 (1.5, 2.4) | 0.13 | 2.0 (1.8, 2.4) | 0.79 | 2.3 (1.7, 3.0) | 0.97 | 2.0 (1.2, 3.1) | 0.42
Screen-detected DCIS | 19-30 | 1.8 (1.4, 2.3) | | 1.6 (1.2, 2.0) | | 2.2 (1.4, 3.3) | | 2.2 (1.4, 3.6) | | 2.8 (1.5, 5.3)
Comparing 11-14 vs. 23-26 months
Women screened, n | 11-14 | 55,278 | | 65,219 | | 53,419 | | 30,497 | | 11,299
Women screened, n | 23-26 | 13,584 | | 14,407 | | 9,907 | | 4,291 | | 1,504
Invasive breast cancer cases, n | 11-14 | 163 | | 274 | | 348 | | 247 | | 78
Invasive breast cancer cases, n | 23-26 | 42 | | 70 | | 76 | | 41 | | 15
DCIS cases, n | 11-14 | 83 | | 127 | | 111 | | 71 | | 20
DCIS cases, n | 23-26 | 26 | | 22 | | 23 | | 12 | | 3
Outcomes, n per 1,000 women screened (95% CI)
False-positive mammography result | 11-14 | 119.1 (103.5, 136.8) | 0.69 | 93.3 (82.8, 105.0) | 0.46 | 79.2 (72.2, 86.8) | 0.91 | 67.6 (60.7, 75.2) | 0.70 | 63.8 (58.2, 69.9) | 0.71
False-positive mammography result | 23-26 | 115.8 (98.7, 135.4) | | 89.9 (78.8, 102.4) | | 79.6 (70.3, 90.2) | | 65.7 (56.7, 76.0) | | 61.2 (47.3, 78.7)
False-negative mammography result | 11-14 | 1.2 (1.0, 1.5) | 0.20 | 1.2 (1.0, 1.5) | 0.11 | 1.2 (0.9, 1.6) | 0.32 | 1.4 (1.1, 2.0) | 0.95 | 1.2 (0.7, 1.8) | 0.44
False-negative mammography result | 23-26 | 0.9 (0.5, 1.5) | | 0.8 (0.4, 1.4) | | 0.8 (0.4, 1.8) | | 1.4 (0.6, 3.4) | | 2.0 (0.7, 6.0)
Additional imaging recommended^†^ | 11-14 | 122.4 (106.7, 139.9) | 0.77 | 98.3 (87.7, 109.9) | 0.57 | 86.6 (79.5, 94.3) | 0.55 | 76.6 (69.3, 84.5) | 0.98 | 71.3 (65.4, 77.7) | 0.98
Additional imaging recommended^†^ | 23-26 | 119.9 (102.6, 139.7) | | 95.5 (83.9, 108.5) | | 88.8 (79.2, 99.5) | | 76.7 (66.5, 88.2) | | 71.1 (57.1, 88.3)
Biopsy recommended^†^ | 11-14 | 14.7 (12.2, 17.8) | 0.31 | 15.1 (12.2, 18.6) | 0.66 | 15.2 (13.5, 17.2) | 0.03 | 16.6 (14.5, 18.9) | 0.85 | 13.2 (10.8, 16.0) | 0.33
Biopsy recommended^†^ | 23-26 | 16.9 (11.9, 24.0) | | 15.8 (11.7, 21.3) | | 18.8 (15.2, 23.2) | | 17.0 (12.6, 23.0) | | 16.6 (11.2, 24.7)
Screen-detected invasive cancer | 11-14 | 1.8 (1.5, 2.3) | 0.31 | 3.1 (2.6, 3.7) | 0.05 | 5.5 (4.9, 6.2) | 0.07 | 6.8 (5.8, 7.9) | 0.35 | 5.9 (4.5, 7.8) | 0.33
Screen-detected invasive cancer | 23-26 | 2.3 (1.6, 3.2) | | 4.2 (3.3, 5.4) | | 7.0 (5.7, 8.5) | | 8.4 (5.7, 12.4) | | 8.0 (4.9, 13.1)
Screen-detected DCIS | 11-14 | 1.4 (1.1, 1.8) | 0.20 | 1.9 (1.4, 2.4) | 0.22 | 1.9 (1.6, 2.3) | 0.59 | 2.2 (1.6, 3.0) | 0.69 | 1.6 (0.9, 2.8) | 0.75
Screen-detected DCIS | 23-26 | 1.8 (1.3, 2.7) | | 1.4 (0.9, 2.1) | | 2.2 (1.3, 3.7) | | 2.6 (1.3, 5.1) | | 2.0 (0.6, 6.1)

* 2-sided P-values and 95% confidence intervals from a logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† After positive mammography result.

Abbreviations: CI=confidence interval; DCIS=ductal carcinoma in situ.

Additional published BCSC data about screening intervals indicated that sensitivity, recall rates, and cancer detection rates increased as the months since previous mammography increased, whereas specificity decreased.151

Differences by risk factors. Rates of false-positive mammography results were statistically significantly higher for women with specific risk factors compared with women without them (Table 14). These included women with first-degree relatives with breast cancer compared with no relatives for women aged 40 to 69 years. Women with heterogeneously dense breasts had higher false-positive rates than those with almost entirely fat and scattered fibroglandular densities, or extremely dense breasts, for all ages except aged 80 to 89 years. Rates were also higher among women with previous benign breast biopsies for aged 40 to 79 years. Comparisons based on race and ethnicity indicated the lowest rates among Asians for all age groups.

Table 14 Rates of False-Positive Results After Screening With Digital Mammography by Risk Factors^*^

Risk Factor | | Age, y
Risk Factor | | 40-49 | | 50-59 | | 60-69 | | 70-79 | | 80-89
Women screened, n | | 113,770 | | 127,958 | | 94,507 | | 50,204 | | 18,752
False-positive, n | | 13,784 | | 11,923 | | 7,633 | | 3,494 | | 1,223
Number per 1,000 women screened per round (95% CI)
First-degree relatives with breast cancer | None | 118.7 (104.3, 134.7) | 0.03 | 90.4 (81.1, 100.7) | 0.005 | 79.4 (71.8, 87.7) | 0.02 | 68.6 (61.1, 76.8) | 0.11 | 63.3 (56.8, 70.5) | 0.05
First-degree relatives with breast cancer | One or more | 139.8 (113.9, 170.5) | | 109.0 (92.3, 128.2) | | 87.2 (77.2, 98.4) | | 75.0 (67.6, 83.1) | | 73.1 (64.1, 83.3)
Breast density^†^ | Fat-Scattered | 108.4 (95.5, 122.7) | <0.001 | 80.5 (71.1, 90.9) | <0.001 | 74.1 (66.4, 82.6) | <0.001 | 67.3 (60.4, 74.9) | 0.003 | 60.3 (54.0, 67.4) | 0.001
Breast density^†^ | Hetero- geneous | 142.2 (120.2, 167.4) | | 115.8 (100.3, 133.2) | | 101.8 (91.0, 113.8) | | 88.7 (78.7, 99.9) | | 82.4 (72.6, 93.5)
Breast density^†^ | Extreme | 112.1 (94.4, 132.7) | | 92.7 (77.5, 110.5) | | 75.2 (64.7, 87.1) | | 57.7 (43.9, 75.5) | | 85.1 (61.7, 116.2)
Benign breast biopsy | None | 114.3 (99.8, 130.5) | 0.001 | 85.9 (76.7, 96.0) | <0.001 | 74.6 (66.8, 83.1) | <0.001 | 63.4 (56.2, 71.3) | <0.001 | 63.0 (56.3, 70.6) | 0.09
Benign breast biopsy | Previous | 167.3 (140.6, 197.9) | | 122.5 (106.2, 140.7) | | 98.6 (88.8, 109.3) | | 88.6 (79.1, 99.2) | | 71.6 (62.3, 82.3)
Race/ethnicity | White | 127.0 (115.5, 139.4) | 0.001 | 97.6 (89.5, 106.4) | 0.01 | 83.8 (77.4, 90.7) | 0.006 | 73.5 (67.7, 79.8) | <0.001 | 68.9 (62.6, 75.7) | 0.04
Race/ethnicity | Black | 92.6 (82.0, 104.5) | | 78.9 (65.2, 95.3) | | 64.5 (53.6, 77.3) | | 58.9 (51.7, 67.0) | | 52.4 (43.6, 63.0)
Race/ethnicity | Asian | 85.2 (72.2, 100.4) | | 67.6 (56.5, 80.7) | | 58.0 (47.9, 70.2) | | 43.6 (36.9, 51.6) | | 35.8 (29.6, 43.4)
Race/ethnicity | Hispanic | 125.4 (106.8, 146.7) | | 80.9 (69.1, 94.6) | | 72.9 (60.3, 87.8) | | 60.7 (50.6, 72.8) | | 55.7 (31.3, 97.2)
Race/ethnicity | Other | 127.8 (105.8, 153.6) | | 102.3 (88.5, 117.8) | | 91.5 (76.2, 109.5) | | 72.6 (53.3, 98.2) | | 48.9 (29.3, 80.6)
Menopausal hormone therapy | None | 123.3 (107.4, 141.2) | 0.69 | 91.8 (81.6, 103.2) | 0.27 | 76.2 (69.2, 84.0) | 0.22 | 67.6 (61.1, 74.8) | 0.01 | 62.2 (55.5, 69.8)
Menopausal hormone therapy | Combination | 122.0 (78.8, 184.1) | | 131.1 (99.5, 170.7) | | 122.5 (87.3, 169.2) | | 105.9 (81.8, 136.0) | | 94.0 (74.0, 118.8)
Menopausal hormone therapy | Estrogen | 108.7 (84.4, 138.8) | | 101.3 (87.1, 117.6) | | 97.6 (77.3, 122.5) | | 114.0 (94.8, 136.5) | | 89.1 (68.5, 115.1)
Oral contraceptives | No current | 122.9 (107.2, 140.6) | 0.05 | 93.6 (83.1, 105.4) | 0.63 | NA | | NA | | NA
Oral contraceptives | Current use | 106.2 (86.4, 130.0) | | 97.0 (81.3, 115.2)
Body mass index, kg/m^2^ | <25 | 129.0 (113.8, 145.9) | 0.009 | 99.5 (89.3, 110.8) | 0.04 | 85.8 (77.9, 94.4) | 0.14 | 70.5 (62.0, 80.0) | 0.78 | 73.9 (60.6, 89.8) | 0.33
Body mass index, kg/m^2^ | 25 to <30 | 124.8 (110.1, 141.2) | | 93.6 (85.0, 103.0) | | 78.6 (69.5, 88.9) | | 72.7 (64.8, 81.6) | | 62.2 (51.4, 75.1)
Body mass index, kg/m^2^ | ≥30 | 107.2 (96.0, 119.5) | | 86.1 (77.7, 95.2) | | 81.1 (74.1, 88.6) | | 74.2 (64.1, 85.7) | | 73.8 (59.1, 91.9)

* 2-sided P-values and 95% confidence intervals from a logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† Categories include: almost entirely fat=fat; scattered fibroglandular densities=scattered; heterogeneously dense=heterogeneous; and extremely dense=extreme.

Abbreviations: kg=kilogram; m=meter; NA=not applicable; peri=perimenopausal; pre=premenopausal; post=postmenopausal.

Premenopausal women had the highest false-positive rates for women aged 40 to 59 years compared with perimenopausal and postmenopausal women. Women using menopausal hormone therapy had the highest rates for aged 70 to 79 years, while comparisons for other age groups were not statistically significant. Women with lower body mass (BMI <30) had higher false positive rates for aged 40 to 59 years.

Rates of false-negative results were higher for women with first-degree relatives with breast cancer for aged 40 to 79 years, although results were of borderline statistical significance for aged 50 to 69 years (Table 15). Women with almost entirely fat and scattered fibroglandular densities had lower rates than those with other types of breast density for ages 40 to 69 years. Rates were higher among women with previous benign breast biopsies for aged 50 to 89 years, and women with lower body mass (BMI <30) for ages 50 to 59 years. Other comparisons between groups were not statistically significant.

Table 15 Rates of False-Negative Results After Screening With Digital Mammography by Risk Factors^*^

Risk Factor | | Age, y
Risk Factor | | 40-49 | | 50-59 | | 60-69 | | 70-79 | | 80-89
Women screened, n | | 113,770 | | 127,958 | | 94,507 | | 50,204 | | 18,752
False-negative mammography result, n | | 115 | | 139 | | 112 | | 73 | | 24
Number per 1,000 women screened per round (95% CI)
First-degree relatives with breast cancer | None | 0.9 (0.8, 1.1) | 0.02 | 1.0 (0.8, 1.2) | 0.09 | 1.1 (0.8, 1.4) | 0.10 | 1.2 (0.9, 1.6) | 0.01 | 1.2 (0.8, 1.9) | 0.49
First-degree relatives with breast cancer | One or more | 1.8 (1.3, 2.5) | | 1.6 (1.1, 2.4) | | 1.7 (1.1, 2.7) | | 2.4 (1.6, 3.7) | | 1.6 (0.8, 3.1)
Breast density | Fat-Scattered | 0.4 (0.3, 0.6) | <0.001 | 0.6 (0.4, 0.8) | 0.002 | 0.8 (0.5, 1.1) | 0.006 | 1.0 (0.6, 1.5) | 0.01 | 0.9 (0.5, 1.6) | 0.25
Breast density | Heterogeneous | 1.3 (1.0, 1.7) | | 1.4 (1.0, 2.0) | | 1.7 (1.3, 2.3) | | 2.3 (1.6, 3.4) | | 1.1 (0.5, 2.4)
Breast density | Extreme | 1.7 (1.2, 2.5) | | 1.6 (0.9, 2.8) | | 1.2 (0.6, 2.7) | | 5.6 (2.4, 12.9) | | 6.9 (2.5, 18.5)
Benign breast biopsy^†^ | None | 0.9 (0.8, 1.1) | 0.53 | 0.8 (0.7, 1.1) | 0.002 | 0.8 (0.6, 1.1) | 0.001 | 0.9 (0.6, 1.3) | 0.004 | 0.9 (0.5, 1.6) | 0.02
Benign breast biopsy^†^ | Previous | 1.1 (0.7, 1.7) | | 1.7 (1.3, 2.3) | | 2.1 (1.6, 2.8) | | 2.6 (1.8, 3.9) | | 2.6 (1.6, 4.2)
Race/ethnicity | White | 1.2 (1.0, 1.4) | 0.31 | 1.2 (0.9, 1.4) | 0.04 | 1.3 (1.0, 1.6) | 0.36 | 1.7 (1.2, 2.4) | 0.29 | 1.4 (0.9, 2.3) | 0.77
Race/ethnicity | Black | 0.7 (0.3, 1.4) | | 1.2 (0.6, 2.2) | | 1.5 (0.8, 2.9) | | 0.9 (0.3, 2.3) | | 1.0 (0.2, 6.4)
Race/ethnicity | Asian | 0.8 (0.5, 1.3) | | 1.1 (0.7, 1.7) | | 0.6 (0.3, 1.2) | | 0.8 (0.4, 1.6) | | 0^‡^
Race/ethnicity | Hispanic | 0.5 (0.2, 1.6) | | 0.2 (0.0, 1.1) | | 0.7 (0.2, 2.4) | | 0.8 (0.1, 4.6) | | 3.3 (0.4, 23.9)
Race/ethnicity | Other | 1.1 (0.4, 3.2) | | 1.6 (0.6, 4.1) | | 1.2 (0.2, 7.1) | | 1.5 (0.3, 8.5) | | 5.4 (1.0, 27.8)
Menopausal status | Pre | 1.2 (1.0, 1.4) | 0.17 | 1.3 (0.9, 1.9) | 0.53 | NA | | NA | | NA
Menopausal status | Peri | 0.8 (0.2, 2.5) | | 1.0 (0.5, 2.1)
Menopausal status | Post | 0.7 (0.4, 1.3) | | 1.0 (0.8, 1.3)
Menopausal hormone therapy | None | 1.0 (0.9, 1.2) | 0.76 | 1.0 (0.8, 1.2) | 0.37 | 1.0 (0.8, 1.3) | 0.33 | 1.3 (0.9, 1.8) | 0.58 | 1.2 (0.8, 2.0) | 0.62
Menopausal hormone therapy | Combination | 0^‡^ | | 1.9 (0.9, 3.7) | | 2.3 (1.0, 5.6) | | 0^‡^ | | 3.1 (1.5, 6.6)
Menopausal hormone therapy | Estrogen only | 1.5 (0.2, 10.1) | | 0.4 (0.1, 2.6) | | 1.2 (0.4, 3.1) | | 0.8 (0.1, 5.6) | | 2.5 (0.4, 13.7)
Oral contraceptives | No current | 1.0 (0.8, 1.2) | 0.77 | 1.1 (0.9, 1.3) | 0.54 | NA | | NA | | NA
Oral contraceptives | Current use | 1.1 (0.6, 2.1) | | 1.4 (0.6, 3.5)
Body mass index, kg/m^2^ | <25 | 1.4 (1.2, 1.7) | 0.06 | 1.3 (1.0, 1.6) | 0.008 | 1.3 (0.9, 1.8) | 0.66 | 2.4 (1.6, 3.6) | 0.09 | 1.7 (0.7, 3.8) | 0.96
Body mass index, kg/m^2^ | 25 to <30 | 0.8 (0.6, 1.3) | | 1.0 (0.7, 1.6) | | 1.2 (0.7, 2.1) | | 1.0 (0.5, 1.8) | | 1.6 (0.7, 3.7)
Body mass index, kg/m^2^ | ≥30 | 0.7 (0.3, 1.4) | | 0.4 (0.2, 0.8) | | 1.0 (0.6, 1.8) | | 1.0 (0.4, 2.4) | | 0^‡^

* 2-sided P-value and 95% confidence intervals from logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† Categories include: almost entirely fat=fatty; scattered fibroglandular densities=scattered; heterogeneously dense=heterogeneous; and extremely dense=extreme.

‡ No false-negative outcomes. Category omitted from model used to obtain CI and P-value.

Abbreviations: kg=kilogram; m=meter; NA=not applicable; peri=perimenopausal; pre=premenopausal; post=postmenopausal.

Risk factors associated with differences in rates of recommendations for additional imaging were similar to those for false positive mammography results (Table 16). Rates were highest among women with first-degree relatives with breast cancer for all ages, heterogeneously dense breasts (ages 40 to 79), previous benign breast biopsies (ages 40 to 79), premenopausal status (ages 40 to 50), use of menopausal hormone therapy (age 70 to 79), and lower BMI (ages 40 to 49). Comparisons based on race and ethnicity indicated the lowest rates among Asians for all age groups.

Table 16 Rates of Recommendations for Additional Imaging After Screening With Digital Mammography by Risk Factors^*^

Risk Factor | | Age, y
Risk Factor | | 40-49 | | 50-59 | | 60-69 | | 70-79 | | 80-89
Women screened, n | | 113,770 | | 127,958 | | 94,507 | | 50,204 | | 18,752
Additional imaging recommended, n | | 14,209 | | 12,604 | | 8,380 | | 3,968 | | 1,396
Number per 1,000 women screened per round (95% CI)
First-degree relatives with breast cancer | None | 122.1 (107.7, 138.1) | 0.02 | 95.2 (85.8, 105.6) | 0.003 | 86.7 (79.0, 95.1) | 0.002 | 77.5 (69.9, 85.7) | 0.02 | 71.7 (64.6, 79.5) | 0.01
First-degree relatives with breast cancer | One or more | 145.6 (119.6, 176.2) | | 117.1 (99.7, 137.0) | | 98.3 (87.9, 109.8) | | 86.9 (79.1, 95.4) | | 86.0 (75.5, 97.7)
Breast density | Fat-Scattered | 110.8 (97.9, 125.2) | 0.001 | 84.4 (74.8, 95.1) | <0.001 | 81.0 (73.1, 89.6) | <0.001 | 75.6 (68.5, 83.4) | 0.003 | 68.9 (61.7, 76.9) | 0.002
Breast density | Heterogeneous | 146.0 (123.9, 171.3) | | 121.6 (105.8, 139.3) | | 110.6 (99.7, 122.6) | | 99.0 (87.9, 111.4) | | 93.6 (82.4, 106.2)
Breast density | Extreme | 116.5 (98.4, 137.4) | | 98.4 (83.1, 116.2) | | 81.0 (70.3, 93.2) | | 63.3 (49.7, 80.1) | | 92.0 (66.6, 125.7)
Benign breast biopsy | None | 117.8 (103.4, 134.0) | 0.001 | 90.9 (81.7, 101.0) | <0.001 | 81.9 (74.1, 90.6) | <0.001 | 72.2 (65.1, 79.9) | <0.001 | 72.1 (64.3, 80.7) | 0.07
Benign breast biopsy | Previous | 172.5 (145.9, 202.8) | | 129.3 (112.8, 147.8) | | 108.2 (98.2, 118.9) | | 100.5 (90.0, 112.1) | | 82.7 (72.9, 93.7)
Race/ethnicity | White | 131.1 (119.4, 143.8) | 0.001 | 103.2 (94.8, 112.3) | 0.01 | 92.4 (85.7, 99.4) | 0.005 | 83.3 (77.1, 90.1) | 0.004 | 78.0 (71.1, 85.5) | 0.11
Race/ethnicity | Black | 95.9 (85.0, 108.0) | | 82.6 (68.4, 99.4) | | 70.8 (59.3, 84.3) | | 66.3 (59.1, 74.4) | | 60.3 (49.1, 74.0)
Race/ethnicity | Asian | 89.1 (76.0, 104.2) | | 73.5 (62.1, 86.8) | | 64.6 (54.0, 77.0) | | 52.6 (44.9, 61.4) | | 40.5 (33.4, 48.9)
Race/ethnicity | Hispanic | 127.8 (109.2, 149.0) | | 84.6 (71.9, 99.3) | | 76.9 (64.1, 92.0) | | 72.1 (61.6, 84.3) | | 62.3 (38.7, 98.9)
Race/ethnicity | Other | 131.6 (109.8, 157.1) | | 109.8 (97.1, 123.8) | | 98.8 (82.5, 117.8) | | 84.7 (64.0, 111.3) | | 65.2 (39.4, 106.2)
Menopausal status | Pre | 135.4 (117.4, 155.6) | 0.01 | 124.6 (113.6, 136.4) | <0.001 | NA | | NA | | NA
Menopausal status | Peri | 109.0 (92.8, 127.7) | | 101.4 (78.7, 129.8)
Menopausal status | Post | 114.2 (103.1, 126.4) | | 92.7 (84.0, 102.1)
Menopausal hormone therapy | None | 127.0 (111.2, 144.8) | 0.63 | 97.0 (86.7, 108.5) | 0.28 | 83.8 (76.5, 91.7) | 0.18 | 76.5 (69.8, 83.9) | 0.01 | 71.5 (64.2, 79.6) | 0.20
Menopausal hormone therapy | Combination | 125.8 (83.6, 185.0) | | 137.4 (105.5, 177.1) | | 129.5 (96.3, 172.0) | | 120.7 (94.9, 152.4) | | 106.6 (79.4, 141.6)
Menopausal hormone therapy | Estrogen only | 110.1 (85.6, 140.7) | | 105.4 (90.9, 121.8) | | 106.1 (86.0, 130.3) | | 125.1 (106.4, 146.6) | | 106.4 (82.6, 136.1)
Oral contraceptives | No current | 126.6 (110.9, 144.2) | 0.05 | 99.0 (88.3, 110.7) | 0.85 | NA | | NA | | NA
Oral contraceptives | Current use | 110.4 (90.9, 133.6) | | 100.3 (84.4, 118.9)
Body mass index, kg/m^2^ | <25 | 133.9 (118.1, 151.3) | 0.006 | 105.9 (95.6, 117.2) | 0.05 | 93.4 (85.4, 102.1) | 0.31 | 79.5 (70.5, 89.5) | 0.28 | 83.4 (69.8, 99.5) | 0.20
Body mass index, kg/m^2^ | 25 to <30 | 129.2 (114.7, 145.2) | | 99.3 (90.4, 108.9) | | 88.7 (79.1, 99.4) | | 84.1 (75.5, 93.6) | | 69.5 (58.5, 82.3)
Body mass index, kg/m^2^ | ≥30 | 110.7 (99.4, 123.2) | | 93.1 (84.2, 102.8) | | 89.2 (82.1, 96.8) | | 89.3 (78.5, 101.5) | | 88.4 (71.5, 108.8)

* 2-sided P-values and 95% confidence intervals from a logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† Categories include: almost entirely fat=fat; scattered fibroglandular densities=scattered; heterogeneously dense=heterogeneous; and extremely dense=extreme.

Abbreviations: kg=kilogram; m=meter; NA=not applicable; peri=perimenopausal; pre=premenopausal; post=postmenopausal.

Rates of recommendations for biopsy were statistically significantly higher for women aged 40 to 69 years with first-degree relatives with breast cancer, and for women aged 40 to 79 years with previous breast biopsies (Table 17). Women aged 40 to 59 years with heterogeneously dense or extremely dense breasts had higher rates than women with less dense breasts, while for women aged 60 to 79 years, rates were highest for women with heterogeneously dense breasts only. Higher rates were also associated with premenopausal status for age 50 to 59 years; no current use of oral contraceptives for age 40 to 49 years; lower BMI for age 40 to 49, but higher BMI for age 70 to 79. Other comparisons between groups were not statistically significant.

Table 17 Rates of Recommendations for Biopsy After Screening With Digital Mammography by Risk Factors^*^

Risk Factor | | Age, y
Risk Factor | | 40-49 | | 50-59 | | 60-69 | | 70-79 | | 80-89
Women screened, n | | 113,770 | | 127,958 | | 94,507 | | 50,204 | | 18,752
Biopsy recommended, n | | 1,863 | | 2,030 | | 1,562 | | 880 | | 293
Number per 1,000 women screened per round (95% CI)
First-degree relatives with breast cancer | None | 15.7 (12.6, 19.4) | 0.002 | 14.8 (11.8, 18.4) | <0.001 | 15.8 (13.7, 18.3) | 0.002 | 17.0 (14.7, 19.6) | 0.09 | 15.2 (12.8, 18.0) | 0.24
First-degree relatives with breast cancer | One or more | 21.1 (16.9, 26.3) | | 21.9 (17.5, 27.3) | | 20.1 (17.0, 23.7) | | 20.3 (16.7, 24.6) | | 17.6 (14.1, 22.1)
Breast density^†^ | Fat-Scattered | 12.2 (9.9, 15.0) | <0.001 | 11.8 (9.6, 14.5) | <0.001 | 15.6 (13.7, 17.7) | 0.008 | 16.2 (14.2, 18.4) | 0.007 | 14.2 (12.0, 16.8) | 0.07
Breast density^†^ | Heterogeneous | 18.9 (15.8, 22.5) | | 20.2 (17.3, 23.7) | | 19.3 (16.9, 22.2) | | 21.0 (18.0, 24.5) | | 19.0 (15.5, 23.2)
Breast density^†^ | Extreme | 20.2 (16.8, 24.3) | | 19.2 (14.3, 25.7) | | 13.8 (10.5, 18.2) | | 13.0 (7.2, 23.3) | | 16.1 (8.0, 32.1)
Benign breast biopsy | None | 14.8 (11.8, 18.7) | <0.001 | 13.9 (11.1, 17.3) | <0.002 | 15.0 (12.7, 17.8) | <0.001 | 15.3 (13.1, 17.7) | <0.001 | 15.8 (13.4, 18.7) | 0.54
Benign breast biopsy | Previous | 27.8 (22.8, 33.7) | | 25.1 (20.1, 31.2) | | 21.8 (19.1, 24.9) | | 25.2 (21.4, 29.7) | | 17.1 (13.7, 21.5)
Race/ethnicity | White | 16.7 (13.7, 20.3) | 0.21 | 16.6 (13.6, 20.2) | 0.39 | 17.6 (15.6, 20.0) | 0.05 | 18.7 (16.6, 21.2) | 0.23 | 16.2 (13.5, 19.4) | 0.12
Race/ethnicity | Black | 13.6 (10.4, 17.8) | | 14.7 (10.4, 20.6) | | 13.9 (10.6, 18.0) | | 14.9 (11.4, 19.5) | | 8.9 (4.4, 18.0)
Race/ethnicity | Asian | 16.2 (10.6, 24.5) | | 14.8 (9.5, 22.9) | | 12.0 (6.9, 20.6) | | 11.8 (6.8, 20.3) | | 9.2 (5.6, 15.3)
Race/ethnicity | Hispanic | 16.3 (10.3, 25.6) | | 11.9 (8.1, 17.5) | | 14.2 (11.4, 17.6) | | 15.9 (10.1, 25.1) | | 16.4 (8.5, 31.5)
Race/ethnicity | Other | 19.8 (14.4, 27.3) | | 17.4 (10.5, 28.6) | | 16.4 (10.8, 24.8) | | 16.6 (10.0, 27.6) | | 5.4 (0.7, 39.2)
Menopausal status | Pre | 17.6 (14.0, 22.1) | 0.49 | 19.8 (15.7, 24.9) | 0.02 | NA | | NA | | NA
Menopausal status | Peri | 17.8 (14.4, 22.0) | | 16.4 (10.6, 25.4)
Menopausal status | Post | 15.8 (12.5, 20.0) | | 15.4 (12.1, 19.4)
Menopausal hormone therapy | None | 16.3 (13.2, 20.2) | 0.34 | 15.6 (12.6, 19.2) | 0.50 | 15.9 (13.9, 18.3) | 0.37 | 17.2 (15.1, 19.4) | 0.14 | 15.2 (12.8, 17.9) | 0.13
Menopausal hormone therapy | Combination | 15.2 (8.2, 28.2) | | 18.3 (12.7, 26.3) | | 16.9 (12.6, 22.6) | | 33.0 (23.7, 45.9) | | 21.9 (14.0, 34.2)
Menopausal hormone therapy | Estrogen only | 26.4 (14.7, 47.2) | | 18.3 (12.3, 27.2) | | 21.0 (14.5, 30.2) | | 25.3 (17.7, 36.1) | | 32.2 (22.2, 46.4)
Oral contraceptives | No current | 16.7 (13.6, 20.6) | 0.007 | 16.0 (13.1, 19.5) | 0.32 | NA | | NA | | NA
Oral contraceptives | Current use | 12.5 (9.5, 16.3) | | 13.0 (7.0, 24.3)
Body mass index, kg/m^2^ | <25 | 21.4 (17.0, 26.8) | 0.02 | 19.3 (14.7, 25.1) | 0.40 | 17.4 (14.4, 21.0) | 0.12 | 16.5 (13.5, 20.1) | 0.02 | 17.1 (13.8, 21.2) | 0.26
Body mass index, kg/m^2^ | 25 to <30 | 17.6 (13.7, 22.6) | | 18.0 (13.3, 24.4) | | 18.9 (15.3, 23.4) | | 21.9 (18.2, 26.3) | | 16.6 (12.5, 21.9)
Body mass index, kg/m^2^ | ≥30 | 15.3 (12.3, 19.2) | | 18.4 (14.5, 23.4) | | 22.2 (18.1, 27.2) | | 26.7 (21.9, 32.4) | | 26.6 (18.5, 38.1)

* 2-sided P-values and 95% confidence intervals from a logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† Categories include: almost entirely fat=fat; scattered fibroglandular densities=scattered; heterogeneously dense=heterogeneous; and extremely dense=extreme.

Abbreviations: kg=kilogram; m=meter; NA=not applicable; peri=perimenopausal; pre=premenopausal; post=postmenopausal.

Rates of false-positives, false-negatives, recommendations for additional imaging, and recommendations for biopsies were lowest for women with almost entirely fat breasts for all ages. False-negative rates were highest for women with extremely dense breasts for all ages, except those aged 60 to 69 years (Table 18). Rates of false-positives, recommendations for additional imaging, and recommendations for biopsies were highest for women with heterogeneously dense breasts or for the combined category of heterogeneously and extremely dense breasts, except for women aged 40 to 49 years where rates of recommendations for biopsies were highest among women with extremely dense breasts.

Table 18 Rates of False-Positive and False-Negative Digital Mammography Results and Recommendations for Additional Imaging and Biopsies by Different Breast Density Categories^*^

| | Age, y
| | 40-49 | | 50-59 | | 60-69 | | 70-79 | | 80-89
Women screened, n | | 113,770 | | 127,958 | | 94,507 | | 50,204 | | 18,752
False-positive mammography results Number per 1,000 women screened per round (95% CI)
A | Fat-Scattered | 108.4 (95.5, 122.7) | <0.001 | 80.5 (71.1, 90.9) | <0.001 | 74.1 (66.4, 82.6) | <0.001 | 67.3 (60.4, 74.9) | 0.003 | 60.3 (54.0, 67.4) | 0.001
A | Heterogeneous | 142.2 (120.2, 167.4) | | 115.8 (100.3, 133.2) | | 101.8 (91.0, 113.8) | | 88.7 (78.7, 99.9) | | 82.4 (72.6, 93.5)
A | Extreme | 112.1 (94.4, 132.7) | | 92.7 (77.5, 110.5) | | 75.2 (64.7, 87.1) | | 57.7 (43.9, 75.5) | | 85.1 (61.7, 116.2)
B | Fat | 63.0 (51.2, 77.4) | <0.001 | 52.1 (44.9, 60.3) | <0.001 | 48.5 (43.1, 54.4) | <0.001 | 45.4 (39.7, 51.9) | <0.001 | 39.5 (32.1, 48.5) | <0.001
B | Scattered | 116.8 (102.9, 132.3) | | 87.7 (77.1, 99.6) | | 81.6 (72.7, 91.4) | | 73.4 (65.4, 82.2) | | 65.8 (58.4, 73.9)
B | Heterogeneous-Extreme | 135.3 (113.9, 160.0) | | 112.0 (96.9, 129.2) | | 98.9 (88.4, 110.4) | | 86.2 (76.4, 97.1) | | 82.7 (72.6, 93.9)
C | Fat | 63.0 (51.2, 77.4) | <0.001 | 52.1 (44.9, 60.3) | <0.001 | 48.5 (43.1, 54.4) | <0.001 | 45.4 (39.7, 51.9) | <0.001 | 39.5 (32.1, 48.5) | <0.001
C | Scattered | 116.8 (102.9, 132.3) | | 87.7 (77.1, 99.6) | | 81.6 (72.7, 91.4) | | 73.4 (65.4, 82.2) | | 65.8 (58.4, 73.9)
C | Heterogeneous | 142.2 (120.2, 167.4) | | 115.8 (100.3, 133.2) | | 101.8 (91.0, 113.8) | | 88.7 (78.7, 99.9) | | 82.4 (72.6, 93.5)
C | Extreme | 112.1 (94.4, 132.7) | | 92.7 (77.5, 110.5) | | 75.2 (64.7, 87.1) | | 57.7 (43.9, 75.5) | | 85.1 (61.7, 116.2)
D | Fat-Scattered | 108.4 (95.5, 122.7) | 0.003 | 80.5 (71.1, 90.9) | <0.001 | 74.1 (66.4, 82.6) | <0.001 | 67.3 (60.4, 74.9) | <0.001 | 60.3 (54.0, 67.4) | <0.001
D | Heterogeneous-Extreme | 135.3 (113.9, 160.0) | | 112.0 (96.9, 129.2) | | 98.9 (88.4, 110.4) | | 86.2 (76.4, 97.1) | | 82.7 (72.6, 93.9)
False-negative mammography results Number per 1,000 women screened per round (95% CI)
A | Fat-Scattered | 0.4 (0.3, 0.6) | <0.001 | 0.6 (0.4, 0.8) | 0.002 | 0.8 (0.5, 1.1) | 0.006 | 1.0 (0.6, 1.5) | 0.01 | 0.9 (0.5, 1.6) | 0.25
A | Heterogeneous | 1.3 (1.0, 1.7) | | 1.4 (1.0, 2.0) | | 1.7 (1.3, 2.3) | | 2.3 (1.6, 3.4) | | 1.1 (0.5, 2.4)
A | Extreme | 1.7 (1.2, 2.5) | | 1.6 (0.9, 2.8) | | 1.2 (0.6, 2.7) | | 5.6 (2.4, 12.9) | | 6.9 (2.5, 18.5)
B | Fat | 0.2 (0.0, 0.9) | <0.001 | 0.3 (0.1, 0.7) | <0.001 | 0.6 (0.2, 1.5) | 0.007 | 0.3 (0.1, 1.1) | 0.001 | 0.4 (0.1, 3.1) | 0.14
B | Scattered | 0.5 (0.3, 0.7) | | 0.7 (0.5, 0.9) | | 0.8 (0.6, 1.2) | | 1.2 (0.7, 1.9) | | 1.0 (0.6, 1.7)
B | Heterogeneous-Extreme | 1.4 (1.2, 1.8) | | 1.5 (1.1, 1.9) | | 1.6 (1.2, 2.2) | | 2.6 (1.8, 3.7) | | 1.7 (0.8, 3.3)
C | Fat | 0.2 (0.0, 0.9) | <0.001 | 0.3 (0.1, 0.7) | <0.001 | 0.6 (0.2, 1.5) | 0.02 | 0.3 (0.1, 1.1) | 0.002 | 0.4 (0.1, 3.1) | 0.17
C | Scattered | 0.5 (0.3, 0.7) | | 0.7 (0.5, 0.9) | | 0.8 (0.6, 1.2) | | 1.2 (0.7, 1.9) | | 1.0 (0.6, 1.7)
C | Heterogeneous | 1.3 (1.0, 1.7) | | 1.4 (1.0, 2.0) | | 1.7 (1.3, 2.3) | | 2.3 (1.6, 3.4) | | 1.1 (0.5, 2.4)
C | Extreme | 1.7 (1.2, 2.5) | | 1.6 (0.9, 2.8) | | 1.2 (0.6, 2.7) | | 5.6 (2.4, 12.9) | | 6.9 (2.5, 18.5)
D | Fat-Scattered | 0.4 (0.3, 0.6) | <0.001 | 0.6 (0.4, 0.8) | <0.001 | 0.8 (0.5, 1.1) | 0.002 | 1.0 (0.6, 1.5) | 0.003 | 0.9 (0.5, 1.6) | 0.18
D | Heterogeneous-Extreme | 1.4 (1.2, 1.8) | | 1.5 (1.1, 1.9) | | 1.6 (1.2, 2.2) | | 2.6 (1.8, 3.7) | | 1.7 (0.8, 3.3)
Recommendations for additional imaging Number per 1,000 women screened per round (95% CI)
A | Fat-Scattered | 110.8 (97.9, 125.2) | 0.001 | 84.4 (74.8, 95.1) | <0.001 | 81.0 (73.1, 89.6) | <0.001 | 75.6 (68.5, 83.4) | 0.003 | 68.9 (61.7, 76.9) | 0.002
A | Heterogeneous | 146.0 (123.9, 171.3) | | 121.6 (105.8, 139.3) | | 110.6 (99.7, 122.6) | | 99.0 (87.9, 111.4) | | 93.6 (82.4, 106.2)
A | Extreme | 116.5 (98.4, 137.4) | | 98.4 (83.1, 116.2) | | 81.0 (70.3, 93.2) | | 63.3 (49.7, 80.1) | | 92.0 (66.6, 125.7)
B | Fat | 64.4 (52.3, 79.1) | <0.001 | 54.1 (46.5, 62.8) | <0.001 | 53.4 (47.9, 59.4) | <0.001 | 52.0 (46.5, 58.2) | <0.001 | 44.8 (36.6, 54.6) | <0.001
B | Scattered | 119.4 (105.5, 135.0) | | 92.1 (81.2, 104.3) | | 89.0 (79.9, 99.1) | | 82.1 (73.9, 91.2) | | 75.2 (66.5, 84.8)
B | Heterogeneous-Extreme | 139.3 (117.7, 164.1) | | 117.8 (102.4, 135.3) | | 107.3 (96.7, 118.9) | | 96.1 (85.5, 107.9) | | 93.5 (82.1, 106.3)
C | Fat | 64.4 (52.3, 79.1) | <0.001 | 54.1 (46.5, 62.8) | <0.001 | 53.4 (47.9, 59.4) | <0.001 | 52.0 (46.5, 58.2) | <0.001 | 44.8 (36.6, 54.6) | 0.001
C | Scattered | 119.4 (105.5, 135.0) | | 92.1 (81.2, 104.3) | | 89.0 (79.9, 99.1) | | 82.1 (73.9, 91.2) | | 75.2 (66.5, 84.8)
C | Heterogeneous | 146.0 (123.9, 171.3) | | 121.6 (105.8, 139.3) | | 110.6 (99.7, 122.6) | | 99.0 (87.9, 111.4) | | 93.6 (82.4, 106.2)
C | Extreme | 116.5 (98.4, 137.4) | | 98.4 (83.1, 116.2) | | 81.0 (70.3, 93.2) | | 63.3 (49.7, 80.1) | | 92.0 (66.6, 125.7)
D | Fat-Scattered | 110.8 (97.9, 125.2) | 0.003 | 84.4 (74.8, 95.1) | <0.001 | 81.0 (73.1, 89.6) | <0.001 | 75.6 (68.5, 83.4) | 0.001 | 68.9 (61.7, 76.9) | <0.001
D | Heterogeneous-Extreme | 139.3 (117.7, 164.1) | | 117.8 (102.4, 135.3) | | 107.3 (96.7, 118.9) | | 96.1 (85.5, 107.9) | | 93.5 (82.1, 106.3)
Recommendations for biopsy Number per 1,000 women screened per round (95% CI)
A | Fat-Scattered | 12.2 (9.9, 15.0) | <0.001 | 11.8 (9.6, 14.5) | <0.001 | 15.6 (13.7, 17.7) | 0.008 | 16.2 (14.2, 18.4) | 0.007 | 14.2 (12.0, 16.8) | 0.07
A | Heterogeneous | 18.9 (15.8, 22.5) | | 20.2 (17.3, 23.7) | | 19.3 (16.9, 22.2) | | 21.0 (18.0, 24.5) | | 19.0 (15.5, 23.2)
A | Extreme | 20.2 (16.8, 24.3) | | 19.2 (14.3, 25.7) | | 13.8 (10.5, 18.2) | | 13.0 (7.2, 23.3) | | 16.1 (8.0, 32.1)
B | Fat | 7.5 (5.5, 10.1) | <0.001 | 8.4 (6.0, 11.7) | <0.001 | 11.7 (9.5, 14.6) | <0.001 | 12.8 (10.2, 16.1) | 0.003 | 9.7 (5.8, 16.0) | 0.04
B | Scattered | 13.1 (10.6, 16.1) | | 12.7 (10.3, 15.6) | | 16.7 (14.7, 19.0) | | 17.1 (14.9, 19.6) | | 15.4 (12.5, 18.8)
B | Heterogeneous-Extreme | 19.2 (16.2, 22.7) | | 20.1 (16.9, 23.7) | | 18.7 (16.6, 21.2) | | 20.4 (17.4, 23.8) | | 18.7 (15.2, 23.0)
C | Fat | 7.5 (5.5, 10.1) | <0.001 | 8.4 (6.0, 11.7) | <0.001 | 11.7 (9.5, 14.6) | <0.001 | 12.8 (10.2, 16.1) | 0.003 | 9.7 (5.8, 16.0) | 0.06
C | Scattered | 13.1 (10.6, 16.1) | | 12.7 (10.3, 15.6) | | 16.7 (14.7, 19.0) | | 17.1 (14.9, 19.6) | | 15.4 (12.5, 18.8)
C | Heterogeneous | 18.9 (15.8, 22.5) | | 20.2 (17.3, 23.7) | | 19.3 (16.9, 22.2) | | 21.0 (18.0, 24.5) | | 19.0 (15.5, 23.2)
C | Extreme | 20.2 (16.8, 24.3) | | 19.2 (14.3, 25.7) | | 13.8 (10.5, 18.2) | | 13.0 (7.2, 23.3) | | 16.1 (8.0, 32.1)
D | Fat-Scattered | 12.2 (9.9, 15.0) | <0.001 | 11.8 (9.6, 14.5) | <0.001 | 15.6 (13.7, 17.7) | 0.002 | 16.2 (14.2, 18.4) | 0.008 | 14.2 (12.0, 16.8) | 0.03
D | Heterogeneous-Extreme | 19.2 (16.2, 22.7) | | 20.1 (16.9, 23.7) | | 18.7 (16.6, 21.2) | | 20.4 (17.4, 23.8) | | 18.7 (15.2, 23.0)

* 2-sided P-values and 95% confidence intervals from a logistic regression model that accounts for clustering by radiology facility using generalized estimating equations.

† Categories include: almost entirely fat=fat; scattered fibroglandular densities=scattered; heterogeneously dense=heterogeneous; and extremely dense=extreme.

Table 19 U.S. Studies of Cumulative False-Positive Mammography and Biopsy Results

Author, year | Study design | Population; age, years; participants, n | Study years; comparison | Outcome measures | Results
New studies
Hubbard et al, 2011^143^ | Post-intervention series | U.S., 7 mammography registries in the BCSC; 40-59; 169,456 | 1994-2006; annual vs. biennial screening by age | FP results (no diagnosis of invasive carcinoma or DCIS within 1 year of screening or before the next screening); recalls (BIRADS 0, 3, 4, 5) | Cumulative probability of FP mammography after 10 years, % (95% CI); - Age 40: annual, 61.3 (59.4 to 63.1); biennial, 41.6 (40.6 to 42.5); - Age 50: annual, 61.3 (58.0 to 64.7); biennial, 42.0 (40.4 to 43.7); Cumulative probability of FP biopsy after 10 years, % (95% CI); - Age 40: annual, 7.0 (6.1 to 7.8); biennial, 4.8 (4.4 to 5.2); - Age 50: annual, 9.4 (7.4 to 11.5); biennial, 6.4 (5.6 to 7.2)
Kerlikowske et al, 2013^144^ | Post-intervention series | U.S., 7 mammography registries in the BCSC; 40-74; 11,474 with breast cancer, 922,2624 without | 1994-2008; annual vs. biennial vs. triennial screening by age, breast density, and menopausal hormone therapy | FP results (no diagnosis of invasive carcinoma or DCIS within 1 year of screening or before the next screening mammogram), recalls (BIRADS 0, 3, 4, 5) | Cumulative probability of FP mammography after 10 years, by breast density,^*^ % (95% CI); - Age 40-49: annual: 36 (34 to 38); 60 (59 to 61); 69 (68 to 70); 66 (64 to 67); biennial: 21 (20 to 22); 39 (38 to 39); 46 (46 to 47); 43 (42 to 44); triennial: 14 (13 to 15); 27 (26 to 27); 33 (31 to 34); 33 (32 to 34).; - Age 50-74: annual: 30 (29 to 31); 50 (49 to 51); 60 (59 to 61); 59 (57 to 60); biennial: 17 (17 to 18); 31 (30 to 31); 39 (38 to 39); 38 (37 to 38); triennial: 12 (12 to 13); 22 (21 to 22); 28 (28 to 29); 27 (26 to 28).; Cumulative probability of FP biopsy after 10 years, by breast density,^*^ % (95% CI); - Age 40-49: annual: 6 (5 to 7); 9 (8 to 10); 12 (11 to 14); 12 (11 to 14); biennial: 3 (2 to 3); 5 (4 to 5); 7 (6 to 7); 7 (6 to 7); triennial: 2 (2 to 2); 3 (3 to 4); 4 (3 to 4); 3 (2 to 4).; - Age 50-74: annual: 5 (5 to 6); 8 (8 to 9); 11 (10 to 12); 11 (10 to 12); biennial: 3 (3 to 3); 5 (4 to 5); 6 (6 to 7); 6 (6 to 7); triennial: 2 (2 to 2); 3 (3 to 4); 5 (4 to 5); 5 (4 to 5).; Highest cumulative rates of FP mammography (66% to 69%) or biopsy (12% to 14%): annual mammography; extremely or heterogeneously dense breasts; age 40-49; used combined HT.
2009 review
Elmore et al, 1998^149^ | Post-intervention series | U.S., randomly sampled patients from 11 health centers in an HMO; 40-69 | 1983-1995; annual vs. biennial screening | FP test results (not a true positive=breast cancer diagnosed on the basis of pathological findings within 1 year of mammography) | Cumulative risk of at least one FP after 10 screening mammograms, % (95% CI); - Age 40-49: 56 (39.5 to 75.8); Age 50-59: 47 (37.8 to 63.0);; - Overall: 49 (40.3 to 64.1).; Cumulative risk of FP biopsy, % (95% CI); - Overall: 19 (9.8 to 41.2)

* Categories include: fatty; scattered fibroglandular densities; heterogenously dense; extremely dense.

Abbreviations: BCSC=Breast Cancer Surveillance Consortium; BIRADS=Breast Imaging Reporting and Data System; CI=confidence interval; DCIS=ductal carcinoma in situ; FP=false-positive; HMO=health maintenance organization; HT=hormone therapy; n=number; U.S.=United States; vs.=versus.

Two studies published since the 2009 review estimated the cumulative probability of false-positive results after 10 years of mammography screening based on data from the BCSC.143,144

Data collected from film and digital screening mammography performed between 1994 and 2006 indicated that when screening began at age 40 years, the cumulative probability of receiving at least one false-positive mammography result after 10 years was 61 percent (95% CI, 59% to 63%) with annual, and 41 percent (95% CI, 41% to 43%) with biennial screening.143 Estimates were similar when screening began at age 50 years. The cumulative probability of receiving a false-positive biopsy recommendation after 10 years of screening was 7 percent (95% CI, 6% to 8%) with annual versus 5 percent (95% CI, 4% to 5%) with biennial screening for women who initiated screening at age 40 years; and 9 percent (95% CI, 7% to 12%) with annual versus 6 percent (95% CI, 6% to 7%) with biennial for women who began at age 50 years.

A study of BCSC data collected between 1994 and 2008 also evaluated 10-year cumulative probability estimates for false-positive mammography and biopsy results, but stratified results by age, breast density, and use of menopausal hormone therapy.144 Rates of false-positive mammography results were highest among women receiving annual mammography that had extremely dense breasts and were either 40 to 49 years old (65.5%) or used combination hormone therapy (65.8%). Rates were lower among women 50 to 74 years receiving biennial or triennial mammography that had scattered fibroglandular densities (39.7% and 21.9%, respectively) or almost entirely fat breasts (17.4% and 12.1%, respectively). These rates were similar regardless of menopausal estrogen use. The highest rates were among women age 40 to 49 years undergoing annual screening that had heterogeneously dense (68.9%) or extremely dense (65.5%) breasts. The highest rates of false-positive biopsy were related to similar characteristics and ranged from 12 to 14 percent.

#### Overdiagnosis

##### Previous Reports

A review of eight RCTs of mammography screening152 and eight additional studies153-160 in the previous report provided estimates of overdiagnosis that ranged from non-existent to nearly 50 percent of diagnosed breast cancer cases. Methods for estimating overdiagnosis varied in many ways, particularly by the type of comparison groups, assumptions about lead time, and the denominator used to calculate the rates.161,162 The different methodologies led to wide variations in estimates and a lack of agreement as to the true rate of overdiagnosis from mammography screening.

##### New Studies

A meta-analysis of three RCTs,163,164 a systematic review of 13 observational studies,161 and 17 individual studies69,165-180 of overdiagnosis were identified for the current update (Table 20). Estimates of overdiagnosis were primarily based on screening trials, screening programs and registries, or modeled data. Studies differed by patient populations of various ages and with different risks for breast cancer; screening and followup times; screening policies, uptake, and intensity; and underlying cancer incidence trends. Estimates differed in their numerators and denominators; whether they included both invasive cancer and DCIS; assumptions about lead time and progression of invasive cancer and DCIS; and whether they reported relative or absolute changes.

Table 20 Studies of Overdiagnosis

Author, year | Age, years | Study years | Data source | Comparison groups | Approach, lead time adjustment | Overdiagnosis measures as defined by each study | Overdiagnosis rate of invasive cancer + DCIS | Overdiagnosis rate of invasive cancer | Overdiagnosis rate of DCIS
2014 update
Bleyer and Welch, 2012^165^ | ≥40 | 1976-2008 | SEER; United States | Population before vs. after widespread screening | EI; no adjustment | Change in incidence before and after introduction of screening with 3 estimates of baseline incidence.; - Best guess: incidence increases 0.25% annually; - Extreme: incidence increases 0.50% annually; - Very extreme: using highest observed incidence, assume a 0.50% incidence increase | - Best guess: 31%; - Extreme: 26%; - Very extreme: 22% | NR | NR
Coldman and Phillips, 2013^166^ | 40-89 | 1970-2009 | Breast cancer registry; Canada | Population before vs. after widespread screening | EI; compensatory drop | - Participation estimate: cumulative incidence with active screening vs. never screened or nonactive screening.; - Population estimate: observed vs. expected population cumulative incidence in 2005-2009. | - Participation estimate: 7.3%; - Population estimate: 6.7% | - Participation estimate: 5.4%; - Population estimate: -0.7% | NR
de Gelder et al, 2011^167^ | 49-74 | 2004-2006 | Screening program (biennial); Netherlands | Modeled incidence of screening vs. predicted incidence without screening | LT; statistical adjustment; preclinical DCIS: mean 5.2 years; preclinical invasive: 2.6 years | Microsimulation analysis (digital mammography);; - Baseline model: 18% are screen-detectable preclinical DCIS; 11% progress to invasive cancer, 5% are clinically diagnosed, 2% regress.; - Progressive model: all tumors have preclinical screen-detectable DCIS stage and none regress; 96% invasive with no screening, 4% are clinically diagnosed.; - Non-progressive model: no preclinical screen-detected DCIS, majority regress, 2% are clinically diagnosed. | - Baseline model: 2.5% all cases; 8.2% screen-detected; - Progressive model: 1.4% all cases; 5.0% screen-detected; - Non-progressive model: 7.7% all cases; 25.2% screen-detected | NR | NR
de Gelder et al, 2011^168,*^ | 0-69; 0-74 | 1990-1998; 1998-2007 | Screening program (biennial); Netherlands | Modeled incidence of screening vs. predicted incidence without screening | LT; compensatory drop; mean 2.6 years | Microsimulation screening analysis; excess cancers minus deficit cancers divided by the total number of breast cancers in the absence of screening in women 0-100 years. | 1-year estimates 1990-1998: 1.0%; 6.1%; 9.1%; 11.4%; 10.0%; 9.4%; 8.8%; 5.6% 1-year estimates 1998-2007: 4.9%; 10.0%; 7.4%; 4.7%; 4.7%; 4.9%; 4.3%; 4.4%; 2.8% | NR | NR
Duffy et al, 2010^110^ | 50-69 | 1977-1998; 1974-2003 | Swedish Two-County Trial; U.K. National Breast Screening Program | Active vs. passive screening; population before vs. after widespread screening | EI; compensatory drop | - Swedish Trial: Estimated expected incidence trends in the prescreening period vs. observed cases, adjusted for prevalence peak.; - U.K. Program: Observed cases of breast cancer, minus any deficit in ages 65-69 or ≥70 years. | - Overall: 4%-7%; - Swedish Trial: 4.3 cases per 1,000 women screened for 20 years; - U.K. Program: 2.3 cases per 1,000 women screened for 20 years | NR | NR
Falk et al, 2013^169,†^ | 50-69 | 1995-2009 | Norwegian Breast Cancer Screening Program (biennial) | Women screened vs. those never invited or did not attend screening | EI; compensatory drop | Women attending screening adjusted for compliance with screening vs. 3 reference rates:; - 40 year olds 1993-1995; - Observed rates of invasive breast cancer 1980-1984; - Cohort of women born 1903-1907 | 16.5%; 16.3%; 13.9% | 11.3%; 11.2%; 9.6% | NR
Gunsoy et al, 2014^180^ | 40-73 | 1971-2010 | Data from various sources in the U.K. | Women screened vs. not screened | Multiple statistical adjustments | Markov model of the difference between cumulative incidence of invasive + DCIS with denominators:; - Cases diagnosed in absence of screening age 40-85; - Cases diagnosed in screening period; - Screen-detected breast cancers | - All cases: 4.3 to 8.9%; - Screening period: 6.7 to 10.1%; - Screen-detected: 11.8 to 13.5%; - Highest rates with frequent screening | NR | NR
Hellquist et al, 2012^170^ | 40-49 | 1986-2005 | Screening for Young Women Trial; Sweden | Population in areas with vs. without screening | EI; statistical adjustment; up to 1.5 years | Incidence in screening group vs. controls. Corrected for prescreening difference, prevalence peak bias (excluded prevalence screen data), trend bias (change in incidence per year of age). | Rate ratio: 1.01 (95% CI 0.94 to 1.08) | Rate ratio: 0.95 (95% CI 0.88 to 1.01) | NR
Jørgensen et al, 2009^171,‡^ | 50-69 | 1991-2003 vs. 1971-1990 | Screening program; Copenhagen and Funen, Denmark | Population in areas with (1991-2003) vs. without (1971-1990) screening | EI; compensatory drop | Ratio of incidence between screened and non-screened areas for the screened age group. | 33% | NR | NR
Kalager et al, 2012^172,§^ | 50-69 | 1996-2005 | Norwegian Breast Cancer Screening Program (biennial) | Population in areas with vs. without screening | EI; compensatory drop; Approach 1: 10-year lead time; Approach 2: 5 or 2-year | - Approach 1: Incidence rates in the screening and non-screening groups for women aged 50-79 years.; - Approach 2: Excluded all cases of cancer detected in the first screening round, compares incidence in screened women vs. women 2-5 years older. | NR | - Approach 1: entire country: 25%, region 1: 18%; - Approach 2: 5-year lead time: 15%, 2-year lead time: 20% | NR
Marmot et al, 2013^163,164^ | 40-69 | 1976-2001 | Meta-analysis of Canadian National Breast Screening Study and Malmö I Trial | Randomized trials; screening vs. usual care | EI; none | Excess incidence of breast cancer (both invasive cancer and DCIS) in the screening population was compared with the incidence in the absence of screening | - Short case accrual: 19.0% (95% CI, 15.2-22.7%; 3 trials); - Long case accrual: 10.7% (95% CI, 9.3- 12.2%; 3 trials) | NR | NR
Martinez-Alonso et al, 2010^173^ | 40-69 | 1980-2004 | Cancer registry; Catalonia, Spain | Modeled pre vs. post screening incidence | EI; statistical adjustments | Probabilistic model for birth cohorts: 1935, 1940, 1945, 1950; observed vs. expected cumulative incidence. | NR | 1935: 0.4% 1940: 23.3% 1945: 30.6% 1950: 46.6% | NR
Miller et al, 2014^69^ | 40-59 | 1980-1985 | Canadian National Breast Screening Study | Randomized trial; screening vs. usual care | EI; none | Excess of breast cancer cases in mammography arm vs. the control arm of trial. | NR | 22% of screen-detected cancer | NR
Morrell et al, 2010^174^ | 50-69 | 1999-2001 | Screening program (biennial); Australia | Screened vs. unscreened age group or prior to screening implementation | EI; statistical adjustment; 2- or 5-year lead times | Observed annual incidence minus expected annual incidence divided by expected annual incidence;; - Interpolation approach: incidence in unscreened women (≤40 or ≥80) modeled by 5-year age group.; - Extrapolation approach: incidence for the period prior to the introduction of screening modeled for all 5-year age groups and extrapolated to 1999-2001. | NR | - Interpolation: 2-year: 51%; 5-year: 42%;; - Extrapolation: 2-year: 36%, 5-year: 30%; - Rates higher for 50-59 vs. 60-69 | NR
Njor et al, 2013^175^ | 56-70 | 1991-2005 | Screening program; Copenhagen and Funen, Denmark | Population in areas with vs. without screening | EI; compensatory drop | Cumulative incidence in screened population vs. expected incidence in unscreened counties | ≥8 years followup: Copenhagen, 3% (-14% to 25%), Funen, 0.7% (-9% to 12%) | NR | NR
Puliti, et al, 2009^176^ | 60-69 | 1990-NR | Screening program; Florence, Italy | Screening vs. pre-screening | EI; compensatory drop | Ratio of cumulative incidence of breast cancer in the invited group to those in the non-invited group at least 5 years after last screening, assuming 1.2% annual trend in pre-screening incidence. | Rate ratio: 1.01 (95% CI 0.95 to 1.07) | Rate ratio: 0.99 (95% CI 0.94 to 1.05) | NR
Seigneurin et al, 2011^177^ | 50-69 | 1991-2006 | Cancer registry; Isere, France | Modeled screening incidence | LT; statistical adjustment, 2-4 years | Stochastic simulation model, driven by all-cause mortality, lifetime probability of breast cancer, natural course of breast cancer, and cancer detection; adjusted for sojourn time. | NR | All diagnosed cancers: 1.5%, screen detected: 3.3% | All diagnosed cancers: 28.0%, screen detected: 31.9%
Yen et al, 2012^178^ | 40-74 | 1977-2005 | Swedish Two-County Trial; data from 1 county only (Dalarna) | Active screening vs. passive screening | EI; compensatory drop | Cumulative incidence in active screening vs. usual care groups | Relative risk: 1.00 (95% CI 0.92 to 1.08) | Relative risk: 0.99 (95% CI 0.88 to 1.55) | Relative risk: 1.17 (95% CI 0.88 to 1.55)
Zahl et al, 2012^179^ | 40-79 | 1991-2009 | Norway Cancer Registry | Screening vs. post-screening | EI; compensatory drop | Define overdiagnosis as increase in number of cancer diagnoses among those who are invited for screening and the reduction in the number of diagnoses among those no longer invited. | ∼50% | NR | NR
2009 report
de Koning et al, 2006^155^ | 50-74 | 1989-2001 | National data from The Netherlands | Screening vs nonscreening (biennial) | Statistical adjustments; assumptions of DCIS progression | Microsimulation model | 3% in screened population 8% screen-detected | NR | NR
Duffy et al, 2005^157^ | 40-74 | 1977-1985 | Swedish Two-county Trial | Active vs. passive screening | Lead time statistical adjustments | Markov multistate model | 1% in screened population | NR | NR
Duffy et al, 2005^157^ | 39-59 | 1982-1996 | Gothenburg trial | Screening vs. no screening | Lead time statistical adjustments | Markov multistate model | 2% in screened population | NR | NR
Olsen et al, 2006^156^ | 50-71 | 1991-1996 | Copenhagen, Denmark screening program (biennial) | Incidence in screened women | Statistical adjustments | Chronic disease statistical model of screen-detected overdiagnosis | Prevalence: 7.8%; Incidence: 0.5% | NR | NR
Paci et al, 2004^154^ | 50-69 | 1985-1999 | Florence, Italy; screening program | Incidence in screening vs. prescreening | EI; corrected for lead time | Observed/expected cases | 5% | 2% | 3%
Paci et al, 2006^153^ | 50-74 | 1986-2001 | Italy; screening program | Prescreening incidence | EI; corrected for lead time | Observed/expected cases | 4.6%; range -0.6% to 9.7% varies by age (highest in 50-54 and 65-74) | 3.2% | 1.4%
Yen et al, 2003^158^ | 40-69 | | Swedish Two-county Trial, United Kingdom, Netherlands, Australia, New York | Screening vs. not screening | LT; statistical adjustment | Six state Markov model | NR | NR | Prevalence: 37% Incidence: 4%
Yen et al, 2003^158^ | 40-69 | | Swedish Two-county Trial | Screening vs. not screening | LT; statistical adjustment | Six state Markov model | NR | NR | 40-49: 19%, 3% 50-59: 23%, 4% 60-69: 46%, 6%
Zackrisson et al, 2006^159^ | 55-69 | 1978-1986 | Malmö trial | Randomized screening vs. no screening | EI; compensatory drop | Comparison of incidence in screened vs. unscreened | 10% of incidence in control group | 7% | 3%
Zahl et al, 2004^160^ | 50-69 | 1971-2000 | Norway and Sweden | Prescreening incidence | EI; compensatory drop | Changes in age-specific incidence rates associated with the introduction of screening programs | NR | 30% of incidence in screened population | NR

* An additional 6 model estimates for each year are published in this paper to show the range of estimates varies by selection of the denominator.

† Population overlap with Kalager; may have data to calculate by age group.

‡ Same Copenhagen population as Olsen.

§ Population overlap with Falk.

Abbreviations: CI=confidence interval; DCIS=ductal carcinoma in situ; EI=excess incidence approach; LT=lead time approach; NR=not reported; SEER=Surveillance, Epidemiology, and End Results Program; U.K.=United Kingdom; vs.=versus.

Various methods were used to estimate overdiagnosis. The most common methods determined the differences between the incidence of cancer in the presence and in the absence of screening (observed excess incidence approach); or made inferences about the lead time or natural history of breast cancer and estimated the corresponding frequency of overdiagnosis (lead-time approach).162 In addition, at least seven different measures of overdiagnosis were reported in published papers.168 How differences in study characteristics, methods, and measures effect estimates of overdiagnosis have been well described,162-164,168,181,182 yet there is currently no consensus about the most appropriate approach.164

Estimates from RCTs. Data from three RCTs that did not provide screening of controls at the end of the trial were considered to be the least biased estimates of overdiagnosis in a comprehensive review commissioned by Cancer Research U.K. and the Department of Health in England.163,164 The Malmö I and Canadian National Breast Screening Study (CNBSS-1 and CNBSS-2) trials provided randomized comparison groups, and followup times that extended sufficiently beyond the screening period to differentiate earlier diagnosis from overdiagnosis.163

Using results of the Malmö I159 and two Canadian trials,76,78 the excess incidence of breast cancer (both invasive cancer and DCIS) in the screening population was compared with the incidence in the absence of screening (Table 21). For the short case accrual method that includes cases identified only during the screening period, overdiagnosis was estimated to be 19.0 percent (95% CI, 15.2% to 22.7%; I^2^=64.8%; p=0.058; 3 trials). For the long case accrual method that includes cases identified throughout the screening and followup periods, overdiagnosis was 10.7 percent (95% CI, 9.3% to 12.2%; I^2^=22.3%; p=0.276; 3 trials). Estimates for women age 40 to 49 years in the CNBSS-1 trial were higher (22.7% for short case accrual; 12.4% for long case accrual) than for women age 50 to 59 years in the CNBSS-2 trial (16.0% and 9.7%, respectively), and women age 55 to 69 years in the Malmö trial (18.7% and 10.5%, respectively).

Table 21 Overdiagnosis Estimates From Randomized, Controlled Trials Without Screening of Control Groups

Trial (reference) | Age, years | Overdiagnosis, % (95% CI) Short-case accrual^*^ | Overdiagnosis, % (95% CI) Long-case accrual^*^
Malmö I159 | 55-69 | 18.7 (15.1 to 22.4) | 10.5 (8.4 to 12.7)
CNBSS-I 76 | 40-49 | 22.7 (18.4 to 27.0) | 12.4 (9.9 to 14.9)
CNBSS- 2^78^ | 50-59 | 16.0 (12.5 to 19.5) | 9.7 (7.5 to 11.9)
Meta-analysis163 | 40-69 | 19.0 (15.2 to 22.7; I^2^=64.8%; p=0.058) | 10.7 (9.3 to 12.2; I^2^=22.3%; p=0.276)

* Excess cancers as a proportion of cancers diagnosed during the screening period (short-case accrual) or over the followup period (long-case accrual) in women invited for screening.

Abbreviations: CI=confidence interval; CNBSS=Canadian National Breast Screening Study.

However, overdiagnosis estimates from the trials included in this meta-analysis used different denominators. The Malmö I trial included all breast cancer cases, not just those identified with screening, while the Canadian trials included only cancer cases detected by screening. If these were calculated similarly, results from Malmö would be 23 percent instead of the 11 percent estimate used.81 In addition, more recently published long-term followup of the two Canadian trials 15 years after enrollment indicated a 22 percent overdiagnosis rate for combined age groups.69

Data from the other RCTs are susceptible to over- or underestimating overdiagnosis because women in the control groups were offered screening at the end of the screening periods.163,164 If cases from screened control groups were included in the estimate of overdiagnosis, differences between comparison groups would be reduced and overdiagnosis would be underestimated. If these cases were excluded, overdiagnosis estimates would be inflated because the control group would not have been followed up long enough to determine accurate estimates. New publications of overdiagnosis reported from trials that screened control groups indicated none or minimal overdiagnosis, including the Swedish Two-County trial110,178 and Screening for Young Women Trial.170

Estimates from screening programs and registries. A systematic review for the EUROSCREEN Working Group included 13 observational studies providing estimates of overdiagnosis in European population-based screening programs.161 Five newer studies in this review are included in this update,110,167,171,173,176 and three older studies were included in the previous report (Table 20).153,156,160 These studies differed by many of the study characteristics, methods, and measures previously described that limited comparisons and prohibited combined estimates. In particular, for studies comparing screening and nonscreening populations from different time periods, adjustments for breast cancer risk were dependent on correct estimates of temporal trends. Also, denominators defining the populations at risk were inconsistent across studies (e.g., breast cancer diagnosis in an entire population versus women of a specific age who attended screening). Importantly, most studies used denominators that included all breast cancer cases, rather than screen-detected cases, leading to lower estimates.

Unadjusted estimates from the 13 observational studies included in the EUROSCREEN review indicated overdiagnosis rates ranging from 0 to 54 percent.161 For six studies that adjusted overdiagnosis estimates for breast cancer risk and lead time, rates varied from 1 to 10 percent.

European studies published since the EUROSCREEN systematic review include three studies of the Norwegian Breast Cancer Screening Program (NBCSP),169,172,179 and one from Denmark.171,175 The Norwegian studies reported overdiagnosis rates of 13.9 to 16.5 percent of invasive cancer + DCIS, and 9.6 to 11.3 percent of invasive cancer only, when comparing women screened with those never invited or nonattenders;169 15 to 25 percent of invasive cancer depending on region and lead time assumptions when comparing populations in regions with versus without screening;172 and 50 percent of invasive cancer + DCIS when comparing screening versus discontinuation of screening that assumes that all increases in incidence were due to overdiagnosis.179 The Danish study estimated overdiagnosis as the cumulative incidence of breast cancer + DCIS in regions with screening compared with expected cumulative incidence. For women followed for at least 8 years, the estimates were 3 percent in Copenhagen and 0.7 percent in Funen.175 These results contrast with the estimate of 33 percent overdiagnosis in an earlier study of the same regions that used ratios of incidence between screened and nonscreened areas for the screened age group.171

An analysis of the Canadian British Columbia Cancer Registry between 1970 and 2009 provided two estimates of overdiagnosis in women age 40 to 89 years.166 Rates were 17.3 percent of invasive cancer + DCIS and 5.4 percent for invasive cancer only when using cumulative incidence rates of women involved in active screening compared with women who were never screened or not actively screened. A second estimate compared the observed and expected cumulative population incidence rates between two time periods, resulting in estimates of 6.7 percent of invasive cancer + DCIS and -0.7 percent for invasive cancer only.

The only study conducted in the United States was not based on screening programs, but on comparisons of the expected increase in the incidence of early-stage cancer detected with mammography screening with the actual decrease in late-stage cancer incidence in women over a 40-year period using Surveillance, Epidemiology, and End Results (SEER) data.165 Overdiagnosis rates based on different incidence trend assumptions were estimated from 22 to 31 percent.

Estimates from models. Although several statistical models of overdiagnosis have been published, these studies have been less acceptable to guideline development groups because of the many assumptions that were used to construct them.163,164 Results of the models are heavily dependent on estimates of lead time and of progression rates from DCIS to invasive cancer. The longer the lead time, the more the estimate decreases with time. Assignment of these assumptions can be subjective. Six new studies of models of screening populations in The Netherlands,167,168 United Kingdom,180 France,177 Spain,173 and Australia,174 met inclusion criteria for this update (Table 20).

A microsimulation model for estimating overdiagnosis in screening programs in The Netherlands provided 1-year estimates across different time periods that ranged from 1.0 to 11.4 percent.168 Another microsimulation model of screening programs in The Netherlands provided estimates based on assumptions of the progression from DCIS to invasive cancer.167 These included overdiagnosis estimates of 1.4 to 7.7 percent of all breast cancer, and 5.0 to 25.2 percent of screen-detected breast cancer.

A Markov simulation model estimated overdiagnosis for different screening strategies in the United Kingdom, including annual, triennial, and combination strategies for different age groups.180 For all invasive + DCIS cases diagnosed from age 40 to 85 years, overdiagnosis estimates ranged from 4.3 percent for triennial screening for women age 50 to 70 years, to 8.9 percent for annual screening from age 40 to 73 years. For screen-detected invasive + DCIS cases, overdiagnosis estimates ranged from 11.8 percent for triennial screening for women age 50 to 70 years, to 13.5 percent for annual screening from age 40 to 46 years followed by triennial screening from age 47 to 73 years.

A French study utilized a stochastic process for modeling all-cause mortality, lifetime probability of breast cancer, the natural course of breast cancer, and the detection of breast cancer clinically or by screening mammography.177 Overdiagnosis estimates included 1.5 percent of all diagnosed and 3.3 percent of screen-detected invasive cancer cases, and 28 percent of all diagnosed and 31.9 percent of screen-detected DCIS cases. In a Spanish population, a Poisson regression model was used to estimate expected incidence, accounting for age at diagnosis, reproductive factors, use of mammography, and year of birth.173 Estimates of overdiagnosis of invasive cancer varied from 0.4 percent in the oldest to 46.6 percent for the youngest cohort.

An Australian study estimated incidence in unscreened age groups (≤40 or ≥80 years) and in all age groups prior to implementation of screening adjusting for risk factors and lead time.174 Assuming a 2-year lead time, estimates from the first approach ranged from 27 to 66 percent, while estimates from the second approach were 36 to 47 percent. In general, rates were higher among women age 50 to 59 than 60 to 69.

#### Anxiety, Distress, and Other Psychological Responses

##### Previous Reports

A systematic review of 54 studies evaluated the adverse psychological effects of mammography screening programs.183 Most were cohort studies, and 24 used validated psychological measurement scales to assess the effects of screening. Studies indicated that women who received clear communication of their negative mammography results had minimal anxiety.183 Results were mixed in studies of women who were recalled for further testing as a result of screening. In several studies, women had persistent anxiety, despite eventual negative results, whereas some showed only transient anxiety.183 Some studies showed no differences between anxiety levels of women who had initial negative screening mammography results and those who had false-positive results.183

A second systematic review of 23 studies (in 27 publications, of which 15 were included in the systematic review described above) specifically examined the effects of false-positive screening mammography results on women age 40 years or older.184 Twenty studies were included that measured psychological distress, anxiety, and worry. False-positive mammography results had no consistent effect on most women's general anxiety and depression but increased breast cancer-specific distress, anxiety, apprehension, and perceived breast cancer risk for some.184

##### New Studies

A good-quality review of seven studies examined the effects of false-positive screening mammography results on women (Table 22).185 Three studies that evaluated breast cancer specific worry or distress reported significantly more distress among women with false-positive results, even after 35 months (1 study), than women with normal screening results. The most distress was observed among women who had biopsies (RR 2.07; 95% CI, 1.22 to 3.52), FNA (RR 1.80; 95% CI, 1.17 to 2.77), and early recall (RR 1.82; 95% CI, 1.22 to 2.72).183,186,187 Two studies that evaluated general anxiety and depression found no differences between women with true versus false-positive results.188,189Among six studies that evaluated re-attendance rates after receiving a false-positive result, two studies reported that women with false-positive results were less likely to return for their next mammogram (RR 0.97; 95% CI, 0.96 to 0.98 and RR 0.92; 95% CI, 0.86 to 0.98);186,190 while two studies reported no differences.191,192 One study reported an increase in re-attendance when women were given letters tailored to their last screening result (RR 1.10; 95% CI, 1.00 to 1.21).193

Table 22 Systematic Reviews of Psychological Harms From False-Positive vs. Normal Screening Mammography Results

Author, year quality rating | Inclusion criteria | Searches | Number of studies; number of participants | Re-attendance | Anxiety | Depression | Breast cancer worry/distress
Bond et al, 2013^185^ Good | Studies in the U.K. comparing psychological and behavioral outcomes of women with FP vs. normal screening mammograms. | Multiple databases through November 2011 | 7 studies^*^ of psychological harms N=3,168; re-attendance N=151,490 | - Lower in FP vs. normal (2 studies); - No difference (2 studies); - Higher in FP vs. normal if given tailored letters (1 study) | No difference (2 studies) | No difference (2 studies) | Higher in FP vs. normal (3 studies)
Hafslund and Nortvedt, 2009^194^ Fair | Studies of women not at high risk; ages 40-74 years invited to mammography screening. | Multiple databases January 1995 to July 2007 | 17 studies^†^ N=18,097 | NR | Higher in FP vs. normal (15 studies) | NR | Higher in FP vs. normal (15 studies)
2009 Review
Brewer et al, 2007^184^ Fair | Studies comparing psychological and behavioral outcomes of women with FP vs. normal screening mammograms. | Multiple databases through September 2006 | 23 studies N=313,967 | - Lower in FP vs. normal in U.S. (RR 1.07; 95% CI 1.02 to 1.12; 5 studies); - Lower in normal vs. FP in Canada (RR 0.63; 95%CI 0.50 to 0.80; 2 studies); - No differences in Europe (RR 0.97; 95% CI 0.93 to 1.01; 5 studies) | - Higher in FP vs. normal (4 studies); - No differences (4 studies); - Conflicting results over time (2 studies) | - Lower in FP vs. normal (7 studies); - No differences (1 study); - Conflicting results based on measure (1 study) | - Higher in FP vs. normal (4 studies); - No differences (3 studies); - Conflicting results over time (2 studies)
Brett et al, 2005^183^ Fair | Studies of the psychological impact of mammography screening. | Multiple databases 1982 to 2003 | 54 studies N=NR | NR | Higher in FP vs. normal (14 studies) | NR | Higher in FP vs. normal (9 studies)

* 5 of 7 studies were included in at least one of the systematic reviews included in the 2009 review.

† 13 of 17 studies were included in at least one of the systematic reviews included in the 2009 review.

Abbreciations: CI=confidence interval; FP=false-positive; N=number; NR=not reported; RR=risk ratio; U.K.=United Kingdom; U.S.=United States; vs.=versus.

Another review rated fair-quality evaluated 17 studies of women age 40 to 74 years and reported that those with false-positive results had more anxiety, psychological distress, and breast cancer specific worry after screening (15 studies) compared with those with normal screening results.194 In two studies anxiety increased when women were recalled for biopsies,195,196 and in one study, anxiety persisted for 2 years after screening.197 The findings in these reviews are consistent with those from the previous report.183,184

In addition to the reviews, 10 observational studies published after the reviews met inclusion criteria (Table 23). These include two fair-quality prospective cohort studies198,199 and three fair-quality retrospective cohort studies (Appendix B2-4);200-202 two good-quality203,204 and one fair-quality205 nested case-control studies; one fair-quality case-control study;206 and one before-after study207 that was not quality rated because rating criteria are not available for this study design.

Table 23 Summary of Results of New Studies of Psychological Harms

Author, year | Study design | Population | Comparisons, N | Measures | Re-attendance | Anxiety | Depression | Breast cancer worry | General QOL
Bredal et al, 2013^207^ | Before-after | Women recalled in a screening program in Norway | A) At recall (n=640) B) 4 weeks later | HADS (score ≥11) | NR | 0 | 0 | NR | NR
Brodersen and Siersma, 2013^203^ | Nested case-control | Screening programs in Denmark | A) FP (n=272) B) Normal (n=864) C) TP (n=174) | COS-BC | NR | - Immediate: higher A+C vs. B; no difference A vs. C; - 3-years after: higher C vs. A+B and A vs. B | NR | 0 | NR
Espasa et al, 2012^206^ | Case-control | Screening program in Spain | A) FP (n=100) B) Normal (n=50) | HADS, structured interview | NR | 0 | 0 | Higher FP vs. normal | NR
Fitzpatrick et al, 2011^200^ | Retrospective cohort | Screening program in the United Kingdom | A) FP (n=9,746) B) Normal (n=148,589) | Re-attendance | - Decreased: women >55, open biopsy, longer time to diagnosis; - Increased: repeat screens, screened in mobile unit | NR | NR | NR | NR
Gibson et al, 2009^198^ | Prospective cohort | New Hampshire Mammography Network and New Hampshire Women for Health study | A) FP (n=2,107) B) Normal (n=11,384) | WHQ | NR | NR | Higher for non-white with FP vs. normal | NR | NR
Hafslund et al, 2012^205^ | Nested case-control | Screening programs in Norway | A) FP (n=128) B) Normal (n=195) | SF-36, HADS | NR | 0 | More cases for FP vs. normal | NR | Lower for FP vs. normal
Keyzer-Dekker, 2012^199^ | Prospective cohort | Women with abnormal results in The Netherlands | A) 1st screen recalls (n=186) B) Repeat screen recalls (n=296) | STAI, NEO-FFI, CES-D, WHOQOL | NR | 0^*^ | 0^*^ | NR | NR
Klompenhouwer et al, 2014 | Retrospective cohort | Screening program in The Netherlands | A) Normal screen (n=373,474) B) 1st screen recalls (n=6,672) C) repeat screen recalls for different lesion (n=161) D) repeat screen recalls for same lesion (n=89) | Re-attendance | - 93.2% vs. 65.4% vs. 56.7% vs. 44.3%; - 44.3% for all recalled groups combined | NR | NR | NR | NR
Maxwell et al, 2013^201^ | Retrospective cohort | Screening program in the United Kingdom | First screening A) Open biopsy (n=110) b) Needle sampling (n=1,374) C) No tissue sampling (n=2,703) | Re-attendance | Increased for C, but no change for A or B | NR | NR | NR | NR
Maxwell et al, 2013^201^ | Retrospective cohort | Screening program in the United Kingdom | Repeat screening A) Open biopsy (n=199) b) Needle sampling (n=1,052) C) No tissue sampling (n=4,009) | Re-attendance | Decreased for A and B, but no change for C | NR | NR | NR | NR
Tosteson et al, 2014^204^ | Nested case-control | Women participating in DMIST in the United States | A) FP (n=494) immediate B) FP 1-year after | STAI, EuroQOL EQ-5D | NR | Decreased A to B | NR | NR | 0
Tosteson et al, 2014^204^ | Nested case-control | Women participating in DMIST in the United States | C) Normal (n=534) immediate D) Normal 1-year after | STAI, EuroQOL EQ-5D | NR | 0 | NR | NR | 0

* Both groups improved over time.

Abbreviations: 0=comparison studied but not statistically significantly different; CES-D=Center for Epidemiological Studies-Depression Scale; COS-BC=Consequences of Screening in Breast Cancer; DMIST=Digital Mammographic Imaging Screening Trial; FP=false-positive; HADS=Hospital Depression and Anxiety Scale; n=number; NEO-FFI=Neuroticism-Extraversion-Openness-Five Factor Inventory; NR = not reported; QOL=quality of life; SF-36=Short-form 36 Health Survey; STAI=Spielberger State-Trait Anxiety Inventory; TP=true positive; vs.=versus; WHOQOL=World Health Organization Quality of Life Assessment Instrument; WHQ=Women's Health Questionnaire.

Five studies compared women receiving false-positive results with those receiving normal screening results,198,203-206 and reported similar findings as the reviews. Women with false-positive versus normal screening results experienced more breast cancer worry (49% vs. 10%, p<0.0001) and had more worries that affected mood or daily activities (31% vs. 2%, p<0.0001).206 These women also had lower mental functioning and vitality measured by the Short Form 36 Health Survey (SF-36) at 6 months (mean mental functioning score: 80.6 vs. 85.0; p=0.03; mean vitality score: 70.3 vs. 77.0; p=0.02).205 A study of 323 participants reported higher depression scores on the Hospital Anxiety and Depression Scale (HADS) – Depression Subscale (HADS-D) for women with false-positive versus normal screening results (6-months mean: 3.2 vs. 2.4, p=0.045), however neither group reached clinical thresholds.205 Other studies of general anxiety and depression measured with the HADS or State-Trait Anxiety Inventory (STAI) reported no significant differences between groups.198,204,206 However, in a study of 13,491 women, analysis of racial sub-groups indicated increased depression among non-white women (6%; n=847) with false-positive results (OR 3.23; 95% CI, 1.32 to 7.91).198

Psychological outcomes of women with false-positive, normal screen, and true-positive results (breast cancer diagnosis) were compared in a good-quality nested case-control study using the Consequences of Screening in Breast Cancer questionnaire.203 Immediately after screening, women with normal screening results had better scores on all subscales compared with women with either false-positive or true-positive results (p<0.001 for all outcomes), but there were no differences between women with false-positive and true positive results. By 3 years after screening, women with normal screening results continued to have better scores on all subscales compared with women with true-positive results (p<0.002 for all outcomes). However, women with normal screening results also had better scores than those with false-positive results on subscales for sense of dejection, anxiety, negative impact on behavior or sleep, social network, existential values, and on single items of feeling less attractive and keeping mind off things (p<0.03 for all outcomes). Women with false-positive results had better scores than women with true-positive results on all but the breast examination and worried about breast cancer subscales (p<0.03 for all outcomes).

Anxiety and depression were evaluated in a before-after study of women with false-positive and true-positive results at the time of mammography recall and 4 weeks after.207 The proportion meeting the HADS threshold for anxiety (score >11) decreased from recall to 4 weeks for women with false-positive (15% to 5.5%) and true positive results (19% to 17%). The proportion meeting the HADS threshold for depression (score >11) also decreased from recall to 4 weeks (1.4% to 1.3%) for women with false-positive results, but increased for women with true positive results (1.3% vs. 6.9%). In multivariate models, factors predicting anxiety or depression at followup included low general life expectations, previous history of anxiety and/or depression, and anxiety at baseline. Satisfaction with information also predicted depression. Anxiety and depression were also evaluated in a fair-quality prospective cohort study of 482 women that compared women recalled after their first screening mammography with those recalled after a repeat screening mammography.199 Both groups had similar anxiety and depression scores initially that significantly declined over the following 6 months.

Three studies compared re-attendance rates of women with false-positive screening mammography results with women with normal screening results. 200-202 As with the systematic review of studies on re-attendance, the results of these studies were also inconsistent. One study reported higher re-attendance rates for women with normal results (93.2% vs. 52.1% for false-positive result), and the lowest rates for women recalled to screening more than once for different lesions (44.3%).202 The other two studies reported higher rates of re-attendance for women with false-positive compared with normal screening results (90.7% vs. 89.0%, p<0.001^200^ and 87.7% vs. 86.0%, difference of 1.61%, 95% CI, 0.54% to 2.62%).201 The OR for re-attendance was higher for women who did not receive tissue sampling after false-positive versus normal mammography screening (OR 1.20, 95% CI, 1.10 to 1.30).201 Older women had lower odds of re-attendance at both prevalent (OR 0.89, 95% CI 0.86 to 0.93) and incident screening rounds (OR 0.99, 95% CI 0.98 to 0.99).

In a study of women with false-positive results, ORs for re-attendance were lower for women receiving open biopsies (adjusted OR [AOR] 0.4, 95% CI, 0.3 to 0.6) but not core needle biopsies compared with women receiving no tissue sampling.200 This study also found that older women had reduced odds of re-attendance (AOR 0.8, 95% CI, 0.7 to 0.9 for women aged 55 to 59 years and 0.8, 95% CI, 0.6 to 0.9 for women aged 60 to 62 years compared with women aged 50 to 54 years).

#### Radiation Exposure

##### Previous Reports

In the previous report, estimates of radiation exposure were provided by a systematic review that included various types of studies of radiation exposure as a basis for predicting risk for inducing breast cancer.14 However, these estimates were not specific for radiation induced risk or mortality attributable to mammography or breast imaging.

##### New Studies

No studies directly measured the association between radiation exposure from mammography screening and the incidence of breast cancer and death for film, digital, or tomosynthesis. The general concern about the harms of radiation exposure stems from the assumption that higher doses of radiation induce cancers. Two-view digital mammography and screen-film mammography involve an average mean glandular radiation dose (MGD) of 3.7 and 4.7 mGy, respectively, and are considered low dose, low energy radiation. Radiation exposure for tomosynthesis is generally considered to be up to twice the dose of digital mammography.

Two modeling studies provided estimates of radiation exposure, breast cancer incidence, and death (Table 24).208,209 In a study based on theoretical estimates, the average estimated MGD and the lifetime attributable risk (LAR) of radiation induced breast cancer incidence and mortality were calculated based on age-specific estimates in the United States screening population.208 Results indicated that a 40 year old woman undergoing a single, bilateral, two-view screening mammogram has an LAR of breast cancer incidence of 5 to 7 cases per 100,000, and an LAR of breast cancer mortality of 1.3 to 1.7 deaths per 100,000. There was little effect on estimated risk when screening ended at age 80 years or later. Risks were similar for digital breast tomosynthesis (LAR 1.3 to 2.6 deaths).

Table 24 Models of Radiation Exposure, Breast Cancer Incidence, and Death

Author, year | Study design | Population; age, years | Method | Outcome measures | Results
Hendrick, 2010^208^ | Modeling Study | U.S. based sources; 40-80 | Theoretical estimates are based on long-term followup of acute exposures to higher levels of ionizing radiation and a linear no-threshold extrapolation of risks at low doses. Model assumes 3.7mGy to 4.7 mGy per exam. | Breast cancer cases and mortality | LAR of breast cancer incidence and mortality, per 100,000; - 40 years: 5-7 cases; 1.3-1.7 deaths; - 50 years: 2-3 cases; 0.7-0.9 deaths; - 80 years: 0.1-0.2 cases; <0.1 deaths; LARs of breast cancer incidence and mortality in women undergoing annual screening mammography, per 100,000; - Screening 40-80 years: 72-91 cases; 20-25 deaths; - Screening 50-80 years: 31-40 cases; 10-12 deaths
Yaffe and Mainprize, 2011^209^ | Modeling study | U.S. based sources; 40-74 | Model based on digital mammography and radiation exposure estimates of 3.7 mGy per exam | Estimated lifetime radiation induced breast cancer cases and deaths | Number of radiation induced breast cancer cases and deaths in 100,000 women; - Annual screen 40-49 years: 59 cases, 7.6 deaths; - Annual 50-59 years: 27 cases, 3.1 deaths; - Biennial 50-59 years: 14 cases, 1.6 deaths; - Annual 40-59 years: 85 cases, 11 deaths; - Annual 40-49 years, biennial to 59 years: 73 cases, 9 deaths; - Annual 40-55 years, biennial to 74 years: 86 cases, 11 deaths

Abbreviations: LAR=lifetime attributable risk; mGy=milli Gray (unit of radiation); U.S.=United States.

A modeling study based on assumptions from the first study208 created an excess absolute risk model to predict the number of radiation induced breast cancers attributable to the radiation dose received for a single typical digital mammogram.209 Results indicated that the estimated number of deaths due to radiation induced cancer was between 2 per 100,000 in women age 50 to 59 years screened biennially, and up to 11 per 100,000 in women screened annually between ages 40 to 59 years. Women age 40 to 49 years undergoing annual mammographic screening would have an absolute risk of radiation induced mortality of 7.6 per 100,000. The calculations in this study are based on radiation doses from digital mammography, whereas previous estimates based on film mammography used higher doses per examination (3.7 mGy vs. 4.5 mGy, respectively).

#### Pain During Procedures

##### Previous Reports

A systematic review of 22 studies of pain and discomfort associated with mammography indicated that many women experience pain during the procedure (range, 1% to 77%), but few would consider this a deterrent from future screening.14 In these studies, pain was associated with the stage of the menstrual cycle, anxiety, and the anticipation of pain.14

A good-quality systematic review of seven intervention trials to reduce pain with screening mammography210 indicated that discomfort was reduced when written or verbal information was provided to women, and when a breast cushion was used. Use of different breast compression strategies or premedication with acetaminophen had no significant effects in reducing discomfort.

##### New Studies

Breast compression is used during mammography to create uniform density, reduce breast thickness, and flatten overlying skin and tissues, which contributes to sharper images and reduces the radiation dose. However, compression may add to the discomfort of mammography for some women.

A good-quality recent review of 20 observational studies, most cross-sectional, examined pain or discomfort after screening mammography and its effect on re-attendance for future screening mammography (Table 25).211 Seven studies reported the proportion of women who experienced pain with previous mammography who directly stated this as their reason for non-re-attendance. In these studies, actual non-re-attendance indicating pain as the reason ranged from 11 to 46 percent (5 studies), and intended future non-re-attendance because of pain ranged from 3 to 18 percent (2 studies).

Table 25 Systematic Reviews of Pain With Mammography

Author, year | Inclusion criteria | Databases; search dates | Number of studies (designs); number of participants | Methods for rating quality and synthesizing results | Results | Quality rating; limitations
Whelehan et al, 2013^211^ | Studies of pain or discomfort of screening mammography and re-attendance. | MEDLINE, EMBASE, PsychINFO, CINAHL, ASSIA, Cochrane Database of Systematic Reviews, Sociological Abstracts, SSCI, SCI, and NHS online literature database; October 2012. | 20 observational studies (most cross-sectional surveys); causation N=5,741, association N=NR. | Quality based on individual factors;^*^ studies combined separately for causation vs. association; actual vs. intended re-attendance data were considered more valid. | Causation (7 studies) Response rates: 32-79%; - Actual non-re-attendance indicating pain as the reason (5 studies): 11-46%; - Intended future non-re-attendance due to pain (2 studies): 2.7% and 17.5%; Association (15 studies); - Actual re-attendance (10 studies): no difference between women who experienced pain vs. no pain (RR 1.38; 95% CI, 0.94 to 2.02; 5 studies); higher pain scores in non re-attenders vs. re-attenders in 2 of 3 studies (p=0.001 and p<0.05).; - Intended re-attendance (5 studies): no differences (3 studies), less intent for women with pain (2 studies) with OR 0.61 (95% CI, 0.38 to 0.98) in one study. | Fair; unclear how study quality was used to formulate conclusions; did not describe characteristics of all included studies; did not assess publication bias.
2009 Review
Armstrong et al, 2007^14^ | Studies of risks of screening mammography for women in their 40s. | MEDLINE, Pre-MEDLINE, and the Cochrane Central Register of Controlled Trials; May 2005. | 22 studies (3 RCTs, 5 prospective cohort, 1 retrospective cohort, 13 cross-sectional); N=13,008. | Centre for Evidence-based Medicine criteria; based on study design and rates of attrition; methods of synthesis NR. | - Prevalence of pain from mammography varied from 28-77%.; - Degree of pain was associated with stage of menstrual cycle (3 studies), anxiety (2 studies), and pre-mammography anticipation of pain (4 studies). | Fair; no synthesis of data; unclear how study quality was used to formulate conclusions; study designs not pre-specified; did not assess publication bias.
Miller et al, 2008^210^ | RCTs of interventions that reduce or relieve the pain and discomfort of screening mammography. | MEDLINE, EMBASE, CINAHL, and Cochrane Breast Cancer Specialised Register; 2006. | 7 RCTs; N=1,771. | Quality (levels A, B, C) based on generation and concealment of allocation sequence, comparability of groups at baseline, intention-to-treat analysis, and double-blinding after allocation; heterogeneity of studies allowed qualitative synthesis only. | Information provided before mammography vs. usual care (3 trials):; - 44% vs. 24% (p=0.009) experienced less discomfort than expected with verbal information (1 trial).; - Pain scores were lower with written information in one trial (mean VAS16.5 vs. 24.5, p<0.05), but no differences were found in another trial.; Breast compression strategies (2 trials):; - Participant vs. technologist compression indicated 57% felt no difference in discomfort, 31% less, 13% more;; - No difference with normal vs. one second of reduced compression.; Premedication (1 study): acetaminophen vs. none (mean VAS scores 23.7 vs. 22.8, p=0.896). Breast cushion (1 study): reduced pain for cushion vs. no cushion (mean VAS pain 20.34 vs. 34.94, p<0.0001). | Good; did not assess publication bias.

* Factors include whether intended or actual re-attendance was measured, survey response rate/participation rate, measures of pain or discomfort, consistency of the timing of outcome measurement, quality of statistical analysis, and robustness of ascertaining re-attendance rate.

Abbreviations: ASSIA=Applied Social Sciences Index and Abstracts; CI=confidence interval; CINAHL=Cumulative Index to Nursing and Allied Health Literature; EMBASE= Excerpta Medica database; N=number; NHS=National Health Services; NR=not reported; OR=odds ratio; RCT=randomized, controlled trial; RR=relative risk; SCI=Science Citation Index; SSCI=Social Sciences Citation Index; VAS=Visual Analogue Scale; vs.=versus.

Fifteen studies reported the proportion of women who experienced pain with previous mammography and the proportion of women who re-attended as an outcome, but did not directly ask non-re-attenders for their reasons. There was no difference in actual re-attendance between women who experienced pain and those who did not (RR 1.38; 95% CI, 0.94 to 2.02; 5 studies).211 However, non-re-attenders had significantly higher pain scores compared with re-attenders in two of three studies. Two studies reported less intent to re-attend for women with pain, with OR 0.61 (95% CI, 0.38 to 0.98) in one study; while three others reported no differences in intended re-attendance and pain. This review is consistent with findings from the previous report.

## Key Question 6 How Do the Harms of Routine Breast Cancer Screening Vary by Different Screening Modality?

### Summary

- Four of five observational studies demonstrated statistically significantly lower rates of recall for tomosynthesis and mammography compared with mammography alone.
- A U.S. study comparing tomosynthesis and mammography with mammography alone reported a reduction of 16 recalls per 1,000 women and an increase in cancer detection of 1.2 cases per 1,000 women, but also an increase of 1.3 biopsies per 1,000 women. Another U.S. study reported a 38 percent reduction in recall rates when tomosynthesis was added to digital mammography versus mammography alone.
- Women receiving mammography and CBE compared with mammography alone had higher recalls in a study from Canada (55 per 10,000 additional recalls with CBE).
- No studies evaluated screening with ultrasound or MRI in women who are not at high risk for breast cancer.

### Evidence

#### Previous Reports

Previous evidence reviews for the USPSTF did not address this question.

#### New Studies

There are no RCTs of screening using tomosynthesis, ultrasound, or MRI in women who are not at high risk for breast cancer. Six observational studies compared false-positive recall rates of screening for breast cancer using mammography and tomosynthesis,146,147,212-214 or CBE215 compared with mammography alone (Table 26). No studies evaluated MRI screening in women who are not at high-risk for breast cancer. Use of supplemental imaging for women with dense breasts is included in a separate report.

Table 26 Studies of Harms of Screening With Different Modalities

Author, year | Study design | Population; age, years; participants, n | Study years; comparison | Outcome measures | Results | Quality rating
Mammography ± tomosynthesis
Haas et al, 2013^214^ | Case series | U.S., multisite hospital and outpatient centers; DM, 7,058; DM + T, 6,100 | 2011 to 2012; DM vs. DM +T | Recall rate (%); adjusted odds of recall | Recall, DM vs. DM + T by age (% relative change,95% CI): Total 8.4 vs. 12; -29.7 (19.1 to 36.5), p<.01; 40 to 49, 10.4 vs. 16.3; -35.8 (24.2 to 45.7), p<.01; 50 to 59, 7.6 vs. 10.6; -28 (12.7 to 44.6); p<.01; 60 to 69, 7.4 vs. 10.7; -30.3 (12.3 to 44.6), p=.01; ≥70, 6.7 vs 7.9; -15.4; NS Adjusted recall OR, 0.62 (0.55 to 0.70); p<.0001 | NR
Friedewald et al, 2014^212^ | Post-intervention series | U.S., multicenter; mean age 57; DM, 281,187; DM + T, 173,663 | 2010 to 2012; DM vs. DM + T | Recall and biopsy rates, per 1,000 | Recall, DM vs. DM + T (change, 95% CI): 107/1,000 vs. 91/1,000; -16.1 (-18.0 to -14.2), p<0.001 Biopsy, DM vs. DM + T (change, 95% CI): 18.1/1,000 vs. 19.3/1,000; +1.3 (0.4 to 2.1), p=0.004 | NR
Rose et al, 2013^146^ | Case series | U.S., multisite community-based breast center; >18 years; 18,202 DM and 10,878 DM + T | 2011 to 2012; DM vs. DM + T | Recall rate, % | Recall, DM vs. DM + T by age (% relative change): <50, 10.3% vs. 6.5% (-37.2); 50 to 64, 7.6% vs. 5.1% (-32.9); age >64, 7.9% vs. 4.2% (-46.6); total, 8.7% vs. 5.5% (-37.5); NS | NR
Ciatto et al, 2013^213^ | Post-intervention series | Italy; population-based screening program (STORM); ≥48; 7,292 | 2011 to June 2012; biennial DM vs. DM + T | Recall rate, % | Recall, DM vs. DM + T: total, 141 (2%) vs. 73 (1%), p<0.0001; age <60, 89 (2.2%) vs. 41 (1%); age >60, 52 (2%) vs. 32 (1%) | NR
Skaane et al, 2013^147^ | Post-intervention series | Norway, Oslo screening program; 50 to 69; 12,631 | 2010 to 2011; DM vs. DM+T (biennial screening) | Recall rate, per 1,000 | Recall, DM vs. DM + T: 61.1/1,000 vs. 53.1/1,000 (-13%); RR 0.85 (p<0.001) | NR
Mammography ± clinical breast exam
Chiarelli et al, 2009^215^ | Cohort | Canada; 40-69; 290,230 | 2002 to 2003; biennial M (n=57,715) vs. CBE + M (n=232,515) | Recall rate, % | Recall, M vs. CBE ± M: 6.5% vs. 8.7% (+2.2% for CBE), or 55/10,000 additional FP with CBE | Fair

Abbreviations: CBE=clinical breast exam; CI=confidence interval; DM=digital mammography; FP=false-positive; M=mammography; n=sample size; NR=not reported; NS=not statistically significant; OR=odds ratio; RR=relative risk; STORM=Screening with Tomosynthesis or standard Mammography; T=tomosynthesis; U.S.=United States; vs.=versus.

Four of five studies demonstrated statistically significantly lower rates of recall for tomosynthesis and mammography compared with mammography alone.146,147,212-214 One of the U.S. studies reported a reduction of 16 recalls per 1,000 women (95% CI, -18 to -14, p<0.001), increase of 1.3 biopsies per 1,000 women (95% CI, 0.4 to 2.1; p=0.004), increase in cancer detection of 1.2 per 1,000 women (95% CI, 0.8 to 1.6; p<0.001), and increase in invasive cancer detection of 1.2 per 1,000 women (95% CI, 0.8 to 1.6; p<0.001).212

Recall reductions were not statistically significant in another smaller U.S. study.146 Importantly, there was an overall reduction in false positives and an increase in biopsies, accompanied by an increase in cancer detection involving only invasive cancers, regardless of breast density or age. 212 Another smaller, U.S. observational study demonstrated reduced recall rates with tomosynthesis after controlling for age, breast density, and breast cancer risk (AOR 0.62, 95% CI, 0.55 to 0.70; p<0.0001) versus mammography alone.214 Two European studies also found significantly lower rates of recalls for women screened with tomosynthesis and mammography (1% vs. 2%, p<0.0001;^213^ and 53/1,000 vs. 61/1,000; p=0.001).147

Women receiving mammography and CBE compared with mammography alone had higher recalls in a study from Canada (8.7% vs. 6.5%; 55/10,000 additional recalls with CBE).215

## Contextual Question 1 What Are the Rates of Specific Adverse Effects of Current Treatment Regimens for Invasive Breast Cancer and DCIS in the United States?

Rates of specific adverse effects of breast cancer treatment regimens are not provided in centralized sources, but rather the available information is found in publications of surgical case series, clinical trials, and information from drug package inserts. Examples of rates of several recommended and commonly used treatments in the U.S. are summarized in Table 27.

Table 27 Examples of Specific Adverse Effects of Selected Treatments for Breast Cancer

Treatment | Adverse Effect and Rate^*^
Surgery
Mastectomy216 | Wound infection 3.8%; skin flap necrosis 10% to 18%; chronic chest wall pain >10%. Other adverse effects include phantom breast syndrome, arm morbidity, seroma, pneumothorax, brachial plexopathy, lymphedema.
Lymph node biopsy | Average false-negative 8.4% (range: 0% to 29% across 69 studies);249 >1% of patients experienced allergic reactions to dye used during the procedure in a trial of 5588 patients.250 5% with sentinel node biopsy and 16% to 18% with axillary lymph node dissection following sentinel node biopsy develop clinical lymphedema.251,252
Radiation^†,217^
Dose: 50 Gy in 25 fractions over 5 weeks | Based on 1,854 women: among women with breast conserving surgery—breast shrinkage 25%; breast induration 18%; telangiectasia 5%; breast edema 10%; among women who received lymphatic radiotherapy, shoulder stiffness 9%; arm edema 12%. Adverse effects experienced by <5% of patients: symptomatic rib fracture, symptomatic lung fibrosis, ischemic heart disease, brachial plexopathy.
Dose: 41.6 Gy in 13 fractions over 5 weeks | Based on 750 women: among women with breast conserving surgery—breast shrinkage 27%; breast induration 24%; telangiectasia 6%; breast edema 11%; among women who received lymphatic radiotherapy—shoulder stiffness 11%; arm edema 17%. Adverse effects experienced by <5% of patients: symptomatic rib fracture, symptomatic lung fibrosis, ischemic heart disease, brachial plexopathy.
Dose: 40 Gy in 15 fractions over 3 weeks | Based on 1,110 women: among women with breast conserving surgery—breast shrinkage 22%; breast induration 13%; breast edema 5%. Adverse effects experienced by <5% of patients: telangiectasia, symptomatic rib fracture, symptomatic lung fibrosis, ischemic heart disease, brachial plexopathy, shoulder stiffness and arm edema in women who received lymphatic radiotherapy.
Dose: 39 Gy in 13 fractions over 5 weeks | Based on 737 women: among women with breast conserving surgery—breast shrinkage 23%; breast induration 18%; breast edema 7%; among women who received lymphatic radiotherapy—shoulder stiffness 9%; arm edema 7%. Adverse effects experienced by <5% of patients: telangiectasia, symptomatic rib fracture, symptomatic lung fibrosis, ischemic heart disease, brachial plexopathy.
Endocrine therapy
Anastrozole | Anastrozole treatment for 5 years219,253 (% of patients with common adverse events in a trial of 3125 postmenopausal patients with localized invasive breast cancer): fatigue 19%; nausea and vomiting 13%; hot flushes 36%; mood disturbances 19%; musculoskeletal disorders 36%. Adverse effects experienced by <5% of patients: vaginal bleeding, vaginal discharge, ischemic cardiovascular disease, ischemic cerebrovascular events, venous thromboembolic events, deep venous thromboembolic events, carpal tunnel syndrome. Goserelin 3.6 mg given subcutaneously every 28 days plus anastrozole 1 mg/day for a mean of 47.8 months254 (% of patients each adverse events in a trial of 453 premenopausal patients who had undergone primary surgery for stage I or II breast cancer): arthralgia 24.7%; bone pain 28.3%; fatigue 20.5%; depression, sleep disturbances 21.4%; nausea and vomiting 7.1%; morning stiffness 7.3%; hot flushes 5.5%. Adverse effects experienced by <5% of patients: fracture, cognitive disorder, dizziness, peripheral nerve disease, muscle cramp, fever, hypertonia, tachycardia, thrombosis, leg edema, cutaneous reaction skin disease, impaired vision, uterine polyp, periodontal disease.
Letrozole | Letrozole 2.5 mg/day for five years255 (% of patients with adverse events in a trial of 3975 postmenopausal patients with hormone receptor positive breast cancer): hot flashes 33.5%; night sweats 13.9%; fracture 5.7%; arthralgia 20.3%; myalgia 6.4%. Adverse effects experienced by <5% of patients: cerebrovascular accident or transient ischemic attack, thromboembolic event, cardiac event, other cardiovascular events, vaginal bleeding.
Tamoxifen | Tamoxifen 10 vs. 20 mg/day orally for 6 months256(% of patients reporting adverse events which occurred in >10% of patients in a trial of 30 women with breast cancer): hot flashes 30%; nausea 17%; pharyngitis 17%; fatigue 13%. Tamoxifen 20 mg/day orally for 5 years218(% of patients with adverse reactions in a trial of 1422 patients with primary operable breast cancer over the course of 5 years): hot flashes 64%; vaginal discharge 30%; irregular menses 25%; fluid retention 32%; nausea 24%; skin changes 19%; diarrhea 11%; weight gain 38%; weight loss 22%. Adverse effects experienced by <5% of patients: thromboembolic vein, death. Other serious adverse effects of tamoxifen include an increased risk of endometrial cancer and uterine sarcoma.
Exemestane | Extramestane 25 mg/day orally for 5 years257 (% of patients with adverse reactions in a trial of 4852 postmenopausal patients with hormone receptor positive breast cancer): flushes and sweats 35%; hypertension 6%; breast or nipple disorder 6%; vaginal dryness 7%; fractures 5%; joint disorders 36%; muscle disorders 11%; osteoporosis 10%; other musculoskeletal and connective disuse disorders 15%; headache 8%; dizziness 5%; other nervous system disorders 17%; depression 9%; sleep disorder or insomnia 13%; other psychiatric disorders 8%; hyperlipidemia 5%; weight increase 7%. Adverse effect experienced by <5% of patients: arrhythmia, cardiac failure, myocardial ischemia or infarction, other cardiac disorders, embolism, peripheral arterial disease, venous thrombosis, other vascular disorders, endometrial abnormalities, genital or vaginal discharge, postmenopausal bleeding, vulvovaginal disorders, cerebrovascular insufficiency or infarction or thrombosis, nerve compression disorders, loss or reduction of libido, abnormal liver function tests, endocrine disorders, renal and urinary disorders.
Neoadjuvant/adjuvant chemotherapy
AC (doxorubicin/cyclophosphamide) followed by paclitaxel | Doxorubicin 60 mg/m^2^by 5 to 15-minute IV infusion and cyclophosphamide 600 mg/m^2^by 30 to 60-minute IV infusion every 3 weeks for 4 cycles followed by 175 mg/m^2^paclitaxel by 1-hour IV infusion weekly for 12 doses258(% of patients with common toxic effects and neuropathies resulting from the paclitaxel component of therapy in 1231 patients with lymph node-positive or high risk, lymph node-negative breast cancer after mastectomy or breast conserving surgery): grade 2, 3, or 4 neuropathy 27%. Adverse effects experienced by <5% of patients: neutropenia, febrile neutropenia, infections, stomatitis, fatigue, myalgia, arthralgia, lacrimation.
TC (docetaxel and cyclophosphamide) | Docetaxel 75 mg/m^2^and cyclophosphamide 600 mg/m^2^as 1-hour IV infusion on day 1 of a 3-week cycle (4 cycles total)259(frequency [%] of side effects in 506 patients with operable stage I to III invasive breast cancer after surgical excision of the primary tumor): anemia <7%; neutropenia 63%; thrombocytopenia <3%; asthenia <79%; edema <35%; fever 24%; infection <20%; myalgia <35%; nausea <55%; phlebitis <12%; stomatitis <35%; vomiting <16%.
TCH (docetaxel/carboplatin/trastuzumab) +/- pertuzumab | Docetaxel 75 mg/m^2^plus carboplatin administered at area under the plasma concentration curve x6 mg/mL/minute concurrently with trastuzumab at 2mg/kg every 3 weeks for 6 cycles followed by trastuzumab 6 mg/kg every 3 weeks to complete 1 year of treatment260(% of patients with adverse events in a trial of 1056 patients with HER2 positive early-stage breast cancer): irregular menses 26.5%; sensory neuropathy 36%; nail changes 28%; myalgia 38.9%; neutropenia 65.9%; leukopenia 48.2%; febrile neutropenia 9.6% neutropenic infection 11.2%; anemia 5.8% thrombocytopenia: 6.1%. Adverse effect experiences by <5% of patiets: arthralgia, fatigue, hand-foot syndrome, diarrhea, nausea, vomiting, motor neuropathy, renal failure, grade 3 or 4 creatinine elevation, leukemia. Trastuzumab at an initial dose of 8 mg/kg, followed by 6 mg/kg; pertuzumab at an initial dose of 840 mg, followed by 420 mg, carboplatin was administered at a dose of 6x area under the plasma concentration-time curve and docetaxel was given at 75 mg/m^2^ 261(% of patients with the most common adverse events during neoadjuvant treatment in a trial of 76 patients with HER2 positive breast cancer): diarrhea 72.4%; alopecia 53.9%; nausea 44.7%; neutropenia 48.7%; vomiting 39/5%; fatigue 42.1%; anemia 36.8%; mucosal inflammation 17.1%; constipation 15.8%; dyspepsia 22.4%; febrile neutropenia 17.1%; leukopenia 11.8%; anemia 17.1%; thrombocytopenia 11.8%. Adverse effects experienced by <5% of patients: drug hypersensitivity, alanine aminotransferase increase. Results reported as % of patients with the most common adverse events during adjuvant treatment in a trial of 67 patients with HER2 positive breast cancer: radiation skin injury 10.4%; arthralgia 9%; hot flushes 6%; diarrhea 9%; fatigue 7.5%; musculoskeletal chest pain 7.5%; peripheral edema 6%; erythema 6%. Adverse effects experienced by <5% of patients: headache, musculoskeletal pain, neutropenia.
Chemotherapy regimens (metastatic cancer)
Paclitaxel (taxane) | Paclitaxel 80mg/m^2^weekly via 1 hour infusion until disease progression or limiting toxicity (HER-2 + patients also received trastuzumab 2mg/kg via 30 minute infusion following a 4 mg/kg loading dose administered over 90 minutes)262 (% of patients with grade 3 or 4 nonhematologic toxicity in a trial of 577 patients metastatic breast cancer): infection 6%; diarrhea 5%; dyspnea 7%; edema 6%; neurosensory 24%; neuromotor 9%; malaise/fatigue 6%; Hyperglycemia: 5%. Two treatment related deaths attributable to pneumonia, and one secondary malignancy also occurred all in patients without trastuzumab. Paclitaxel 175mg/m^2^every 3 weeks via 3 hour infusion until disease progression or limiting toxicity (HER-2 + patients also received trastuzumab 2mg/kg via 30 minute infusion following a 4 mg/kg loading dose administered over 90 minutes)262(% of patients with grade 3 or 4 nonhematologic toxicity in a trial of 158 patients metastatic breast cancer): neurosensory 12%; Hyperglycemia: 8%. Adverse effects experienced by <5% of patients: infection, diarrhea, dyspnea, edema, neuromotor, malaise/fatigue. One secondary malignancy also occurred in a patient without trastuzumab.
Docetaxel (taxane) | Docetaxel 50 mg/m^2^as a 1-hour IV infusion on days 1 and 8 every 3 weeks (100 mg/m^2^per cycle) for a median of 5 cycles263(% of patients with adverse effects in a trial of 88 patients with metastatic breast cancer): neutropenia 94%; thrombocytopenia 11%; anemia 90%; alopecia 91%; asthenia 82%; skin 64%; diarrhea 62%; nausea 54%; vomiting 43%; stomatitis 54%; neurosensory 48%; infection 16%; weight gain 28%; myalgia 18%; hypersensitivity reactions 4%.
Capecitabine (anti metabolite) | Capecitabine 1250 mg/m^2^twice/day orally for 14 days followed by a 7-day rest period, continued for a maximum of 15 cycles264(% of patients with common adverse events in a trial of 126 patients with anthracycline and taxane pretreated metastatic breast cancer): hand-foot syndrome 71%; nausea 48%; asthenia 35%; vomiting 27%; neutropenia 26%; stomatitis 25%.

* This is not a comprehensive list of all potential adverse effects and reflects only events where rates were available.

† Results reported as % of patients experiencing adverse event during 10 years followup in 1,854 women with completely excised invasive breast cancer after primary surgery followed by chemotherapy and endocrine treatment where prescribed.217

Abbreviations: Gy=gray (unit of radiation); HER2= human epidermal growth factor receptor 2; IV = intravenous; kg=kilograms; m=meter; mg=milligram.

Most patients with DCIS and Stage I to III invasive cancer receive surgery, including lumpectomy or mastectomy with sentinel lymph node biopsy and, with more extensive disease, axillary lymph node dissection. Many will also undergo reconstruction surgery. The most common adverse effects include wound infection, skin flap necrosis, and chronic chest wall pain.216 Approximately 5 percent of patients with sentinel lymph node biopsy and 16 to 18 percent with axillary lymph node dissection develop clinical lymphedema. Some patients experience phantom breast syndrome, pneumothorax, and brachial plexopathy.

Radiation therapy is provided to women with DCIS and Stage I to III disease, and with increasing frequency as the stage of disease progresses. Adverse effects to radiation therapy vary by dose and regimen. For example, among women with breast conserving surgery, a dose of 50 Gy (unit of radiation) in 25 fractions over 5 weeks may cause breast shrinkage in 25 percent, breast induration 18 percent, telangiectasia 5 percent, and breast edema 10 percent. Symptomatic rib fracture, lung fibrosis, ischemic heart disease and brachial plexopathy occur in less than 5 percent.217

Endocrine therapy for 5 to 10 years, depending on the drug, is indicated for patients with ER positive DCIS and Stage I to III disease. For some women, tamoxifen causes hot flashes, vaginal discharge, and irregular menses. Less common adverse effects are thromboembolism, endometrial cancer, and cataracts.218 Anastrozole or other aromatase inhibitors are alternatives to tamoxifen that may cause hot flashes and joint pain. Less common adverse effects are vaginal bleeding, vaginal discharge, thromboembolic events, cataracts, and carpal tunnel syndrome.219

Several neoadjuvant/adjuvant chemotherapy regimens are available to treat patients with Stage I to III disease, and selection is based on ER, PR, and HER2 status. Adverse effects include short-term (hair loss, nausea, vomiting, fatigue, neuropathy, neutropenia) and long-term (persistent neuropathy, heart failure) adverse effects that depend on regimen, duration, and age (examples in Table 27). Chemotherapy regimens for Stage IV disease are usually provided over extended periods of time because Stage IV disease is not curable. While extended treatment regimens can control the disease for variable amounts of time depending on disease biology, they may have many adverse effects. These include neutropenia, fatigue, anemia, neuropathy, hair loss, nausea, and stomatitis, among others.

## Contextual Question 2 What Are the Absolute Incidence Rates of DCIS and Localized and Advanced Invasive Breast Cancer in Screened and Nonscreened Populations in the United States?

Absolute incidence rates for DCIS and localized and advanced invasive breast cancer are not provided according to screened and nonscreened populations in the United States. The majority of cases of DCIS are identified by mammography screening and the increased incidence of DCIS corresponds to the advent of widespread screening.32 The most recent rates from SEER for invasive cancer include 129.6 per 100,000 for all age groups; 45.2 per 100,000 for age less than 50 years; and 350.4 per 100,000 for age 50 years or greater.220 Rates of DCIS include 35.5 pre 100,000 for all age groups; 14.4 per 100,000 for less than 50 years, and 100.0 per 100,000 for age 50 years or greater.220

## Contextual Question 3 How Do Women Weight Harms and Benefits of Screening Mammography, and How Do They Use This Information in Their Decisions to Undergo Screening?

Research that describes how women weigh the benefits and harms of screening mammography and use this information for clinical decision making is limited. A Cochrane review of RCTs evaluating the effects of personalized risk communication on informed decision making found no association between provision of numerical information and uptake of mammography for women 40 years or older (OR 0.95; 95% CI, 0.78 to 1.15; 6 trials).221 However, there was an association for greater uptake of mammography when categorical information was given compared with general risk information (OR 1.29; 95% CI, 1.11 to 1.51; 6 trials). The review found that 45 percent (592/1309) of those who received personalized risk information made informed choices, compared with only 20 percent (229/1135) of those who received generic risk information (OR 4.48; 95% CI, 3.62 to 5.53; 3 trials).

Four main themes describing factors that influence a woman's decision to attend breast cancer screening were identified in a review of 12 observational studies.222 These included psychological and practical factors; issues related to ethnicity; influence of socioeconomic status; and issues related to the screening program. In these studies, cancer anxiety and worry was associated with both the promotion and avoidance of breast cancer screening.223,224 Some women cited embarrassment as their reason for non-attendance,224 particularly women of specific religious groups.225 Most women expressed a preference for a female medical professional performing the screening mammography.224 Black women were more likely to get information about mammography from their primary physician, while white women were more likely to have received their information from media sources.226

In these studies, rates of screening uptake were lower among low-income populations161,224,227-230 and non-English speakers, and higher income households were twice as likely to attend mammography screening.228 Lower uptake rates were also associated with lower levels of education, the lack of health insurance, and unemployment. Women from lower socioeconomic backgrounds did not consider themselves at risk for breast cancer and focused on perceived negative aspects of screening and the intrinsic costs (time, embarrassment, and discomfort).231 In contrast, many women overestimated their risk and the mortality reduction from mammography screening resulting in higher uptake of screening.232,233