# Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,61,62 the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework outlining the key questions and included patient populations, interventions, and outcomes (Figure 3).

Figure 3 Analytic Framework and Key Questions

Key Questions:

In the target population of women age 40 years and older*:

1. What is the effectiveness of routine mammography screening in reducing breast cancer–specific and all-cause mortality, and how does it differ by age, risk factor‡, and screening interval?
2. What is the effectiveness of routine mammography screening in reducing the incidence of advanced breast cancer and treatment-related morbidity§, and how does it differ by age, risk factor‡, and screening interval?
3. How does the effectiveness of routine breast cancer screening in reducing breast cancer–specific and all-cause mortality vary by different screening modality║?
4. How does the effectiveness of routine breast cancer screening in reducing the incidence of advanced breast cancer and treatment-related morbidity§ vary by different screening modality║?
5. What are the harms¶ of routine mammography screening, and how do they differ by age, risk factor‡, and screening interval?
6. How do the harms¶ of routine breast cancer screening vary by different screening modality║?

Contextual Questions:

1. What are the rates of specific adverse effects of current treatment regimens for invasive breast cancer and ductal carcinoma in situ (DCIS) in the United States?
2. What are the absolute incidence rates of DCIS and localized and advanced invasive breast cancer in screened and nonscreened populations in the United States?
3. How do women weigh the harms and benefits of screening mammography and how do they use this information in their decisions to undergo screening?

* Excludes women with pre-existing breast cancer; clinically significant BRCA mutations, Li-Fraumeni syndrome, Cowden syndrome, hereditary diffuse gastric cancer, or other familial breast cancer syndromes; high-risk lesions (DCIS, LCIS, ADH, ALH); or previous large doses of chest radiation (≥ 20 Gy) before age 30.

† Addresses contextual question 1.

‡ Risk factors include: family history, breast density, race/ethnicity, menopausal status, current use of menopausal hormone therapy or oral contraceptives, prior benign breast biopsy, and, for women age >50 years, body mass index.

§ Morbidity includes: physical adverse effects of treatment, quality of life measures, other measures of impairment.

║ Screening modalities include: mammography (digital, tomosynthesis), magnetic resonance imaging (MRI), ultrasound, and clinical breast examination (alone or in combination).

¶ Harms include: false positive findings, anxiety, false positive biopsies, false negative findings, false reassurance, overdiagnosis and resulting overtreatment, and radiation exposure.

Abbreviations: ADH=atypical ductal hyperplasia; ALH=atypical lobular hyperplasia; BRCA=breast cancer gene; DCIS=ductal carcinoma in situ; Gy=gray (unit of absorbed radiation); KQ=key question; LCIS=lobular carcinoma in situ; MRI=magnetic resonance imaging.

Figure 3 is an analytic framework that depicts the pathway for breast cancer screening for women over 40 years of age without pre-existing breast cancer, clinically significant BRCA mutations, Li-Fraumeni syndrome, Cowden syndrome, hereditary diffuse gastric cancer or other familiar breast cancer syndromes, high-risk lesions or previous large doses of chest radiation before age 30. The figure shows that screening can lead to early detection of invasive breast cancer, which would be followed by treatment leading to reduced advanced disease or morbidity from treatment, and to final outcomes of reduced mortality from breast cancer or all-causes. The figure indicates that there are potential harms of screening and treatment. The figure also shows that screening could directly impact the outcomes of reduced advanced disease or morbidity from treatment, as well as reducing mortality outcomes. The figure is further described in the text of the report on page 7.

The target population for the USPSTF recommendation served as the focus of the systematic review. This population includes women age 40 years and older and excludes women with physical signs or symptoms of breast abnormalities and those at high-risk for breast cancer whose surveillance and management are beyond the scope of the USPSTF's recommendations for prevention services. Women at high-risk are those with risk factors known to increase their risks of breast cancer to levels that make them eligible for screening or followup services outside of recommendations for women without these risk factors. Women at high-risk include those with pre-existing breast cancer; BRCA1 or BRCA2 mutations and their untested first-degree relatives18 and other hereditary genetic syndromes associated with more than a 15 percent lifetime risk of developing breast cancer (including Li-Fraumeni syndrome, Cowden syndrome, or hereditary diffuse gastric cancer);19 previously diagnosed high-risk breast lesions (DCIS, LCIS, ADH, ALH); and high-dose radiation therapy to the chest between the ages of 10 and 30. Women with lower risks for breast cancer are generally eligible for routine screening and are relevant to the USPSTF's recommendations.

### Key Questions

1. What is the effectiveness of routine mammography screening in reducing breast cancer–specific and all–cause mortality, and how does it differ by age, risk factors, and screening intervals?
2. What is the effectiveness of routine mammography screening in reducing the incidence of advanced breast cancer and treatment-related morbidity, and how does it differ by age, risk factors, and screening intervals?
3. How does the effectiveness of routine breast cancer screening in reducing breast cancer–specific and all-cause mortality vary by different screening modality?
4. How does the effectiveness of routine breast cancer screening in reducing the incidence of advanced breast cancer and treatment-related morbidity vary by different screening modality?
5. What are the harms of routine mammography screening, and how do they differ by age, risk factors, and screening intervals?
6. How do the harms of routine breast cancer screening vary by different screening modality?

Risk factors considered in this review are common among women who are not at high-risk for breast cancer as defined above. These include family history of breast cancer (not including genetic syndromes described above), breast density, race/ethnicity, menopausal status, current use of menopausal hormone therapy or oral contraceptives, prior benign breast biopsy, and BMI for women older than age 50 years.

Outcomes related to benefits included in this review are reduced breast cancer mortality, all-cause mortality, advanced breast cancer, and morbidity related to breast cancer treatment. Other outcomes, such as increased breast cancer awareness and peace of mind with screening, are not included. Treatment-related morbidity includes physical adverse effects of treatment, quality of life measures, and other measures of impairment. Screening modalities include mammography (digital, tomosynthesis), MRI, ultrasound, and CBE (alone or in combination). Only breast imaging technologies approved for screening by the U.S. Food and Drug Administration are included in this review, consistent with the scope of the USPSTF.

Harms include false-positive and false-negative mammography results, false reassurance, anxiety and worry, overdiagnosis and resulting overtreatment, and radiation exposure. Overdiagnosis refers to women receiving a diagnosis of DCIS or invasive breast cancer who had abnormal lesions that were unlikely to become clinically evident during their lifetimes in the absence of screening. Overdiagnosis may have more effect on women with shorter life expectancies because of age or comorbid conditions.

### Contextual Questions

Three contextual questions were also requested by the USPSTF to provide additional background information. Contextual questions are not reviewed using systematic review methodology but are addressed using the strongest, most relevant evidence. These include the following.

1. What are the rates of specific adverse effects of current treatment regimens for invasive breast cancer and DCIS in the United States?
2. What are the absolute incidence rates of DCIS and localized and advanced invasive breast cancer in screened and nonscreened populations in the United States?
3. How do women weigh the harms and benefits of screening mammography and how do they use this information in their decisions to undergo screening?

## Search Strategies

In conjunction with the systematic review investigators, a research librarian searched the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Ovid MEDLINE (all searches through December 2014) for relevant studies and systematic reviews. Reference lists of articles were also reviewed. Search dates varied because some key questions (Key Questions 1, 3, 5, 6) were included in the 2009 systematic review and required only updates of studies published since the previous search in 2008. Other key questions were not addressed by the previous review and required searches that covered longer time periods (Key Questions 2 and 4, and cohort studies for Key Questions 1 and 3). These searches extended to 1996 because this corresponds to the last time the USPSTF evaluated similar data, and represents a period when practice was shifting to digital mammography in the United States. The contextual questions have a shorter time period for searches because they require the most current data to be clinically relevant. Search strategies are available in Appendix A1.

In addition, unpublished data from the Breast Cancer Surveillance Consortium (BCSC) on screening with digital mammography were evaluated. The BCSC is a collaborative network of mammography registries with linkages to pathology databases and tumor registries across the United States supported by the National Cancer Institute (NCI).63,64 These data draw from community samples that are representative of the larger, national population and may be more applicable to current practice in the United States than other published sources.

Also, unpublished updated data from the Canadian and Swedish Two-County randomized controlled trials (RCTs) were obtained from the trial investigators.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. Studies were selected on the basis of prespecified inclusion and exclusion criteria developed for each key question (Appendix A2). The selection of studies is summarized in a flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

Studies of women at high-risk for breast cancer as defined above or with previously diagnosed breast cancer were not included. Studies most clinically relevant to practice in the United States were selected over studies that were less relevant. Relevance was determined by practice setting, population, date of publication, use of technologies and therapies in current practice, and other factors. Also, studies of higher-quality and those with designs ranked higher in the study design-based hierarchy of evidence, such as RCTs over observational studies, were emphasized because they are less susceptible to bias.

To determine the effectiveness of screening, RCTs, observational studies of screening cohorts, and systematic reviews of screening with mammography (film, digital, tomosynthesis) and other modalities (MRI, ultrasound, CBE alone or in combination) were included. Valid comparisons evaluated outcomes of groups of women exposed to screening versus nonscreening, not comparisons of detection methods that do not capture a woman's longitudinal screening experience (e.g., rates of screen-detected vs. nonscreen-detected cancer).

Outcomes included breast cancer specific and all-cause mortality (Key Questions 1 and 3) and advanced breast cancer and treatment-related morbidity (Key Questions 2 and 4). While advanced breast cancer is classified as metastatic disease (Stage IV) by the AJCC TNM system,36 most screening studies defined advanced breast cancer at much lower thresholds, including Stage IIA or higher, lymph node positive disease, or tumor size of 20 mm or larger.65 Studies providing outcomes specific to age, risk factors, screening intervals, and modalities were preferred over studies providing general outcomes, when available. Risk factors conferring a moderate, as opposed to high, level of risk were included as listed previously.17,66

The harms of screening were determined from several study designs and data sources. For mammography, searches focused on recently published systematic reviews and meta-analyses of radiation exposure, pain during procedures, patient anxiety and other psychological responses, consequences of false-positive and false-negative mammography results, and overdiagnosis. Specific searches for primary studies published more recently than the included systematic reviews and meta-analyses were also conducted.

Performance characteristics of screening methods (e.g., sensitivity, specificity, positive predictive value); accuracy of breast density determination; use of supplemental screening technologies; and a new model of radiation exposure are presented in separate reports. Studies of cost-effectiveness of screening were not addressed in this update.

## Data Abstraction and Quality Rating

Details of the study design, patient population, setting, screening method, interventions, analysis, followup, and results were abstracted by one investigator and confirmed by a second. Two investigators independently applied criteria developed by the USPSTF61,62 to rate the quality of each study as good, fair, or poor for studies designed as RCTs, cohort studies, case-control studies, and systematic reviews (Appendix A5). USPSTF criteria to rate other study designs included in this review are not available. Discrepancies were resolved through consensus. Only data from RCTs rated fair- or good-quality were included in the meta-analyses.

## Meta-Analysis of Mammography Screening Trials

Several meta-analyses were conducted to determine more precise summary estimates for the effectiveness of breast cancer screening when adequate data were reported by trials. Clinical and methodological diversity and statistical heterogeneity were considered to determine the appropriateness of meta-analysis. All outcomes (breast cancer mortality, all-cause mortality, and advanced cancer occurrence) were binary. A random-effects model was used to combine relative risks (RRs) as the effect measure of the meta-analyses, while incorporating variation among studies. A profile-likelihood model was used to combine studies in the primary analyses.67 The presence of statistical heterogeneity among the studies was assessed by using the standard Cochran's chi-square test, and the magnitude of heterogeneity by using the I^2^ statistic.68

To account for clinical heterogeneity and obtain clinically meaningful estimates, the analyses were stratified by age group (39 to 49 years, 50 to 59 years, 60 to 69 years, 70 to 74 years, or ≥75 years), whenever possible. Investigators of two recently published updates of trials provided additional age-stratified data for the meta-analysis.69,70 Two definitions were used to evaluate advanced breast cancer outcomes (stage and tumor size).

For breast cancer mortality, two methods of including cases in estimates were used because each offers advantages and disadvantages, and may provide additional insights to the interpretation of results. The long case accrual method counts all of the breast cancer cases contributing to breast cancer deaths. In this method, the case accrual time is equivalent to or close to the followup time. The short case accrual method includes only deaths that occur among cases of breast cancer diagnosed during the screening intervention period, and in some trials, within an additional defined case accrual period. These methods are further described in the results section.

To facilitate the interpretation of the combined RR for breast cancer mortality, the absolute rate reduction for 100,000 women-years of followup (i.e., 10,000 women followed for 10 years) was calculated for each age group based on the combined RR and the combined cancer rate of the control group. The combined cancer rate of the control group was obtained using a random effects Poisson model for each age group using data from the trials. All analyses were performed using Stata/IC 13.1 (StataCorp, College Station, TX).

## Analysis of BCSC Data

Background information and additional details about methods of the BCSC are described in Appendix A6. Data were obtained from the BCSC Statistical Coordinating Center for 405,191 women ages 40 to 89 years who had routine screening with digital mammography during 2003 to 2011 at participating facilities at six BCSC breast imaging registries. Results were stratified by age in decades to determine age-specific outcomes. Routine screening required at least one mammography examination within the previous 2 years (defined as 30 months). For women with several mammography examinations during this time period, one result was randomly selected to be included in the calculations. These data comprise a defined subset of BCSC data intended to represent the experience of a cohort of regularly screened women without histories of breast cancer or current breast symptoms.

Screening mammography examinations were those designated as such by the radiologist or radiology technologist performed more than 9 months after a previous imaging examination in women without histories of breast cancer, breast augmentation, or mastectomies. This approach eliminated the possibility that a woman's first mammogram was included because first mammograms are more likely to be read as false positives. Unilateral exams were also excluded. Mammography information included Breast Imaging Reporting and Data System (BI-RADS) breast density, assessment scores, and recommendations for further workup. In addition, prior to each mammography examination, women completed questionnaires that included demographic and medical history information, including previous mammography information.

Data include the numbers of positive and negative mammography results and, of these, the numbers of normal screening and false-negative results based on followup data within 1 year of mammography screening and before the next screening examination. Positive versus negative initial and final results were defined according to standardized terminology and assessments of the American College of Radiology BI-RADS 4^th^ edition atlas71 and BCSC standard definitions.72 Each screening mammography examination was given an initial BI-RADS assessment based on the screening views only. Positive initial results included four assessment categories: needs additional imaging evaluation (category 0), probably benign (category 3) with a recommendation for immediate work-up (these were treated as a category 0 based on the recommendation), suspicious abnormality (category 4), or highly suggestive of malignancy (category 5).73 Negative results included assessments of negative (category 1) or benign findings (category 2), or category 3 without a recommendation for immediate work-up.

For women who had positive screening mammography results, data were evaluated on the number of women receiving a recommendation for additional imaging, the number receiving a recommendation for biopsy, and diagnoses including invasive breast cancer, DCIS, and no cancer. Recommendation for biopsy was defined as a positive final result after all imaging including work-up of an abnormal screening examination. Positive final results included BI-RADS assessments of 4 or 5 or 0 with a recommendation for biopsy.73 Negative final results included an assessment of 1, 2, or 3 or 0 with a recommendation for normal or short-interval followup or clinical exam.

From these data, age-specific rates (numbers per 1,000 women per screening round) of invasive breast cancer, DCIS, false-positive and false-negative mammography results, recommendations for additional imaging, and recommendations for biopsies were calculated.

Age groups were further divided into sub-categories to determine whether outcomes differed by time since last mammography screening or risk factors. Two measures of time since last mammography screening were evaluated to represent broad and narrow estimates of one versus two years (9 to 18 versus 19 to 30 months; 11 to 14 versus 23 to 26 months).

Risk factors included those mostly commonly associated with breast cancer.17 These included first-degree relatives with breast cancer (none, ≥1); breast density (almost entirely fat, scattered fibroglandular densities, heterogeneously dense, extremely dense); benign breast biopsy (none, previous); race/ethnicity (white, black, Asian, Hispanic, other); menopausal status (pre, peri, postmenopausal); menopausal hormone therapy use (none, combination [estrogen with progestin], estrogen only); oral contraceptive use (no current use, current use), and body mass index (BMI) (<25, 25 to <30, ≥30 kg/m^2^). Since the BCSC data do not include information on types of menopausal hormone therapy, the analysis assumes that a woman with a uterus uses combination therapy, while a woman without a uterus uses estrogen-only therapy. The main analysis analyzed three categories of breast density, combining almost entirely fat and scattered fibroglandular densities into one group. As a sensitivity analysis, density was analyzed in three additional ways: (1) three categories, combining heterogeneously dense and extremely dense into one group; (2) four separate BI-RADS categories; and (3) two categories that combine almost entirely fat and scattered fibroglandular densities into one group and heterogeneously dense and extremely dense into another group.

From these data, age-specific rates (numbers per 1,000 women per screening round) of false-positive and false-negative mammography results, recommendations for additional imaging, and recommendations for biopsies were calculated and comparisons by age, time since last mammography screening, and risk factors were determined. To account for correlation among mammograms interpreted at the same radiology facility, robust standard errors from logistic regression were estimated using generalized estimating equations with an independence working correlation matrix. Differences between groups were assessed by 2-sided P-values with 95% confidence intervals (CIs).

## Data Synthesis

The aggregate internal validity (quality) of the body of evidence for each key question was assessed ("good," "fair," "poor") using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence.61,62

## External Review

The draft report was reviewed by content experts from multiple disciplines, USPSTF members, AHRQ Project Officers, and collaborative partners and revised prior to finalization (Appendix A7).

## Response to Public Comment

A draft version of the evidence report was posted for public comment on the USPSTF website from April 18 to May 18, 2015. Comments from 13 contributors were directly relevant to the systematic review, while comments from other contributors were outside its scope, or concerned the recommendation statement, CISNET model, or other evidence reports. Most comments addressed four major issues detailed below, while additional comments suggested adding studies that were either already included or were previously considered, but did not meet prespecified inclusion criteria; or correcting minor errors that have since been corrected.

### Inclusion of Observational Studies

The evidence report includes nearly 200 observational studies of breast cancer screening including 83 studies of benefits. Results of studies of the effectiveness of screening in reducing breast cancer mortality are reported for both observational studies and RCTs. For women age 50 to 69 years, the trials indicated statistically significant reductions in breast cancer mortality ranging from 0.78 to 0.81 depending on whether short or long case accrual methods were used. Observational studies indicated reductions of 0.69 to 0.75. For women age 40 to 49, few data from observational studies were available because most European countries collecting these data do not screen younger women. For women age 70 and older, data from both RCTs and observational studies were not available.

RCTs are the least biased study design for determining efficacy/effectiveness, and provide a stronger body of evidence than observational studies. When RCTs and studies of other designs have similar results, such as breast cancer mortality reduction for women age 50 to 69 years, the body of evidence is stronger. Observational studies are subject to important biases that limit their use in determining effectiveness. Most importantly, they lack comparability of comparison groups that is only attainable through randomization. Many observational studies that compare characteristics of breast cancer diagnoses between screened and unscreened women provide comparisons between screen-detected and nonscreened-detected cases. This approach categorizes all cancer cases identified outside of a screening mammogram as nonscreen-detected, even though a woman may have had prior screening mammography.

In RCTs, intension-to-screen analysis is essential to determining efficacy/effectiveness, and is comparable to intension-to-treat analysis for drug trials. Data from trials not using intension-to-screen analysis, or from observational studies, provide outcomes for women who self-select screening. While outcomes from women who self-select screening may be useful for planning health care services, they do not provide valid measures of efficacy/effectiveness. This is a major difference between how evidence-based guideline groups and some professional societies interpret the research literature.

### Inclusion of RCTs

The evidence review describes the RCTs of screening and their limitations in detail. No trials met criteria for good quality (all RCTs in the meta-analysis were fair-quality; a poor-quality trial was excluded).

The meta-analyses of RCTs for breast cancer mortality outcomes use two methods in order to more precisely explain the results of the trials and provide a range of outcomes. There are advantages and disadvantages to these methods, and these are described in the evidence review. While both methods have been used for individual trials and for some of the Swedish trials collectively, no other systematic reviews have taken this rigorous approach across all trials. Results of some of the trials appear in both estimates because the trial investigators only published short case accrual results. Rather than eliminate trials from the meta-analysis, the “longest followup available” from each trial was included and those based on short case accrual are clearly indicated (this was also the approach in the 2009 meta-analysis44).

Regarding outcomes related to advanced breast cancer, most of the diagnostic outcomes of the trials were based on early stages of disease (Stage IIA or localized), not advanced. To address the key question about prevention of advanced disease, the meta-analysis used the most advanced disease categories available from the trials. These results indicated reduced risk with screening for women age 50 and older. The connection between being diagnosed with advanced breast cancer and dying is not a key question of this evidence review. This link is acknowledged in the analytic framework.

### Screening Intervals

None of the RCTs were designed to evaluate screening intervals. The observational data, including studies from the BCSC, are based on women who self-select screening and adhere, or not, to specific periods of time between screening. Comparisons between women who electively screen annually versus biennially are inherently biased because these women differ in many ways. Estimates from BCSC data are approximations that reflect opportunistic screening in a fluctuating population of women whose information was collected by the participating registries. The BCSC data need to be interpreted with these limitations in mind.

### Harms

The studies on overdiagnosis are described in detail in the evidence review and the general conclusion is that they are too methodologically heterogeneous to provide reliable estimates. Until a consensus definition with common metrics is determined, these estimates are uncertain.