# Introduction

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update their 2009 recommendation on screening for breast cancer.1 In 2009, the USPSTF recommended biennial screening mammography for women ages 50 to 74 years (B recommendation). They determined that the decision to start regular, biennial screening mammography before the age of 50 years should be an individual one and take patient context into account, including the patient's values regarding specific benefits and harms (C recommendation). The USPSTF concluded that evidence was insufficient to assess the additional benefits and harms of screening mammography in women age 75 years or older (I Statement).

The USPSTF also recommended against teaching breast self-examination (BSE) as a cancer screening strategy (D recommendation), and concluded that evidence was insufficient to assess the additional benefits and harms of clinical breast examination (CBE) beyond screening mammography in women age 40 years or older (I Statement). The USPSTF concluded that the evidence was insufficient to assess the additional benefits and harms of either digital mammography or magnetic resonance imaging (MRI) instead of film mammography as screening modalities for breast cancer (I Statement).

This report updates evidence on the effectiveness of mammography in decreasing breast cancer mortality, all-cause mortality, and advanced breast cancer among women who are not at high risk for breast cancer; harms of screening; and how effectiveness and harms vary by age, risk factors, screening intervals, and screening modalities. This report includes studies relevant to current medical practice in the United States and highlights gaps as well as strengths in evidence. Additional reviews and analyses for the USPSTF are provided in separate reports including systematic reviews of the performance characteristics of screening methods and the accuracy of breast density determination and use of supplemental screening technologies, and a model of radiation exposure.

## Condition Definition

Breast cancer is a proliferation of malignant cells that arises in the breast tissue, specifically in the terminal ductal-lobular unit, and represents a continuum of disease ranging from noninvasive to invasive carcinoma.2 Noninvasive carcinoma, or an in situ lesion, does not invade the surrounding stroma and does not metastasize. Noninvasive lesions are confined to either the duct (ductal carcinoma in situ [DCIS]),3 or to the lobule (lobular carcinoma in situ [LCIS], now categorized as lobular intraepithelial neoplasia [LIN]).3 LCIS is considered a marker for increased risk of invasive ductal or lobular breast cancer,4 while some forms of DCIS are considered precursor lesions for invasive ductal carcinoma. DCIS is heterogeneous and has varying clinical behavior and pathologic characteristics.5

Unlike noninvasive lesions, invasive breast cancer invades the basement membrane into the adjacent stroma, and therefore, has metastatic potential. The most common sites of metastasis include adjacent lymph nodes, lung, liver, and bone.2 Approximately 70 to 80 percent of invasive breast cancer cases are invasive or infiltrating ductal carcinoma and approximately 10 percent are invasive lobular carcinoma.2 Other less common histologic subtypes of invasive breast cancer include apocrine, medullary, metaplastic, mucinous, papillary, and tubular.2

## Prevalence and Burden of Disease

Breast cancer is the second mostcommon cancer in women in the United States after non-melanoma skin cancer, and is the second leading cause of cancer death after lung cancer.6,7 In 2015, an estimated 231,840 women in the United States will be diagnosed with breast cancer and 40,290 will die, representing 14 percent of all new cancer cases and 6.8 percent of all cancer deaths.8 Incidence rates have been stable over the last 10 years and death rates have been falling approximately 1.9 percent each year between 2002 and 2011. According to lifetime risk estimates for the general population, 12.3 percent of women will develop breast cancer during their lives, and 2.8 percent will die from the disease.9 The overall 5-year relative survival rate for breast cancer in 2006 was 90.6 percent, and an estimated 2,899,726 women were living with breast cancer in the United States in 2011.^8^

## Etiology and Natural History

Current research on the etiology of breast cancer focuses on clarifying the role of both inherited and acquired mutations in oncogenes and tumor suppressor genes and the consequences these mutations may have on the cell cycle, as well as investigating various prognostic biological markers. The contribution of external influences, such as environmental exposures, have on regulatory genes is unclear. Currently, no single environmental or dietary exposure has been found to cause a specific genetic mutation that causes breast cancer. Exposure to both endogenous and exogenous estrogen is important in tumorigenesis and growth. Other potential causes of breast cancer include inflammation and virally mediated carcinogenesis.10

Whether DCIS is a precursor lesion or a marker of risk is uncertain. With the widespread use of screening mammography in the United States, nearly 90 percent of DCIS cases are now diagnosed only on imaging studies, most commonly by the presence of microcalcifications. These represent approximately 23 percent of all breast cancer cases.11 Although DCIS is the most common type of noninvasive breast cancer, its natural history is poorly understood. Older studies of palpable DCIS lesions indicated that 14 to 53 percent of untreated DCIS progressed to invasive cancer over 8 to 22 years.12-14 The rate of progression of mammography detected DCIS is not known. Characteristics associated with subsequent invasive breast cancer include young age, black race, indication for biopsy, tumor characteristics such as high nuclear grade, comedo-type necrosis, tumor size;15 and high breast density.16

## Risk Factors

Although many risk factors have been associated with breast cancer in epidemiologic studies, most relationships are weak or inconsistent.17 Most women who develop breast cancer have no identifiable risk factors beyond sex and age. However, a small number of clinically significant risk factors are associated with high risks for breast cancer and can be used to identify women who may be eligible for screening outside routine screening recommendations. These include women with BRCA1 or BRCA2 mutations and their untested first-degree relatives,18 and other hereditary genetic syndromes associated with more than a 15 percent lifetime risk, including Li-Fraumeni syndrome, Cowden syndrome, or hereditary diffuse gastric cancer.19 Previously diagnosed high-risk breast lesions, including LCIS, atypical ductal hyperplasia (ADH), atypical lobular hyperplasia (ALH), flat epithelial atypia, papillary atypia, and apocrine atypia significantly increase risk for breast cancer.20 Estimated 10-year breast cancer risks associated with breast lesions include 17.3 percent with ADH, 20.7 percent with ALH, 23.7 percent with LCIS, and 26.0 percent with severe ADH.20 Also, women with a history of high-dose radiation therapy to the chest between the ages of 10 to 30 years, such as for treatment of Hodgkin lymphoma, are also considered at high risk.19

Family history of breast cancer, particularly among first-degree relatives, is also an important risk factor. Approximately 5 to 10 percent of women with breast cancer have a mother or sister with breast cancer, and up to 20 percent have either a first-degree or a second-degree relative with breast cancer.21-25 The degree of risk associated with family history varies according to familial patterns of disease. Estimates of lifetime risk of breast cancer determined by kindred analysis of over 15 or 20 percent are considered high.

Additional factors that increase risk to lower degrees than described above include older age; current use of menopausal hormone therapy using combined estrogen and progestin regimens;26 current use of oral contraceptives;17 nulliparity;17 high body mass index (BMI) for postmenopausal women only;27 and higher breast density.28 Breast density is a radiographic measure of breast tissue that is associated with increased risk for breast cancer and reduced mammography sensitivity. Breast density is currently described by four categories: almost entirely fat, scattered fibroglandular densities, heterogeneously dense, and extremely dense.29 Approximately 40 percent of women have heterogeneously dense breasts and 10 percent have extremely dense breasts. Increased breast density is more common among younger women.30 Compared with women with scattered fibroglandular densities, hazard ratios for breast cancer are 1.6 for premenopausal women with heterogeneously dense breasts and 2.0 for those with extremely dense breasts.28

Empiric models that incorporate several of these risk factors have been developed to predict breast cancer risk for individual women.31 All of the models include age and number of first-degree relatives with breast cancer into their calculations, but vary in their complexity. Studies of their diagnostic accuracy indicate that the models are poor predictors of an individual's risk.31 It remains unclear how to apply these models to selecting candidates for breast cancer screening.

## Rationale for Screening and Screening Strategies

Breast cancer has a known asymptomatic phase that can be identified with mammography and could be more effectively treated in early stages than when clinical signs and symptoms present. While screening may not reduce mortality for some aggressive cancer types,32 and has less impact on slowly progressive types,33,34 survival may be improved for other types of cancer when they are identified at localized stages.

## Interventions and Treatment

Current treatment for breast cancer in the United States involves a combination of therapies including surgery, radiation, hormonal therapy, and chemotherapy based on stage (0 to IV) and status of estrogen receptor (ER), progesterone receptor (PR), and human epidermal growth factor receptor 2 (HER2).35 Clinical staging using the American Joint Committee on Cancer (AJCC) TNM system guides treatment and informs prognosis (Table 1).36 In this system, stage grouping is based on tumor size (T), lymph node involvement (L), and presence of metastasis (M). Main categories are expressed as DCIS (stage 0), localized (Stage I, IIA, IIB, or T3, N1, M0), locally advanced or regional (Stage III), and metastatic disease (Stage IV). Survival varies by stage, and the 5-year relative survival rates for breast cancer in the United States are 99 percent with localized, 84 percent with regional, and 23 percent with metastatic disease.9

Table 1 Breast Cancer Staging System^*^

Description
Primary tumor (T) | T1=tumor size ≤20 mm T2=>20 mm but ≤50 mm T3=>50 mm T4=tumor of any size with direct extension to the chest wall and/or skin
Regional lymph nodes (N) | N0=no regional lymph node metastases N1mi=micrometastases N1=metastases to moveable ipsilateral axillary lymph nodes N2=metastases in ipsilateral axillary lymph nodes that are clinically fixed N3=metastases that are more extensive
Distant metastasis (M) | M0=no evidence of distant metastases M1=distant detectable metastases as determined by clinical and radiographic means
Stage
0 | DCIS
I | IA=T1, N0, M0 IB=T0, N1mi, M0 or T1, N1mi, M0
II | IIA=T0, N1, M0 or T1, N1, M0 or T2, N0, M0 IIB=T2, N1, M0 or T3, N0, M0
III | Larger size tumors with various combinations of lymph node involvement that are more extensive than stage II, but no distant metastases
IV | Distant metastases (M1)

* Adapted from 2014 National Comprehensive Cancer Network Clinical Practice Guidelines in Oncology.36

Abbreviations: DCIS=ductal carcinoma in situ; mm=millimeter.

Treatment regimens are highly individualized according to each patient's clinical status and preferences (Table 2). In addition, many patients are recruited to clinical trials of new regimens. Surgical therapies for DCIS and localized and regional invasive cancer include lumpectomy or total mastectomy with or without reconstruction. Surgery also involves sentinel lymph node biopsy for selected cases of DCIS, axillary node staging for localized disease, and axillary node dissection for regional disease. Surgical therapy is performed in only selected cases of metastatic disease. Radiation therapy generally follows surgery. Whole breast radiation may be added to lumpectomy for DCIS, localized, and regional disease. Radiation to the lymph nodes and chest wall, if involved, may be indicated for localized and regional disease.

Table 2 Treatment of DCIS and Invasive Breast Cancer by Stage^*^

Treatment | 0 (DCIS) | I, IIA, IIB, or T3, N1, M0 | III (locally advanced) | IV (metastatic)
Surgery | Total mastectomy ± sentinel node biopsy ± reconstruction; or lumpectomy without lymph node surgery. | Total mastectomy or lumpectomy + axillary staging ± breast reconstruction. | If response to pre-operative therapy, total mastectomy or lumpectomy + axillary dissection ± delayed breast reconstruction. | None
Radiation | Whole breast radiation may be added to lumpectomy. | Radiation to whole breast and lymph nodes if involved; follows chemotherapy if provided. | Radiation to chest wall and lymph nodes. | Selective radiation to bone or brain metastases.
Chemotherapy^†^ | None | Systemic adjuvant therapy as indicated by ER, PR, and HER2 status and predictive tests for chemotherapy benefit. | - Pre-operative systemic therapy.; - 1-year therapy with trastuzumab if HER2-positive. | - If bone disease present, denosumab, zoledronic acid, or pamidronate.; - If ER and PR-negative; or ER and/or PR-positive and endocrine refractory; consider chemotherapy.^‡^
Endocrine treatment^§^ | If ER-positive, consider tamoxifen for 5 years for prevention. | If ER-positive, tamoxifen for 10 years or aromatase inhibitor for 5 years (if post-menopausal only) or switching strategy of tamoxifen/aromatase inhibitor. | If ER-positive, tamoxifen for 10 years or aromatase inhibitor for 5 years (if post-menopausal only) or switching strategy of tamoxifen/aromatase inhibitor. | - Treatment regimen based on receptor status.; - If ER positive, consider ovarian ablation/ suppression for premenopausal women

* Adapted from 2014 National Comprehensive Cancer Network Clinical Practice Guidelines in Oncology.35

† Neoadjuvant/adjuvant chemotherapy: HER2-negative disease=AC (doxorubicin/cyclophosphamide) followed by paclitaxel, or TC (docetaxel and cyclophosphamide); HER2-positive disease=doxorubicin/cyclophosphamide followed by paclitaxel plus trastuzumab ±pertuzumab, or TCH (docetaxel/carboplatin/trastuzumab) ± pertuzumab.

‡ Chemotherapy regimens for stage IV (metastatic cancer): preferred single agents=anthracyclines (doxorubicin, pegylated liposomal doxorubin), taxanes (paclitaxel, docetaxel, nab-paclitaxel), anti-metabolites (capecitabine, gemcitabine), other microtubule inhibitors (vinorelbine, eribulin); chemotherapy combinations=CAF/FAC (cyclophosphamide/doxorubicin/fluorouracil), FEC (fluorouracil/epirubicin/cyclophosphamide), AC (doxorubicin/cyclophosphamide), EC (epirubicin/cyclophosphamide), CMF (cyclophosphamide/methotrexate/fluorouracil), docetaxel/capecitabine, GT (gemcitabine/paclitaxel), gemcitabine/carboplatin, paclitaxel/bevacizumab.

§ Endocrine therapy for systemic disease: stage I-III=non-steroidal aromatase inhibitor (anastrozole, letrozole); steroidal aromatase inactivator (exemestane); tamoxifen; stage IV=non-steroidal aromatase inhibitor (anastrozole, letrozole); steroidal aromatase inactivator including exemestane, exemestane + everolimus, fulvestrant, tamoxifen or toremifene, megestrol acetate, fluoxymesterone, ethinyl estradiol.

Abbreviations: DCIS=ductal carcinoma in situ; ER=estrogen receptor; HER2=human epidermal growth factor receptor 2; PR=progesterone receptor.

Endocrine treatment is recommended for ER-positive patients at all stages. Usual regimens include 5 years of tamoxifen for DCIS, 10 years of extended adjuvant hormonal therapy (tamoxifen with or without aromatase inhibitors) for localized and regional disease, and additional regimens for metastatic disease.35,37 Premenopausal ER-positive patients with metastatic disease may also consider ovarian ablation or suppression.

Systemic neoadjuvant/adjuvant chemotherapy for invasive cancer is determined by ER, PR, and HER2 status, and predictive tests for chemotherapy benefit.38,39 Chemotherapy is given after surgery for localized disease. Patients with regional disease generally receive chemotherapy before or after breast surgery and incorporate one year of trastuzumab (Herceptin). Chemotherapy for metastatic disease involves more complicated regimens depending on receptor status, tumor biology, and initial responses.35,38-40

## Current Clinical Practice

Mammography screening in the United States is generally opportunistic, unlike the many screening programs organized as public health services in other countries. Mammography is provided by radiology units of hospitals and outpatient facilities as well as by stand-alone imaging centers. Services range from imaging alone to comprehensive services that may be integrated within breast centers. As such, there is considerable variation in current clinical practice depending on the patient population, provider practice, community, and institutional policy, although national accreditation and professional groups define practice standards and quality benchmarks to assure consistency of care.

While there is general consensus that mammography screening is beneficial for many women, conflicting screening recommendations have led to practice variability. Issues lacking consensus include the optimal ages to begin and end routine screening; optimal screening intervals; defining and balancing the benefits of screening with potential harms; appropriate use of various imaging modalities including supplemental technologies; values and preferences of women regarding screening; and how all of these considerations vary depending on a woman's risk for breast cancer.

Despite variation in clinical practices and guidelines, rates of screening mammography in the United States are generally high and have remained relatively stable for the past decade.41,42 Data from the HEDIS® Health Plan measure set indicate that mammography screening between 2009 and 2011 was performed by 71 percent of eligible women covered by commercial plans, 69 percent for Medicare plans, and 51 percent for Medicaid plans.43 The Patient Protection and Affordable Care Act mandates insurance coverage for annual screening mammography beginning at age 40 years with no co-pay or deductible charges. However, this coverage applies to only the annual screening mammogram, and subsequent related services are not similarly covered.

Breast cancer screening for women without risk factors indicating high risk is conducted using periodic mammography (Figure 1). Digital mammography has generally replaced film in the United States, and newer technologies, such as digital tomosynthesis, are rapidly disseminating. Imaging modalities are further described in Table 3. In general, approximately 90 percent of women in a screening round have normal mammography results and are advised to return in 1 or 2 years, while 10 percent are recalled for additional imaging to visualize areas of concern identified on the screening mammogram.44 Additional imaging may involve special mammographic views, ultrasound, MRI, or tomosynthesis. Approximately 10 percent of women having additional imaging are identified with suspicious breast lesions requiring biopsies.44

Figure 1 Breast Cancer Screening Clinical Pathway

Abbreviation: MRI=magnetic resonance imaging.

Figure 1 is a clinical pathway describing the process for breast cancer screening. The figure shows the process leading from routine screening with digital mammography and/or tomosynthesis to the outcomes of either biopsy of suspicious lesions or routine screening. One possible pathway is to have normal results leading to continued routine screening. A second pathway shows supplemental imaging via ultrasound, tomosynthesis, MRI, or other methods after normal results due to breast density, this can either lead to no biopsy and a return to normal screening, or a biopsy of any suspicious lesions. A third pathway shows results requiring additional imaging after the first screening round leading to additional diagnostic imaging using special views, tomosynthesis, MRI, ultrasound, or other imaging techniques. As a result of the diagnostic imaging patients may undergo biopsy of suspicious lesions or be returned to routine screening, potentially with the addition of shorter-interval screening in some patients. Additional information about typical screening pathways is described in the text of the report on page 5.

Table 3 Imaging Modalities for Breast Cancer Screening of Average-Risk Women^*^

Imaging modality^†^ | Description; indication for use; average radiation dose (MQSA)237 | Limitations | Summary of performance^‡^
Mammography | - A screening mammogram is performed in a woman with no clinical symptoms or complaints to detect early stage or clinically occult breast cancer.; - Two views (craniocaudal and mediolateral oblique) of each breast are obtained for routine evaluation. | Limitations vary by type of mammography | Variable performance by type of mammography
Film mammography | - Uses x-rays transmitted through the breast tissue to create an image that is processed and displayed as a grayscale image directly on a film.; - Adequate breast compression is required.; - Women with larger breasts may require more than two views of each breast to ensure imaging of all breast tissues.; - Average radiation dose is 4.7 mGy. | - Limited sensitivity in women with radiographically dense breasts.; - Subject to artifacts from processing and storage.; - Inability to manipulate the image following exposure. | All women:; - Sensitivity 0.41 ±0.03; - Specificity 0.98 ±0.001; - PPV 0.13 ±0.01; Women <50:; - Sensitivity 0.35 ±0.06; - Specificity 0.98 ±0.001; - PPV 0.07 ±0.01
Digital mammography (DM) | - Digital detectors convert the x-ray photons to an electronic signal that is changed to a digital image and is processed and displayed as a gray scale image to be stored or sent electronically. Software can be used to help interpret digital images.; - Available in >90% of imaging centers in the United States as of 2013.^238^; - May be more effective than film in women <50; woman with heterogeneously or extremely dense breast tissue; or pre- or perimenopausal women.; - Average radiation dose is 3.7 mGy. | - Less spatial resolution compared with film.; - More expensive (1.5 to 4 times cost of film).239 | All women:; - Sensitivity 0.41 ±0.03; - Specificity 0.98 ±0.001; - PPV 0.12 ±0.01; Women <50:; - Sensitivity 0.49 ±0.06; - Specificity 0.97 ±0.001; - PPV 0.08 ±0.01
Tomosynthesis | - A modification of DM that acquires images of a stationary, compressed breast at multiple angles during a short scan.; - Individual images are reconstructed to generate a series of thin sections of images that can be displayed individually or in a loop.; - Used in combination with standard DM for screening. Average radiation dose 1 to 2 times DM. | When performed in the screening setting, the patient is exposed to approximately twice the usual radiation dose, which can be even greater if the patient has dense or thick breasts. | Compared to digital mammography: PPV for recall 6.4% (±2.1%; 95% CI,1.7% to 2.5%, p<0.001)212
Ultrasound | - Sound waves used to create images of the breast using a non-invasive, hand held device. Images obtained by radiologist or technologist and are operator dependent. Whole breast ultrasound recently approved by the FDA for screening of patients with dense breasts.; - Not currently indicated for routine screening.; - There are no RCTs showing survival benefit of screening women with dense breasts with supplemental whole breast ultrasound screening (whole breast ultrasound) in addition to mammography.; - Several states have now implemented standard reporting on breast density, which includes the recommendation for ultrasound for dense breasts.; - No radiation. | - Not an appropriate initial screening modality for breast cancer, but has been approved as an adjunct to mammography for screening in women with increased breast density.240; - Ultrasound alone is not a good breast cancer screening tool and has many false-positive and false-negative results.; - No uniform standards for performance.; - Variable image quality depending on the skill and experience of the examiner.; - Highly operator dependent and there can be significant intra- and inter-observer variability.; - Limited ability to detect DCIS. | No data for average risk women; available performance measures are based on studies of women with increased risk and dense breasts.46
MRI with and without contrast | - Magnetic fields are used to create an image of the breast. Intravenous contrast agent given for the procedure.; - Not indicated for screening in average-risk populations; diagnostic modality in specific subpopulations.; - No radiation. | Not an appropriate initial screening modality for breast cancer, but has been promoted as a screening test among women at elevated risk, including BRCA1/2 mutation carrier, strong family history of breast cancer, or several genetic syndromes. | No data for average risk women; available performance measures are based on studies of high-risk women. 46

Adapted from 2013 ACR BIRADS Atlas 5th Edition.29

* Average-risk women: women with <15% lifetime risk of breast cancer. Performance measures may vary based on risk, including breast density.

† Does not include other technologies not approved for screening: Positron emission mammography (PEM) and breast specific gamma imaging (BSGI).

‡ Performance based on DMIST: Pisano ED. Diagnostic performance of digital versus film mammography for breast-cancer screening. N Engl J Med. 2005;353(17):1773-83. [pmid: 16169887]. .

Abbreviations: BRCA=breast cancer susceptibility gene; CI=confidence interval; DCIS=ductal carcinoma in situ; DM=digital mammography; FDA=U.S. Food and Drug Administration; mGy=milligray; MQSA=Mammography Quality Standards Act; MRI=magnetic resonance imaging; PPV=positive predictive value; RCT=randomized controlled trial.

Additional imaging after screening mammography has traditionally been reserved to further visualize incompletely evaluated breast lesions. However, in response to public concerns about breast density, 21 states have passed breast density notification legislation requiring that reports of patients' breast density be provided to them with their mammography results.45 Most laws encourage patients to have a discussion of additional screening options with their primary physicians and some mandate insurance coverage for supplemental imaging, including screening MRI, ultrasound, and tomosynthesis. Descriptive studies of supplemental imaging for patients with dense breasts, in addition to other risk factors in some studies, suggest increased rates of cancer detection, but also increased false-positive results with MRI and ultrasound.46-50 Randomized trials of the effectiveness of supplemental imaging have not been reported.51

Screening MRI is recommended for certain high-risk groups, including women with BRCA1 or BRCA2 mutations and their untested first-degree relatives, women with greater than 20 percent lifetime risk of developing breast cancer as defined by risk prediction models, and women who have received high-dose radiation therapy to the chest between the ages of 10 and 30 years.52 Use of MRI for screening women who are not at high risk for breast cancer is not recommended,52 and experts suggest that MRI should not be performed in settings where the capacity for MR-guided biopsy does not exist. Currently, there are no studies investigating MRI use in women who are not at high risk, and none showing decreased mortality with MRI screening for women at any risk level.

If tissue sampling is recommended, a biopsy is performed (Figure 2). The type of biopsy is based on the characteristics of the lesion as well as patient and physician preferences. Current biopsy techniques include fine-needle aspiration (FNA), stereotactic core biopsy (for nonpalpable, mammographic lesions), ultrasound-guided or MRI-guided core biopsy, non-image-guided core biopsy (for palpable lesions), incisional biopsy, or excisional biopsy. These techniques vary in the level of invasiveness and amount of tissue acquired, impacting their yield and patient experience. Although more invasive than FNA, core biopsies, as well as incisional and excisional biopsies, offer the pathologist a sample with intact cellular architecture, and thereby allow additional pathologic examination of the breast tissue. Testing includes examination of cellular receptors (e.g., ER/PR, HER2/neu receptor), as well as identification of tumor type and grade.53,54 Ultrasound of the ipsilateral axilla has become a common practice when malignancy is suspected on imaging, and can help guide FNA or core biopsy of abnormal axillary lymph nodes. This additional information contributes to appropriate treatment planning for a patient who is newly diagnosed with breast cancer, and often allows for definitive surgery to be completed with a single-stage procedure.55

Figure 2 Clinical Pathway After Biopsy

Abbreviation: MRI=magnetic resonance imaging.

Figure 2 describes the potential clinical pathways after biopsy results have been obtained. If biopsy shows invasive cancer, the stage grade and receptor status are determined before treatment. If the biopsy shows ductal carcinoma in situ, the grade and receptor status are determined before treatment. If biopsy shows lobular intraepithelial neoplasia patients will receive excisional biopsy, annual mammography, and may be considered for hormonal therapy. If biopsy shows atypical ductal hyperplasia or other atypical types the next steps would be excisional biopsy, annual mammography, consideration of annual breast MRI, and consideration of hormonal therapy. If the biopsy shows fibroadenoma some women may need repeat ultrasound in 6 and 12 months followed by routine mammography, others will progress straight to routine mammography. If the biopsy shows that the lesion is benign and nonproliferative it would be followed up in 6 to 12 months and then patients would return to routine mammography. Additional information about biopsy if tissue sampling is recommended can be found on page 5 of the report.

## Recommendations of Other Groups

The American Cancer Society recommends yearly mammograms starting at age 40 and continuing for as long as the woman is in good health. BSEs are optional for women beginning in their 20s, while CBEs are recommended about every 3 years for women in their 20s and 30s.56

The American Academy of Family Physicians (AAFP) recommends the decision to conduct screening mammography prior to age 50 should be individualized and take into consideration the patient's context and risk factors. For women between ages 50 and 74, the AAFP recommends biennial screening in addition to recommending against clinicians teaching women BSE.57

The American Congress of Obstetrics and Gynecologists (ACOG) recommends that mammography screening be offered annually to women beginning at age 40. ACOG recommends annual CBE for women ages 40 and older, and every 1 to 3 years for women ages 20 to 39. ACOG also endorses educating women ages 20 and older regarding breast self-awareness.58

The American College of Radiology (ACR) recommends annual screening mammography for asymptomatic women 40 years of age and older.59 The decision as to when to stop routine mammography screening should be made on an individual basis by each woman and her physician based on a woman's overall health.

The National Comprehensive Cancer Network (NCCN) recommends annual screening mammography, clinical breast exam, and breast awareness for asymptomatic, average risk women age 40 years and older.60