# Evidence and Quality Tables

Appendix B1 Quality Ratings of Systematic Reviews

Appendix B2 Evidence Table of Results of New Studies of Psychological Harms

Appendix B3 Quality Ratings of Cohort Studies

Appendix B4 Quality Ratings for Case-Control Studies