# Detailed Methods

## Appendix A1 Search Strategies

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

-------------------------------------------------------------------------------

1. exp mammography/
2. exp physical examination/
3. exp magnetic resonance imaging/
4. exp ultrasonography/
5. exp mass screening/
6. ((clinical or physical$ or manual$ or routin$ or (regular$ adj2 schedul$)) adj5 (breast$ adj2 exam$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
7. 2 or 3 or 4 or 5 or 6
8. exp breast/
9. exp breast diseases/di, ra, us, pa, ep, mo
10. 8 or 9
11. 7 and 10
12. 1 or 11
13. exp Mortality/
14. exp death/
15. exp survival analysis/
16. exp survivors/
17. mo.fs.
18. exp life tables/
19. exp life expectancy/
20. 13 or 14 or 15 or 16 or 17 or 18 or 19
21. 12 and 20
22. ((III$ or IV$ or advanc$ or late) adj5 stag$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
23. (tnm adj7 (t3 or t4 or n1 or n2 or n3 or n4 or n5 or n6 or m1)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
24. ((cancer$ or tumor$ or tumour$ or malig$ or adenocarcin$ or nepolas$) adj5 (advanc$ or spread$ or infiltrat$ or metasta$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
25. 22 or 23 or 24
26. 12 and 25
27. exp “Outcome Assessment (Health Care)”/
28. 12 and 27
29. exp incidence/
30. 12 and 29
31. exp Neoplasm Metastasis/
32. exp neoplasm staging/
33. exp neoplasm grading/
34. 31 or 32 or 33
35. 12 and 34
36. 26 or 28 or 30 or 35
37. exp Breast Neoplasms/
38. 36 and 37
39. exp Mammography/ae, ct [Adverse Effects, Contraindications]
40. exp Physical Examination/ae, ct
41. exp Mass Screening/ae, ct [Adverse Effects, Contraindications]
42. 40 or 41
43. 10 and 42
44. 13 or 43
45. exp Diagnostic Errors/
46. (overtest$ or overdiagnos$ or over-test$ or over-diagnos$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
47. misdiagnos$.mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
48. (false$ adj (positiv$ or negativ$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
49. ((incorrect$ or false$ or wrong$ or bias$ or mistake$ or error$ or erroneous$) adj3 (result$ or finding$ or outcome$ or test$ or diagnos$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
50. ((inappropriat$ or unnecess$ or unneed$) adj3 (treat$ or surg$ or therap$ or procedur$ or biops$ or interven$ or regimen$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
51. (observ$ adj3 bias$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
52. iatrogen$.mp.
53. 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52
54. 12 and 53
55. exp “Wounds and Injuries”/ci, et [Chemically Induced, Etiology]
56. exp Stress, Psychological/
57. exp Prejudice/
58. exp Stereotyping/
59. 55 or 56 or 57 or 58
60. 12 and 59
61. 44 or 54 or 60
62. exp “sensitivity and specificity”/
63. 12 and 62
64. exp *Breast Neoplasms/di, pa, ra, us
65. 63and 64

Databases: EBM Reviews - Cochrane Central Register of Controlled Trials, Database of Abstracts Reviews of Effects, Health Technology Assessment, and NHS Economic Evaluation Database

Search Strategy:

-------------------------------------------------------------------------------

1. (mammogra$ or magnetic resonance imag$ or mri or ultrasound$ or ultrasonog$ or screen$ or ((clinical or physical$ or manual$ or routin$ or (regular$ adj2 schedul$)) adj5 exam$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. (Mortal$ or death$ or dead or dying or die or dies or died or surviv$ or life table$ or life expectanc$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. 1 and 2 and 3
5. ((III$ or IV$ or advanc$ or late) adj5 stag$).mp.
6. (tnm adj7 (t3 or t4 or n1 or n2 or n3 or n4 or n5 or n6 or m1)).mp.
7. ((cancer$ or tumor$ or tumour$ or malig$ or adenocarcin$ or nepolas$) adj5 (advanc$ or spread$ or infiltrat$ or metasta$)).mp.
8. ((cancer$ or Neoplas$ or tumor$ or tumour$ or malig$ or carcino$) adj5 (Metasta or staging$ or stage or stages or grading or grades or graded or grade)).mp.
9. ((outcome$ or ((treat$ or therap$) adj3 result$)) adj5 (evaluat$ or compar$ or assess$)).mp.
10. 5 or 6 or 7 or 8
11. 1 and 2 and 10
12. 1 and 2 and 9
13. (overtest$ or overdiagnos$ or over-test$ or over-diagnos$ or overtreat$ or over-treat$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14. misdiagnos$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15. (false$ adj (positiv$ or negativ$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
16. ((incorrect$ or false$ or wrong$ or bias$ or mistake$ or error$ or erroneous$) adj3 (result$ or finding$ or outcome$ or test$ or diagnos$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
17. ((inappropriat$ or unnecess$ or unneed$) adj3 (treat$ or surg$ or therap$ or procedur$ or biops$ or interven$ or regimen$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
18. (observ$ adj3 bias$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19. iatrogen$.mp.
20. (diagnos$ adj5 (erroneous$ or error$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
21. ((anguish$ or (emotion$ or psych$ or mental$ or physical$ or social$ or socio$)) adj5 (stress$ or tension$ or pain$ or fear$ or undesir$ or unwant$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
22. (harm$ or advers$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
23. (prejudic$ or stereotyp$ or stigma$ or unfair$).mp.
24. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23
25. 1 and 2 and 24
26. (((((test$ or diagnos$ or screen$) adj3 (sensitiv$ and Specific)) or (fals$ adj3 (positiv$ or negativ$)) or ((type I or type II) adj5 error$) or (Predict$ or prognos$)) adj5 (Value$ or valid$ or accura$ or correct$)) or (ROC adj2 Curv$) or (Signal adj Noise adj3 Ratio$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27. 1 and 2 and 26

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

-------------------------------------------------------------------------------

1. (mammogra$ or magnetic resonance imag$ or mri or ultrasound$ or ultrasonog$ or screen$ or ((clinical or physical$ or manual$ or routin$ or (regular$ adj2 schedul$)) adj5 exam$)).mp. [mp=title, abstract, full text, keywords, caption text]
2. ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$)).mp. [mp=title, abstract, full text, keywords, caption text]
3. (Mortal$ or death$ or dead or dying or die or dies or died or surviv$ or life table$ or life expectanc$).mp. [mp=title, abstract, full text, keywords, caption text]
4. 1 and 2 and 3
5. ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (Mortal$ or death$ or dead or dying or die or dies or died or surviv$ or life table$ or life expectanc$)).mp. [mp=title, short title, abstract, full text, keywords, caption text]
6. 1 and 5
7. ((mammogra$ or magnetic resonance imag$ or mri or ultrasound$ or ultrasonog$ or screen$ or ((clinical or physical$ or manual$ or routin$ or (regular$ adj2 schedul$)) adj5 exam$)) adj15 (Mortal$ or death$ or dead or dying or die or dies or died or surviv$ or life table$ or life expectanc$)).mp. [mp=title, short title, abstract, full text, keywords, caption text] (387)
8. 2 and 7
9. 6 or 8
10. ((mammogra$ or magnetic resonance imag$ or mri or ultrasound$ or ultrasonog$ or screen$ or ((clinical or physical$ or manual$ or routin$ or (regular$ adj2 schedul$)) adj5 exam$)) adj10 ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$))).mp. [mp=title, short title, abstract, full text, keywords, caption text]
11. 3 and 10
12. 6 or 9 or 11
13. ((III$ or IV$ or advanc$ or late) adj5 stag$).mp.
14. (tnm adj7 (t3 or t4 or n1 or n2 or n3 or n4 or n5 or n6 or m1)).mp.
15. ((cancer$ or tumor$ or tumour$ or malig$ or adenocarcin$ or nepolas$) adj5 (advanc$ or spread$ or infiltrat$ or metasta$)).mp.
16. ((cancer$ or Neoplas$ or tumor$ or tumour$ or malig$ or carcino$) adj5 (Metasta or staging$ or stage or stages or grading or grades or graded or grade)).mp. (502)
17. ((outcome$ or ((treat$ or therap$) adj3 result$)) adj5 (evaluat$ or compar$ or assess$)).mp.
18. 13 or 14 or 15 or 16
19. 1 and 2 and 18
20. 1 and 2 and 17
21. (overtest$ or overdiagnos$ or over-test$ or over-diagnos$ or overtreat$ or over-treat$).mp. [mp=title, abstract, full text, keywords, caption text]
22. misdiagnos$.mp. [mp=title, abstract, full text, keywords, caption text]
23. (false$ adj (positiv$ or negativ$)).mp. [mp=title, abstract, full text, keywords, caption text]
24. ((incorrect$ or false$ or wrong$ or bias$ or mistake$ or error$ or erroneous$) adj3 (result$ or finding$ or outcome$ or test$ or diagnos$)).mp. [mp=title, abstract, full text, keywords, caption text]
25. ((inappropriat$ or unnecess$ or unneed$) adj3 (treat$ or surg$ or therap$ or procedur$ or biops$ or interven$ or regimen$)).mp. [mp=title, abstract, full text, keywords, caption text]
26. (observ$ adj3 bias$).mp. [mp=title, abstract, full text, keywords, caption text]
27. iatrogen$.mp.
28. (diagnos$ adj5 (erroneous$ or error$)).mp. [mp=title, abstract, full text, keywords, caption text]
29. ((anguish$ or (emotion$ or psych$ or mental$ or physical$ or social$ or socio$)) adj5 (stress$ or tension$ or pain$ or fear$ or undesir$ or unwant$)).mp. [mp=title, abstract, full text, keywords, caption text]
30. (harm$ or advers$).mp. [mp=title, abstract, full text, keywords, caption text]
31. (prejudic$ or stereotyp$ or stigma$ or unfair$).mp.
32. 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31
33. 1 and 2 and 32
34. (((((test$ or diagnos$ or screen$) adj3 (sensitiv$ and Specific)) or (fals$ adj3 (positiv$ or negativ$)) or ((type I or type II) adj5 error$) or (Predict$ or prognos$)) adj5 (Value$ or valid$ or accura$ or correct$)) or (ROC adj2 Curv$) or (Signal adj Noise adj3 Ratio$)).mp. [mp=title, abstract, full text, keywords, caption text]
35. 1 and 2 and 34

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | KQs 1–6: Women age ≥40 years. | Men, women age <40 years, women with pre-existing breast cancer; clinically significant BRCA mutations, Li-Fraumeni syndrome, Cowden syndrome, hereditary diffuse gastric cancer, or other familial breast cancer syndromes; high-risk breast lesions (DCIS, LCIS, ADH, ALH); or previous large doses of chest radiation (≥20 Gy) before age 30.
Intervention | KQs 1, 2, 5: Screening mammography (all methods, i.e., film, digital, tomosynthesis). KQs 3, 4, 6: Screening mammography (all methods) combined with other modality; other screening modality (i.e., MRI, ultrasound). | KQs 1, 2, 5: Mammography for diagnosis or surveillance KQs 3, 4, 6: Breast imaging or examinations for diagnosis or surveillance
Comparisons | KQs 1, 2, 5: Mammography in women ages 40–49 vs. 50–59 vs. 60–69 vs. 70–79 years (or other age comparisons); annual mammography vs. biennial vs. triennial vs. alternate intervals vs. none; presence of risk factor vs. none (e.g., family history, extremely dense breast tissue). KQs 3, 4, 6: Mammography (all types, i.e., film, digital, tomosynthesis) vs. other modality vs. mammography (all types) combined with other modality, including MRI and ultrasound; interval and age differences by modality. | KQs 1, 2, 5: Data not provided by age, interval, or risk factor KQs 3, 4, 6: Data not provided by modality, age, or interval
Outcomes: Benefits | Final health outcomes: Reduced breast cancer mortality and all-cause mortality. Intermediate outcomes: Reduced incidence of advanced breast cancer and treatment-related morbidity (i.e., physical adverse effects of treatment, quality of life measures, and other measures of impairment). | Outcomes not listed as included
Outcomes: Harms | False-positive findings; anxiety; adverse impact on quality of life; false-positive biopsy; false-negative findings; false reassurance; overdiagnosis; overtreatment; radiation exposure. | Outcomes not listed as included
Timing | Immediate, short-term, and long-term outcomes; duration of followup. | No followup
Setting | Settings and populations of women applicable to U.S. primary care practice. | Settings not applicable to U.S. primary care practice
Study Design | Effectiveness: RCTs; prospective and retrospective cohort studies. Harms: RCTs, prospective and retrospective cohort studies, case-control studies, cross-sectional studies, systematic reviews, meta-analyses, and modeling studies; others considered. | Case reports, case series; studies outside of search dates unless updates of previous trials
Language | English-language abstracts (includes English-language abstracts of non English-language papers) and papers. | Non English-language papers
Contextual Question 1 | U.S. rates of specific adverse effects of current treatment regimens for invasive breast cancer and DCIS from published sources and databases, obtained using a best evidence approach. | Non U.S. rates, older regimens (see search dates)
Contextual Question 2 | Absolute incidence rates of DCIS and localized and advanced invasive breast cancer in screened and nonscreened populations in the United States from published sources and databases, obtained using a best evidence approach. | Non U.S. rates, older estimates (see search dates)
Contextual Question 3 | Descriptive papers of how women's perceptions of the benefits and harms of breast cancer screening affect their clinical decision-making regarding breast cancer screening in the United States. | Studies of women in other countries; older studies (see search dates)
Data Sources | Ovid MEDLINE, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Breast Cancer Surveillance Consortium database. | Sources not listed as included
Search Dates^*^ | Effectiveness key questions included in the previous report (KQs 1 & 3): RCTs published between 2008 and February 2014 and updates of earlier trials. Cohort studies published between 1996 and February 2014. Effectiveness Key Questions not included in the previous report (KQ 2 & 4): RCTs and cohort studies published between 1996 and February 2014. Harms (KQs 5, 6): Studies published between 2008 and February 2014 and updates of earlier studies. Contextual questions (1–3): Studies published between 2010 and February 2014. | Studies published outside of the specified search dates that were not included in previous USPSTF systematic reviews.

* Search dates vary because some key questions (KQs 1, 3, 5, 6) were included in the previous systematic review and require only an update of studies published since the previous search in 2008. Other key questions were not addressed by the previous review and require a search that covers a longer time period (KQ 2 & 4, and cohort studies for KQ 1 & 3). These searches extend to 1996 because this corresponds to the last time the USPSTF evaluated similar data and represents a period when practice was shifting to digital mammography in the United States. The contextual questions have a shorter time period for searches because they require current data.

Abbreviations: ADH=atypical ductal hyperplasia; ALH=atypical lobular hyperplasia; BRCA=breast cancer susceptibility gene; DCIS=ductal carcinoma in situ; Gy=gray (unit of absorbed radiation dose [1 Gy=100 rads]); KQ=key question; LCIS=lobular carcinoma in situ; MRI=magnetic resonance imaging; RCT=randomized, controlled trial; U.S.=United States; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

## Appendix A3 Literature Flow by Key Question

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Publications were used for multiple key questions; trials reported data in multiple publications; 84 publications were included.

Abbreviations: BCSC=Breast Cancer Surveillance Consortium; n=sample size; RCT=randomized controlled trial.

Appendix A3 is a flow diagram that summarizes the search and selection of articles. There were 12,004 citations identified by searching MEDLINE, the Cochrane databases, and other sources including reference lists, hand searching, and suggestions by experts. Of these 9,970 were excluded at the abstract level because they did not address a key question or only addressed background information. The remaining 2,034 articles were pulled and reviewed for relevance to the key questions. There were 1,950 full-text articles excluded for the following reasons: wrong population, wrong intervention, wrong outcomes, wrong study design for the key question, wrong publication type, a study included in an included systematic review, a review not meeting inclusion criteria, wrong comparison, study outside our search dates, and no original data to include; publication or dataset with longer followup, more complete data or same data already included in review. Some studies may have addressed more than one key question, and the trials may have reported data in multiple publications. A total of 84 publications in 75 studies were included. For key question 1, 3 updated RCTs, 5 old RCTs with no updates, 4 reviews covering 57 studies, and 8 observational studies were included. For key question 2, 4 RCTs, 1 review covering 5 RCTs, 12 observational studies, and analyses of BCSC data were included. For key question 3 no studies were found. For key question 4, 2 observational studies were included. For key question 5, 10 reviews covering 134 studies, 1 meta-analysis of 3 RCTs, 40 observational studies, 2 modeling studies, and BCSC analyses were included. For key question 6, 6 observational studies were included.

## Appendix A4 List of Excluded Studies

3D mammography shows promise as next breast screening technique. Oncology. 2003;17(6):814. 900. Exclusion: wrong publication type. [pmid: 12846125].
16-year mortality from breast cancer in the UK Trial of Early Detection of Breast Cancer. Lancet. 1999;353(9168):1909-14. Exclusion: studies outside of search dates. [pmid: 10371568].
Advances in breast imaging. Although mammography remains standard for breast cancer screening, several newer technologies are helping to fine-tune diagnosis. Harv Womens Health Watch. 2010;17(9):1-3. Exclusion: wrong publication type.
Breast carcinoma stage in relation to time interval since last mammography: a registry-based study. The Romagna Cancer Registry and Collaborators. Cancer. 1997;80(8):1432-7. Exclusion: wrong intervention. [pmid: 9338467].
Breast MRI for detection or diagnosis of primary or recurrent breast cancer. Technol Eval Cent Asses Program Exec Summ. Executive Summary. 2004;19(1):1-9. Exclusion: review not meeting inclusion criteria.
Breast-cancer screening with mammography in women aged 40-49 years. Swedish Cancer Society and the Swedish National Board of Health and Welfare. Int J Cancer. 1996;68(6):693-9. Exclusion: wrong publication type. [pmid: 8980168].
Computer-aided detection of malignancy with magnetic resonance imaging of the breast. Technol Eval Cent Asses Program Exec Summ. Executive Summary. 2006;21(4):1-3. Exclusion: wrong study design for key question.
Computer-aided detection with full-field digital mammography. Technol Eval Cent Asses Program Exec Summ. Executive Summary. 2006;21(3):1-3. Exclusion: review not meeting inclusion criteria.
Full-field digital mammography. Technol Eval Cent Asses Program Exec Summ. Executive Summary. 2006;20(16):1-3. Exclusion: wrong comparison.
Magnetic resonance imaging of the breast: differential diagnosis of a breast lesion to avoid biopsy. Tecnologica MAP Suppl. 2001:30-2. Exclusion: wrong outcomes. [pmid: 11933939].
Mammograms for older women. Health News. 2000;6(12):7. Exclusion: wrong publication type.
Mammographic screening for breast cancer: few new data. Prescrire Int. 2008;17(93):24-7. Exclusion: wrong publication type. [pmid: 18383654].
Mammography benefits appear to have no age limit. Mayo Clin Womens Healthsource. 2008;12(11):3. Exclusion: wrong publication type.
The Million Women Study: design and characteristics of the study population. The Million Women Study Collaborative Group. Breast Cancer Res. 1999;1(1):73-80. Exclusion: wrong publication type. [pmid: 11056681].
Obesity increases risk of death from breast cancer. Clin J Oncol Nurs. 2002;6(3):125. Exclusion: wrong publication type.
Screening mammography. Prescrire Int. 2006;15(85):192-3. Exclusion: wrong publication type. [pmid: 17128530].
Summaries for patients. Does use of screening mammography explain racial and ethnic differences in death from breast cancer?. [Original report in Ann Intern Med. 2006 Apr 18;144(8):541-53; PMID: 16618951]. Ann Intern Med. 2006;144(8):I18. Exclusion: wrong publication type.
Summaries for patients. Mammograms in women age 40 to 49: results of the Canadian Breast Cancer Screening study. [Original report in Ann Intern Med. 2002 Sep 3;137(5 Part 1):305-12; PMID: 12204013]. Ann Intern Med. 2002;137(5 Part 1):I28. Exclusion: wrong publication type. [pmid: 12204045].
Summaries for patients. Screening for breast cancer: recommendations from the U.S. Preventive Services Task Force. [Original report in Ann Intern Med. 2002 Sep 3;137(5 Part 1):347-60; PMID: 12204020]. Ann Intern Med. 2002;137(5 Part 1):I47. Exclusion: wrong publication type. [pmid: 12204048].
Summaries for patients. Screening for breast cancer: U.S. Preventive Services Task Force recommendations. [Original report in Ann Intern Med. 2009 Nov 17;151(10):716-26, W-236; PMID: 19920272]. Ann Intern Med. 2009;151(10):I44. Exclusion: wrong publication type. [pmid: 19920254].
Summaries for patients: the accuracy of film versus digital screening mammography. [Original report in Ann Intern Med. 2011 Oct 18;155(8):493-502; PMID: 22007043]. Ann Intern Med. 2011;155(8):I30. Exclusion: wrong publication type.
Summaries for patients: the benefits and harms of more and less frequent screening mammography. [Original report in Ann Intern Med. 2011 Oct 18;155(8):481-92; PMID: 22007042]. Ann Intern Med. 2011;155(8):I14. Exclusion: wrong publication type. [pmid: 22007059].
Abbey CK, Eckstein MP, Boone JM. An equivalent relative utility metric for evaluating screening mammography. Med Decis Making. 2010;30(1):113-22. Exclusion: wrong outcomes. [pmid: 19706880].
Abdolell M, Tsuruda K, Schaller G, et al. Statistical evaluation of a fully automated mammographic breast density algorithm. Comput Math Methods Med. 2013;2013:651091. Exclusion: wrong outcomes. [pmid: 23737861].
Abdullah N, Mesurolle B, El-Khoury M, et al. Breast imaging reporting and data system lexicon for US: interobserver agreement for assessment of breast masses. Radiology. 2009;252(3):665-72. Exclusion: wrong outcomes. [pmid: 19567644].
Abraham L, Geller BM, Yankaskas BC, et al. Accuracy of self-reported breast cancer among women undergoing mammography. Breast Cancer Res Treat. 2009;118(3):583-92. Exclusion: wrong outcomes. [pmid: 19301119].
Absetz P, Aro AR, Sutton SR. Experience with breast cancer, pre-screening perceived susceptibility and the psychological impact of screening. Psychooncology. 2003;12(4):305-18. Exclusion: included in an included systematic review, not directly used. [pmid: 12748969].
Achat H, Close G, Taylor R. Who has regular mammograms? Effects of knowledge, beliefs, socioeconomic status, and health-related factors. Prev Med. 2005;41(1):312-20. Exclusion: wrong outcomes. [pmid: 15917027].
Agliozzo S, De Luca M, Bracco C, et al. Computer-aided diagnosis for dynamic contrast-enhanced breast MRI of mass-like lesions using a multiparametric model combining a selection of morphological, kinetic, and spatiotemporal features. Med Phys. 2012;39(4):1704-15. Exclusion: wrong outcomes. [pmid: 22482596].
Agner SC, Soman S, Libfeld E, et al. Textural kinetics: a novel dynamic contrast-enhanced (DCE)-MRI feature for breast lesion classification. J Digit Imaging. 2011;24(3):446-63. Exclusion: wrong outcomes. [pmid: 20508965].
Aiken LS, Jackson KM. Mammography benefits for women under 50: a closer look at the controversy. Womens Health. 1996;2(4):235-42. discussion 61-6. Exclusion: wrong publication type. [pmid: 9421558].
Akcil M, Karaagaoglu E, Demirhan B. Diagnostic accuracy of fine-needle aspiration cytology of palpable breast masses: an SROC curve with fixed and random effects linear meta-regression models. Diagn Cytopathol. 2008;36(5):303-10. Exclusion: wrong outcomes. [pmid: 18418880].
Alcusky M, Philpotts L, Bonafede M, et al. The patient burden of screening mammography recall. J Womens Health (Larchmt). Suppl 1. 2014;23:S11-9. Exclusion: wrong outcomes. [pmid: 25247382].
Al-Damegh SA. Emerging issues in medical imaging. Indian J Med Ethics. 2005;2(4):123-5. Exclusion: wrong publication type. [pmid: 16619437].
Alexander FE. The Edinburgh Randomized Trial of Breast Cancer Screening. J Natl Cancer Inst. Monographs. 1997;(22):31-5. Exclusion: studies outside of search dates.
Alexander FE, Anderson TJ, Brown HK, et al. 14 years of follow-up from the Edinburgh randomised trial of breast-cancer screening. Lancet. 1999;353(9168):1903-8. Exclusion: studies outside of search dates. [pmid: 10371567].
Alexander FE, Anderson TJ, Hubbard AL. Screening status in relation to biological and chronological characteristics of breast cancers: a cross sectional survey. J Med Screen. 1997;4(3):152-7. Exclusion: wrong study design for key question. [pmid: 9368873].
Alexander FE, Brown HK, Prescott RJ. Improved classification of socio-economic status explains differences in all-cause mortality in a randomised trial of breast cancer screening. J Epidemiol Biostat. 1998;3(2):219-24. Exclusion: wrong outcomes.
Al-Foheidi M, Al-Mansour MM, Ibrahim EM. Breast cancer screening: review of benefits and harms, and recommendations for developing and low-income countries. Med Oncol. 2013;30(2):471. Exclusion: review not meeting inclusion criteria. [pmid: 23420062].
Alhabshi SMI, Rahmat K, Abdul Halim N, et al. Semi-quantitative and qualitative assessment of breast ultrasound elastography in differentiating between malignant and benign lesions. Ultrasound Med Biol. 2013;39(4):568-78. Exclusion: wrong intervention. [pmid: 23384468].
Alimoglu E, Alimoglu MK, Ceken K, et al. Bi-RADS category 3 nonpalpable breast masses on sonography: long-term results of a prospective cohort study. J Clin Ultrasound. 2012;40(3):125-34. Exclusion: wrong population. [pmid: 22362168].
Alimoglu E, Alimoglu MK, Kabaalioglu A, et al. Mammography-related pain and anxiety. Tani Girisim Radyol. 2004;10(3):213-7. Exclusion: included in an included systematic review, not directly used. [pmid: 15470624].
Alimoglu E, Bayraktar SD, Bozkurt S, et al. Follow-up versus tissue diagnosis in BI-RADS category 3 solid breast lesions at US: A cost-consequence analysis. Diagn Interv Radiol. 2012;18(1):3-10. Exclusion: wrong outcomes. [pmid: 21997885].
Allen MW, Hendi P, Schwimmer J, et al. Decision analysis for the cost effectiveness of sestamibi scintimammography in minimizing unnecessary biopsies. Q J Nucl Med. 2000;44(2):168-85. Exclusion: wrong study design for key question. [pmid: 10967626].
Allgood PC, Duffy SW, Warren R, et al. Audit of negative assessments in a breast-screening programme in women who later develop breast cancer-implications for survival. Breast. 2006;15(4):503-9. Exclusion: wrong outcomes. [pmid: 16290937].
Allgood PC, Warwick J, Warren RML, et al. A case-control study of the impact of the East Anglian breast screening programme on breast cancer mortality. Br J Cancer. 2008;98(1):206-9. Exclusion: included in an included systematic review, not directly used. [pmid: 18059396].
Alsaker MDK, Janszky I, Opdahl S, et al. Weight change in adulthood and risk of postmenopausal breast cancer: the HUNT study of Norway. Br J Cancer. 2013;109(5):1310-7. Exclusion: wrong outcomes. [pmid: 23880822].
Alto H. Geomatics for precise 3D breast imaging. Technol Cancer Res Treat. 2005;4(1):29-38. Exclusion: wrong intervention. [pmid: 15649085].
American Cancer Society. Cancer facts and figures. 2007. Available at:http://www.cancer.org/acs/groups/content/@nho/documents/document/caff2007pwsecuredpdf.pdf. September 19, 2014. Exclusion: wrong comparison.
Amirikia KC, Mills P, Bush J, et al. Higher population-based incidence rates of triple-negative breast cancer among young African-American women : Implications for breast cancer screening recommendations. Cancer. 2011;117(12):2747-53. Exclusion: wrong outcomes. [pmid: 21656753].
Andersen KG, G R, Kroman N, Flyger H, Kehlet H. Persistent pain after targeted intraoperative radiotherapy (TARGIT) or external breast radiotherapy for breast cancer: A randomized trial. Breast. 2012;21(1):46-9. Exclusion: wrong outcomes. [pmid: 21865044].
Andersen MR, Hager M, Su C, et al. Analysis of the cost-effectiveness of mammography promotion by volunteers in rural communities. Health Educ Behav. 2002;29(6):755-70. Exclusion: wrong outcomes. [pmid: 12456132].
Andersen SB, Vejborg I, von Euler-Chelpin M. Participation behaviour following a false positive test in the Copenhagen mammography screening programme. Acta Oncol. 2008;47(4):550-5. Exclusion: wrong outcomes. [pmid: 18465321].
Anderson E, Berg J, Black R, et al. Prospective surveillance of women with a family history of breast cancer: auditing the risk threshold. Br J Cancer. 2008;98(4):840-4. Exclusion: wrong comparison. [pmid: 18283300].
Anderson WF, Jatoi I, Devesa SS. Assessing the impact of screening mammography: Breast cancer incidence and mortality rates in Connecticut (1943-2002). Breast Cancer Res Treat. 2006;99(3):333-40. Exclusion: wrong comparison. [pmid: 16703451].
Anderson WF, Matsuno RK, Sherman ME, et al. Estimating age-specific breast cancer risks: a descriptive tool to identify age interactions. Cancer Causes Control. 2007;18(4):439-47. Exclusion: wrong study design for key question. [pmid: 17216325].
Anonymous. Digital mammography more sensitive for younger women. J Natl Med Assoc. 2006;98(1):101. Exclusion: wrong outcomes.
Antonio ALM, Crespi CM. Predictors of interobserver agreement in breast imaging using the Breast Imaging Reporting and Data System. Breast Cancer Res Treat. 2010;120(3):539-46. Exclusion: review not meeting inclusion criteria. [pmid: 20300960].
Anttila A, Koskela J, Hakama M. Programme sensitivity and effectiveness of mammography service screening in Helsinki, Finland. J Med Screen. 2002;9(4):153-8. Exclusion: included in an included systematic review, not directly used. [pmid: 12518004].
Anttila A, Sarkeala T, Hakulinen T, et al. Impacts of the Finnish service screening programme on breast cancer rates. BMC Public Health. 2008;8:38. Exclusion: wrong comparison. [pmid: 18226204].
Anttinen J, Kautiainen H, Kuopio T. Role of mammography screening as a predictor of survival in postmenopausal breast cancer patients. Br J Cancer. 2006;94(1):147-51. Exclusion: wrong population. [pmid: 16333306].
Aro AR, Absetz-Ylöstalo P, Eerola T, et al. Pain and discomfort during mammography. European Journal of Cancer Part A. 1996;32(10):1674-9. Exclusion: included in an included systematic review, not directly used. [pmid: 8983273].
Aro AR, Pilvikki Absetz S, van Elderen TM, et al. False-positive findings in mammography screening induces short-term distress - breast cancer-specific concern prevails longer. Eur J Cancer. 2000;36(9):1089-97. Exclusion: studies outside of search dates. [pmid: 10854941].
Aro AR, Pilvikki Absetz S, Van Elderen TM, et al. False-positive findings in mammography screening induces short-term distress - Breast cancer-specific concern prevails longer. Eur J Cancer. 2000;36(9):1089-97. Exclusion: included in an included systematic review, not directly used. [pmid: 10854941].
Arora N, Martins D, Ruggerio D, et al. Effectiveness of a noninvasive digital infrared thermal imaging system in the detection of breast cancer. Am J Surg. 2008;196(4):523-6. Exclusion: wrong intervention. [pmid: 18809055].
Ascunce EN, Moreno-Iribas C, Barcos Urtiaga A, et al. Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 2007;14(1):14-20. Exclusion: included in an included systematic review, not directly used. [pmid: 17362566].
Ascunce N, Ederra M, Delfrade J, et al. Impact of intermediate mammography assessment on the likelihood of false-positive results in breast cancer screening programmes. Eur Radiol. 2012;22(2):331-40. Exclusion: wrong comparison. [pmid: 21901564].
Atkins CD. Potential hazards of mammography. J Clin Oncol. 2007;25(5):604. author reply 5. Exclusion: wrong publication type. [pmid: 17290073].
Aubard Y, Genet D, Eyraud JL, et al. Impact of screening on breast cancer detection. Retrospective comparative study of two periods ten years apart. Eur J Gynaecol Oncol. 2002;23(1):37-41. Exclusion: wrong comparison. [pmid: 11876389].
Austoker J. Breast self examination. BMJ. 2003;326(7379):1-2. Exclusion: wrong intervention. [pmid: 12511431].
Autier P. Breast cancer screening. Eur J Cancer. Suppl 3. 2011;47:S133-46. Exclusion: review not meeting inclusion criteria. [pmid: 21943967].
Autier P, Boniol M. The incidence of advanced breast cancer in the West Midlands, United Kingdom. Eur J Cancer Prev. 2012;21(3):217-21. Exclusion: wrong study design for key question. [pmid: 22314850].
Autier P, Boniol M, Gavin A, et al. Breast cancer mortality in neighbouring European countries with different levels of screening but similar access to treatment: trend analysis of WHO mortality database. BMJ. 2011;343:d4411. Exclusion: included in an included systematic review, not directly used. [pmid: 21798968].
Autier P, Boniol M, Middleton R, et al. Advanced breast cancer incidence following population-based mammographic screening. Ann Oncol. 2011;22(8):1726-35. Exclusion: review not meeting inclusion criteria. [pmid: 21252058].
Autier P, Koechlin A, Smans M, et al. Mammography screening and breast cancer mortality in Sweden. J Natl Cancer Inst. 2012;104(14):1080-93. Exclusion: wrong study design for key question. [pmid: 22811439].
Autier P, Shannoun F, Scharpantgen A, et al. A breast cancer screening programme operating in a liberal health care system: the Luxembourg Mammography Programme, 1992-1997. Int J Cancer. 2002;97(6):828-32. Exclusion: wrong publication type. [pmid: 11857363].
Avis NE, Smith KW, Link CL, et al. Increasing mammography screening among women over age 50 with a videotape intervention. Prev Med. 2004;39(3):498-506. Exclusion: studies outside of search dates. [pmid: 15313089].
Ayer T, Chhatwal J, Alagoz O, et al. Informatics in radiology: comparison of logistic regression and artificial neural network models in breast cancer risk estimation. Radiographics. 2010;30(1):13-22. Exclusion: wrong outcomes. [pmid: 19901087].
Ayoola A, Alagarsamy S, Jaboin J, et al. Increase in mastectomies performed in patients in the community setting undergoing MRI. Breast J. 2011;17(3):256-9. Exclusion: wrong population. [pmid: 21410587].
Azavedo E, Zackrisson S, Mejare I, et al. Is single reading with computer-aided detection (CAD) as good as double reading in mammography screening? A systematic review. BMC Medical Imaging. 2012;12:22. Exclusion: wrong outcomes. [pmid: 22827803].
Bae MS, Moon WK, Chang JM, et al. Breast cancer detected with screening US: reasons for nondetection at mammography. Radiology. 2014;270(2):369-77. Exclusion: wrong outcomes. [pmid: 24471386].
Baeten SA, Baltussen RMPM, Uyl-de Groot CA, et al. Reducing disparities in breast cancer survival--the effect of large-scale screening of the uninsured. Breast J. 2011;17(5):548-9. Exclusion: wrong publication type. [pmid: 21790843].
Bailar JC 3rd, MacMahon B. Randomization in the Canadian National Breast Screening Study: a review for evidence of subversion. CMAJ. 1997;156(2):193-9. Exclusion: wrong publication type. [pmid: 9012720].
Bailey SL, Sigal BM, Plevritis SK. A simulation model investigating the impact of tumor volume doubling time and mammographic tumor detectability on screening outcomes in women aged 40-49 years. J Natl Cancer Inst. 2010;102(16):1263-71. Exclusion: wrong study design for key question. [pmid: 20664027].
Baines CJ. The mammography controversy: full steam ahead versus reasonable caution. AJR Am J Roentgenol. 2013;200(1):W96-7. Exclusion: wrong publication type. [pmid: 23255779].
Baines CJ. Mammography screening: are women really giving informed consent? (Countering the counterpoint). J Natl Cancer Inst. 2003;95(20):1512-3. Exclusion: wrong publication type. [pmid: 14559872].
Baines CJ. Mammography screening: are women really giving informed consent?. [Erratum appears in J Natl Cancer Inst. 2003 Nov 19;95(22):1728]. J Natl Cancer Inst. 2003;95(20):1508-11. Exclusion: wrong publication type. [pmid: 14559870].
Baines CJ, McFarlane DV, Miller AB. The role of the reference radiologist; estimates of inter-observer agreement and potential delay in cancer detection in the national breast screening study. Invest Radiol. 1990;25(9):971-6. Exclusion: wrong comparison. [pmid: 2211054].
Baines CJ, Miller AB. Mammography versus clinical examination of the breasts. J Natl Cancer Inst. Monographs. 1997;(22):125-9. Exclusion: review not meeting inclusion criteria.
Baines CJ, Miller AB, Kopans DB, et al. Canadian National Breast Screening Study: assessment of technical quality by external review. AJR Am J Roentgenol. 1990;155(4):743-7. discussion 8-9. Exclusion: wrong outcomes. [pmid: 2119103].
Baines CJ, Vidmar M, McKeown-Eyssen G, et al. Impact of menstrual phase on false-negative mammograms in the Canadian National Breast Screening Study. Cancer. 1997;80(4):720-4. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 9264355].
Baker DR. Magnetic resonance imaging of occult breast cancer. Clin Breast Cancer. 2000;1(1):66-7. Exclusion: wrong study design for key question. [pmid: 11899392].
Baker JA, Rosen EL, Crockett MM, et al. Accuracy of segmentation of a commercial computer-aided detection system for mammography. Radiology. 2005;235(2):385-90. Exclusion: wrong outcomes. [pmid: 15770043].
Baker S, Wall M, Bloomfield A. Breast cancer screening for women aged 40 to 49 years--what does the evidence mean for New Zealand?. N Z Med J. 2005;118(1221):U1628. Exclusion: review not meeting inclusion criteria. [pmid: 16138166].
Baker S, Wall M, Bloomfield A. What is the most appropriate breast-cancer screening interval for women aged 45 to 49 years in New Zealand?. N Z Med J. 2005;118(1221):U1636. Exclusion: review not meeting inclusion criteria. [pmid: 16138174].
Baker SG. Modelling the cumulative risk of a false-positive screening test. Stat Methods Med Res. 2011;20(3):291-3. author reply 3-4. Exclusion: wrong publication type. [pmid: 21609977].
Baker SG, Kramer BS, Prorok PC. Comparing breast cancer mortality rates before-and-after a change in availability of screening in different regions: extension of the paired availability design. BMC Med Res Methodol. 2004;4:12. Exclusion: wrong study design for key question. [pmid: 15149551].
Bakic PR, Carton A-K, Kontos D, et al. Breast percent density: estimation on digital mammograms and central tomosynthesis projections. Radiology. 2009;252(1):40-9. Exclusion: wrong outcomes. [pmid: 19420321].
Balducci L, Phillips DM. Breast cancer in older women. Am Fam Physician. 1998;58(5):1163-72. Exclusion: review not meeting inclusion criteria. [pmid: 9787281].
Ballard-Barbash R, Klabunde C, Paci E, et al. Breast cancer screening in 21 countries: delivery of services, notification of results and outcomes ascertainment. Eur J Cancer Prev. 1999;8(5):417-26. Exclusion: wrong outcomes. [pmid: 10548397].
Ballard-Barbash R, Taplin SH, Yankaskas BC, et al. Breast Cancer Surveillance Consortium: a national mammography screening and outcomes database. AJR Am J Roentgenol. 1997;169(4):1001-8. Exclusion: wrong publication type. [pmid: 9308451].
Baltic S. Analysis of mammography trials renews debate on mortality reduction. J Natl Cancer Inst. 2001;93(22):1678-9. Exclusion: wrong publication type. [pmid: 11717322].
Baltzer PAT, Freiberg C, Beger S, et al. Clinical MR-mammography: are computer-assisted methods superior to visual or manual measurements for curve type analysis? A systematic approach. Acad Radiol. 2009;16(9):1070-6. Exclusion: wrong intervention. [pmid: 19523854].
Baltzer PAT, Renz DM, Kullnig PE, et al. Application of computer-aided diagnosis (CAD) in MR-mammography (MRM): do we really need whole lesion time curve distribution analysis?. Acad Radiol. 2009;16(4):435-42. Exclusion: wrong intervention. [pmid: 19268855].
Banik S, Rangayyan RM, Desautels JEL. Detection of architectural distortion in prior mammograms. IEEE Trans Med Imaging. 2011;30(2):279-94. Exclusion: wrong outcomes. [pmid: 20851789].
Banks E. Hormone replacement therapy and the sensitivity and specificity of breast cancer screening: a review. J Med Screen. 2001;8(1):29-34. Exclusion: review not meeting inclusion criteria. [pmid: 11373847].
Banks E, Reeves G, Beral V, et al. Predictors of outcome of mammography in the National Health Service Breast Screening Programme. J Med Screen. 2002;9(2):74-82. Exclusion: wrong comparison. [pmid: 12133927].
Banks E, Reeves G, Beral V, et al. Hormone replacement therapy and false positive recall in the Million Women Study: patterns of use, hormonal constituents and consistency of effect. Breast Cancer Res. 2006;8(1):R8. Exclusion: wrong outcomes. [pmid: 16417651].
Banning M. Perceptions of breast health awareness in Black British women. Eur J Oncol Nurs. 2011;15(2):173-7. Exclusion: wrong outcomes. [pmid: 20855234].
Barchielli A, Federico M, De Lisi V, et al. In situ breast cancer: incidence trend and organised screening programmes in Italy. Eur J Cancer. 2005;41(7):1045-50. Exclusion: wrong outcomes. [pmid: 15862754].
Barchielli A, Paci E. Trends in breast cancer mortality, incidence, and survival, and mammographic screening in Tuscany, Italy. Cancer Causes Control. 2001;12(3):249-55. Exclusion: included in an included systematic review, not directly used. [pmid: 11405330].
Barchielli A, Paci E, Giorgi D. Recent trends of in situ carcinoma of the breast and mammographic screening in the Florence area, Italy. Cancer Causes Control. 1999;10(4):313-7. Exclusion: wrong comparison. [pmid: 10482490].
Bare M, Sentis M, Galceran J, et al. Interval breast cancers in a community screening programme: frequency, radiological classification and prognostic factors. Eur J Cancer Prev. 2008;17(5):414-21. Exclusion: wrong outcomes. [pmid: 18714182].
Barlow WE, Chi C, Carney PA, et al. Accuracy of screening mammography interpretation by characteristics of radiologists. J Natl Cancer Inst. 2004;96(24):1840-50. Exclusion: wrong outcomes. [pmid: 15601640].
Barlow WE, White E, Ballard-Barbash R, et al. Prospective breast cancer risk prediction model for women undergoing screening mammography. J Natl Cancer Inst. 2006;98(17):1204-14. Exclusion: wrong study design for key question. [pmid: 16954473].
Barnett JB. The relationship between obesity and breast cancer risk and mortality. Nutr Rev. 2003;61(2):73-6. Exclusion: wrong study design for key question. [pmid: 12674440].
Barratt AL, Les Irwig M, Glasziou PP, et al. Benefits, harms and costs of screening mammography in women 70 years and over: a systematic review. Med J Aust. 2002;176(6):266-71. Exclusion: review not meeting inclusion criteria. [pmid: 11999259].
Barth RJ Jr., Gibson GR, Carney PA, et al. Detection of breast cancer on screening mammography allows patients to be treated with less-toxic therapy. AJR Am J Roentgenol. 2005;184(1):324-9. Exclusion: wrong outcomes. [pmid: 15615996].
Barton MB, Elmore JG. Pointing the way to informed medical decision making: test characteristics of clinical breast examination. J Natl Cancer Inst. 2009;101(18):1223-5. Exclusion: wrong publication type. [pmid: 19720968].
Barton MB, Harris R, Fletcher SW. The rational clinical examination. Does this patient have breast cancer? The screening clinical breast examination: should it be done? How?. JAMA. 1999;282(13):1270-80. Exclusion: wrong intervention. [pmid: 10517431].
Barton MB, Morley DS, Moore S, et al. Decreasing women's anxieties after abnormal mammograms: a controlled trial. J Natl Cancer Inst. 2004;96(7):529-38. Exclusion: wrong outcomes. [pmid: 15069115].
Bassett L, Butler D. Mammography and early breast cancer detection. Am Fam Physician. 1991;43(2):547-57. Exclusion: wrong publication type. [pmid: 1990738].
Bastardis-Zakas K, Iatrakis G, Navrozoglou I, et al. Maximizing the benefits of screening mammography for women 40-49 years old. Clin Exp Obstet Gynecol. 2010;37(4):278-82. Exclusion: review not meeting inclusion criteria. [pmid: 21355457].
Baum M. Breast cancer screening comes full circle. J Natl Cancer Inst. 2004;96(20):1490-1. Exclusion: wrong publication type. [pmid: 15494593].
Baydush AH, Catarious DM, Abbey CK, et al. Computer aided detection of masses in mammography using subregion Hotelling observers. Med Phys. 2003;30(7):1781-7. Exclusion: wrong study design for key question. [pmid: 12906196].
Bazzocchi M, Mazzarella F, Del Frate C, et al. CAD systems for mammography: a real opportunity? A review of the literature. Radiol Med (Torino). 2007;112(3):329-53. Exclusion: wrong study design for key question. [pmid: 17440698].
BCA BCA. Health is Not Just Healthcare: Inequities in Breast Cancer. 2013. Exclusion: wrong publication type.
Beam CA, Layde PM, Sullivan DC. Variability in the interpretation of screening mammograms by US radiologists. Findings from a national sample. Arch Intern Med. 1996;156(2):209-13. Exclusion: wrong outcomes. [pmid: 8546556].
Becker N, Hakama M, Nyström L. Evaluation of effectiveness of quality-assured mammography screening in Germany: sample size considerations and design options. Eur J Cancer Prev. 2007;16(3):225-31. Exclusion: wrong study design for key question. [pmid: 17415093].
Beckett JR, Kotre CJ, Michaelson JS. Analysis of benefit:risk ratio and mortality reduction for the UK Breast Screening Programme. Br J Radiol. 2003;76(905):309-20. Exclusion: wrong study design for key question. [pmid: 12763946].
Beckmann KR, Roder DM, Hiller JE, et al. Do breast cancer risk factors differ among those who do and do not undertake mammography screening?. J Med Screen. 2013;20(4):208-19. Exclusion: wrong outcomes. [pmid: 24153439].
Beemsterboer PM, Warmerdam PG, Boer R, et al. Radiation risk of mammography related to benefit in screening programmes: a favourable balance?. J Med Screen. 1998;5(2):81-7. Exclusion: studies outside of search dates. [pmid: 9718526].
Behjatnia B, Sim J, Bassett LW, et al. Does size matter? Comparison study between MRI, gross, and microscopic tumor sizes in breast cancer in lumpectomy specimens. Int J Clin Exp Pathol. 2010;3(3):303-9. Exclusion: wrong intervention. [pmid: 20224728].
Benndorf M, Baltzer PAT, Vag T, et al. Breast MRI as an adjunct to mammography: Does it really suffer from low specificity? A retrospective analysis stratified by mammographic BI-RADS classes. Acta Radiol. 2010;51(7):715-21. Exclusion: wrong outcomes. [pmid: 20707656].
Bennett IC, Muller J, Cockburn L, et al. Outcomes of multimodality breast screening for women at increased risk of familial breast cancer. World J Surg. 2010;34(5):979-86. Exclusion: wrong population. [pmid: 20108093].
Bennett IC, Robert DA, Osborne JM, et al. Discomfort during mammography: A survey of women attending a breast screening center. Breast Dis. 1994;7(1):35-41. Exclusion: included in an included systematic review, not directly used.
Bennett ML, Welman CJ, Celliers LM. How reassuring is a normal breast ultrasound in assessment of a screen-detected mammographic abnormality? A review of interval cancers after assessment that included ultrasound evaluation. Clin Radiol. 2011;66(10):928-39. Exclusion: wrong outcomes. [pmid: 21718976].
Bennett RL, Blanks RG, Moss SM. Does the accuracy of single reading with CAD (computer-aided detection) compare with that of double reading?: A review of the literature. Clin Radiol. 2006;61(12):1023-8. Exclusion: review not meeting inclusion criteria. [pmid: 17097423].
Bennett RL, Blanks RG, Patnick J, et al. Results from the UK NHS Breast Screening Programme 2000-05. J Med Screen. 2007;14(4):200-4. Exclusion: wrong study design for key question. [pmid: 18078565].
Bennett RL, Evans AJ, Kutt E, et al. Pathological and mammographic prognostic factors for screen detected cancers in a multi-centre randomised, controlled trial of mammographic screening in women from age 40 to 48 years. Breast. 2011;20(6):525-8. Exclusion: wrong comparison. [pmid: 21696957].
Bennett RL, Moss SM. Screening outcomes in women over age 70 who self-refer in the NHSBSP in England. J Med Screen. 2011;18(2):91-5. Exclusion: wrong comparison. [pmid: 21852702].
Bennett RL, Sellars SJ, Blanks RG, et al. An observational study to evaluate the performance of units using two radiographers to read screening mammograms. Clin Radiol. 2012;67(2):114-21. Exclusion: wrong outcomes. [pmid: 22070944].
Bennett RL, Sellars SJ, Moss SM. Interval cancers in the NHS breast cancer screening programme in England, Wales and Northern Ireland. Br J Cancer. 2011;104(4):571-7. Exclusion: wrong outcomes. [pmid: 21285989].
Beral V, Alexander M, Duffy S, et al. The number of women who would need to be screened regularly by mammography to prevent one death from breast cancer. J Med Screen. 2011;18(4):210-2. Exclusion: wrong publication type. [pmid: 22184734].
Beral V, Banks E, Reeves G, et al. Hormone replacement therapy and high incidence of breast cancer between mammographic screens. Lancet. 1997;349(9058):1103-4. Exclusion: wrong publication type. [pmid: 9107273].
Berg AO. The mammography debate. Am Fam Physician. 2002;66(12):2211-2. Exclusion: wrong publication type. [pmid: 12507159].
Berg AO. Mammography screening: are women really giving informed consent? (Counterpoint). J Natl Cancer Inst. 2003;95(20):1511-2. discussion 2-3. Exclusion: wrong publication type. [pmid: 14559871].
Berg WA. Supplemental screening sonography in dense breasts. Radiol Clin North Am. 2004;42(5):845-51. vi. Exclusion: review not meeting inclusion criteria. [pmid: 15337420].
Berg WA, Blume JD, Cormack JB, et al. Combined screening with ultrasound and mammography vs mammography alone in women at elevated risk of breast cancer. [Erratum appears in JAMA. 2010 Apr 21;303(15):1482]. JAMA. 2008;299(18):2151-63. Exclusion: wrong population. [pmid: 18477782].
Berg WA, Mendelson EB. Technologist-performed handheld screening breast US imaging: how is it performed and what are the outcomes to date?. Radiology. 2014;272(1):12-27. Exclusion: wrong publication type. [pmid: 24956046].
Berg WA, Zhang Z, Lehrer D, et al. Detection of breast cancer with addition of annual screening ultrasound or a single screening MRI to mammography in women with elevated breast cancer risk. JAMA. 2012;307(13):1394-404. Exclusion: wrong population. [pmid: 22474203].
Bernardi D, Caumo F, Macaskill P, et al. Effect of integrating 3D-mammography (digital breast tomosynthesis) with 2D-mammography on radiologists' true-positive and false-positive detection in a population breast screening trial. Eur J Cancer. 2014;50(7):1232-8. Exclusion: wrong intervention. [pmid: 24582915].
Bernardi D, Ciatto S, Pellegrini M, et al. Prospective study of breast tomosynthesis as a triage to assessment in screening. Breast Cancer Res Treat. 2012;133(1):267-71. Exclusion: wrong population. [pmid: 22270938].
Berrington de Gonzalez A. Estimates of the potential risk of radiation-related cancer from screening in the UK. J Med Screen. 2011;18(4):163-4. Exclusion: wrong publication type. [pmid: 22184730].
Berrington de Gonzalez A, Reeves G. Mammographic screening before age 50 years in the UK: comparison of the radiation risks with the mortality benefits. Br J Cancer. 2005;93(5):590-6. Exclusion: studies outside of search dates. [pmid: 16136033].
Berry DA. Benefits and risks of screening mammography for women in their forties: a statistical appraisal. J Natl Cancer Inst. 1998;90(19):1431-9. Exclusion: wrong publication type. [pmid: 9776408].
Berry DA. The screening mammography paradox: better when found, perhaps better not to find. Br J Cancer. 2008;98(11):1729-30. Exclusion: wrong publication type. [pmid: 18506172].
Berry DA, Cronin KA, Plevritis SK, et al. Effect of screening and adjuvant therapy on mortality from breast cancer. N Engl J Med. 2005;353(17):1784-92. Exclusion: wrong study design for key question. [pmid: 16251534].
Berry DA, Inoue L, Shen Y, et al. Modeling the impact of treatment and screening on U.S. breast cancer mortality: a Bayesian approach. J Natl Cancer Inst. Monographs. 2006;(36):30-6. Exclusion: wrong study design for key question.
Bick U, Diekmann F. Digital mammography: what do we and what don't we know?. Eur Radiol. 2007;17(8):1931-42. Exclusion: wrong publication type. [pmid: 17429645].
Bick U, Engelken F, Diederichs G, et al. MRI of the breast as part of the assessment in population-based mammography screening. Fortschr Geb Rontgenstr Nuklearmed. 2013;185(9):849-56. Exclusion: wrong outcomes.
Biesheuvel C, Barratt A, Howard K, et al. Effects of study methods and biases on estimates of invasive breast cancer overdetection with mammography screening: a systematic review. Lancet Oncol. 2007;8(12):1129-38. Exclusion: review not meeting inclusion criteria. [pmid: 18054882].
Bijwaard H, Brenner A, Dekkers F, et al. Breast cancer risk from different mammography screening practices. Radiat Res. 2010;174(3):367-76. Exclusion: wrong population. [pmid: 20726723].
Bitterman A, Bleicher RJ, Cabot MC, et al. Sentinel lymphadenectomy: a new alternative for managing early breast cancer. Isr Med Assoc J. 2002;4(10):803-9. Exclusion: wrong publication type. [pmid: 12389345].
Black WC, Fletcher SW. Effects of estrogen on screening mammography: another complexity. J Natl Cancer Inst. 1996;88(10):627-8. Exclusion: wrong publication type. [pmid: 8627634].
Black WC, Haggstrom DA, Welch HG. All-cause mortality in randomized trials of cancer screening. J Natl Cancer Inst. 2002;94(3):167-73. Exclusion: review not meeting inclusion criteria. [pmid: 11830606].
Blair S, McElroy M, Middleton MS, et al. The efficacy of breast MRI in predicting breast conservation therapy. J Surg Oncol. 2006;94(3):220-5. Exclusion: wrong intervention. [pmid: 16900536].
Blamey RW, Wilson AR, Patnick J. ABC of breast diseases: screening for breast cancer. BMJ. 2000;321(7262):689-93. Exclusion: review not meeting inclusion criteria. [pmid: 10987778].
Blanchard K, Colbert JA, Kopans DB, et al. Long-term risk of false-positive screening results and subsequent biopsy as a function of mammography use. Radiology. 2006;240(2):335-42. Exclusion: studies outside of search dates. [pmid: 16864665].
Blanchard K, Colbert JA, Puri D, et al. Mammographic screening: patterns of use and estimated impact on breast carcinoma survival. Cancer. 2004;101(3):495-507. Exclusion: wrong study design for key question. [pmid: 15274062].
Blanks RG, Bennett RL, Patnick J, et al. The effect of changing from one to two views at incident (subsequent) screens in the NHS breast screening programme in England: impact on cancer detection and recall rates. Clin Radiol. 2005;60(6):674-80. Exclusion: wrong outcomes. [pmid: 16038694].
Blanks RG, Day NE, Moss SM. Monitoring the performance of breast screening programmes: use of indirect standardisation in evaluating the invasive cancer detection rate. J Med Screen. 1996;3(2):79-81. Exclusion: wrong outcomes. [pmid: 8849764].
Blanks RG, Moss SM, McGahan CE, et al. Effect of NHS breast screening programme on mortality from breast cancer in England and Wales, 1990-8: comparison of observed with predicted mortality. BMJ. 2000;321(7262):665-9. Exclusion: included in an included systematic review, not directly used. [pmid: 10987769].
Blanks RG, Moss SM, Patnick J. Results from the UK NHS breast screening programme 1994-1999. J Med Screen. 2000;7(4):195-8. Exclusion: wrong comparison. [pmid: 11202586].
Bliss JM, Gray R. Breast cancer and hormone-replacement therapy: the Million Women Study. Lancet. 2003;362(9392):1328-9. author reply 30-1. Exclusion: wrong publication type. [pmid: 14575984].
Bloom JR, Stewart SL, Hancock SL. Breast cancer screening in women surviving Hodgkin disease. Am J Clin Oncol. 2006;29(3):258-66. Exclusion: wrong population. [pmid: 16755179].
Bluekens AMJ, Holland R, Karssemeijer N, et al. Comparison of digital screening mammography and screen-film mammography in the early detection of clinically relevant cancers: a multicenter study. Radiology. 2012;265(3):707-14. Exclusion: wrong comparison. [pmid: 23033499].
Bluekens AMJ, Karssemeijer N, Beijerinck D, et al. Consequences of digital mammography in population-based breast cancer screening: initial changes and long-term impact on referral rates. Eur Radiol. 2010;20(9):2067-73. Exclusion: wrong comparison. [pmid: 20407901].
Bobo JK, Lee NC, Thames SF. Findings from 752,081 clinical breast examinations reported to a national screening program from 1995 through 1998. J Natl Cancer Inst. 2000;92(12):971-6. Exclusion: wrong outcomes. [pmid: 10861308].
Bock K, Borisch B, Cawson J, et al. Effect of population-based screening on breast cancer mortality. [Erratum appears in Lancet. 2013 Feb 16; 381 (9866) 536]. Lancet. 2011;378(9805):1775-6. Exclusion: wrong publication type. [pmid: 22098846].
Boer R, de Koning HJ, van der Maas PJ. A longer breast carcinoma screening interval for women age older than 65 years?. Cancer. 1999;86(8):1506-10. Exclusion: wrong study design for key question. [pmid: 10526279].
Boetes C, Veltman J, van Die L, et al. The role of MRI in invasive lobular carcinoma. Breast Cancer Res Treat. 2004;86(1):31-7. Exclusion: wrong intervention. [pmid: 15218359].
Boggs DA, Rosenberg L, Pencina MJ, et al. Validation of a breast cancer risk prediction model developed for Black women. J Natl Cancer Inst. 2013;105(5):361-7. Exclusion: wrong outcomes. [pmid: 23411594].
Bogner HR, Wittink MN. Depression as a risk factor for underuse of mammography. J Womens Health (Larchmt). 2004;13(6):739-42. Exclusion: wrong publication type. [pmid: 15333289].
Bolivar AV, Gomez SS, Merino P, et al. Computer-aided detection system applied to full-field digital mammograms. Acta Radiol. 2010;51(10):1086-92. Exclusion: wrong outcomes. [pmid: 20883182].
Bondy ML, Newman LA. Assessing breast cancer risk: evolution of the Gail Model. J Natl Cancer Inst. 2006;98(17):1172-3. Exclusion: wrong publication type. [pmid: 16954464].
Bonneux L. Mortality reduction by breast-cancer screening. Lancet. 2003;362(9379):245. Exclusion: wrong publication type. [pmid: 12885491].
Boone JM, Lindfors KK, Seibert JA. Determining sensitivity of mammography from screening data, cancer incidence, and receiver-operating characteristic curve parameters. Med Decis Making. 2002;22(3):228-37. Exclusion: wrong outcomes. [pmid: 12058780].
Borch KB, Lund E, Braaten T, et al. Physical activity and the risk of postmenopausal breast cancer - the Norwegian Women and Cancer Study. J Negat Results Biomed. 2014;13:3. Exclusion: wrong outcomes. [pmid: 24580799].
Bordas P, Jonsson H, Nyström L, et al. Early breast cancer deaths in women aged 40-74 years diagnosed during the first 5 years of organised mammography service screening in north Sweden. Breast. 2004;13(4):276-83. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 15325661].
Bordas P, Jonsson H, Nyström L, et al. Interval cancer incidence and episode sensitivity in the Norrbotten Mammography Screening Programme, Sweden. J Med Screen. 2009;16(1):39-45. Exclusion: wrong outcomes. [pmid: 19349530].
Bordoni A, Probst-Hensch NM, Mazzucchelli L, et al. Assessment of breast cancer opportunistic screening by clinical-pathological indicators: a population-based study. Br J Cancer. 2009;101(11):1925-31. Exclusion: wrong outcomes. [pmid: 19861962].
Borrayo EA, Hines L, Byers T, et al. Characteristics associated with mammography screening among both Hispanic and non-Hispanic white women. J Womens Health (Larchmt). 2009;18(10):1585-894. Exclusion: wrong outcomes. [pmid: 19754247].
Bourez RLJH, Rutgers EJT, Van De Velde CJH. Will we need lymph node dissection at all in the future?. Clin Breast Cancer. 2002;3(5):315-22. discussion 23-5. Exclusion: wrong outcomes. [pmid: 12533260].
Boyd NF, Jong RA, Yaffe MJ, et al. A critical appraisal of the Canadian National Breast Cancer Screening Study. Radiology. 1993;189(3):661-3. Exclusion: wrong publication type. [pmid: 8234686].
Boyd NF, Melnichouk O, Martin LJ, et al. Mammographic density, response to hormones, and breast cancer risk. J Clin Oncol. 2011;29(22):2985-92. Exclusion: wrong outcomes. [pmid: 21709206].
Boyer B, Balleyguier C, Granat O, et al. CAD in questions/answers Review of the literature. Eur J Radiol. 2009;69(1):24-33. Exclusion: wrong publication type. [pmid: 18977103].
Bradley CJ, Given CW, Roberts C. Late stage cancers in a Medicaid-insured population. Med Care. 2003;41(6):722-8. Exclusion: wrong population. [pmid: 12773838].
Braillon A, Bewley S. Lost opportunity to usefully examine French breast cancer screening mortality. Cancer epidemiol. 2011;35(3):306. author reply 7-8. Exclusion: wrong publication type. [pmid: 21466985].
Braithwaite D, Zhu W, Hubbard RA, et al. Screening outcomes in older US women undergoing multiple mammograms in community practice: does interval, age, or comorbidity score affect tumor characteristics or false positive rates?. J Natl Cancer Inst. 2013;105(5):334-41. Exclusion: wrong comparison. [pmid: 23385442].
Brandt KR, Craig DA, Hoskins TL, et al. Can digital breast tomosynthesis replace conventional diagnostic mammography views for screening recalls without calcifications? A comparison study in a simulated clinical setting. AJR Am J Roentgenol. 2013;200(2):291-8. Exclusion: wrong intervention. [pmid: 23345348].
Bredart A, Kop JL, Fall M, et al. Anxiety and specific distress in women at intermediate and high risk of breast cancer before and after surveillance by magnetic resonance imaging and mammography versus standard mammography. Psychooncology. 2012;21(11):1185-94. Exclusion: wrong population. [pmid: 21812069].
Breen N, Yabroff KR, Meissner HI. What proportion of breast cancers are detected by mammography in the United States?. Cancer Detect Prev. 2007;31(3):220-4. Exclusion: wrong study design for key question. [pmid: 17573202].
Brekelmans CT, Bartels CC, Crepin E, et al. Breast cancer screening in high-risk women. Rotterdam Committee of Medical and Genetic Counseling. Dis Markers. 1999;15(1-3):34-6. Exclusion: wrong population. [pmid: 10595248].
Brekelmans CT, van Gorp JM, Peeters PH, et al. Histopathology and growth rate of interval breast carcinoma. Characterization of different subgroups. Cancer. 1996;78(6):1220-8. Exclusion: wrong outcomes. [pmid: 8826943].
Brem RF, Baum J, Lechner M, et al. Improvement in sensitivity of screening mammography with computer-aided detection: a multiinstitutional trial. AJR Am J Roentgenol. 2003;181(3):687-93. Exclusion: wrong outcomes. [pmid: 12933460].
Brem RF, Hoffmeister JW, Rapelyea JA, et al. Impact of breast density on computer-aided detection for breast cancer. [Erratum appears in AJR Am J Roentgenol. 2005 Jun; 184 6 1968]. AJR Am J Roentgenol. 2005;184(2):439-44. Exclusion: wrong outcomes. [pmid: 15671360].
Brem RF, Ioffe M, Rapelyea JA, et al. Invasive lobular carcinoma: detection with mammography, sonography, MRI, and breast-specific gamma imaging. AJR Am J Roentgenol. 2009;192(2):379-83. Exclusion: wrong population. [pmid: 19155397].
Brenner DJ, Sawant SG, Hande MP, et al. Routine screening mammography: how important is the radiation-risk side of the benefit-risk equation?. Int J Radiat Biol. 2002;78(12):1065-7. Exclusion: wrong population. [pmid: 12556334].
Brenner RJ. False-negative mammograms. Medical, legal, and risk management implications. Radiol Clin North Am. 2000;38(4):741-57. Exclusion: wrong publication type. [pmid: 10943275].
Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. Exclusion: included in an included systematic review, not directly used. [pmid: 11873891].
Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. Exclusion: included in an included systematic review, not directly used. [pmid: 11873891].
Brett J, Austoker J, Ong G. Do women who undergo further investigation for breast screening suffer adverse psychological consequences? A multi-centre follow-up study comparing different breast screening result groups five months after their last breast screening appointment. J Public Health Med. 1998;20(4):396-403. Exclusion: studies outside of search dates. [pmid: 9923945].
Brett J, Austoker J, Ong G. Do women who undergo further investigation for breast screening suffer adverse psychological consequences? A multi-centre follow-up study comparing different breast screening result groups five months after their last breast screening appointment. J Public Health Med. 1998;20(4):396-403. Exclusion: included in an included systematic review, not directly used. [pmid: 9923945].
Brewster AM, Thompson P, Sahin AA, et al. Copy number imbalances between screen- and symptom-detected breast cancers and impact on disease-free survival. Cancer Prev Res (Phila). 2011;4(10):1609-16. Exclusion: wrong comparison. [pmid: 21795423].
Brewster D, Everington D, Harkness E, et al. Incidence of and mortality from breast cancer since introduction of screening. Scottish figures show higher incidence and similar mortality. BMJ. 1996;312(7031):639-40. Exclusion: wrong publication type. [pmid: 8595361].
Brewster DH, Sharpe KH, Clark DI, et al. Declining breast cancer incidence and decreased HRT use. Lancet. 2009;373(9662):459-60. author reply 61. Exclusion: wrong publication type. [pmid: 19200912].
Brewster DH, Stockton DL. Ascertainment of breast cancer by the Scottish Cancer Registry: an assessment based on comparison with five independent breast cancer trials databases. Breast. 2008;17(1):104-6. Exclusion: wrong study design for key question. [pmid: 17855094].
Briedis D, Siu KKW, Paganin DM, et al. Analyser-based mammography using single-image reconstruction. Phys Med Biol. 2005;50(15):3599-611. Exclusion: wrong study design for key question. [pmid: 16030385].
Brodersen J, Jorgensen KJ, Gotzsche PC. The benefits and harms of screening for cancer with a focus on breast screening. Pol Arch Med Wewn. 2010;120(3):89-94. Exclusion: review not meeting inclusion criteria. [pmid: 20332715].
Broeders M, Moss S, Nyström L, et al. The impact of mammographic screening on breast cancer mortality in Europe: a review of observational studies. J Med Screen. Suppl 1. 2012;19:14-25. Exclusion: review not meeting inclusion criteria. [pmid: 22972807].
Broeders MJ, Peer PG, Straatman H, et al. Diverging breast cancer mortality rates in relation to screening? A comparison of Nijmegen to Arnhem and the Netherlands, 1969-1997. Int J Cancer. 2001;92(2):303-8. Exclusion: wrong outcomes. [pmid: 11291061].
Broeders MJM, Verbeek ALM, Straatman H, et al. Repeated mammographic screening reduces breast cancer mortality along the continuum of age. J Med Screen. 2002;9(4):163-7. Exclusion: wrong study design for key question. [pmid: 12518006].
Brouckaert O, Schoneveld A, Truyers C, et al. Breast cancer phenotype, nodal status and palpability may be useful in the detection of overdiagnosed screening-detected breast cancers. Ann Oncol. 2013;24(7):1847-52. Exclusion: wrong outcomes. [pmid: 23680691].
Brown M, Eccles C, Wallis MG. Geographical distribution of breast cancers on the mammogram: an interval cancer database. Br J Radiol. 2001;74(880):317-22. Exclusion: wrong outcomes. [pmid: 11387148].
Brown SBF, Morrison DS, Cooke TG. Increasing incidence of breast cancer: distinguishing between the effects of birth cohort and a national breast screening programme. Breast Cancer Res Treat. 2009;116(3):603-7. Exclusion: wrong outcomes. [pmid: 18855136].
Bruening W, Uhl S, Fontanarosa J, et al. Noninvasive Diagnostic Tests for Breast Abnormalities: Update of a 2006 Review. AHRQ Comparative Effectiveness Reviews. 2012. Exclusion: review not meeting inclusion criteria.
Bucchi L, Barchielli A, Ravaioli A, et al. Screen-detected vs clinical breast cancer: the advantage in the relative risk of lymph node metastases decreases with increasing tumour size. Br J Cancer. 2005;92(1):156-61. Exclusion: wrong study design for key question. [pmid: 15597100].
Bucchi L, Foca F, Ravaioli A, et al. Receipt of adjuvant systemic therapy among patients with high-risk breast cancer detected by mammography screening. Breast Cancer Res Treat. 2009;113(3):559-66. Exclusion: wrong outcomes. [pmid: 18317924].
Bucchi L, Puliti D, Ravaioli A, et al. Breast screening: axillary lymph node status of interval cancers by interval year. Breast. 2008;17(5):477-83. Exclusion: wrong outcomes. [pmid: 18455401].
Buchberger W, DeKoekkoek-Doll P, Springer P, et al. Incidental findings on sonography of the breast: clinical significance and diagnostic workup. AJR Am J Roentgenol. 1999;173(4):921-7. Exclusion: wrong outcomes. [pmid: 10511149].
Buchberger W, Niehoff A, Obrist P, et al. Clinically and mammographically occult breast lesions: detection and classification with high-resolution sonography. Semin Ultrasound CT MR. 2000;21(4):325-36. Exclusion: wrong intervention. [pmid: 11014255].
Buiatti E, Barchielli A, Bartolacci S, et al. Stage-specific incidence of breast cancer before the beginning of organized screening programs in Italy. Cancer Causes Control. 2002;13(1):65-71. Exclusion: wrong intervention. [pmid: 11899119].
Buiatti E, Barchielli A, Bartolacci S, et al. The impact of organised screening programmes on the stage-specific incidence of breast cancer in some Italian areas. Eur J Cancer. 2003;39(12):1776-82. Exclusion: wrong outcomes. [pmid: 12888374].
Buist DSM, Porter PL, Lehman C, et al. Factors contributing to mammography failure in women aged 40-49 years. J Natl Cancer Inst. 2004;96(19):1432-40. Exclusion: wrong population. [pmid: 15467032].
Buist DSM, Walker R, Bowles EJA, et al. Screening mammography use among current, former, and never hormone therapy users may not explain recent declines in breast cancer incidence. Cancer Epidemiol Biomarkers Prev. 2012;21(5):720-7. Exclusion: wrong outcomes. [pmid: 22301831].
Bull AR, Campbell MJ. Assessment of the psychological impact of a breast screening programme. Br J Radiol. 1991;64(762):510-5. Exclusion: included in an included systematic review, not directly used. [pmid: 2070180].
Bulliard JL, De Landtsheer JP, Levi F. Results from the Swiss mammography screening pilot programme. Eur J Cancer. 2003;39(12):1761-9. Exclusion: wrong comparison. [pmid: 12888372].
Bulliard JL, Ducros C, Dayer E, et al. Variation in performance in low-volume mammography screening programmes: experience from Switzerland. Cancer epidemiol. 2011;35(3):293-7. Exclusion: wrong outcomes. [pmid: 20729158].
Bulliard JL, Ducros C, Jemelin C, et al. Effectiveness of organised versus opportunistic mammography screening. Ann Oncol. 2009;20(7):1199-202. Exclusion: wrong comparison. [pmid: 19282467].
Bulpitt CJ, Benos AS, Nicholl CG, et al. Should medical screening of the elderly population be promoted?. Gerontology. 1990;36(4):230-45. Exclusion: review not meeting inclusion criteria. [pmid: 2272526].
Burani R, Caimi F, Maggioni C, et al. Quality assessment of the mammographic screening programme in the Azienda Sanitaria locale Provincia Milano 1 -- analysis of interval cancers and discussion of possible causes of diagnostic error. Radiol Med (Torino). 2005;109(3):260-7. Exclusion: wrong outcomes. [pmid: 15775895].
Burhenne LJ, Burhenne HJ. The Canadian National Breast Screening Study: a Canadian critique. AJR Am J Roentgenol. 1993;161(4):761-3. Exclusion: wrong publication type. [pmid: 8372753].
Burke JP, Power C, Gorey TF, et al. A comparative study of risk factors and prognostic features between symptomatic and screen detected breast cancer. Eur J Surg Oncol. 2008;34(2):149-53. Exclusion: wrong comparison. [pmid: 17498912].
Burnside E, Belkora J, Esserman L. The impact of alternative practices on the cost and quality of mammographic screening in the United States. Clin Breast Cancer. 2001;2(2):145-52. Exclusion: wrong outcomes. [pmid: 11899786].
Burnside ES, Sickles EA, Sohlich RE, et al. Differential value of comparison with previous examinations in diagnostic versus screening mammography. AJR Am J Roentgenol. 2002;179(5):1173-7. Exclusion: wrong outcomes. [pmid: 12388494].
Burrell HC, Sibbering DM, Wilson AR, et al. Screening interval breast cancers: mammographic features and prognosis factors. Radiology. 1996;199(3):811-7. Exclusion: wrong outcomes. [pmid: 8638010].
Burstein HJ, Polyak K, Wong JS, et al. Ductal carcinoma in situ of the breast. N Engl J Med. 2004;350(14):1430-41. Exclusion: wrong population. [pmid: 15070793].
Burton RC, Bell RJ, Thiagarajah G, et al. Adjuvant therapy, not mammographic screening, accounts for most of the observed breast cancer specific mortality reductions in Australian women since the national screening program began in 1991. Breast Cancer Res Treat. 2012;131(3):949-55. Exclusion: wrong comparison. [pmid: 21956213].
Buscombe JR, Cwikla JB, Holloway B, et al. Prediction of the usefulness of combined mammography and scintimammography in suspected primary breast cancer using ROC curves. J Nucl Med. 2001;42(1):3-8. Exclusion: wrong population. [pmid: 11197976].
Buyse M, Loi S, van't Veer L, et al. Validation and clinical utility of a 70-gene prognostic signature for women with node-negative breast cancer. J Natl Cancer Inst. 2006;98(17):1183-92. Exclusion: wrong intervention. [pmid: 16954471].
Byng JW, Boyd NF, Little L, et al. Symmetry of projection in the quantitative analysis of mammographic images. Eur J Cancer Prev. 1996;5(5):319-27. Exclusion: wrong outcomes. [pmid: 8972250].
Caban ME, Kuo Y-F, Mahnken JD, et al. Mammography use may partially mediate disparities in tumor size at diagnosis in women with social security disabilities. Women Health. 2007;46(4):1-17. Exclusion: wrong comparison. [pmid: 18512449].
Cabanes A, Vidal E, Pérez-Gómez B, et al. Age-specific breast, uterine and ovarian cancer mortality trends in Spain: changes from 1980 to 2006. Cancer epidemiol. 2009;33(3-4):169-75. Exclusion: included in an included systematic review, not directly used. [pmid: 19766076].
Cady B, Chung MA. Preventing invasive breast cancer: another benefit from mammographic screening. Cancer. 2011;117(14):3064-8. Exclusion: wrong publication type. [pmid: 21246518].
Cady B, Michaelson JS, Chung MA. The “tipping point” for breast cancer mortality decline has resulted from size reductions due to mammographic screening. Ann Surg Oncol. 2011;18(4):903-6. Exclusion: wrong publication type. [pmid: 21267787].
Cady B, Stone MD, Schuler JG, et al. The new era in breast cancer. Invasion, size, and nodal involvement dramatically decreasing as a result of mammographic screening. Arch Surg. 1996;131(3):301-8. Exclusion: wrong study design for key question. [pmid: 8611096].
Callaway MP, Boggis CR, Astley SA, et al. The influence of previous films on screening mammographic interpretation and detection of breast carcinoma. Clin Radiol. 1997;52(7):527-9. Exclusion: wrong outcomes. [pmid: 9240705].
Calle EE, Feigelson HS, Hildebrand JS, et al. Postmenopausal hormone use and breast cancer associations differ by hormone regimen and histologic subtype. [Erratum appears in Cancer. 2009 Apr 1;115(7):1587]. Cancer. 2009;115(5):936-45. Exclusion: wrong outcomes. [pmid: 19156895].
Campbell JB. Breast cancer-race, ethnicity, and survival: a literature review. Breast Cancer Res Treat. 2002;74(2):187-92. Exclusion: review not meeting inclusion criteria. [pmid: 12186379].
Caproni N, Marchisio F, Pecchi A, et al. Contrast-enhanced ultrasound in the characterisation of breast masses: utility of quantitative analysis in comparison with MRI. Eur Radiol. 2010;20(6):1384-95. Exclusion: wrong intervention. [pmid: 20033178].
Carcaise-Edinboro P, Bradley CJ, Dahman B. Surveillance mammography for Medicaid/Medicare breast cancer patients. J Cancer Surviv. 2010;4(1):59-66. Exclusion: wrong intervention. [pmid: 20091247].
Carles M, Vilaprinyo E, Cots F, et al. Cost-effectiveness of early detection of breast cancer in Catalonia (Spain). BMC Cancer. 2011;11:192. Exclusion: wrong outcomes. [pmid: 21605383].
Carlos RC. Declining screening mammography rates: a multigenerational loss of opportunity?. AJR Am J Roentgenol. 2009;192(2):388-9. Exclusion: wrong publication type. [pmid: 19155399].
Carmichael AR. Obesity as a risk factor for development and poor prognosis of breast cancer. BJOG. 2006;113(10):1160-6. Exclusion: review not meeting inclusion criteria. [pmid: 16945118].
Carney JK, Ewing JF, Finley CA. Progress in breast cancer screening: Vermont's efforts. J Public Health Manag Pract. 1996;2(2):57-63. Exclusion: studies outside of search dates. [pmid: 10186669].
Carney PA, Abraham LA, Miglioretti DL, et al. Factors associated with imaging and procedural events used to detect breast cancer after screening mammography. AJR Am J Roentgenol. 2007;188(2):385-92. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 17242246].
Carney PA, Bogart TA, Geller BM, et al. Association between time spent interpreting, level of confidence, and accuracy of screening mammography. AJR Am J Roentgenol. 2012;198(4):970-8. Exclusion: wrong outcomes. [pmid: 22451568].
Carney PA, Cook AJ, Miglioretti DL, et al. Use of clinical history affects accuracy of interpretive performance of screening mammography. J Clin Epidemiol. 2012;65(2):219-30. Exclusion: wrong outcomes. [pmid: 22000816].
Carney PA, Goodrich ME, O'Mahony DM, et al. Mammography in New Hampshire: characteristics of the women and the exams they receive. J Community Health. 2000;25(3):183-98. Exclusion: wrong outcomes. [pmid: 10868813].
Carney PA, Sickles EA, Monsees BS, et al. Identifying minimally acceptable interpretive performance criteria for screening mammography. Radiology. 2010;255(2):354-61. Exclusion: wrong outcomes. [pmid: 20413750].
Carter KJ, Castro F, Kessler E, et al. Simulation of breast cancer screening: quality assessment of two protocols. J Healthc Qual. 2004;26(6):31-8. Exclusion: wrong study design for key question. [pmid: 15603093].
Carter TI, Reilly JJ. Missed opportunities: clinical antecedents in the diagnosis of advanced breast cancer. Ann Surg Oncol. 2012;19(9):2782-5. Exclusion: wrong population. [pmid: 22526911].
Castells X, Roman M, Romero A, et al. Breast cancer detection risk in screening mammography after a false-positive result. Cancer epidemiol. 2013;37(1):85-90. Exclusion: wrong outcomes. [pmid: 23142338].
Castro F, Carter KJ, Kessler E, et al. The relation of breast cancer staging to screening protocol compliance: a computer simulation study. Comput Biol Med. 2005;35(2):91-101. Exclusion: wrong outcomes. [pmid: 15567180].
Cates C, Senn S. Screening mammography re-evaluated. Lancet. 2000;355(9205):750. author reply 2. Exclusion: wrong publication type. [pmid: 10703824].
Caumo F, Bernardi D, Ciatto S, et al. Incremental effect from integrating 3D-mammography (tomosynthesis) with 2D-mammography: Increased breast cancer detection evident for screening centres in a population-based trial. Breast. 2014;23(1):76-80. Exclusion: wrong outcomes. [pmid: 24316152].
Caumo F, Brunelli S, Tosi E, et al. On the role of arbitration of discordant double readings of screening mammography: experience from two Italian programmes. Radiol Med (Torino). 2011;116(1):84-91. Exclusion: wrong outcomes. [pmid: 20981500].
Caumo F, Vecchiato F, Pellegrini M, et al. Analysis of interval cancers observed in an Italian mammography screening programme (2000-2006). Radiol Med (Torino). 2009;114(6):907-14. Exclusion: wrong outcomes. [pmid: 19551342].
Caumo F, Vecchiato F, Strabbioli M, et al. Interval cancers in breast cancer screening: comparison of stage and biological characteristics with screen-detected cancers or incident cancers in the absence of screening. Tumori. 2010;96(2):198-201. Exclusion: wrong outcomes. [pmid: 20572574].
Cawson JN, Nickson C, Amos A, et al. Invasive breast cancers detected by screening mammography: a detailed comparison of computer-aided detection-assisted single reading and double reading. J Med Imaging Radiat Oncol. 2009;53(5):442-9. Exclusion: wrong outcomes. [pmid: 19788479].
Cecchini RS, Costantino JP, Cauley JA, et al. Body mass index and the risk for developing invasive breast cancer among high-risk women in NSABP P-1 and STAR breast cancer prevention trials. Cancer Prev Res (Phila). 2012;5(4):583-92. Exclusion: wrong intervention. [pmid: 22318751].
Celaya MO, Berke EM, Onega TL, et al. Breast cancer stage at diagnosis and geographic access to mammography screening (New Hampshire, 1998-2004). Rural Remote Health. 2010;10(2):1361. Exclusion: wrong comparison. [pmid: 20438282].
Centre for R, Dissemination. Clinical and economic outcomes analyses of women developing breast cancer in a managed care organization. (Provisional abstract). NHS Economic Evaluation Database. 2014;(1). Exclusion: wrong outcomes.
Centre for R, Dissemination. Costs, effects and cost-effectiveness of breast cancer control in Ghana. (Provisional abstract). NHS Economic Evaluation Database. 2014;(1). Exclusion: wrong outcomes.
Centre for R, Dissemination. Tailored breast cancer screening program with microdose mammography, US, and MR imaging: short-term results of a pilot study in 40-49-year-old women. (Provisional abstract). NHS Economic Evaluation Database. 2014;(1). Exclusion: wrong publication type.
Chae EY, Kim HH, Cha JH, et al. Evaluation of screening whole-breast sonography as a supplemental tool in conjunction with mammography in women with dense breasts. J Ultrasound Med. 2013;32(9):1573-8. Exclusion: wrong outcomes. [pmid: 23980217].
Chagpar AB, McMasters KM, Saul J, et al. Body mass index influences palpability but not stage of breast cancer at diagnosis. Am Surg. 2007;73(6):555-60. discussion 60. Exclusion: wrong population. [pmid: 17658091].
Chan SWW, Cheung PSY, Chan S, et al. Benefit of ultrasonography in the detection of clinically and mammographically occult breast cancer. World J Surg. 2008;32(12):2593-8. Exclusion: wrong intervention. [pmid: 17960454].
Chang HR, Cole B, Bland KI. Nonpalpable breast cancer in women aged 40-49 years: a surgeon's view of benefits from screening mammography. J Natl Cancer Inst. Monographs. 1997;(22):45-9. Exclusion: wrong comparison.
Chang JM, Moon WK, Cho N, et al. Breast cancers initially detected by hand-held ultrasound: detection performance of radiologists using automated breast ultrasound data. Acta Radiol. 2011;52(1):8-14. Exclusion: wrong outcomes. [pmid: 21498319].
Chang R-F, Chang-Chien K-C, Takada E, et al. Breast density analysis in 3-D whole breast ultrasound images. Conf Proc IEEE Eng Med Biol Soc. 2006;1:2795-8. Exclusion: wrong outcomes. [pmid: 17945741].
Chang Y, Schechter CB, van Ravesteyn NT, et al. Collaborative modeling of the impact of obesity on race-specific breast cancer incidence and mortality. Breast Cancer Res Treat. 2012;136(3):823-35. Exclusion: wrong outcomes. [pmid: 23104221].
Chang YH, Zheng B, Gur D. Robustness of computerized identification of masses in digitized mammograms. A preliminary assessment. Invest Radiol. 1996;31(9):563-8. Exclusion: wrong intervention. [pmid: 8877493].
Chay WY, Ong WS, Tan PH, et al. Validation of the Gail model for predicting individual breast cancer risk in a prospective nationwide study of 28,104 Singapore women. Breast Cancer Res. 2012;14(1):R19. Exclusion: wrong intervention. [pmid: 22289271].
Chen C, Orel SG, Schnall MD, et al. Breast conservation treatment for patients presenting with axillary lymphadenopathy from presumed primary breast cancer: the role of breast magnetic resonance imaging for staging. Clin Breast Cancer. 2002;3(3):219-22. Exclusion: wrong study design for key question. [pmid: 12196282].
Chen DR, Jeng LB, Kao A, et al. Comparing thallium-201 spect mammoscintigraphy and ultrasonography to detect breast cancer in mammographical dense breasts. Neoplasma. 2003;50(3):222-6. Exclusion: wrong intervention. [pmid: 12937857].
Chen HH, Thurfjell E, Duffy SW, et al. Evaluation by Markov chain models of a non-randomised breast cancer screening programme in women aged under 50 years in Sweden. J Epidemiol Community Health. 1998;52(5):329-35. Exclusion: wrong study design for key question. [pmid: 9764285].
Chen J-H, Mehta RS, Nalcioglu O, et al. Magnetic resonance imaging evaluation of noninflammatory breast cancer with skin involvement after neoadjuvant chemotherapy. [Erratum appears in Ann Surg Oncol. 2011 Dec;18 Suppl 3:S329 Note: Mehta, Rita S [added]]. Ann Surg Oncol. 2010;17(7):1964-5. Exclusion: wrong publication type. [pmid: 20180030].
Chen L, Chen Y, Diao XH, et al. Comparative study of automated breast 3-D ultrasound and handheld B-mode ultrasound for differentiation of benign and malignant breast masses. Ultrasound Med Biol. 2013;39(10):1735-42. Exclusion: wrong outcomes. [pmid: 23849390].
Chen TH-H, Yen AM-F, Wu GH-M, et al. Multiple detection modalities and disease natural history of breast cancer. Stud Health Technol Inform. 2007;129(Pt 1):78-81. Exclusion: wrong study design for key question. [pmid: 17911682].
Chen TR, Tyan YS, Teng PS, et al. Population dose from medical exposure in Taiwan for 2008. Med Phys. 2011;38(6):3139-48. Exclusion: wrong publication type. [pmid: 21815388].
Chen W, Giger ML, Lan L, et al. Computerized interpretation of breast MRI: investigation of enhancement-variance dynamics. Med Phys. 2004;31(5):1076-82. Exclusion: wrong outcomes. [pmid: 15191295].
Chen W-M, Chang R-F, Moon WK, et al. Breast cancer diagnosis using three-dimensional ultrasound and pixel relation analysis. Ultrasound Med Biol. 2003;29(7):1027-35. Exclusion: wrong outcomes. [pmid: 12878249].
Chen Y, Brock G, Wu D. Estimating key parameters in periodic breast cancer screening-application to the Canadian National Breast Screening Study data. Cancer epidemiol. 2010;34(4):429-33. Exclusion: wrong study design for key question. [pmid: 20434974].
Chen Z, Wu AH, Gauderman WJ, et al. Does mammographic density reflect ethnic differences in breast cancer incidence rates?. Am J Epidemiol. 2004;159(2):140-7. Exclusion: wrong comparison. [pmid: 14718215].
Cheng Y-C, Wu N-Y, Ko JS, et al. Breast cancers detected by breast MRI screening and ultrasound in asymptomatic Asian women: 8 years of experience in Taiwan. Oncology. 2012;82(2):98-107. Exclusion: wrong comparison. [pmid: 22328009].
Chiarelli AM, Edwards SA, Prummel MV, et al. Digital compared with screen-film mammography: performance measures in concurrent cohorts within an organized breast screening program. Radiology. 2013;268(3):684-93. Exclusion: wrong comparison. [pmid: 23674784].
Chiarelli AM, Edwards SA, Sheppard AJ, et al. Favourable prognostic factors of subsequent screen-detected breast cancers among women aged 50-69. Eur J Cancer Prev. 2012;21(6):499-506. Exclusion: wrong study design for key question. [pmid: 22273849].
Chiarelli AM, Halapy E, Nadalin V, et al. Performance measures from 10 years of breast screening in the Ontario Breast Screening Program, 1990/91 to 2000. Eur J Cancer Prev. 2006;15(1):34-42. Exclusion: wrong comparison. [pmid: 16374227].
Chiarelli AM, Kirsh VA, Klar NS, et al. Influence of patterns of hormone replacement therapy use and mammographic density on breast cancer detection. Cancer Epidemiol Biomarkers Prev. 2006;15(10):1856-62. Exclusion: wrong outcomes. [pmid: 17035392].
Chiarelli AM, Mai V, Halapy EE, et al. Effect of screening result on waiting times to assessment and breast cancer diagnosis: results from the Ontario Breast Screening Program. Can J Public Health. Revue Canadienne de Sante Publique. 2005;96(4):259-63. Exclusion: wrong comparison. [pmid: 16625791].
Chiarelli AM, Prummel MV, Muradali D, et al. Effectiveness of screening with annual magnetic resonance imaging and mammography: results of the initial screen from the ontario high risk breast screening program. J Clin Oncol. 2014;32(21):2224-30. Exclusion: wrong population. [pmid: 24934793].
Chida K, Komatsu Y, Sai M, et al. Reduced compression mammography to reduce breast pain. Clin Imaging. 2009;33(1):7-10. Exclusion: wrong outcomes. [pmid: 19135922].
Chiu C, Morrell S, Page A, et al. Population-based mammography screening and breast cancer incidence in New South Wales, Australia. Cancer Causes Control. 2006;17(2):153-60. Exclusion: wrong outcomes. [pmid: 16425093].
Chlebowski RT. Nutrition and physical activity influence on breast cancer incidence and outcome. Breast. Suppl 2. 2013;22:S30-7. Exclusion: wrong publication type. [pmid: 24074789].
Chlebowski RT, Anderson G, Manson JE, et al. Estrogen alone in postmenopausal women and breast cancer detection by means of mammography and breast biopsy. J Clin Oncol. 2010;28(16):2690-7. Exclusion: wrong intervention. [pmid: 20439627].
Chlebowski RT, Anderson G, Pettinger M, et al. Estrogen plus progestin and breast cancer detection by means of mammography and breast biopsy. Arch Intern Med. 2008;168(4):370-7. quiz 45. Exclusion: wrong intervention. [pmid: 18299491].
Chlebowski RT, Anderson GL. The influence of time from menopause and mammography on hormone therapy-related breast cancer risk assessment. J Natl Cancer Inst. 2011;103(4):284-5. Exclusion: wrong publication type. [pmid: 21278357].
Chlebowski RT, Hendrix SL, Langer RD, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women's Health Initiative Randomized Trial. JAMA. 2003;289(24):3243-53. Exclusion: wrong intervention. [pmid: 12824205].
Chlebowski RT, Johnson KC, Kooperberg C, et al. Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. 2008;100(22):1581-91. Exclusion: wrong intervention. [pmid: 19001601].
Chlebowski RT, Kuller LH, Prentice RL, et al. Breast cancer after use of estrogen plus progestin in postmenopausal women. N Engl J Med. 2009;360(6):573-87. Exclusion: wrong outcomes. [pmid: 19196674].
Cho N, Kim SJ, Choi HY, et al. Features of prospectively overlooked computer-aided detection marks on prior screening digital mammograms in women with breast cancer. AJR Am J Roentgenol. 2010;195(5):1276-82. Exclusion: wrong intervention. [pmid: 20966340].
Cho N, Moon WK, Cha JH, et al. Differentiating benign from malignant solid breast masses: comparison of two-dimensional and three-dimensional US. Radiology. 2006;240(1):26-32. Exclusion: wrong outcomes. [pmid: 16684920].
Chou C-P, Pan H-B, Hsu G-C, et al. Assessing the first 3 years of Taiwan's nationwide population-based mammography screening program. Breast J. 2012;18(5):498-9. Exclusion: wrong publication type. [pmid: 22897616].
Christensen LH, Engholm G, Cortes R, et al. Reduced mortality for women with mammography-detected breast cancer in east Denmark and south Sweden. Eur J Cancer. 2006;42(16):2773-80. Exclusion: wrong comparison. [pmid: 16989996].
Christiansen CL, Wang F, Barton MB, et al. Predicting the cumulative risk of false-positive mammograms. J Natl Cancer Inst. 2000;92(20):1657-66. Exclusion: studies outside of search dates. [pmid: 11036111].
Chu KC, Tarone RE, Kessler LG, et al. Recent trends in U.S. breast cancer incidence, survival, and mortality rates. J Natl Cancer Inst. 1996;88(21):1571-9. Exclusion: wrong outcomes. [pmid: 8901855].
Chuwa EWL, Yeo AWY, Koong HN, et al. Early detection of breast cancer through population-based mammographic screening in Asian women: a comparison study between screen-detected and symptomatic breast cancers. Breast J. 2009;15(2):133-9. Exclusion: wrong population. [pmid: 19292798].
Ciatto S. Recommending mammography screening beyond 80 years of age: a time for caution. Womens Health (Lond Engl). 2008;4(4):333-5. Exclusion: wrong publication type. [pmid: 19072499].
Ciatto S, Ambrogetti D, Collini G, et al. Computer-aided detection (CAD) of cancers detected on double reading by one reader only. Breast. 2006;15(4):528-32. Exclusion: wrong intervention. [pmid: 16236517].
Ciatto S, Bernardi D, Pellegrini M, et al. Proportional incidence and radiological review of large (T2+) breast cancers as surrogate indicators of screening programme performance. Eur Radiol. 2012;22(6):1250-4. Exclusion: wrong outcomes. [pmid: 22200899].
Ciatto S, Catarzi S, Lamberini MP, et al. Interval breast cancers in screening: the effect of mammography review method on classification. Breast. 2007;16(6):646-52. Exclusion: wrong intervention. [pmid: 17624779].
Ciatto S, Houssami N, Ambrogetti D, et al. Minority report - false negative breast assessment in women recalled for suspicious screening mammography: imaging and pathological features, and associated delay in diagnosis. Breast Cancer Res Treat. 2007;105(1):37-43. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 17115112].
Ciatto S, Houssami N, Apruzzese A, et al. Reader variability in reporting breast imaging according to BI-RADS assessment categories (the Florence experience). Breast. 2006;15(1):44-51. Exclusion: wrong outcomes. [pmid: 16076556].
Ciatto S, Visioli C, Paci E, et al. Breast density as a determinant of interval cancer at mammographic screening. Br J Cancer. 2004;90(2):393-6. Exclusion: wrong comparison. [pmid: 14735182].
Clark R. Re: Accuracy of screening mammography interpretation by characteristics of radiologists. J Natl Cancer Inst. 2005;97(12):936. Exclusion: wrong publication type. [pmid: 15956657].
Coates RJ, Uhler RJ, Brogan DJ, et al. Patterns and predictors of the breast cancer detection methods in women under 45 years of age (United States). Cancer Causes Control. 2001;12(5):431-42. Exclusion: wrong population. [pmid: 11545458].
Coates RJ, Uhler RJ, Hall HI, et al. Risk of breast cancer in young women in relation to body size and weight gain in adolescence and early adulthood. Br J Cancer. 1999;81(1):167-74. Exclusion: wrong population. [pmid: 10487629].
Coburn NG, Chung MA, Fulton J, et al. Decreased breast cancer tumor size, stage, and mortality in Rhode Island: an example of a well-screened population. Cancer Control. 2004;11(4):222-30. Exclusion: wrong study design for key question. [pmid: 15284713].
Cockburn J, De Luise T, Hurley S, et al. Development and validation of the PCQ: A questionnaire to measure the psychological consequences of screening mammography. Social Science and Medicine. 1992;34(10):1129-34. Exclusion: included in an included systematic review, not directly used. [pmid: 1641674].
Cockburn J, Staples M, Hurley SF, et al. Psychological consequences of screening mammography. J Med Screen. 1994;1(1):7-12. Exclusion: studies outside of search dates. [pmid: 8790480].
Cockburn J, Staples M, Hurley SF, et al. Psychological consequences of screening mammography. J Med Screen. 1994;1(1):7-12. Exclusion: included in an included systematic review, not directly used. [pmid: 8790480].
Codd MB, Buttimer J, Comber H, et al. Mortality from breast cancer in Ireland prior to the introduction of population-based mammographic screening. Ir J Med Sci. 1999;168(2):87-92. Exclusion: wrong outcomes. [pmid: 10422384].
Cohen MM, Kaufert PA, MacWilliam L, et al. Using an alternative data source to examine randomization in the Canadian National Breast Screening Study. J Clin Epidemiol. 1996;49(9):1039-44. Exclusion: studies outside of search dates. [pmid: 8780614].
Coldman A, Phillips N. Population studies of the effectiveness of mammographic screening. Prev Med. 2011;53(3):115-7. Exclusion: review not meeting inclusion criteria. [pmid: 21798279].
Coldman A, Phillips N, Warren L, et al. Breast cancer mortality after screening mammography in British Columbia women. Int J Cancer. 2007;120(5):1076-80. Exclusion: wrong comparison. [pmid: 17149701].
Coldman AJ, Major D, Doyle GP, et al. Organized breast screening programs in Canada: effect of radiologist reading volumes on outcomes. Radiology. 2006;238(3):809-15. Exclusion: wrong outcomes. [pmid: 16424236].
Coldman AJ, Phillips N. Breast cancer survival and prognosis by screening history. Br J Cancer. 2014;110(3):556-9. Exclusion: wrong intervention. [pmid: 24300976].
Coldman AJ, Phillips N. False-positive screening mammograms and biopsies among women participating in a Canadian provincial breast screening program. Can J Public Health. Revue Canadienne de Sante Publique. 2012;103(6):e420-4. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 23618020].
Coldman AJ, Phillips N, Speers C. A retrospective study of the effect of participation in screening mammography on the use of chemotherapy and breast conserving surgery. Int J Cancer. 2007;120(10):2185-90. Exclusion: wrong population. [pmid: 17290404].
Cole EB, Toledano AY, Lundqvist M, et al. Comparison of radiologist performance with photon-counting full-field digital mammography to conventional full-field digital mammography. Acad Radiol. 2012;19(8):916-22. Exclusion: wrong outcomes. [pmid: 22537503].
Cole EB, Zhang Z, Marques HS, et al. Assessing the stand-alone sensitivity of computer-aided detection with cancer cases from the Digital Mammographic Imaging Screening Trial. AJR Am J Roentgenol. 2012;199(3):W392-401. Exclusion: wrong intervention. [pmid: 22915432].
Collins S, Woodman CB, Threlfall A, et al. Survival rates from interval cancer in NHS breast screening programme. BMJ. 1998;316(7134):832-3. Exclusion: wrong publication type. [pmid: 9549455].
Cong XJ, Shen Y, Miller AB. Estimation of age-specific sensitivity and sojourn time in breast cancer screening studies. Stat Med. 2005;24(20):3123-38. Exclusion: wrong study design for key question. [pmid: 15977269].
Conner P. Breast response to menopausal hormone therapy--aspects on proliferation, apoptosis and mammographic density. Ann Med. 2007;39(1):28-41. Exclusion: review not meeting inclusion criteria. [pmid: 17364449].
Consedine NS. A false-positive on screening mammography has a negative psychosocial impact up to 3 years after receiving the all clear. Evid Based Ment Health. 2013;16(4):115. Exclusion: wrong publication type. [pmid: 23852830].
Cook AJ, Elmore JG, Miglioretti DL, et al. Decreased accuracy in interpretation of community-based screening mammography for women with multiple clinical risk factors. J Clin Epidemiol. 2010;63(4):441-51. Exclusion: wrong outcomes. [pmid: 19744825].
Cooper GS, Yuan Z, Bowlin SJ, et al. An ecological study of the effectiveness of mammography in reducing breast cancer mortality. Am J Public Health. 1998;88(2):281-4. Exclusion: wrong study design for key question. [pmid: 9491023].
Cooper GS, Yuan Z, Jethva RN, et al. Use of Medicare claims data to measure county-level variation in breast carcinoma incidence and mammography rates. Cancer Detect Prev. 2002;26(3):197-202. Exclusion: wrong study design for key question. [pmid: 12269766].
Cornford E, Reed J, Murphy A, et al. Optimal screening mammography reading volumes; evidence from real life in the East Midlands region of the NHS Breast Screening Programme. Clin Radiol. 2011;66(2):103-7. Exclusion: wrong outcomes. [pmid: 21216324].
Cornford EJ, Evans AJ, James JJ, et al. The pathological and radiological features of screen-detected breast cancers diagnosed following arbitration of discordant double reading opinions. Clin Radiol. 2005;60(11):1182-7. Exclusion: wrong comparison. [pmid: 16223614].
Corsetti V, Ferrari A, Ghirardi M, et al. Role of ultrasonography in detecting mammographically occult breast carcinoma in women with dense breasts. Radiol Med (Torino). 2006;111(3):440-8. Exclusion: studies outside of search dates. [pmid: 16683089].
Corsetti V, Houssami N, Ferrari A, et al. Breast screening with ultrasound in women with mammography-negative dense breasts: evidence on incremental cancer detection and false positives, and associated cost. Eur J Cancer. 2008;44(4):539-44. Exclusion: wrong comparison. [pmid: 18267357].
Corsetti V, Houssami N, Ghirardi M, et al. Evidence of the effect of adjunct ultrasound screening in women with mammography-negative dense breasts: interval breast cancers at 1 year follow-up. Eur J Cancer. 2011;47(7):1021-6. Exclusion: wrong comparison. [pmid: 21211962].
Couto E, Banks E, Reeves G, et al. Family history and breast cancer tumour characteristics in screened women. Int J Cancer. 2008;123(12):2950-4. Exclusion: wrong study design for key question. [pmid: 18816631].
Cowan WK, Angus B, Gray JC, et al. A study of interval breast cancer within the NHS breast screening programme. J Clin Pathol. 2000;53(2):140-6. Exclusion: wrong outcomes. [pmid: 10767831].
Cowan WK, Kelly P, Sawan A, et al. The pathological and biological nature of screen-detected breast carcinomas: a morphological and immunohistochemical study. J Pathol. 1997;182(1):29-35. Exclusion: wrong comparison. [pmid: 9227339].
Cox B. The effect of service screening on breast cancer mortality rates. Eur J Cancer Prev. 2008;17(4):306-11. Exclusion: wrong study design for key question. [pmid: 18562953].
Cox B. Variation in the effectiveness of breast screening by year of follow-up. J Natl Cancer Inst. Monographs. 1997;(22):69-72. Exclusion: review not meeting inclusion criteria.
Crawford MD, Biankin AV, Rickard MT, et al. The operative management of screen-detected breast cancers. Aust N Z J Surg. 2000;70(3):168-73. Exclusion: wrong comparison. [pmid: 10765897].
Crispo A, Barba M, D'Aiuto G, et al. Molecular profiles of screen detected vs. symptomatic breast cancer and their impact on survival: results from a clinical series. BMC Cancer. 2013;13:15. Exclusion: wrong outcomes. [pmid: 23305429].
Crocetti E, Buzzoni C, Falcini F, et al. Disentangling the roles of mammographic screening and HRT in recent breast cancer incidence trends in italy by analyses based on calendar time and time since screening activation. Breast J. 2010;16(4):350-5. Exclusion: wrong outcomes. [pmid: 20443789].
Cronin KA, Yu B, Krapcho M, et al. Modeling the dissemination of mammography in the United States. Cancer Causes Control. 2005;16(6):701-12. Exclusion: wrong study design for key question. [pmid: 16049809].
Crosignani PG, Rubin BL. Screening before and during the use of oral contraceptives and hormone replacement therapy. The ESHRE Capri Workshop Group. Hum Reprod. 2000;15(2):485-92. Exclusion: wrong publication type. [pmid: 10655328].
Crouchley K, Wylie E, Khong E. Hormone replacement therapy and mammographic screening outcomes in Western Australia. J Med Screen. 2006;13(2):93-7. Exclusion: wrong comparison. [pmid: 16792833].
Crump SR, Shipp MP, McCray GG, et al. Abnormal mammogram follow-up: do community lay health advocates make a difference?. Health Promot Pract. 2008;9(2):140-8. Exclusion: wrong intervention. [pmid: 18340089].
Crystal P, Strano SD, Shcharynski S, et al. Using sonography to screen women with mammographically dense breasts. AJR Am J Roentgenol. 2003;181(1):177-82. Exclusion: wrong population. [pmid: 12818853].
Cui Y, Whiteman MK, Flaws JA, et al. Body mass and stage of breast cancer at diagnosis. Int J Cancer. 2002;98(2):279-83. Exclusion: wrong study design for key question. [pmid: 11857420].
Cunningham JE, Walters CA, Hill EG, et al. Mind the gap: racial differences in breast cancer incidence and biologic phenotype, but not stage, among low-income women participating in a government-funded screening program. Breast Cancer Res Treat. 2013;137(2):589-98. Exclusion: wrong intervention. [pmid: 23239148].
Cupples TE, Cunningham JE, Reynolds JC. Impact of computer-aided detection in a regional screening mammography program. AJR Am J Roentgenol. 2005;185(4):944-50. Exclusion: wrong intervention. [pmid: 16177413].
Cust AE, Stocks T, Lukanova A, et al. The influence of overweight and insulin resistance on breast cancer risk and tumour stage at diagnosis: a prospective study. Breast Cancer Res Treat. 2009;113(3):567-76. Exclusion: wrong outcomes. [pmid: 18330696].
Cuthbertson SA, Goyder EC, Poole J. Inequalities in breast cancer stage at diagnosis in the Trent region, and implications for the NHS Breast Screening Programme. J Public Health (Oxf). 2009;31(3):398-405. Exclusion: wrong study design for key question. [pmid: 19423544].
Cutler WB, Burki RE, Kolter J, et al. Mammography for symptomless women--not so wise?. Climacteric. 2013;16(3):313-5. Exclusion: wrong publication type. [pmid: 23425505].
Cuzick J, Warwick J, Pinney E, et al. Tamoxifen and breast density in women at increased risk of breast cancer. J Natl Cancer Inst. 2004;96(8):621-8. Exclusion: wrong intervention. [pmid: 15100340].
Dahlui M, Gan DEH, Taib NA, et al. Predictors of breast cancer screening uptake: a pre intervention community survey in Malaysia. Asian Pac J Cancer Prev. 2012;13(7):3443-9. Exclusion: wrong outcomes. [pmid: 22994775].
Dai Q, Shu XO, Jin F, et al. Population-based case-control study of soyfood intake and breast cancer risk in Shanghai. Br J Cancer. 2001;85(3):372-8. Exclusion: wrong outcomes. [pmid: 11487268].
Dale PS, Richards M, Mackie GC. Vascular calcifications on screening mammography identify women with increased risk of coronary artery disease and diabetes. Am J Surg. 2008;196(4):537-40. Exclusion: wrong outcomes. [pmid: 18809058].
Danigelis NL, Worden JK, Flynn BS, et al. Increasing mammography screening among low-income African American women with limited access to health information. Prev Med. 2005;40(6):880-7. Exclusion: wrong outcomes. [pmid: 15850891].
Das B, Feuer EJ, Mariotto A. Geographic association between mammography use and mortality reduction in the US. Cancer Causes Control. 2005;16(6):691-9. Exclusion: wrong outcomes. [pmid: 16049808].
Davidson AS, Liao X, Magee BD. Attitudes of women in their forties toward the 2009 USPSTF mammogram guidelines: a randomized trial on the effects of media exposure. Am J Obstet Gynecol. 2011;205(1):30.e1-7. Exclusion: wrong outcomes. [pmid: 22088897].
Davis TC, Arnold C, Berkel HJ, et al. Knowledge and attitude on screening mammography among low-literate, low-income women. Cancer. 1996;78(9):1912-20. Exclusion: studies outside of search dates. [pmid: 8909311].
Day N, McCann J, Camilleri-Ferrante C, et al. Monitoring interval cancers in breast screening programmes: the east Anglian experience. Quality Assurance Management Group of the East Anglian Breast Screening Programme. J Med Screen. 1995;2(4):180-5. Exclusion: wrong outcomes. [pmid: 8719145].
Day N, Warren R. Mammographic screening and mammographic patterns. Breast Cancer Res. 2000;2(4):247-51. Exclusion: wrong publication type. [pmid: 11250716].
Day NE. Overdiagnosis and breast cancer screening. Breast Cancer Res. 2005;7(5):228-9. Exclusion: wrong publication type. [pmid: 16168144].
de Gelder R, Bulliard J-L, de Wolf C, et al. Cost-effectiveness of opportunistic versus organised mammography screening in Switzerland. Eur J Cancer. 2009;45(1):127-38. Exclusion: wrong outcomes. [pmid: 19038540].
de Gelder R, Draisma G, Heijnsdijk EAM, et al. Population-based mammography screening below age 50: balancing radiation-induced vs prevented breast cancer deaths. Br J Cancer. 2011;104(7):1214-20. Exclusion: wrong outcomes. [pmid: 21364575].
de Gelder R, van As E, Tilanus-Linthorst MMA, et al. Breast cancer screening: evidence for false reassurance?. Int J Cancer. 2008;123(3):680-6. Exclusion: studies outside of search dates. [pmid: 18484587].
de Glas NA, de Craen AJ, Bastiaannet E, et al. Effect of implementation of the mass breast cancer screening programme in older women in the Netherlands: population based study. BMJ. 2014;349:g5410. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 25224469].
de Koning HJ. Mammographic screening: evidence from randomised controlled trials. Ann Oncol. 2003;14(8):1185-9. Exclusion: review not meeting inclusion criteria. [pmid: 12881373].
de Koning HJ. Why improvement in survival of screen-detected cases is not necessarily equivalent to benefit?. Breast. 2003;12(5):299-301. Exclusion: wrong publication type. [pmid: 14659143].
De P, Neutel CI, Olivotto I, et al. Breast cancer incidence and hormone replacement therapy in Canada. J Natl Cancer Inst. 2010;102(19):1489-95. Exclusion: wrong comparison. [pmid: 20864685].
Dean JC, Ilvento CC. Improved cancer detection using computer-aided detection with diagnostic and screening mammography: prospective study of 104 cancers. AJR Am J Roentgenol. 2006;187(1):20-8. Exclusion: wrong intervention. [pmid: 16794150].
Dean PB. Comments and response on the USPSTF recommendation on screening for breast cancer. Ann Intern Med. 2010;152(8):539. author reply 43-4. Exclusion: wrong publication type. [pmid: 20157108].
Dean PB. The rationale and current controversies of mammographic screening for breast cancer. Scand J Surg. 2002;91(3):288-92. Exclusion: wrong publication type. [pmid: 12449473].
Dee KE, Sickles EA. Medical audit of diagnostic mammography examinations: comparison with screening outcomes obtained concurrently. AJR Am J Roentgenol. 2001;176(3):729-33. Exclusion: wrong comparison. [pmid: 11222214].
DeFrank JT, Rimer BK, Bowling JM, et al. Influence of false-positive mammography results on subsequent screening: do physician recommendations buffer negative effects?. J Med Screen. 2012;19(1):35-41. Exclusion: wrong comparison. [pmid: 22438505].
Deglise C, Bouchardy C, Burri M, et al. Impact of obesity on diagnosis and treatment of breast cancer. Breast Cancer Res Treat. 2010;120(1):185-93. Exclusion: wrong comparison. [pmid: 19597985].
del Carmen MG, Hughes KS, Halpern E, et al. Racial differences in mammographic breast density. Cancer. 2003;98(3):590-6. Exclusion: wrong outcomes. [pmid: 12879477].
Del Maschio A, Bazzocchi M, Giuseppetti GM, et al. Breast MRI: report on a multicentric national trial by the Study Section of Magnetic Resonance and Breast Imaging. Radiol Med (Torino). 2002;104(4):262-72. Exclusion: wrong publication type. [pmid: 12569307].
Del Turco MR. A critical review of screening for breast cancer. Recent Results Cancer Res. 1996;140:123-30. Exclusion: wrong publication type. [pmid: 8787055].
Del Turco MR, Mantellini P, Ciatto S, et al. Full-field digital versus screen-film mammography: comparative accuracy in concurrent screening cohorts. AJR Am J Roentgenol. 2007;189(4):860-6. Exclusion: wrong comparison. [pmid: 17885057].
Demicheli R, Bonadonna G, Hrushesky WJM, et al. Menopausal status dependence of early mortality reduction due to diagnosis of smaller breast cancers (T1 v T2-T3): relevance to screening. J Clin Oncol. 2004;22(1):102-7. Exclusion: wrong population. [pmid: 14701771].
Demirci S, Nam J, Hubbs JL, et al. Radiation-induced cardiac toxicity after therapy for breast cancer: interaction between treatment era and follow-up duration. Int J Radiat Oncol Biol Phys. 2009;73(4):980-7. Exclusion: wrong population. [pmid: 19251085].
den Heijer M, Seynaeve C, Vanheusden K, et al. Long-term psychological distress in women at risk for hereditary breast cancer adhering to regular surveillance: a risk profile. Psychooncology. 2013;22(3):598-604. Exclusion: wrong population. [pmid: 22315183].
Dershaw DD. Status of mammography after the Digital Mammography Imaging Screening Trial: digital versus film. Breast J. 2006;12(2):99-102. Exclusion: wrong publication type. [pmid: 16509833].
Destounis S, Hanson S, Morgan R, et al. Computer-aided detection of breast carcinoma in standard mammographic projections with digital mammography. Int J Comput Assist Radiol Surg. 2009;4(4):331-6. Exclusion: wrong outcomes. [pmid: 20033580].
Destounis SV, Arieno AL, Morgan RC, et al. Comparison of breast cancers diagnosed in screening patients in their 40s with and without family history of breast cancer in a community outpatient facility. AJR American Journal of Roentgenology. 2014;202(4):928-32. Exclusion: wrong comparison. [pmid: 24660726].
Destounis SV, DiNitto P, Logan-Young W, et al. Can computer-aided detection with double reading of screening mammograms help decrease the false-negative rate? Initial experience. Radiology. 2004;232(2):578-84. Exclusion: wrong intervention. [pmid: 15229350].
Deurloo EE, Muller SH, Peterse JL, et al. Clinically and mammographically occult breast lesions on MR images: potential effect of computerized assessment on clinical reading. Radiology. 2005;234(3):693-701. Exclusion: wrong outcomes. [pmid: 15650040].
Devita VT Jr. Breast cancer screening and mortality. Nat Rev Clin Oncol. 2010;7(2):65. Exclusion: wrong publication type. [pmid: 20118972].
Dibble SL, Israel J, Nussey B, et al. Mammography with breast cushions. Womens Health Issues. 2005;15(2):55-63. Exclusion: wrong intervention. [pmid: 15767195].
Dibble SL, Israel J, Nussey B, et al. Mammography with breast cushions. Women's Health Issues. 2005;15(2):55-63. Exclusion: included in an included systematic review, not directly used. [pmid: 15767195].
Dietzel M, Baltzer PAT, Hopp T, et al. Co-registration of MR-mammography and X-ray mammography. Eur J Radiol. Suppl 1. 2012;81:S27-9. Exclusion: wrong population. [pmid: 23083591].
Dietzel M, Baltzer PAT, Schon K, et al. MR-mammography: high sensitivity but low specificity? New thoughts and fresh data on an old mantra. Eur J Radiol. Suppl 1. 2012;81:S30-2. Exclusion: wrong intervention. [pmid: 23083592].
Dinnes J, Moss S, Melia J, et al. Effectiveness and cost-effectiveness of double reading of mammograms in breast cancer screening: findings of a systematic review. Breast. 2001;10(6):455-63. Exclusion: wrong outcomes. [pmid: 14965624].
Dinshaw K, Mishra G, Shastri S, et al. Determinants of compliance in a cluster randomised controlled trial on screening of breast and cervix cancer in Mumbai, India. 1. Compliance to screening. Oncology. 2007;73(3-4):145-53. Exclusion: wrong outcomes. [pmid: 18408401].
Dinshaw K, Mishra G, Shastri S, et al. Determinants of compliance in a cluster randomised controlled trial on screening of breast and cervix cancer in mumbai, India. 2. Compliance to referral and treatment. Oncology. 2007;73(3-4):154-61. Exclusion: wrong outcomes. [pmid: 18408402].
Diratzouian H, Freedman GM, Hanlon AL, et al. Importance of physical examination in the absence of a mammographic abnormality for the detection of early-stage breast cancer. Clin Breast Cancer. 2005;6(4):330-3. Exclusion: wrong population. [pmid: 16277883].
Dissemination CfRa. Breast cancer diagnosis by scintimammography: a meta-analysis and review of the literature. (Structured abstract). Database of Abstracts of Reviews of Effects. 2014;(1). Exclusion: wrong publication type.
Dissemination CfRa. Computer-aided detection (CAD) in mammography. (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014;(1). Exclusion: wrong intervention.
Dissemination CfRa. The early detection and diagnosis of breast cancer: a literature review. An update. (Structured abstract). Database of Abstracts of Reviews of Effects. 2014;(1). Exclusion: wrong publication type.
Dissemination CfRa. Positron emission tomography: systematic review. PET as a diagnostic test in breast cancer. (Structured abstract). Database of Abstracts of Reviews of Effects. 2014;(1). Exclusion: wrong publication type.
Dixon JM, Ravisekar O, Cunningham M, et al. Factors affecting outcome of patients with impalpable breast cancer detected by breast screening. Br J Surg. 1996;83(7):997-1001. Exclusion: wrong population. [pmid: 8813799].
Djulbegovic B, Hozo I, Lyman GH. Estimating net benefits and harms of screening mammography in women age 40 to 49 years. Ann Intern Med. 2007;147(12):882. Exclusion: wrong publication type. [pmid: 18087062].
Dobson R. Advanced breast cancer more common in area with low uptake of screening. BMJ. 2003;327(7406):72. Exclusion: wrong publication type. [pmid: 12855515].
Dogan L, Kalaylioglu Z, Karaman N, et al. Relationships between epidemiological features and tumor characteristics of breast cancer. Asian Pac J Cancer Prev. 2011;12(12):3375-80. Exclusion: wrong intervention. [pmid: 22471484].
Domingo L, Jacobsen KK, von Euler-Chelpin M, et al. Seventeen-years overview of breast cancer inside and outside screening in Denmark. Acta Oncol. 2013;52(1):48-56. Exclusion: wrong outcomes. [pmid: 22943386].
Domingo L, Romero A, Belvis F, et al. Differences in radiological patterns, tumour characteristics and diagnostic precision between digital mammography and screen-film mammography in four breast cancer screening programmes in Spain. Eur Radiol. 2011;21(9):2020-8. Exclusion: wrong outcomes. [pmid: 21560024].
Domingo L, Romero A, Blanch J, et al. Clinical and radiological features of breast tumors according to history of false-positive results in mammography screening. Cancer epidemiol. 2013;37(5):660-5. Exclusion: wrong outcomes. [pmid: 23962702].
Domingo L, Sala M, Servitja S, et al. Phenotypic characterization and risk factors for interval breast cancers in a population-based breast cancer screening program in Barcelona, Spain. Cancer Causes Control. 2010;21(8):1155-64. Exclusion: wrong outcomes. [pmid: 20349271].
Donnelly J. Breast lump detection: who is more accurate, patients or their GPs?. Int J Clin Pract. 2010;64(4):439-41. Exclusion: wrong intervention. [pmid: 20015214].
Doorenbos AZ, Jacobsen C, Corpuz R, et al. A randomized controlled calendar mail-out to increase cancer screening among urban American Indian and Alaska Native patients. J Cancer Educ. 2011;26(3):549-54. Exclusion: wrong intervention. [pmid: 21472495].
Dorrius MD, Jansen-van der Weide MC, van Ooijen PMA, et al. Computer-aided detection in breast MRI: a systematic review and meta-analysis. Eur Radiol. 2011;21(8):1600-8. Exclusion: wrong outcomes. [pmid: 21404134].
Dorum A, Heimdal K, Lovslett K, et al. Prospectively detected cancer in familial breast/ovarian cancer screening. Acta Obstet Gynecol Scand. 1999;78(10):906-11. Exclusion: wrong comparison. [pmid: 10577622].
Douek M, Davidson T, Taylor I. Breast cancer imaging--what are the optimal modalities?. Eur J Surg Oncol. 1998;24(6):573-82. Exclusion: review not meeting inclusion criteria. [pmid: 9870737].
Douek M, Tobias J. How reliable is MRI for predicting extent of residual breast cancer with different primary medical therapies?. Nat Clin Pract Oncol. 2005;2(3):128-9. Exclusion: wrong population. [pmid: 16264902].
Doyle TC, Elwood JM, Smale P, et al. Clinical outcomes of the Otago-Southland Breast Cancer Screening Programme 1991-1996. N Z Med J. 1998;111(1075):380-3. Exclusion: wrong comparison. [pmid: 9830418].
Driul L, Bernardi S, Bertozzi S, et al. New surgical trends in breast cancer treatment: conservative interventions and oncoplastic breast surgery. Minerva Ginecol. 2013;65(3):289-96. Exclusion: wrong outcomes. [pmid: 23689171].
Drossaert CHC, Boer H, Seydel ER. Does mammographic screening and a negative result affect attitudes towards future breast screening?. J Med Screen. 2001;8(4):204-12. Exclusion: studies outside of search dates. [pmid: 11743037].
Drossaert CHC, Boer H, Seydel ER. Does mammographic screening and a negative result affect attitudes towards future breast screening?. J Med Screen. 2001;8(4):204-12. Exclusion: included in an included systematic review, not directly used. [pmid: 11743037].
Drossaert CHC, Boer H, Seydel ER. Health education to improve repeat participation in the Dutch breast cancer screening programme: Evaluation of a leaflet tailored to previous participants. Patient Educ Couns. 1996;28(2):121-31. Exclusion: included in an included systematic review, not directly used. [pmid: 8852086].
Drossaert CHC, Boer H, Seydel ER. Monitoring women's experiences during three rounds of breast cancer screening: Results from a longitudinal study. J Med Screen. 2002;9(4):168-75. Exclusion: included in an included systematic review, not directly used. [pmid: 12518007].
Drukker K, Giger ML, Horsch K, et al. Computerized lesion detection on breast ultrasound. Med Phys. 2002;29(7):1438-46. Exclusion: wrong outcomes. [pmid: 12148724].
Drukker K, Giger ML, Mendelson EB. Computerized analysis of shadowing on breast ultrasound for improved lesion detection. Med Phys. 2003;30(7):1833-42. Exclusion: wrong outcomes. [pmid: 12906202].
Drukker K, Gruszauskas NP, Sennett CA, et al. Breast US computer-aided diagnosis workstation: performance with a large clinical diagnostic population. Radiology. 2008;248(2):392-7. Exclusion: wrong intervention. [pmid: 18574139].
Drukker K, Horsch KJ, Pesce LL, et al. Interreader scoring variability in an observer study using dual-modality imaging for breast cancer detection in women with dense breasts. Acad Radiol. 2013;20(7):847-53. Exclusion: wrong outcomes. [pmid: 23601952].
Drukker K, Sennett CA, Giger ML. Computerized detection of breast cancer on automated breast ultrasound imaging of women with dense breasts. Med Phys. 2014;41(1):012901. Exclusion: wrong outcomes. [pmid: 24387528].
Drukteinis JS, Mooney BP, Flowers CI, et al. Beyond mammography: new frontiers in breast cancer screening. Am J Med. 2013;126(6):472-9. Exclusion: wrong publication type. [pmid: 23561631].
DuBard CA, Schmid D, Yow A, et al. Recommendation for and receipt of cancer screenings among medicaid recipients 50 years and older. Arch Intern Med. 2008;168(18):2014-21. Exclusion: wrong outcomes. [pmid: 18852404].
Duffy S, Blamey RW. The UKCCCR trial of the frequency of breast cancer screening. [abstract]. Eur J Cancer. 2003;1(46). Exclusion: wrong publication type.
Duffy SW. Lymph node status in screen-detected cancers. Br J Cancer. 2005;92(1):3-4. Exclusion: wrong publication type. [pmid: 15702074].
Duffy SW. Some current issues in breast cancer screening. J Med Screen. 2005;12(3):128-33. Exclusion: wrong publication type. [pmid: 16156943].
Duffy SW, Chen HH, Tabár L, et al. Sojourn time, sensitivity and positive predictive value of mammography screening for breast cancer in women aged 40-49. Int J Epidemiol. 1996;25(6):1139-45. Exclusion: wrong outcomes. [pmid: 9027517].
Duffy SW, Lynge E, Jonsson H, et al. Complexities in the estimation of overdiagnosis in breast cancer screening. Br J Cancer. 2008;99(7):1176-8. Exclusion: wrong study design for key question. [pmid: 18766185].
Duffy SW, Mackay J, Thomas S, et al. Evaluation of mammographic surveillance services in women aged 40-49 years with a moderate family history of breast cancer: a single-arm cohort study. Health Technol Assess. 2013;17(11):vii-xiv. 1. 95. Exclusion: wrong intervention. [pmid: 23489892].
Duffy SW, Michalopoulos D, Sebuodegard S, et al. Trends in aggregate cancer incidence rates in relation to screening and possible overdiagnosis: a word of caution. J Med Screen. 2014;21(1):24-9. Exclusion: wrong outcomes. [pmid: 24446330].
Duffy SW, Nagtegaal ID, Wallis M, et al. Correcting for lead time and length bias in estimating the effect of screen detection on cancer survival. Am J Epidemiol. 2008;168(1):98-104. Exclusion: wrong study design for key question. [pmid: 18504245].
Duffy SW, Sasieni P, Olsen AH, et al. Modelling the likely effect of the increase of the upper age limit from 70 to 73 for breast screening in the UK National Programme. Stat Methods Med Res. 2010;19(5):547-55. Exclusion: wrong study design for key question. [pmid: 20130109].
Duffy SW, Smith RA, Gabe R, et al. Screening for breast cancer. Surg Oncol Clin N Am. 2005;14(4):671-97. Exclusion: review not meeting inclusion criteria. [pmid: 16226686].
Duffy SW, Smith RA, Tabár L. Re: Efficacy of breast cancer screening in the community according to risk level. J Natl Cancer Inst. 2005;97(22):1703. author reply -4. Exclusion: wrong publication type. [pmid: 16288125].
Duffy SW, Tabár L, Chen H-H, et al. The impact of organized mammography service screening on breast carcinoma mortality in seven Swedish counties. Cancer. 2002;95(3):458-69. Exclusion: wrong intervention. [pmid: 12209737].
Duffy SW, Tabár L, Vitak B, et al. The relative contributions of screen-detected in situ and invasive breast carcinomas in reducing mortality from the disease. Eur J Cancer. 2003;39(12):1755-60. Exclusion: wrong study design for key question. [pmid: 12888371].
Duffy SW, Tabár L, Vitak B, et al. Tumor size and breast cancer detection: what might be the effect of a less sensitive screening tool than mammography?. Breast J. Suppl 1. 2006;12:S91-5. Exclusion: wrong study design for key question. [pmid: 16430402].
Duffy SW, Yen AM-F, Chen TH-H, et al. Long-term benefits of breast screening. Breast Cancer Management. 2012;1(1):31-8. Exclusion: review not meeting inclusion criteria.
Duffy SW, M J, Thomas S, Anderson E, et al. Evaluation of mammographic surveillance services in women aged 40-49 years with a moderate family history of breast cancer: a single-arm cohort study. Health technology assessment (Winchester, England). 2013;17(11):vii-xiv. Exclusion: wrong comparison.
Duijm LEM, Groenewoud JH, de Koning HJ, et al. Delayed diagnosis of breast cancer in women recalled for suspicious screening mammography. Eur J Cancer. 2009;45(5):774-81. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 19046632].
Duijm LEM, Groenewoud JH, Fracheboud J, et al. Introduction of additional double reading of mammograms by radiographers: effects on a biennial screening programme outcome. Eur J Cancer. 2008;44(9):1223-8. Exclusion: wrong outcomes. [pmid: 18400488].
Duijm LEM, Groenewoud JH, Jansen FH, et al. Mammography screening in the Netherlands: delay in the diagnosis of breast cancer after breast cancer screening. Br J Cancer. 2004;91(10):1795-9. Exclusion: wrong comparison. [pmid: 15505630].
Duijm LEM, Groenewoud JH, Roumen RMH, et al. A decade of breast cancer screening in The Netherlands: trends in the preoperative diagnosis of breast cancer. Breast Cancer Res Treat. 2007;106(1):113-9. Exclusion: wrong outcomes. [pmid: 17219049].
Duijm LEM, Louwman MWJ, Groenewoud JH, et al. Inter-observer variability in mammography screening and effect of type and number of readers on screening outcome. Br J Cancer. 2009;100(6):901-7. Exclusion: wrong outcomes. [pmid: 19259088].
Dullum JR, Lewis EC, Mayer JA. Rates and correlates of discomfort associated with mammography. Radiology. 2000;214(2):547-52. Exclusion: included in an included systematic review, not directly used. [pmid: 10671609].
Dumane VA, Shankar PM, Piccoli CW, et al. Computer aided classification of masses in ultrasonic mammography. Med Phys. 2002;29(9):1968-73. Exclusion: wrong outcomes. [pmid: 12349916].
Dummin LJ, Cox M, Plant L. Prediction of breast tumor size by mammography and sonography--A breast screen experience. Breast. 2007;16(1):38-46. Exclusion: wrong outcomes. [pmid: 16846736].
Duncan AM. The role of nutrition in the prevention of breast cancer. AACN Clin Issues. 2004;15(1):119-35. Exclusion: review not meeting inclusion criteria. [pmid: 14767370].
Dunn NAM. Effect of false-positive screening mammograms on rescreening in Western Australia. Med J Aust. 2012;197(9):490-1. Exclusion: wrong publication type. [pmid: 23121577].
Duric N, Boyd N, Littrup P, et al. Breast density measurements with ultrasound tomography: a comparison with film and digital mammography. Med Phys. 2013;40(1):013501. Exclusion: wrong intervention. [pmid: 23298122].
Eddy DM, Hasselblad V, McGivney W, et al. The value of mammography screening in women under age 50 years. JAMA. 1988;259(10):1512-9. Exclusion: wrong study design for key question. [pmid: 3123720].
Edge SB. Advances in breast surgery, 2002-2012. J. 2013;11(1):53-9. Exclusion: review not meeting inclusion criteria.
Ei Khouli RH, Jacobs MA, Mezban SD, et al. Diffusion-weighted imaging improves the diagnostic accuracy of conventional 3.0-T breast MR imaging. Radiology. 2010;256(1):64-73. Exclusion: wrong outcomes. [pmid: 20574085].
Ekeberg Ø, Skjauff H, Kåresen R. Screening for breast cancer is associated with a low degree of psychological distress. Breast. 2001;10(1):20-4. Exclusion: included in an included systematic review, not directly used. [pmid: 14965553].
Ekeh AP, Alleyne RS, Duncan AO. Role of mammography in diagnosis of breast cancer in an inner-city hospital. J Natl Med Assoc. 2000;92(8):372-4. Exclusion: wrong comparison. [pmid: 10992681].
Ekwueme DU, Hall IJ, Richardson LC, et al. Estimating personal costs incurred by a woman participating in mammography screening in the National Breast and Cervical Cancer Early Detection Program. Cancer. 2008;113(3):592-601. Exclusion: wrong outcomes. [pmid: 18536027].
Elena PM, Nehmat H, Ermes M, et al. Quality of mammography screening in the Milan programme: evidence of improved sensitivity based on interval cancer proportional incidence and radiological review. Breast. 2009;18(3):208-10. Exclusion: wrong comparison. [pmid: 19359176].
Ellis RL, Meade AA, Mathiason MA, et al. Evaluation of computer-aided detection systems in the detection of small invasive breast carcinoma. Radiology. 2007;245(1):88-94. Exclusion: wrong intervention. [pmid: 17885183].
Ellman R, Angeli N, Christians A, et al. Psychiatric morbidity associated with screening for breast cancer. Br J Cancer. 1989;60(5):781-4. Exclusion: included in an included systematic review, not directly used. [pmid: 2803955].
Elmore JG, Carney PA. Does practice make perfect when interpreting mammography?. J Natl Cancer Inst. 2002;94(5):321-3. Exclusion: wrong publication type. [pmid: 11880465].
Elmore JG, Carney PA, Abraham LA, et al. The association between obesity and screening mammography accuracy. Arch Intern Med. 2004;164(10):1140-7. Exclusion: studies outside of search dates. [pmid: 15159273].
Elmore JG, Fletcher SW. Overdiagnosis in breast cancer screening: time to tackle an underappreciated harm. Ann Intern Med. 2012;156(7):536-7. Exclusion: wrong publication type. [pmid: 22473439].
Elmore JG, Fletcher SW. The risk of cancer risk prediction: “What is my risk of getting breast cancer”?. J Natl Cancer Inst. 2006;98(23):1673-5. Exclusion: wrong publication type. [pmid: 17148763].
Elmore JG, Jackson SL, Abraham L, et al. Variability in interpretive performance at screening mammography and radiologists' characteristics associated with accuracy. Radiology. 2009;253(3):641-51. Exclusion: wrong comparison. [pmid: 19864507].
Elmore JG, Reisch LM, Barton MB, et al. Efficacy of breast cancer screening in the community according to risk level. J Natl Cancer Inst. 2005;97(14):1035-43. Exclusion: wrong outcomes. [pmid: 16030301].
Elsamaloty H, Elzawawi MS, Mohammad S, et al. Increasing accuracy of detection of breast cancer with 3-T MRI. AJR Am J Roentgenol. 2009;192(4):1142-8. Exclusion: wrong population. [pmid: 19304726].
Elting LS, Cooksley CD, Bekele BN, et al. Mammography capacity impact on screening rates and breast cancer stage at diagnosis. Am J Prev Med. 2009;37(2):102-8. Exclusion: wrong outcomes. [pmid: 19524392].
Eltonsy NH, Tourassi GD, Fadeev A, et al. Significance of MPEG-7 textural features for improved mass detection in mammography. Conf Proc IEEE Eng Med Biol Soc. 2006;1:4779-82. Exclusion: wrong study design for key question. [pmid: 17946650].
Emaus M, V W, Bakker M, Monninkhof E, et al. Design of the DENSE trial: MRI as an additional screening modality to detect breast cancer in women aged 50-75 years with extremely dense breasts. Cancer Prev Res (Phila). 2012;5(11 SUPPL. 1). Oct 16 to Oct 19, 2012. Exclusion: wrong publication type.
Engelken F, Bremme R, Bick U, et al. Factors affecting the rate of false positive marks in CAD in full-field digital mammography. Eur J Radiol. 2012;81(8):e844-8. Exclusion: wrong study design for key question. [pmid: 22647420].
Engelman KK, Cupertino AP, Daley CM, et al. Engaging diverse underserved communities to bridge the mammography divide. BMC Public Health. 2011;11(47). Exclusion: wrong publication type.
Erbas B, Amos A, Fletcher A, et al. Incidence of invasive breast cancer and ductal carcinoma in situ in a screening program by age: should older women continue screening?. Cancer Epidemiol Biomarkers Prev. 2004;13(10):1569-73. Exclusion: wrong study design for key question. [pmid: 15466971].
Erbas B, Provenzano E, Armes J, et al. The natural history of ductal carcinoma in situ of the breast: a review. Breast Cancer Res Treat. 2006;97(2):135-44. Exclusion: wrong study design for key question. [pmid: 16319971].
Eriksson L, Czene K, Rosenberg L, et al. The influence of mammographic density on breast tumor characteristics. Breast Cancer Res Treat. 2012;134(2):859-66. Exclusion: wrong comparison. [pmid: 22710708].
Ernst MF, Voogd AC, Coebergh JWW, et al. Breast carcinoma diagnosis, treatment, and prognosis before and after the introduction of mass mammographic screening. Cancer. 2004;100(7):1337-44. Exclusion: wrong study design for key question. [pmid: 15042665].
Ernster VL. Screening mammography for women under 50: considerations for fully informed decision making. Womens Health. 1996;2(4):257-60. discussion 61-6. Exclusion: wrong publication type. [pmid: 9453858].
Ernster VL, Ballard-Barbash R, Barlow WE, et al. Detection of ductal carcinoma in situ in women undergoing screening mammography. J Natl Cancer Inst. 2002;94(20):1546-54. Exclusion: wrong intervention. [pmid: 12381707].
Erpeldinger S, Fayolle L, Boussageon R, et al. Is there excess mortality in women screened with mammography: a meta-analysis of non-breast cancer mortality. Trials. 2013;14:368. Exclusion: wrong outcomes. [pmid: 24192052].
Escobedo LG, Zhong Z, Key C. Breast and cervical cancer screening and disease incidence and stage in New Mexico. Cancer Causes Control. 2002;13(2):137-45. Exclusion: wrong outcomes. [pmid: 11936820].
Esserman L, Cowley H, Eberle C, et al. Improving the accuracy of mammography: volume and outcome relationships. J Natl Cancer Inst. 2002;94(5):369-75. Exclusion: wrong outcomes. [pmid: 11880475].
Esserman LJ, Shieh Y, Rutgers EJT, et al. Impact of mammographic screening on the detection of good and poor prognosis breast cancers. Breast Cancer Res Treat. 2011;130(3):725-34. Exclusion: wrong population. [pmid: 21892702].
Esserman LJ, Thompson IM Jr., Reid B. Overdiagnosis and overtreatment in cancer: an opportunity for improvement. JAMA. 2013;310(8):797-8. Exclusion: wrong publication type. [pmid: 23896967].
Esserman LJ, Thompson IM, Reid B, et al. Addressing overdiagnosis and overtreatment in cancer: a prescription for change. Lancet Oncol. 2014;15(6):e234-e42. Exclusion: wrong publication type. [pmid: 24807866].
Esteve J, Seradour B, Jacquemier J, et al. Does a better grade of tumour occurring in women under hormone replacement therapy compensate for their lower probability of detection by screening mammography. J Med Screen. 2002;9(2):70-3. Exclusion: wrong comparison. [pmid: 12133926].
Etim AE-EP, Schellhase KG, Sparapani R, et al. Effect of model of care delivery on mammography use among elderly breast cancer survivors. Breast Cancer Res Treat. 2006;96(3):293-9. Exclusion: wrong population. [pmid: 16538537].
Etzioni R, Gulati R, Mallinger L, et al. Influence of study features and methods on overdiagnosis estimates in breast and prostate cancer screening. Ann Intern Med. 2013;158(11):831-8. Exclusion: wrong outcomes. [pmid: 23732716].
Etzioni RD, Weiss NS. Analysis of case-control studies of screening: impact of misspecifying the duration of detectable preclinical pathologic changes. Am J Epidemiol. 1998;148(3):292-7. Exclusion: wrong study design for key question. [pmid: 9690367].
Evans A. Hormone replacement therapy and mammographic screening. Clin Radiol. 2002;57(7):563-4. Exclusion: review not meeting inclusion criteria. [pmid: 12096852].
Evans AJ, Kutt E, Record C, et al. Radiological and pathological findings of interval cancers in a multi-centre, randomized, controlled trial of mammographic screening in women from age 40-41 years. Clin Radiol. 2007;62(4):348-52. Exclusion: wrong outcomes. [pmid: 17331828].
Evans AJ, Kutt E, Record C, et al. Radiological findings of screen-detected cancers in a multi-centre randomized, controlled trial of mammographic screening in women from age 40 to 48 years. Clin Radiol. 2006;61(9):784-8. Exclusion: wrong outcomes. [pmid: 16905387].
Evans WP. Breast cancer screening: successes and challenges. CA Cancer J Clin. 2012;62(1):5-9. Exclusion: wrong publication type. [pmid: 22252587].
Everington D, Gilbert FJ, Tyack C, et al. The Scottish breast screening programme's experience of monitoring interval cancers. J Med Screen. 1999;6(1):21-7. Exclusion: wrong outcomes. [pmid: 10321366].
Exbrayat C, Garnier A, Colonna M, et al. Analysis and classification of interval cancers in a French breast cancer screening programme (departement of Isere). Eur J Cancer Prev. 1999;8(3):255-60. Exclusion: wrong comparison. [pmid: 10443955].
Fair AM, Monahan PO, Russell K, et al. The interaction of perceived risk and benefits and the relationship to predicting mammography adherence in African American women. Oncol Nurs Forum. 2012;39(1):53-60. Exclusion: wrong comparison. [pmid: 22201655].
Falk RS, Hofvind S, Skaane P. Overdiagnosis of Invasive Breast Cancer due to Mammography Screening. Ann Intern Med. 2012;157(3):219. author reply 21-2. Exclusion: wrong publication type. [pmid: 22868848].
Fantini S, Heffer EL, Pera VE, et al. Spatial and spectral information in optical mammography. Technol Cancer Res Treat. 2005;4(5):471-82. Exclusion: wrong study design for key question. [pmid: 16173819].
Farham B. Screening--benefits or harms?. S Afr Med J. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 2013;103(5):270-1. Exclusion: wrong publication type. [pmid: 23971101].
Fasching PA, Heusinger K, Loehberg CR, et al. Influence of mammographic density on the diagnostic accuracy of tumor size assessment and association with breast cancer tumor characteristics. Eur J Radiol. 2006;60(3):398-404. Exclusion: wrong outcomes. [pmid: 17030108].
Faulk RM, Sickles EA, Sollitto RA, et al. Clinical efficacy of mammographic screening in the elderly. Radiology. 1995;194(1):193-7. Exclusion: studies outside of search dates. [pmid: 7997552].
Faulkner K, McCormack S, Bennison K. A retrospective analysis of digital stereotaxis in breast screening. Br J Radiol. 2007;80(955):563-8. Exclusion: wrong intervention. [pmid: 17621605].
Fausto A, Casella D, Mantovani L, et al. Clinical value of second-look ultrasound: is there a way to make it objective?. Eur J Radiol. Suppl 1. 2012;81:S36-40. Exclusion: wrong intervention. [pmid: 23083595].
Feeley L, Kiernan D, Mooney T, et al. Digital mammography in a screening programme and its implications for pathology: a comparative study. J Clin Pathol. 2011;64(3):215-9. Exclusion: wrong comparison. [pmid: 21177749].
Feig SA. Age-related accuracy of screening mammography: how should it be measured?. Radiology. 2000;214(3):633-40. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 10715022].
Feig SA. Auditing and benchmarks in screening and diagnostic mammography. Radiol Clin North Am. 2007;45(5):791-800. Exclusion: review not meeting inclusion criteria. [pmid: 17888769].
Feig SA. Current status of screening mammography. Obstet Gynecol Clin North Am. 2002;29(1):123-36. Exclusion: wrong publication type. [pmid: 11892862].
Feig SA. Image quality of screening mammography: effect on clinical outcome. AJR Am J Roentgenol. 2002;178(4):805-7. Exclusion: wrong publication type. [pmid: 11906850].
Feig SA. Increased benefit from shorter screening mammography intervals for women ages 40-49 years. Cancer. 1997;80(11):2035-9. Exclusion: review not meeting inclusion criteria. [pmid: 9392324].
Feig SA. Methods to identify benefit from mammographic screening of women aged 40-49 years. Radiology. 1996;201(2):309-16. Exclusion: wrong publication type. [pmid: 8888216].
Feig SA. Number needed to screen: appropriate use of this new basis for screening mammography guidelines. AJR Am J Roentgenol. 2012;198(5):1214-7. Exclusion: wrong publication type. [pmid: 22528916].
Feig SA. Overdiagnosis of Invasive Breast Cancer and DCIS: Why Do Estimates Vary?. Breast Diseases: A Year Book Quarterly. 2014;25(3):196-201. Exclusion: wrong publication type.
Feig SA. Role and evaluation of mammography and other imaging methods for breast cancer detection, diagnosis, and staging. Semin Nucl Med. 1999;29(1):3-15. Exclusion: review not meeting inclusion criteria. [pmid: 9990680].
Feig SA. Screening mammography controversies: resolved, partly resolved, and unresolved. Breast J. Suppl 1. 2005;11:S3-6. Exclusion: wrong publication type. [pmid: 15725113].
Feig SA, Hendrick RE. Radiation risk from screening mammography of women aged 40-49 years. J Natl Cancer Inst. Monographs. 1997;(22):119-24. Exclusion: wrong outcomes.
Feigelson HS, Henderson BE, Pike MC. Re: Recent trends in U.S. breast cancer incidence, survival, and mortality rates. J Natl Cancer Inst. 1997;89(23):1810-2. Exclusion: wrong study design for key question. [pmid: 9392623].
Fenton A, Panay N. Breast cancer screening--when do we start and how often should it be done?. Climacteric. 2011;14(5):513-4. Exclusion: wrong publication type. [pmid: 21910669].
Fenton JJ, Abraham L, Taplin SH, et al. Effectiveness of computer-aided detection in community mammography practice. J Natl Cancer Inst. 2011;103(15):1152-61. Exclusion: wrong intervention. [pmid: 21795668].
Fenton JJ, Barton MB, Geiger AM, et al. Screening clinical breast examination: how often does it miss lethal breast cancer?. J Natl Cancer Inst. Monographs. 2005;(35):67-71. Exclusion: wrong intervention.
Fenton JJ, Rolnick SJ, Harris EL, et al. Specificity of clinical breast examination in community practice. J Gen Intern Med. 2007;22(3):332-7. Exclusion: wrong intervention. [pmid: 17356964].
Fenton JJ, Taplin SH, Carney PA, et al. Influence of computer-aided detection on performance of screening mammography. N Engl J Med. 2007;356(14):1399-409. Exclusion: wrong outcomes. [pmid: 17409321].
Fenton JJ, Xing G, Elmore JG, et al. Short-term outcomes of screening mammography using computer-aided detection: a population-based study of medicare enrollees. Ann Intern Med. 2013;158(8):580-7. Exclusion: wrong comparison. [pmid: 23588746].
Ferrante JM, Chen P-H, Kim S. The effect of patient navigation on time to diagnosis, anxiety, and satisfaction in urban minority women with abnormal mammograms: a randomized controlled trial. J Urban Health. 2008;85(1):114-24. Exclusion: wrong population. [pmid: 17906931].
Ferrer S, Ramos M, Villaescusa JI, et al. Modelling of the mammographic exposure conditions for radiological detriment study in the Valencian Breast Cancer Screening Programme. Radiat Prot Dosimetry. 2005;116(1-4 Pt 2):396-400. Exclusion: wrong study design for key question. [pmid: 16604667].
Fett MJ. Computer modelling of the Swedish two county trial of mammographic screening and trade offs between participation and screening interval. J Med Screen. 2001;8(1):39-45. Exclusion: wrong study design for key question. [pmid: 11373849].
Feuer EJ. Modeling the impact of adjuvant therapy and screening mammography on U.S. breast cancer mortality between 1975 and 2000: introduction to the problem. J Natl Cancer Inst. Monographs. 2006;(36):2-6. Exclusion: wrong study design for key question.
Feuer EJ, Etzioni R, Cronin KA, et al. The use of modeling to understand the impact of screening on U.S. mortality: examples from mammography and PSA testing. Stat Methods Med Res. 2004;13(6):421-42. Exclusion: wrong study design for key question. [pmid: 15587432].
Field LR, Wilson TE, Strawderman M, et al. Mammographic screening in women more than 64 years old: a comparison of 1- and 2-year intervals. AJR Am J Roentgenol. 1998;170(4):961-5. Exclusion: wrong comparison. [pmid: 9530044].
Fielder H, Rogers C, Gower-Thomas K, et al. Results from 10 years of breast screening in Wales. J Med Screen. 2001;8(1):21-3. Exclusion: wrong comparison. [pmid: 11373845].
Fielder HM, Warwick J, Brook D, et al. A case-control study to estimate the impact on breast cancer death of the breast screening programme in Wales. J Med Screen. 2004;11(4):194-8. Exclusion: included in an included systematic review, not directly used. [pmid: 15563774].
Filippini L, Braga M, Perna E, et al. Results of a mammographic and clinical screening in a health district (USSL) of Brescia, Italy. Tumori. 1996;82(5):430-6. Exclusion: wrong study design for key question. [pmid: 9063517].
Finucane TE. Cost-effectiveness of mammography for older women. Ann Intern Med. 2004;140(10):844. author reply. Exclusion: wrong publication type. [pmid: 15148077].
Fischer DR, Wurdinger S, Boettcher J, et al. Further signs in the evaluation of magnetic resonance mammography: a retrospective study. Invest Radiol. 2005;40(7):430-5. Exclusion: wrong outcomes. [pmid: 15973134].
Fischmann A, Siegmann KC, Wersebe A, et al. Comparison of full-field digital mammography and film-screen mammography: image quality and lesion detection. Br J Radiol. 2005;78(928):312-5. Exclusion: wrong study design for key question. [pmid: 15774591].
Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for Prevention of Breast Cancer: Report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90(18):1371-88. Exclusion: wrong intervention. [pmid: 9747868].
Fisher TJ, Kirk J, Hopper JL, et al. A simple tool for identifying unaffected women at a moderately increased or potentially high risk of breast cancer based on their family history. Breast. 2003;12(2):120-7. Exclusion: wrong outcomes. [pmid: 14659341].
Fitzgerald A, Berentson-Shaw J. Thermography as a screening and diagnostic tool: a systematic review. N Z Med J. 2012;125(1351):80-91. Exclusion: wrong intervention. [pmid: 22426613].
Flamm CR, Ziegler KM, Aronson N. Technology Evaluation Center assessment synopsis: use of magnetic resonance imaging to avoid a biopsy in women with suspicious primary breast lesions. J Am Coll Radiol. 2005;2(6):485-7. Exclusion: studies outside of search dates. [pmid: 17411864].
Flegg KM, Flaherty JJ, Bicknell AM, et al. Surgical outcomes of borderline breast lesions detected by needle biopsy in a breast screening program. World J Surg Oncol. 2010;8:78. Exclusion: wrong outcomes. [pmid: 20822548].
Fleming RM, Dooley WC. Breast enhanced scintigraphy testing distinguishes between normal, inflammatory breast changes, and breast cancer: a prospective analysis and comparison with mammography. Integ Cancer Ther. 2002;1(3):238-45. Exclusion: wrong intervention.
Fletcher SW. Breast cancer screening among women in their forties: an overview of the issues. J Natl Cancer Inst. Monographs. 1997;(22):5-9. Exclusion: review not meeting inclusion criteria.
Fletcher SW. Breast cancer screening: a 35-year perspective. Epidemiol Rev. 2011;33(1):165-75. Exclusion: review not meeting inclusion criteria. [pmid: 21697257].
Fletcher SW, Elmore JG. Clinical practice. Mammographic screening for breast cancer. N Engl J Med. 2003;348(17):1672-80. Exclusion: review not meeting inclusion criteria. [pmid: 12711743].
Flobbe K, Bosch AM, Kessels AGH, et al. The additional diagnostic value of ultrasonography in the diagnosis of breast cancer. Arch Intern Med. 2003;163(10):1194-9. Exclusion: wrong population. [pmid: 12767956].
Flobbe K, Nelemans PJ, Kessels AGH, et al. The role of ultrasonography as an adjunct to mammography in the detection of breast cancer. a systematic review. Eur J Cancer. 2002;38(8):1044-50. Exclusion: wrong outcomes. [pmid: 12008191].
Flowers CI, O'Donoghue C, Moore D, et al. Reducing false-positive biopsies: a pilot study to reduce benign biopsy rates for BI-RADS 4A/B assessments through testing risk stratification and new thresholds for intervention. Breast Cancer Res Treat. 2013;139(3):769-77. Exclusion: wrong intervention. [pmid: 23764994].
Foca F, Mancini S, Bucchi L, et al. Decreasing incidence of late-stage breast cancer after the introduction of organized mammography screening in Italy. Cancer. 2013;119(11):2022-8. Exclusion: wrong outcomes. [pmid: 23504860].
Fontenoy A-M, Langlois A, Chang S-L, et al. Contribution and performance of mobile units in an organized mammography screening program. Can J Public Health. Revue Canadienne de Sante Publique. 2013;104(3):e193-9. Exclusion: wrong outcomes. [pmid: 23823881].
Forastero C, Zamora LI, Guirado D, et al. A Monte Carlo tool to simulate breast cancer screening programmes. Phys Med Biol. 2010;55(17):5213-29. Exclusion: wrong study design for key question. [pmid: 20714045].
Forbes LJ, Linsell L, Atkins L, et al. A promoting early presentation intervention increases breast cancer awareness in older women after 2 years: a randomised controlled trial. Br J Cancer. 2011;105(1):18-21. Exclusion: wrong intervention. [pmid: 21654683].
Ford K, Marcus E, Lum B. Breast cancer screening, diagnosis, and treatment. Dis Mon. 1999;45(9):333-405. Exclusion: review not meeting inclusion criteria. [pmid: 10513286].
Foster KR. Thermographic detection of breast cancer. IEEE Eng Med Biol Mag. 1998;17(6):10-4. Exclusion: wrong publication type. [pmid: 9824754].
Foster RS Jr. Primary breast cancer: opportunities and problems in detection and treatment. J Med Assoc Ga. 1997;86(3):197-200. Exclusion: wrong publication type. [pmid: 9293172].
Fracheboud J, de Koning HJ, Beemsterboer PM, et al. Nation-wide breast cancer screening in The Netherlands: results of initial and subsequent screening 1990-1995. National Evaluation Team for Breast Cancer Screening. Int J Cancer. 1998;75(5):694-8. Exclusion: wrong study design for key question. [pmid: 9495236].
Fracheboud J, de Koning HJ, Beemsterboer PM, et al. Interval cancers in the Dutch breast cancer screening programme. Br J Cancer. 1999;81(5):912-7. Exclusion: wrong outcomes. [pmid: 10555768].
Fracheboud J, Groenewoud JH, Boer R, et al. Seventy-five years is an appropriate upper age limit for population-based mammography screening. Int J Cancer. 2006;118(8):2020-5. Exclusion: wrong comparison. [pmid: 16287064].
Fracheboud J, Otto SJ, van Dijck JAAM, et al. Decreased rates of advanced breast cancer due to mammography screening in The Netherlands. Br J Cancer. 2004;91(5):861-7. Exclusion: wrong outcomes. [pmid: 15292936].
Frede TE. Opportunistic breast cancer early detection in Tyrol, Austria 1996-2004. Is a mammography-screening program necessary?. Eur J Radiol. 2005;55(1):130-8. Exclusion: wrong comparison. [pmid: 15925467].
Freedman DA, Petitti DB, Robins JM. On the efficacy of screening for breast cancer. Int J Epidemiol. 2004;33(1):43-55. Exclusion: wrong publication type. [pmid: 15075144].
Freedman GM, Anderson PR, Goldstein LJ, et al. Routine mammography is associated with earlier stage disease and greater eligibility for breast conservation in breast carcinoma patients age 40 years and older. Cancer. 2003;98(5):918-25. Exclusion: wrong comparison. [pmid: 12942557].
Freeman JL, Goodwin JS, Zhang D, et al. Measuring the performance of screening mammography in community practice with Medicare claims data. Women Health. 2003;37(2):1-15. Exclusion: wrong study design for key question. [pmid: 12733550].
Freer TW, Ulissey MJ. Screening mammography with computer-aided detection: prospective study of 12,860 patients in a community breast center. Radiology. 2001;220(3):781-6. Exclusion: wrong study design for key question. [pmid: 11526282].
Friedenreich CM, Bryant HE, Courneya KS. Case-control study of lifetime physical activity and breast cancer risk. Am J Epidemiol. 2001;154(4):336-47. Exclusion: wrong outcomes. [pmid: 11495857].
Frisell J, Eklund G, Hellström L, et al. The Stockholm breast cancer screening trial - 5-year results and stage at discovery. Breast Cancer Res Treat. 1989;13(1):79-87. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 2706329].
Frisell J, Glas U, Hellstrom L, et al. Randomized mammographic screening for breast cancer in Stockholm. Design, first round results and comparisons. Breast Cancer Res Treat. 1986;8(1):45-54. Exclusion: studies outside of search dates. [pmid: 3790749].
Frost FJ, Tollestrup K, Trinkaus KM, et al. Mammography screening and breast cancer tumor size in female members of a managed care organization. Cancer Epidemiol Biomarkers Prev. 1998;7(7):585-9. Exclusion: wrong comparison. [pmid: 9681526].
Fuglede N, Langballe O, Svendsen AL, et al. Development in incidence of breast cancer in non-screened Danish women, 1973-2002--a population-based study. Int J Cancer. 2006;118(9):2366-9. Exclusion: wrong outcomes. [pmid: 16331626].
Fulton JP, Chiaverini L, Darcy DM. Progress in the control of female breast cancer in Rhode Island, 1987-2000. Med Health R I. 2002;85(6):192-3. Exclusion: wrong outcomes. [pmid: 12101887].
Fulton JP, Darcy D. Progress in the early identification of breast cancer, Rhode Island, 1987-1998. Med Health R I. 2000;83(4):121-2. Exclusion: wrong publication type. [pmid: 10821015].
Furman-Haran E, Eyal E, Shapiro-Feinberg M, et al. Advantages and drawbacks of breast DTI. Eur J Radiol. Suppl 1. 2012;81:S45-7. Exclusion: wrong intervention. [pmid: 23083598].
Fyles AW, McCready DR, Manchul LA, et al. Tamoxifen with or without Breast Irradiation in Women 50 Years of Age or Older with Early Breast Cancer. N Engl J Med. 2004;351(10):963-70. Exclusion: wrong intervention. [pmid: 15342804].
Gabe R, Duffy SW. Evaluation of service screening mammography in practice: the impact on breast cancer mortality. Ann Oncol. Suppl 2. 2005;16:ii153-62. Exclusion: review not meeting inclusion criteria. [pmid: 15958448].
Gabe R, Tryggvadottir L, Sigfusson BF, et al. A case-control study to estimate the impact of the Icelandic population-based mammography screening program on breast cancer death. Acta Radiol. 2007;48(9):948-55. Exclusion: included in an included systematic review, not directly used. [pmid: 18080359].
Gabram SGA, Lund MJB, Gardner J, et al. Effects of an outreach and internal navigation program on breast cancer diagnosis in an urban cancer center with a large African-American population. Cancer. 2008;113(3):602-7. Exclusion: wrong intervention. [pmid: 18613035].
Galit W, Green MS, Lital K-B. Routine screening mammography in women older than 74 years: a review of the available data. Maturitas. 2007;57(2):109-19. Exclusion: review not meeting inclusion criteria. [pmid: 17336004].
Gallagher TH, Cook AJ, Brenner RJ, et al. Disclosing harmful mammography errors to patients. Radiology. 2009;253(2):443-52. Exclusion: wrong outcomes. [pmid: 19710002].
Ganry OF, Peng J, Raverdy NL, et al. Interval cancers in a French breast cancer-screening programme (Somme Department). Eur J Cancer Prev. 2001;10(3):269-74. Exclusion: wrong outcomes. [pmid: 11432715].
Ganz PA, Land SR, Geyer CE Jr., et al. Menstrual history and quality-of-life outcomes in women with node-positive breast cancer treated with adjuvant therapy on the NSABP B-30 trial. J Clin Oncol. 2011;29(9):1110-6. Exclusion: wrong intervention. [pmid: 21300930].
Gao F, Chia K-S, Ng F-C, et al. Interval cancers following breast cancer screening in Singaporean women. Int J Cancer. 2002;101(5):475-9. Exclusion: wrong outcomes. [pmid: 12216077].
Garcia-Manero M, Royo MP, Espinos J, et al. Pregnancy associated breast cancer. Eur J Surg Oncol. 2009;35(2):215-8. Exclusion: wrong population. [pmid: 18550321].
Garcia-Manso A, Garcia-Orellana CJ, Gonzalez-Velasco HM, et al. Study of the effect of breast tissue density on detection of masses in mammograms. Comput Math Methods Med. 2013;2013:213794. Exclusion: wrong study design for key question. [pmid: 23573165].
Garfinkel L, Boring CC, Heath CW Jr. Changing trends. An overview of breast cancer incidence and mortality. Cancer. 1994;74(1 Suppl):222-7. Exclusion: wrong publication type. [pmid: 8004590].
Garg AS, Rapelyea JA, Rechtman LR, et al. Full-field digital mammographic interpretation with prior analog versus prior digitized analog mammography: time for interpretation. AJR Am J Roentgenol. 2011;196(6):1436-8. Exclusion: wrong outcomes. [pmid: 21606310].
Garne JP, Aspegren K, Balldin G, et al. Increasing incidence of and declining mortality from breast carcinoma. Trends in Malmö, Sweden, 1961-1992. Cancer. 1997;79(1):69-74. Exclusion: wrong population. [pmid: 8988728].
Garnick MB. Screening and detection of breast cancer and prostate cancer. JAMA. 2010;303(11):1033. author reply -4. Exclusion: wrong publication type. [pmid: 20233818].
Gartlehner G, Thaler K, Chapman A, et al. Mammography in combination with breast ultrasonography versus mammography for breast cancer screening in women at average risk. Cochrane Database Syst Rev. 2013;4. CD009632. Exclusion: wrong intervention.
Gartlehner G, Thaler KJ, Chapman A, et al. Adjunct ultrasonography for breast cancer screening in women at average risk: a systematic review. International Journal of Evidence-Based Healthcare. 2013;11(2):87-93. Exclusion: wrong intervention. [pmid: 23750571].
Garvican L, Littlejohns P. Comparison of prognostic and socio-economic factors in screen-detected and symptomatic cases of breast cancer. Public Health. 1998;112(1):15-20. Exclusion: wrong intervention. [pmid: 9490883].
Gaudette LA, Silberberger C, Altmayer CA, et al. Trends in breast cancer incidence and mortality. Health reports / Statistics Canada, Canadian Centre for Health Information = Rapports sur la santé / Statistique Canada, Centre canadien d'information sur la santé. 1996;8(2):29-37. Exclusion: wrong study design for key question.
Gayde C, Goolam I, Bangash HK, et al. Outcome of mammography in women with large breasts. Breast. 2012;21(4):493-8. Exclusion: wrong outcomes. [pmid: 22289153].
Ge J, Hadjiiski LM, Sahiner B, et al. Computer-aided detection system for clustered microcalcifications: comparison of performance on full-field digital mammograms and digitized screen-film mammograms. Phys Med Biol. 2007;52(4):981-1000. Exclusion: wrong intervention. [pmid: 17264365].
Gelfand AE, Wang F. Modelling the cumulative risk for a false-positive under repeated screening events. Stat Med. 2000;19(14):1865-79. Exclusion: wrong study design for key question. [pmid: 10867676].
Geller BM, Vacek PM, Skelly J, et al. The use of additional imaging increased specificity and decreased sensitivity in screening mammography. J Clin Epidemiol. 2005;58(9):942-50. Exclusion: studies outside of search dates. [pmid: 16085198].
Gemignani ML. Breast cancer screening: why, when, and how many?. Clin Obstet Gynecol. 2011;54(1):125-32. Exclusion: review not meeting inclusion criteria. [pmid: 21278511].
Gemignani ML, Petrek JA, Borgen PI. Breast cancer and pregnancy. Surg Clin North Am. 1999;79(5):1157-69. Exclusion: wrong population. [pmid: 10572556].
Gennaro G, Hendrick RE, Toledano A, et al. Combination of one-view digital breast tomosynthesis with one-view digital mammography versus standard two-view digital mammography: per lesion analysis. Eur Radiol. 2013;23(8):2087-94. Exclusion: wrong intervention. [pmid: 23620367].
Georgian-Smith D, Moore RH, Halpern E, et al. Blinded comparison of computer-aided detection with human second reading in screening mammography. AJR Am J Roentgenol. 2007;189(5):1135-41. Exclusion: wrong outcomes. [pmid: 17954651].
Gertig DM, Erbas B, Fletcher A, et al. Duration of hormone replacement therapy, breast tumour size and grade in a screening programme. Breast Cancer Res Treat. 2003;80(3):267-73. Exclusion: wrong comparison. [pmid: 14503799].
Ghiasvand R, Bahmanyar S, Zendehdel K, et al. Postmenopausal breast cancer in Iran; risk factors and their population attributable fractions. BMC Cancer. 2012;12:414. Exclusion: wrong outcomes. [pmid: 22992276].
GholamHosseini H, Alizad A, Fatemi M. Fusion of vibro-acoustography images and X-ray mammography. Conf Proc IEEE Eng Med Biol Soc. 2006;1:2803-6. Exclusion: wrong study design for key question. [pmid: 17946531].
Ghosh K, Vachon CM, Pankratz VS, et al. Independent association of lobular involution and mammographic breast density with breast cancer risk. J Natl Cancer Inst. 2010;102(22):1716-23. Exclusion: wrong outcomes. [pmid: 21037116].
Giannakopoulou G, Spyrou GM, Antaraki A, et al. Downgrading BIRADS 3 to BIRADS 2 category using a computer-aided microcalcification analysis and risk assessment system for early breast cancer. Comput Biol Med. 2010;40(11-12):853-9. Exclusion: wrong intervention. [pmid: 20950798].
Gibis B, Busse R, Reese E, et al. Mammography screening as a method for the early detection of breast cancer. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: wrong publication type.
Gibson LJ, Hery C, Mitton N, et al. Risk factors for breast cancer among Filipino women in Manila. Int J Cancer. 2010;126(2):515-21. Exclusion: wrong outcomes. [pmid: 19626603].
Gierach GL, Brinton LA, Sherman ME. Lobular involution, mammographic density, and breast cancer risk: visualizing the future?. J Natl Cancer Inst. 2010;102(22):1685-7. Exclusion: wrong publication type. [pmid: 21037117].
Gifford D. Screening for breast cancer in women over the age of 70. Med Health R I. 2001;84(4):136-7. Exclusion: wrong publication type. [pmid: 11347352].
Giger ML. Computerized analysis of images in the detection and diagnosis of breast cancer. Semin Ultrasound CT MR. 2004;25(5):411-8. Exclusion: wrong study design for key question. [pmid: 15559124].
Gilbert FJ. New screening techniques for breast cancer (MRI). Dis Markers. 1999;15(1-3):115-6. Exclusion: wrong publication type. [pmid: 10595263].
Gilbert FJ, Astley SM, Gillan MGC, et al. Single reading with computer-aided detection for screening mammography. N Engl J Med. 2008;359(16):1675-84. Exclusion: wrong outcomes. [pmid: 18832239].
Gilbert FJ, Cordiner CM, Affleck IR, et al. Breast screening: The psychological sequelae of false-positive recall in women with and without a family history of breast cancer. Eur J Cancer. 1998;34(13):2010-4. Exclusion: included in an included systematic review, not directly used. [pmid: 10070302].
Gill KS, Yankaskas BC. Screening mammography performance and cancer detection among black women and white women in community practice. Cancer. 2004;100(1):139-48. Exclusion: wrong outcomes. [pmid: 14692034].
Gill PG, Farshid G, Luke CG, et al. Detection by screening mammography is a powerful independent predictor of survival in women diagnosed with breast cancer. Breast. 2004;13(1):15-22. Exclusion: wrong comparison. [pmid: 14759711].
Gillett D, Kennedy C, Carmalt H. Breast cancer in young women. Aust N Z J Surg. 1997;67(11):761-4. Exclusion: wrong comparison. [pmid: 9396990].
Giordano L, Cogo C, Patnick J, et al. Communicating the balance sheet in breast cancer screening. J Med Screen. 2012;19(suppl 1):67-71. Exclusion: wrong outcomes. [pmid: 22972812].
Giordano L, Giorgi D, Piccini P, et al. Time trends of some indicators of mammography screening programmes in Italy, 1996-2003. Epidemiol Prev. 2006;30(1 Suppl 3):17-26. Exclusion: wrong comparison. [pmid: 16937843].
Giordano L, Giorgi D, Piccini P, et al. Time trends of process and impact indicators in Italian breast screening programmes--1996-2005. Epidemiol Prev. 2008;32(2 Suppl 1):23-36. Exclusion: wrong study design for key question. [pmid: 18770993].
Giordano L, von Karsa L, Tomatis M, et al. Mammographic screening programmes in Europe: organization, coverage and participation. J Med Screen. 2012;19(suppl 1):72-82. Exclusion: wrong outcomes. [pmid: 22972813].
Giorgi D, Giordano L, Ventura L, et al. Mammography screening in Italy: 2003-2004 survey. Epidemiol Prev. 2006;30(1 Suppl 3):7-16. Exclusion: wrong comparison. [pmid: 16937842].
Giorgi Rossi P, Camilloni L, Mantellini P, et al. Breast cancer diagnostic methods: screen-detected and clinical cases. An Italian survey of women's experiences. Tumori. 2007;93(5):452-60. Exclusion: wrong outcomes. [pmid: 18038877].
Giorgi Rossi P, Federici A, Farchi S, et al. The effect of screening programmes on the treatment of benign breast neoplasms: observations from current practice in Italy. J Med Screen. 2006;13(3):123-8. Exclusion: wrong outcomes. [pmid: 17007652].
Giuliano V, Giuliano C. Improved breast cancer detection in asymptomatic women using 3D-automated breast ultrasound in mammographically dense breasts. Clin Imaging. 2013;37(3):480-6. Exclusion: wrong intervention. [pmid: 23116728].
Given-Wilson RM, Blanks RG. Incident screening cancers detected with a second mammographic view: pathological and radiological features. Clin Radiol. 1999;54(11):724-35. Exclusion: wrong outcomes. [pmid: 10580762].
Glass AG, Lacey JV Jr., Carreon JD, et al. Breast cancer incidence, 1980-2006: combined roles of menopausal hormone therapy, screening mammography, and estrogen receptor status. J Natl Cancer Inst. 2007;99(15):1152-61. Exclusion: wrong outcomes. [pmid: 17652280].
Glasziou P, Irwig L. The quality and interpretation of mammographic screening trials for women ages 40-49. J Natl Cancer Inst. Monographs. 1997;(22):73-7. Exclusion: review not meeting inclusion criteria.
Glueck DH, Lamb MM, Lewin JM, et al. Two-modality mammography may confer an advantage over either full-field digital mammography or screen-film mammography. Acad Radiol. 2007;14(6):670-6. Exclusion: wrong comparison. [pmid: 17502256].
Glynn CG, Farria DM, Monsees BS, et al. Effect of transition to digital mammography on clinical outcomes. Radiology. 2011;260(3):664-70. Exclusion: wrong comparison. [pmid: 21788529].
Goel V, Cohen MM, Kaufert P, et al. Assessing the extent of contamination in the Canadian National Breast Screening Study. Am J Prev Med. 1998;15(3):206-11. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 9791638].
Gojnic M, Petkovic S, Pervulov M, et al. The utility of routine breast ultrasound screening in gynecology. Clin Exp Obstet Gynecol. 2003;30(4):265. Exclusion: wrong publication type. [pmid: 14664430].
Golatta M, Franz D, Harcos A, et al. Interobserver reliability of automated breast volume scanner (ABVS) interpretation and agreement of ABVS findings with hand held breast ultrasound (HHUS), mammography and pathology results. Eur J Radiol. 2013;82(8):e332-6. Exclusion: wrong intervention. [pmid: 23540947].
Goldman LE, Walker R, Miglioretti DL, et al. Facility characteristics do not explain higher false-positive rates in diagnostic mammography at facilities serving vulnerable women. Med Care. 2012;50(3):210-6. Exclusion: wrong intervention. [pmid: 22186768].
Gordon PB. Ultrasound for breast cancer screening and staging. Radiol Clin North Am. 2002;40(3):431-41. Exclusion: review not meeting inclusion criteria. [pmid: 12117185].
Gordon PB, Borugian MJ, Warren Burhenne LJ. A true screening environment for review of interval breast cancers: pilot study to reduce bias. Radiology. 2007;245(2):411-5. Exclusion: wrong outcomes. [pmid: 17848684].
Gorey TF. Advances in breast cancer: clinical and biological lessons from screening. Ir J Med Sci. 1996;165(3):143-50. Exclusion: wrong study design for key question. [pmid: 8824012].
Gorini G, Zappa M, Miccinesi G, et al. Breast cancer mortality trends in two areas of the province of Florence, Italy, where screening programmes started in the 1970s and 1990s. Br J Cancer. 2004;90(9):1780-3. Exclusion: included in an included systematic review, not directly used. [pmid: 15150601].
Goscin CP, Berman CG, Clark RA. Magnetic resonance imaging of the breast. Cancer Control. 2001;8(5):399-406. Exclusion: wrong publication type. [pmid: 11579335].
Goss PE, Ingle JN, Martino S, et al. A randomized trial of letrozole in postmenopausal women after five years of tamoxifen therapy for early-stage breast cancer. N Engl J Med. 2003;349(19):1793-802. Exclusion: wrong intervention. [pmid: 14551341].
Goto M, Sakuma H, Kobayashi S, et al. Dynamic contrast-enhanced MR imaging of the entire breast with spectral-selective inversion fast three dimensional sequence. Magma. 1998;7(2):69-75. Exclusion: wrong outcomes. [pmid: 9951767].
Gotzsche PC. Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2002;94(2):578. author reply 81-3. Exclusion: wrong publication type. [pmid: 11900245].
Gotzsche PC. Increased incidence of invasive breast cancer after the introduction of service screening with mammography in Sweden. Int J Cancer. 2006;118(10):2648. author reply 9. Exclusion: wrong publication type. [pmid: 16353152].
Gotzsche PC. Mortality reduction by breast-cancer screening. Lancet. 2003;362(9379):246. Exclusion: wrong publication type. [pmid: 12885494].
Gotzsche PC. Relation between breast cancer mortality and screening effectiveness: systematic review of the mammography trials. Dan Med Bull. 2011;58(3):A4246. Exclusion: review not meeting inclusion criteria. [pmid: 21371403].
Gotzsche PC. Screening for breast cancer. Ann Intern Med. 2003;138(9):769-70. author reply 70. Exclusion: wrong publication type. [pmid: 12729439].
Gotzsche PC, Jorgensen KJ, Maehlen J, et al. Estimation of lead time and overdiagnosis in breast cancer screening. Br J Cancer. 2009;100(1):219. author reply 20. Exclusion: wrong publication type. [pmid: 19127274].
Gotzsche PC, Jorgensen KJ, Zahl P-H, et al. Why mammography screening has not lived up to expectations from the randomised trials. Cancer Causes Control. 2012;23(1):15-21. Exclusion: review not meeting inclusion criteria. [pmid: 22072221].
Gotzsche PC, Olsen O. Is screening for breast cancer with mammography justifiable?. Lancet. 2000;355(9198):129-34. Exclusion: wrong study design for key question. [pmid: 10675181].
Gower-Thomas K, Fielder HMP, Branston L, et al. Reviewing interval cancers: time well spent?. [Erratum appears in Clin Radiol 2002 Aug;57(8):770]. Clin Radiol. 2002;57(5):384-8. Exclusion: wrong outcomes. [pmid: 12014936].
Gozzi G, Martinoli C, Conti GM, et al. Screening mammography interpretation test: more frequent mistakes. Radiol Med (Torino). 2005;109(3):268-79. Exclusion: wrong publication type. [pmid: 15775896].
Grabler P, Dupuy D, Rai J, et al. Regular screening mammography before the diagnosis of breast cancer reduces black:white breast cancer differences and modifies negative biological prognostic factors. Breast Cancer Res Treat. 2012;135(2):549-53. Exclusion: wrong comparison. [pmid: 22886477].
Gram IT, Lund E, Slenker SE. Quality of life following a false positive mammogram. Br J Cancer. 1990;62(6):1018-22. Exclusion: studies outside of search dates. [pmid: 2257206].
Gram IT, Lund E, Slenker SE. Quality of life following a false positive mammogram. Br J Cancer. 1990;62(6):1018-22. Exclusion: included in an included systematic review, not directly used. [pmid: 2257206].
Gray JAM, Patnick J, Blanks RG. Maximising benefit and minimising harm of screening. BMJ. 2008;336(7642):480-3. Exclusion: wrong publication type. [pmid: 18310003].
Groenewoud JH, Otten JDM, Fracheboud J, et al. Cost-effectiveness of different reading and referral strategies in mammography screening in the Netherlands. Breast Cancer Res Treat. 2007;102(2):211-8. Exclusion: wrong outcomes. [pmid: 17004116].
Gromet M. Comparison of computer-aided detection to double reading of screening mammograms: review of 231,221 mammograms. AJR Am J Roentgenol. 2008;190(4):854-9. Exclusion: wrong outcomes. [pmid: 18356428].
Gross CP, Long JB, Ross JS, et al. The cost of breast cancer screening in the Medicare population. JAMA Intern Med. 2013;173(3):220-6. Exclusion: wrong outcomes. [pmid: 23303200].
Group IW. Epidemiological changes in breast tumours in Italy: the IMPACT study on mammographic screening programmes. Pathologica. 2011;103(5):290-3. Exclusion: wrong study design for key question. [pmid: 22393684].
Grube BJ. Barriers to diagnosis and treatment of breast cancer in the older woman. J Am Coll Surg. 2006;202(3):495-508. Exclusion: review not meeting inclusion criteria. [pmid: 16500255].
Gruszauskas NP, Drukker K, Giger ML, et al. Breast US computer-aided diagnosis system: robustness across urban populations in South Korea and the United States. Radiology. 2009;253(3):661-71. Exclusion: wrong intervention. [pmid: 19864511].
Gruszauskas NP, Drukker K, Giger ML, et al. Performance of breast ultrasound computer-aided diagnosis: dependence on image selection. Acad Radiol. 2008;15(10):1234-45. Exclusion: wrong intervention. [pmid: 18790394].
Gui GP, Hogben RK, Walsh G, et al. The incidence of breast cancer from screening women according to predicted family history risk: Does annual clinical examination add to mammography?. Eur J Cancer. 2001;37(13):1668-73. Exclusion: wrong population. [pmid: 11527694].
Guliato D, Rangayyan RM, Daloia de Carvalho J, et al. Spiculation-preserving polygonal modeling of contours of breast tumors. Conf Proc IEEE Eng Med Biol Soc. 2006;1:2791-4. Exclusion: wrong outcomes. [pmid: 17945740].
Gullate M. The influence of spirituality and religiosity on breast cancer screening delay in African American women: application of the Theory of Reasoned Action and Planned Behavior (TRA/TPB). ABNF J. 2006;17(2):89-94. Exclusion: wrong outcomes. [pmid: 18402350].
Gullatte MM, Phillips JM, Gibson LM. Factors associated with delays in screening of self-detected breast changes in African-American women. J Natl Black Nurses Assoc. 2006;17(1):45-50. Exclusion: studies outside of search dates. [pmid: 17004426].
Guo Q, Shao J, Ruiz VF. Characterization and classification of tumor lesions using computerized fractal-based texture analysis and support vector machines in digital mammograms. Int J Comput Assist Radiol Surg. 2009;4(1):11-25. Exclusion: wrong study design for key question. [pmid: 20033598].
Gur D, Abrams GS, Chough DM, et al. Digital breast tomosynthesis: observer performance study. AJR Am J Roentgenol. 2009;193(2):586-91. Exclusion: wrong outcomes. [pmid: 19620460].
Gur D, Sumkin JH. Screening for early detection of breast cancer: overdiagnosis versus suboptimal patient management. Radiology. 2013;268(2):327-8. Exclusion: wrong publication type. [pmid: 23882095].
Gur D, Sumkin JH, Hardesty LA, et al. Recall and detection rates in screening mammography. Cancer. 2004;100(8):1590-4. Exclusion: wrong outcomes. [pmid: 15073844].
Gur D, Zuley ML, Anello MI, et al. Dose reduction in digital breast tomosynthesis (DBT) screening using synthetically reconstructed projection images: an observer performance study. Acad Radiol. 2012;19(2):166-71. Exclusion: wrong outcomes. [pmid: 22098941].
Haakinson DJ, Leeds SG, Dueck AC, et al. The impact of obesity on breast cancer: a retrospective review. Ann Surg Oncol. 2012;19(9):3012-8. Exclusion: wrong population. [pmid: 22451232].
Habbema JDF, Tan SYGL, Cronin KA. Impact of mammography on U.S. breast cancer mortality, 1975-2000: are intermediate outcome measures informative?. J Natl Cancer Inst. Monographs. 2006;(36):105-11. Exclusion: wrong study design for key question.
Habermann EB, Virnig BA, Riley GF, et al. The impact of a change in Medicare reimbursement policy and HEDIS measures on stage at diagnosis among Medicare HMO and fee-for-service female breast cancer patients. Med Care. 2007;45(8):761-6. Exclusion: wrong comparison. [pmid: 17667310].
Habtes I, Friedman D, Raskind-Hood C, et al. Determining the impact of US mammography screening guidelines on patient survival in a predominantly African American population treated in a public hospital during 2008. Cancer. 2013;119(3):481-7. Exclusion: wrong study design for key question. [pmid: 22864994].
Hackshaw A. The benefits and harms of mammographic screening for breast cancer: building the evidence base using service screening programmes. J Med Screen. Suppl 1. 2012;19:1-2. Exclusion: wrong publication type. [pmid: 22972804].
Hackshaw AK, Wald NJ, Michell MJ, et al. An investigation into why two-view mammography is better than one-view in breast cancer screening. Clin Radiol. 2000;55(6):454-8. Exclusion: wrong outcomes. [pmid: 10873691].
Hade EM, Murray DM, Pennell ML, et al. Intraclass correlation estimates for cancer screening outcomes: estimates and applications in the design of group-randomized cancer screening studies. J Natl Cancer Inst Monogr. 2010;2010(40):97-103. Exclusion: wrong outcomes. [pmid: 20386058].
Hadi N, Sadeghi-Hassanabadi A, Talei AR, et al. Assessment of a breast cancer screening programme in Shiraz, Islamic Republic of Iran. East Mediterr Health J. 2002;8(2-3):386-92. Exclusion: wrong outcomes. [pmid: 15339128].
Hahn KME, Bondy ML, Selvan M, et al. Factors associated with advanced disease stage at diagnosis in a population-based study of patients with newly diagnosed breast cancer. Am J Epidemiol. 2007;166(9):1035-44. Exclusion: wrong study design for key question. [pmid: 17690220].
Haikel RL Jr., Mauad EC, Silva TB, et al. Mammography-based screening program: preliminary results from a first 2-year round in a Brazilian region using mobile and fixed units. BMC Womens Health. 2012;12:32. Exclusion: wrong outcomes. [pmid: 23031787].
Hakama M, Pukkala E, Heikkila M, et al. Effectiveness of the public health policy for breast cancer screening in Finland: population based cohort study. BMJ. 1997;314(7084):864-7. Exclusion: included in an included systematic review, not directly used. [pmid: 9093096].
Hakim CM, Chough DM, Ganott MA, et al. Digital breast tomosynthesis in the diagnostic environment: A subjective side-by-side review. AJR Am J Roentgenol. 2010;195(2):W172-6. Exclusion: wrong intervention. [pmid: 20651178].
Halapy EE, Chiarelli AM, Klar N, et al. Breast screening outcomes in women with and without a family history of breast and/or ovarian cancer. J Med Screen. 2004;11(1):32-8. Exclusion: wrong outcomes. [pmid: 15006112].
Halbreich U, Shen J, Panaro V. Are chronic psychiatric patients at increased risk for developing breast cancer?. Am J Psychiatry. 1996;153(4):559-60. Exclusion: wrong comparison. [pmid: 8599407].
Hall AB, Wall M, Lancia N, et al. Air force breast cancer detection and treatment trends. Am Surg. 2013;79(5):E209-11. Exclusion: wrong publication type. [pmid: 23635573].
Hall FM. Mammographically determined breast density and cancer risk. Radiology. 2008;248(3):1083. author reply. Exclusion: wrong publication type.
Hall FM. The rise and impending decline of screening mammography. Radiology. 2008;247(3):597-601. Exclusion: wrong publication type. [pmid: 18487527].
Hall HI, Coates RJ, Uhler RJ, et al. Stage of breast cancer in relation to body mass index and bra cup size. Int J Cancer. 1999;82(1):23-7. Exclusion: wrong outcomes. [pmid: 10360815].
Hall HI, Uhler RJ, Coughlin SS, et al. Breast and cervical cancer screening among Appalachian women. Cancer Epidemiol Biomarkers Prev. 2002;11(1):137-42. Exclusion: wrong publication type. [pmid: 11815412].
Hall IJ, Newman B, Millikan RC, et al. Body size and breast cancer risk in black women and white women: the Carolina Breast Cancer Study. Am J Epidemiol. 2000;151(8):754-64. Exclusion: wrong outcomes. [pmid: 10965972].
Halladay JR, Yankaskas BC, Bowling JM, et al. Positive predictive value of mammography: comparison of interpretations of screening and diagnostic images by the same radiologist and by different radiologists. AJR Am J Roentgenol. 2010;195(3):782-5. Exclusion: wrong outcomes. [pmid: 20729460].
Hambly NM, McNicholas MM, Phelan N, et al. Comparison of digital mammography and screen-film mammography in breast cancer screening: a review in the Irish breast screening program. AJR Am J Roentgenol. 2009;193(4):1010-8. Exclusion: wrong comparison. [pmid: 19770323].
Hampton T. Research findings point to advances in breast cancer screening and treatment. JAMA. 2007;298(4):389-90. Exclusion: wrong publication type. [pmid: 17652285].
Han B-K, Choe YH, Ko Y-H, et al. Stereotactic core-needle biopsy of non-mass calcifications: outcome and accuracy at long-term follow-up. Korean J Radiol. 2003;4(4):217-23. Exclusion: wrong population. [pmid: 14726638].
Han D, Nie J, Bonner MR, et al. Lifetime adult weight gain, central adiposity, and the risk of pre- and postmenopausal breast cancer in the Western New York exposures and breast cancer study. Int J Cancer. 2006;119(12):2931-7. Exclusion: wrong study design for key question. [pmid: 17016824].
Han PK, Kobrin SC, Klein WM, et al. Perceived ambiguity about screening mammography recommendations: association with future mammography uptake and perceptions. Cancer Epidemiol Biomarkers Prev. 2007;16(3):458-66. Exclusion: wrong outcomes. [pmid: 17372241].
Hanigan MH. Possible role of mammography in increased incidence of breast cancer not considered. Arch Intern Med. 2009;169(10):998-9. Exclusion: wrong publication type. [pmid: 19468098].
Hanin L, Pavlova L. Optimal screening schedules for prevention of metastatic cancer. Stat Med. 2013;32(2):206-19. Exclusion: wrong study design for key question. [pmid: 22807074].
Harding C, Knox WF, Faragher EB, et al. Hormone replacement therapy and tumour grade in breast cancer: prospective study in screening unit. [Erratum appears in BMJ 1996 Jul 27;313(7051):198]. BMJ. 1996;312(7047):1646-7. Exclusion: wrong intervention. [pmid: 8664718].
Harmer C, Staples M, Kavanagh AM. Evaluation of breast cancer incidence: is the increase due entirely to mammographic screening?. Cancer Causes Control. 1999;10(5):333-7. Exclusion: wrong publication type. [pmid: 10530601].
Harms SE. Multicenter, double-blind, randomized, intraindividual crossover comparison of gadobenate dimeglumine and gadopentetate dimeglumine for breast MR imaging (DETECT trial). Breast Dis. 2012;23(1):37-8. Exclusion: wrong publication type.
Harms SE, Flamig DP. Breast MRI. Clin Imaging. 2001;25(4):227-46. Exclusion: wrong publication type. [pmid: 11566083].
Harris DH, Bates JH, Cress R, et al. Stage of breast cancer diagnosis among medically underserved women in California receiving mammography through a state screening program. Cancer Causes Control. 2004;15(7):721-9. Exclusion: wrong comparison. [pmid: 15280630].
Harris R. Variation of benefits and harms of breast cancer screening with age. J Natl Cancer Inst. Monographs. 1997;(22):139-43. Exclusion: wrong publication type. [pmid: 8998183].
Hartman AR, Daniel BL, Kurian AW, et al. Breast magnetic resonance image screening and ductal lavage in women at high genetic risk for breast carcinoma. Cancer. 2004;100(3):479-89. Exclusion: wrong population. [pmid: 14745863].
Harvey JA, Pinkerton JV, Herman CR. Short-term cessation of hormone replacement therapy and improvement of mammographic specificity. J Natl Cancer Inst. 1997;89(21):1623-5. Exclusion: wrong publication type. [pmid: 9362162].
Haukka J, Byrnes G, Boniol M, et al. Trends in breast cancer mortality in Sweden before and after implementation of mammography screening. PLoS ONE. 2011;6(9):e22422. Exclusion: included in an included systematic review, not directly used. [pmid: 21966354].
Heimann R, Bradley J, Hellman S. The benefits of mammography are not limited to women of ages older than 50 years. Cancer. 1998;82(11):2221-6. Exclusion: wrong comparison. [pmid: 9610702].
Heimann R, Munsell M, McBride R. Mammographically detected breast cancers and the risk of axillary lymph node involvement: is it just the tumor size?. Cancer J. 2002;8(3):276-81. Exclusion: wrong comparison. [pmid: 12074328].
Heinzen MT, Yankaskas BC, Kwok RK. Comparison of woman-specific versus breast-specific data for reporting screening mammography performance. Acad Radiol. 2000;7(4):232-6. Exclusion: wrong outcomes. [pmid: 10766095].
Heleno BM, Lindberg L, Brodersen J. Alternative estimates for the likelihood that a woman with screen-detected breast cancer has had her “life saved” by that screening. Arch Intern Med. 2012;172(8):672. Exclusion: wrong publication type. [pmid: 22529240].
Helmond FA. Breast cancer and hormone-replacement therapy: the Million Women Study. Lancet. 2003;362(9392):1330. author reply -1. Exclusion: wrong publication type. [pmid: 14575988].
Helvie MA. Digital mammography imaging: breast tomosynthesis and advanced applications. Radiol Clin North Am. 2010;48(5):917-29. Exclusion: review not meeting inclusion criteria. [pmid: 20868894].
Helvie MA, Chang JT, Hendrick RE, et al. Reduction in late-stage breast cancer incidence in the mammography era: Implications for overdiagnosis of invasive cancer. Cancer. 2014;120(17):2649-56. Exclusion: wrong outcomes. [pmid: 24840597].
Helvie MA, Hadjiiski L, Makariou E, et al. Sensitivity of noncommercial computer-aided detection system for mammographic breast cancer detection: pilot clinical trial. Radiology. 2004;231(1):208-14. Exclusion: wrong outcomes. [pmid: 14990808].
Hemminki K, Bermejo JL. Effects of screening for breast cancer on its age-incidence relationships and familial risk. Int J Cancer. 2005;117(1):145-9. Exclusion: wrong outcomes. [pmid: 15880571].
Hendrick RE, Cole EB, Pisano ED, et al. Accuracy of soft-copy digital mammography versus that of screen-film mammography according to digital manufacturer: ACRIN DMIST retrospective multireader study. Radiology. 2008;247(1):38-48. Exclusion: wrong comparison. [pmid: 18372463].
Hendrick RE, Cutter GR, Berns EA, et al. Community-based mammography practice: services, charges, and interpretation methods. AJR Am J Roentgenol. 2005;184(2):433-8. Exclusion: wrong outcomes. [pmid: 15671359].
Hendrick RE, Pisano ED, Averbukh A, et al. Comparison of acquisition parameters and breast dose in digital mammography and screen-film mammography in the American College of Radiology Imaging Network digital mammographic imaging screening trial. AJR Am J Roentgenol. 2010;194(2):362-9. Exclusion: wrong comparison. [pmid: 20093597].
Hendrick RE, Smith RA, Rutledge JH 3rd, et al. Benefit of screening mammography in women aged 40-49: a new meta-analysis of randomized controlled trials. J Natl Cancer Inst. Monographs. 1997;(22):87-92. Exclusion: review not meeting inclusion criteria. [pmid: 8978412].
Henry KA, Boscoe FP, Johnson CJ, et al. Breast cancer stage at diagnosis: is travel time important?. J Community Health. 2011;36(6):933-42. Exclusion: wrong outcomes. [pmid: 21461957].
Henry KA, Sherman R, Farber S, et al. The joint effects of census tract poverty and geographic access on late-stage breast cancer diagnosis in 10 US States. Health Place. 2013;21:110-21. Exclusion: wrong outcomes. [pmid: 23454732].
Herrada J, Iyer RB, Atkinson EN, et al. Relative value of physical examination, mammography, and breast sonography in evaluating the size of the primary tumor and regional lymph node metastases in women receiving neoadjuvant chemotherapy for locally advanced breast carcinoma. Clin Cancer Res. 1997;3(9):1565-9. Exclusion: wrong population. [pmid: 9815844].
Hersch J, J J, Barratt A, Irwig L, Houssami N, Jacklyn G, Thornton H, Dhillon H, McCaffery K. Overdetection in breast cancer screening: Development and preliminary evaluation of a decision aid. BMJ Open. 2014;4(9). Exclusion: wrong outcomes.
Heyding RK, Cheung AM, Mocarski EJM, et al. A community-based intervention to increase screening mammography among disadvantaged women at an inner-city drop-in center. Women Health. 2005;41(1):21-31. Exclusion: wrong outcomes. [pmid: 16048866].
Heyes GJ, Mill AJ, Charles MW. Enhanced biological effectiveness of low energy X-rays and implications for the UK breast screening programme. Br J Radiol. 2006;79(939):195-200. Exclusion: wrong publication type. [pmid: 16498030].
Heyes GJ, Mill AJ, Charles MW. Mammography-oncogenecity at low doses. J Radiol Prot. 2009;29(2A):A123-32. Exclusion: wrong population. [pmid: 19454801].
Heywang-Kobrunner SH, Viehweg P, Heinig A, et al. Contrast-enhanced MRI of the breast: accuracy, value, controversies, solutions. Eur J Radiol. 1997;24(2):94-108. Exclusion: wrong study design for key question. [pmid: 9097051].
Hider P, Nicholas B. The early detection and diagnosis of breast cancer: a literature review – an update. NZHTA REPORT. 1999;2(2). Exclusion: review not meeting inclusion criteria.
Highfield L. Spatial patterns of breast cancer incidence and uninsured women of mammography screening age. Breast J. 2013;19(3):293-301. Exclusion: wrong outcomes. [pmid: 23521583].
Hill DA, Nibbe A, Royce ME, et al. Method of detection and breast cancer survival disparities in Hispanic women. Cancer Epidemiol Biomarkers Prev. 2010;19(10):2453-60. Exclusion: wrong comparison. [pmid: 20841385].
Hillman BJ, Harms SE, Stevens G, et al. Diagnostic performance of a dedicated 1.5-T breast MR imaging system. Radiology. 2012;265(1):51-8. Exclusion: wrong intervention. [pmid: 22923716].
Hirose K, Hamajima N, Takezaki T, et al. Physical exercise reduces risk of breast cancer in Japanese women. Cancer Sci. 2003;94(2):193-9. Exclusion: wrong outcomes. [pmid: 12708496].
Hislop TG, Harris SR, Jackson J, et al. Satisfaction and anxiety for women during investigation of an abnormal screening mammogram. Breast Cancer Res Treat. 2002;76(3):245-54. Exclusion: included in an included systematic review, not directly used. [pmid: 12462385].
Hislop TG, Worth AJ, Kan L, et al. Post screen-detected breast cancer within the Screening Mammography Program of British Columbia. Breast Cancer Res Treat. 1997;42(3):235-42. Exclusion: wrong outcomes. [pmid: 9065607].
Ho WT, Lam PWT. Clinical performance of computer-assisted detection (CAD) system in detecting carcinoma in breasts of different densities. Clin Radiol. 2003;58(2):133-6. Exclusion: wrong outcomes. [pmid: 12623042].
Hoerger TJ, Ekwueme DU, Miller JW, et al. Estimated effects of the National Breast and Cervical Cancer Early Detection Program on breast cancer mortality. Am J Prev Med. 2011;40(4):397-404. Exclusion: wrong study design for key question. [pmid: 21406272].
Hoff SR, Abrahamsen A-L, Samset JH, et al. Breast cancer: missed interval and screening-detected cancer at full-field digital mammography and screen-film mammography-- results from a retrospective review. [Erratum appears in Radiology. 2013 Jan;266(1):367]. Radiology. 2012;264(2):378-86. Exclusion: wrong comparison. [pmid: 22700555].
Hoff SR, Samset JH, Abrahamsen A-L, et al. Missed and true interval and screen-detected breast cancers in a population based screening program. Acad Radiol. 2011;18(4):454-60. Exclusion: wrong outcomes. [pmid: 21216632].
Hoffman RM, Lewis CL, Pignone MP, et al. Decision-making processes for breast, colorectal, and prostate cancer screening: the DECISIONS survey. Med Decis Making. 2010;30(5 Suppl):53s-64s. Exclusion: wrong outcomes. [pmid: 20881154].
Hofvind S. Organised mammographic screening--more benefits than harms. Tidsskr Nor Laegeforen. 2013;133(6):619-20. Exclusion: wrong publication type. [pmid: 23552154].
Hofvind S, Geller B, Vacek PM, et al. Using the European guidelines to evaluate the Norwegian Breast Cancer Screening Program. Eur J Epidemiol. 2007;22(7):447-55. Exclusion: wrong comparison. [pmid: 17594526].
Hofvind S, Geller BM, Rosenberg RD, et al. Screening-detected breast cancers: discordant independent double reading in a population-based screening program. Radiology. 2009;253(3):652-60. Exclusion: wrong comparison. [pmid: 19789229].
Hofvind S, Geller BM, Skelly J, et al. Sensitivity and specificity of mammographic screening as practised in Vermont and Norway. Br J Radiol. 2012;85(1020):e1226-32. Exclusion: wrong outcomes. [pmid: 22993383].
Hofvind S, Moller B, Thoresen S, et al. Use of hormone therapy and risk of breast cancer detected at screening and between mammographic screens. Int J Cancer. 2006;118(12):3112-7. Exclusion: wrong comparison. [pmid: 16395702].
Hofvind S, Ponti A, Patnick J, et al. False-positive results in mammographic screening for breast cancer in Europe: a literature review and survey of service screening programmes. J Med Screen. Suppl 1. 2012;19:57-66. Exclusion: review not meeting inclusion criteria. [pmid: 22972811].
Hofvind S, Sakshaug S, Ursin G, et al. Breast cancer incidence trends in Norway--explained by hormone therapy or mammographic screening?. Int J Cancer. 2012;130(12):2930-8. Exclusion: wrong study design for key question. [pmid: 21732346].
Hofvind S, Sorum R, Thoresen S. Incidence and tumor characteristics of breast cancer diagnosed before and after implementation of a population-based screening-program. Acta Oncol. 2008;47(2):225-31. Exclusion: wrong outcomes. [pmid: 17851868].
Hofvind S, Thoresen S, Tretli S. The cumulative risk of a false-positive recall in the Norwegian Breast Cancer Screening Program. Cancer. 2004;101(7):1501-7. Exclusion: wrong study design for key question. [pmid: 15378474].
Hofvind S, Vacek PM, Skelly J, et al. Comparing screening mammography for early breast cancer detection in Vermont and Norway. J Natl Cancer Inst. 2008;100(15):1082-91. Exclusion: wrong comparison. [pmid: 18664650].
Holland DW, Boucher LD, Mortimer JE. Tubular breast cancer experience at Washington University: a review of the literature. Clin Breast Cancer. 2001;2(3):210-4. Exclusion: review not meeting inclusion criteria. [pmid: 11899414].
Holowaty PH, Miller AB, Baines CJ, et al. Canadian National breast screening study: First screen results as predictors of future breast cancer risk. Cancer Epidemiol Biomarkers Prev. 1993;2(1):11-9. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 8420606].
Hooley RJ, Greenberg KL, Stackhouse RM, et al. Screening US in patients with mammographically dense breasts: initial experience with Connecticut Public Act 09-41. Radiology. 2012;265(1):59-69. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 22723501].
Horn J, Åsvold BO, Opdahl S, et al. Reproductive factors and the risk of breast cancer in old age: a Norwegian cohort study. Breast Cancer Res Treat. 2013;139(1):237-43. Exclusion: wrong comparison. [pmid: 23605085].
Horsch K, Giger ML, Metz CE. Potential effect of different radiologist reporting methods on studies showing benefit of CAD. Acad Radiol. 2008;15(2):139-52. Exclusion: wrong outcomes. [pmid: 18206613].
Horsch K, Giger ML, Vyborny CJ, et al. Performance of computer-aided diagnosis in the interpretation of lesions on breast sonography. Acad Radiol. 2004;11(3):272-80. Exclusion: wrong outcomes. [pmid: 15035517].
Hou M-F, Chuang H-Y, Ou-Yang F, et al. Comparison of breast mammography, sonography and physical examination for screening women at high risk of breast cancer in taiwan. Ultrasound Med Biol. 2002;28(4):415-20. Exclusion: studies outside of search dates. [pmid: 12049952].
Hou S-I, Sealy D-A, Kabiru CW. Closing the disparity gap: cancer screening interventions among Asians--a systematic literature review. Asian Pac J Cancer Prev. 2011;12(11):3133-9. Exclusion: review not meeting inclusion criteria. [pmid: 22394003].
Houssami N, Cuzick J, Dixon JM. The prevention, detection, and management of breast cancer. Med J Aust. 2006;184(5):230-4. Exclusion: wrong publication type. [pmid: 16515434].
Houssami N, French J, Brennan M, et al. Breast cancer--new and emerging technologies for diagnosis and management. Aust Fam Physician. 2005;34(8):657-61. Exclusion: review not meeting inclusion criteria. [pmid: 16113703].
Houssami N, Given-Wilson R. Incorporating new technologies into clinical practice without evidence of effectiveness in prospective studies: computer-aided detection (CAD) in breast screening reinforces the need for better initial evaluation. Breast. 2007;16(3):219-21. Exclusion: wrong publication type. [pmid: 17512732].
Houssami N, Given-Wilson R, Ciatto S. Early detection of breast cancer: overview of the evidence on computer-aided detection in mammography screening. J Med Imaging Radiat Oncol. 2009;53(2):171-6. Exclusion: review not meeting inclusion criteria. [pmid: 19527363].
Houssami N, Kerlikowske K. The impact of breast density on breast cancer risk and on breast screening. Current Breast Cancer Reports. 2012;4(2):161-8. Exclusion: wrong outcomes.
Houssami N, Macaskill P, Bernardi D, et al. Breast screening using 2D-mammography or integrating digital breast tomosynthesis (3D-mammography) for single-reading or double-reading--evidence to guide future screening strategies. Eur J Cancer. 2014;50(10):1799-807. Exclusion: wrong comparison. [pmid: 24746887].
Howard JM. Breast density changes associated with hormone replacement therapy in postmenopausal women. Effects on the specificity and sensitivity of mamographic screening. Eur J Gynaecol Oncol. 2006;27(1):104. author reply. Exclusion: wrong publication type. [pmid: 16550985].
Howarth D, Sillar R, Lan L, et al. Scintimammography: an adjunctive test for the detection of breast cancer. Med J Aust. 1999;170(12):588-91. Exclusion: wrong intervention. [pmid: 10416428].
Howe GR. Radiation and screening. Radiat Res. 2005;163(6):693-4. Exclusion: wrong publication type. [pmid: 16044493].
Hristova L, Hakama M. Effect of screening for cancer in the Nordic countries on deaths, cost and quality of life up to the year 2017. Acta Oncol. Suppl 9. 1997;36:1-60. Exclusion: review not meeting inclusion criteria. [pmid: 9143316].
Huang Z, Willett WC, Colditz GA, et al. Waist circumference, waist:hip ratio, and risk of breast cancer in the Nurses' Health Study. Am J Epidemiol. 1999;150(12):1316-24. Exclusion: wrong outcomes. [pmid: 10604774].
Hubbard RA, Miglioretti DL. A semiparametric censoring bias model for estimating the cumulative risk of a false-positive screening test under dependent censoring. Biometrics. 2013;69(1):245-53. Exclusion: wrong study design for key question. [pmid: 23383717].
Hubbard RA, Miglioretti DL, Smith RA. Modelling the cumulative risk of a false-positive screening test. Stat Methods Med Res. 2010;19(5):429-49. Exclusion: wrong study design for key question. [pmid: 20356857].
Hughes KS, Schnaper LA, Bellon JR, et al. Lumpectomy plus tamoxifen with or without irradiation in women age 70 years or older with early breast cancer: long-term follow-up of CALGB 9343. J Clin Oncol. 2013;31(19):2382-7. Exclusion: wrong intervention. [pmid: 23690420].
Hughes KS, Schnaper LA, Berry D, et al. Lumpectomy plus tamoxifen with or without irradiation in women 70 years of age or older with early breast cancer. N Engl J Med. 2004;351(10):971-7. Exclusion: wrong intervention. [pmid: 15342805].
Hunt KA, Sickles EA. Effect of obesity on screening mammography: outcomes analysis of 88,346 consecutive examinations. AJR Am J Roentgenol. 2000;174(5):1251-5. Exclusion: wrong comparison. [pmid: 10789771].
Huo Z, Giger ML, Vyborny CJ, et al. Automated computerized classification of malignant and benign masses on digitized mammograms. Acad Radiol. 1998;5(3):155-68. Exclusion: wrong intervention. [pmid: 9522881].
Hupse R, Samulski M, Lobbes MB, et al. Computer-aided detection of masses at mammography: interactive decision support versus prompts. Radiology. 2013;266(1):123-9. Exclusion: wrong intervention. [pmid: 23091171].
Hutton J, Walker LG, Gilbert FJ, et al. Psychological impact and acceptability of magnetic resonance imaging and X-ray mammography: the MARIBS Study. Br J Cancer. 2011;104(4):578-86. Exclusion: wrong population. [pmid: 21326245].
Hwang ES, Cody HS 3rd. Does the proven benefit of mammography extend to breast cancer patients over age 70?. South Med J. 1998;91(6):522-6. Exclusion: wrong study design for key question. [pmid: 9634112].
Hylton NM. Evaluation of gadobenate dimeglumine for contrast-enhanced MRI of the breast. AJR Am J Roentgenol. 2003;181(3):677-8. Exclusion: wrong publication type. [pmid: 12933458].
Iared W, Shigueoka DC, Torloni MR, et al. Comparative evaluation of digital mammography and film mammography: systematic review and meta-analysis. Sao Paulo Med J. 2011;129(4):250-60. Exclusion: wrong comparison. [pmid: 21971901].
Ichikawa LE, Barlow WE, Anderson ML, et al. Time trends in radiologists' interpretive performance at screening mammography from the community-based Breast Cancer Surveillance Consortium, 1996-2004. Radiology. 2010;256(1):74-82. Exclusion: wrong outcomes. [pmid: 20505059].
Ikeda DM, Birdwell RL, O'Shaughnessy KF, et al. Analysis of 172 subtle findings on prior normal mammograms in women with breast cancer detected at follow-up screening. Radiology. 2003;226(2):494-503. Exclusion: wrong outcomes. [pmid: 12563145].
Ildefonso C, Vazquez J, Guinea O, et al. The mammographic appearance of breast carcinomas of invasive ductal type: relationship with clinicopathological parameters, biological features and prognosis. Eur J Obstet Gynecol Reprod Biol. 2008;136(2):224-31. Exclusion: wrong population. [pmid: 17118521].
Institute for Clinical Systems I. Computer aided detection of breast cancer. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: wrong publication type.
Institute for Clinical Systems I. Magnetic resonance imaging (MRI) for the detection of breast abnormalities. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: wrong publication type.
Irvin VL, Kaplan RM. Screening Mammography & Breast Cancer Mortality: Meta-Analysis of Quasi-Experimental Studies. PLoS ONE. 2014;9(6):e98105. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 24887150].
Irwig L, Houssami N, van Vliet C. New technologies in screening for breast cancer: a systematic review of their accuracy. Br J Cancer. 2004;90(11):2118-22. Exclusion: review not meeting inclusion criteria. [pmid: 15150556].
Irwin ML, Crumley D, McTiernan A, et al. Physical activity levels before and after a diagnosis of breast carcinoma: the Health, Eating, Activity, and Lifestyle (HEAL) study. Cancer. 2003;97(7):1746-57. Exclusion: wrong outcomes. [pmid: 12655532].
Ishida DN, Toomata-Mayer TF, Braginsky NS. Beliefs and attitudes of Samoan women toward early detection of breast cancer and mammography utilization. Cancer. 2001;91(1 Suppl):262-6. Exclusion: wrong outcomes. [pmid: 11148591].
Ishida T, Suzuki A, Kawai M, et al. A randomized controlled trial to verify the efficacy of the use of ultrasonography in breast cancer screening aged 40-49 (J-START): 76 196 women registered. Jpn J Clin Oncol. 2014;44(2):134-40. Exclusion: wrong publication type. [pmid: 24407835].
J H. Mammography screening among women aged 40-49 years shows no benefit. CMAJ : Canadian Medical Association journal. 2002;167(8):898. Exclusion: wrong publication type. [pmid: 12406951].
Jacobellis J, Cutter G. Mammography screening and differences in stage of disease by race/ethnicity. Am J Public Health. 2002;92(7):1144-50. Exclusion: wrong comparison. [pmid: 12084699].
Jafri NF, Ayyala RS, Ozonoff A, et al. Screening mammography: does ethnicity influence patient preferences for higher recall rates given the potential for earlier detection of breast cancer?. Radiology. 2008;249(3):785-91. Exclusion: wrong outcomes. [pmid: 18941163].
Jain MG, Miller AB, Rohan TE, et al. Body mass index and mortality in women: follow-up of the Canadian National Breast Screening Study cohort. Int J Obes (Lond). 2005;29(7):792-7. Exclusion: wrong intervention. [pmid: 15809663].
Jalalian A, Mashohor SBT, Mahmud HR, et al. Computer-aided detection/diagnosis of breast cancer in mammography and ultrasound: a review. Clin Imaging. 2013;37(3):420-6. Exclusion: review not meeting inclusion criteria. [pmid: 23153689].
Jamal N, Ng KH, Looi LM, et al. Quantitative assessment of breast density from digitized mammograms into Tabar's patterns. Phys Med Biol. 2006;51(22):5843-57. Exclusion: wrong outcomes. [pmid: 17068368].
James JJ, Cornford EJ. Does computer-aided detection have a role in the arbitration of discordant double-reading opinions in a breast-screening programme?. Clin Radiol. 2009;64(1):46-51. Exclusion: wrong intervention. [pmid: 19070697].
Jamrozik K, Byrne MJ, Dewar JM, et al. The effect of mammographic screening on invasive breast cancer in Western Australia. Med J Aust. 2000;172(5):203-6. Exclusion: wrong comparison. [pmid: 10776390].
Jansen JT, Zoetelief J. Assessment of lifetime gained as a result of mammographic breast cancer screening using a computer model. Br J Radiol. 1997;70(834):619-28. Exclusion: wrong study design for key question. [pmid: 9227256].
Jansen JT, Zoetelief J. Optimisation of mammographic breast cancer screening using a computer simulation model. Eur J Radiol. 1997;24(2):137-44. Exclusion: wrong intervention. [pmid: 9097056].
Jatoi I. The impact of advances in treatment on the efficacy of mammography screening. Prev Med. 2011;53(3):103-4. Exclusion: wrong publication type. [pmid: 21722664].
Jatoi I. Screening clinical breast examination. Surg Clin North Am. 2003;83(4):789-801. Exclusion: wrong intervention. [pmid: 12875596].
Jatoi I, Zhu K, Shah M, et al. Psychological distress in U.S. women who have experienced false-positive mammograms. Breast Cancer Res Treat. 2006;100(2):191-200. Exclusion: studies outside of search dates. [pmid: 16773439].
Jensen A, Vejborg I, Severinsen N, et al. Performance of clinical mammography: a nationwide study from Denmark. Int J Cancer. 2006;119(1):183-91. Exclusion: wrong intervention. [pmid: 16450388].
Jensen AR, Garne JP, Storm HH, et al. Does stage at diagnosis explain the difference in survival after breast cancer in Denmark and Sweden?. Acta Oncol. 2004;43(8):719-26. Exclusion: wrong comparison. [pmid: 15764216].
Jensen AR, Madsen AH, Overgaard J. Trends in breast cancer during three decades in Denmark: stage at diagnosis, surgical management and survival. Acta Oncol. 2008;47(4):537-44. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 18465319].
Jesneck JL, Lo JY, Baker JA. Breast mass lesions: computer-aided diagnosis models with mammographic and sonographic descriptors. Radiology. 2007;244(2):390-8. Exclusion: wrong outcomes. [pmid: 17562812].
Jha MK, Avlonitis VS, Griffith CD, et al. Aggressive local treatment for screen-detected DCIS results in very low rates of recurrence. Eur J Surg Oncol. 2001;27(5):454-8. Exclusion: wrong intervention. [pmid: 11504515].
Ji J, Hemminki K. Risk for contralateral breast cancers in a population covered by mammography: effects of family history, age at diagnosis and histology. Breast Cancer Res Treat. 2007;105(2):229-36. Exclusion: wrong population. [pmid: 17115107].
Jiang Y, Metz CE. BI-RADS data should not be used to estimate ROC curves. Radiology. 2010;256(1):29-31. Exclusion: wrong publication type. [pmid: 20574083].
Jiang Y, Miglioretti DL, Metz CE, et al. Breast cancer detection rate: designing imaging trials to demonstrate improvements. Radiology. 2007;243(2):360-7. Exclusion: wrong outcomes. [pmid: 17456866].
Jiang Y, Nishikawa RM, Schmidt RA, et al. Improving breast cancer diagnosis with computer-aided diagnosis. Acad Radiol. 1999;6(1):22-33. Exclusion: wrong intervention. [pmid: 9891149].
Jimenez-Lee R, Oslak SG, Hedberg K, et al. Surgical outcomes of a breast cancer-screening program for low-income women. Arch Surg. 2003;138(8):884-90. Exclusion: wrong comparison. [pmid: 12912748].
Joensuu H, Asola R, Holli K, et al. Delayed diagnosis and large size of breast cancer after a false negative mammogram. Eur J Cancer. 1994;30A:1299-302. Exclusion: wrong outcomes. [pmid: 7999417].
Joffe MM, Byrne C, Colditz GA. Postmenopausal hormone use, screening, and breast cancer: characterization and control of a bias. Epidemiology. 2001;12(4):429-38. Exclusion: wrong study design for key question. [pmid: 11416781].
John EM, Phipps AI, Knight JA, et al. Medical radiation exposure and breast cancer risk: findings from the Breast Cancer Family Registry. Int J Cancer. 2007;121(2):386-94. Exclusion: wrong intervention. [pmid: 17372900].
Johns LE, Moss SM, Age Trial Management G. False-positive results in the randomized controlled trial of mammographic screening from age 40 (“Age” trial). Cancer Epidemiol Biomarkers Prev. 2010;19(11):2758-64. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 20837718].
Johnson A. ‘Overdiagnosis’ and mortality in breast cancer screening. J R Soc Med. 2012;105(7):317-9. Exclusion: wrong publication type. [pmid: 22843651].
Johnson A, Shekhdar J. Detection by screening mammography is a powerful independent predictor of survival in women diagnosed with breast cancer. Breast. 2005;14(1):79. Exclusion: wrong publication type. [pmid: 15695088].
Johnson ET. Breast cancer racial differences before age 40--implications for screening. J Natl Med Assoc. 2002;94(3):149-56. Exclusion: wrong population. [pmid: 11918384].
Johnson KS, Baker JA, Lee SS, et al. Suspicious breast lesions detected at 3.0 T magnetic resonance imaging: clinical and histological outcomes. Acad Radiol. 2012;19(6):667-74. Exclusion: wrong outcomes. [pmid: 22459645].
Jonas CR, McCullough ML, Teras LR, et al. Dietary glycemic index, glycemic load, and risk of incident breast cancer in postmenopausal women. Cancer Epidemiol Biomarkers Prev. 2003;12(6):573-7. Exclusion: wrong outcomes. [pmid: 12815005].
Jones BA, Kasi SV, Curnen MG, et al. Severe obesity as an explanatory factor for the black/white difference in stage at diagnosis of breast cancer. Am J Epidemiol. 1997;146(5):394-404. Exclusion: wrong population. [pmid: 9290499].
Jones R, McLean L, Young J, et al. Proportion of cancers detected at the first incident screen which were false negative at the prevalent screen. Breast. 1996;5(5):339-43. Exclusion: wrong comparison.
Jonsson H, Bordas P, Wallin H, et al. Service screening with mammography in Northern Sweden: effects on breast cancer mortality - an update. J Med Screen. 2007;14(2):87-93. Exclusion: included in an included systematic review, not directly used. [pmid: 17626708].
Jonsson H, Johansson R, Lenner P. Increased incidence of invasive breast cancer after the introduction of service screening with mammography in Sweden. Int J Cancer. 2005;117(5):842-7. Exclusion: wrong outcomes. [pmid: 15957172].
Jonsson H, Larsson L-G, Lenner P. Detection of breast cancer with mammography in the first screening round in relation to expected incidence in different age groups. Acta Oncol. 2003;42(1):22-9. Exclusion: wrong outcomes. [pmid: 12665327].
Jonsson H, Nyström L, Tornberg S, et al. Service screening with mammography of women aged 50-69 years in Sweden: effects on mortality from breast cancer. J Med Screen. 2001;8(3):152-60. Exclusion: included in an included systematic review, not directly used. [pmid: 11678556].
Jonsson H, Nyström L, Tornberg S, et al. Service screening with mammography. Long-term effects on breast cancer mortality in the county of Gavleborg, Sweden. [Erratum appears in Breast. 2003 Aug;12(4):297]. Breast. 2003;12(3):183-93. Exclusion: included in an included systematic review, not directly used. [pmid: 14659325].
Jonsson H, Tornberg S, Nyström L, et al. Service screening with mammography of women aged 70-74 years in Sweden. Effects on breast cancer mortality. Cancer Detect Prev. 2003;27(5):360-9. Exclusion: wrong study design for key question. [pmid: 14585323].
Jordan S, Lim L, Vilainerun D, et al. Breast cancer in the Thai Cohort Study: an exploratory case-control analysis. Breast. 2009;18(5):299-303. Exclusion: wrong study design for key question. [pmid: 19800794].
Jorgensen KJ. Mammography screening in Norway caused substantial overdiagnosis and did not reduce late-stage breast cancers. Evid Based Med. 2013;18(2):e17. Exclusion: wrong publication type. [pmid: 22923706].
Jorgensen KJ. Mammography screening is not as good as we hoped. Maturitas. 2010;65(1):1-2. Exclusion: wrong publication type. [pmid: 19939593].
Jorgensen KJ. Mammography screening. Benefits, harms, and informed choice. Dan Med J. 2013;60(4):B4614. Exclusion: review not meeting inclusion criteria. [pmid: 23651722].
Jorgensen KJ, Gotzsche PC. Overdiagnosis in publicly organised mammography screening programmes: systematic review of incidence trends. BMJ. 2009;339:b2587. Exclusion: review not meeting inclusion criteria. [pmid: 19589821].
Jorgensen KJ, Gotzsche PC. Who evaluates public health programmes? A review of the NHS Breast Screening Programme. J R Soc Med. 2010;103(1):14-20. Exclusion: wrong publication type. [pmid: 20056665].
Jorgensen KJ, Keen JD, Gotzsche PC. Is mammographic screening justifiable considering its substantial overdiagnosis rate and minor effect on mortality?. Radiology. 2011;260(3):621-7. Exclusion: wrong publication type. [pmid: 21846758].
Jørgensen KJ, Zahl PH, Gøtzsche PC. Breast cancer mortality in organised mammography screening in Denmark: comparative study. BMJ. 2010;340:c1241. Exclusion: included in an included systematic review, not directly used. [pmid: 20332505].
Judkins AF, Akins J. Breast cancer: initial diagnosis and current treatment options. Nurs Clin North Am. 2001;36(3):527-42. Exclusion: wrong publication type. [pmid: 11532667].
Juel I-M, Skaane P, Hoff SR, et al. Screen-film mammography versus full-field digital mammography in a population-based screening program: The Sogn and Fjordane study. Acta Radiol. 2010;51(9):962-8. Exclusion: wrong comparison. [pmid: 20942729].
Jung HJ, Hahn SY, Choi H-Y, et al. Breast sonographic elastography using an advanced breast tissue-specific imaging preset: initial clinical results. J Ultrasound Med. 2012;31(2):273-80. Exclusion: wrong outcomes. [pmid: 22298871].
Junod B, Zahl P-H, Kaplan RM, et al. An investigation of the apparent breast cancer epidemic in France: screening and incidence trends in birth cohorts. BMC Cancer. 2011;11:401. Exclusion: wrong outcomes. [pmid: 21936933].
Kaaks R, Van Noord PA, Den Tonkelaar I, et al. Breast-cancer incidence in relation to height, weight and body-fat distribution in the Dutch “DOM” cohort. Int J Cancer. 1998;76(5):647-51. Exclusion: wrong outcomes. [pmid: 9610720].
Kaas R, Muller SH, Hart AAM, et al. Stage of breast cancers found during the surveillance of women with a familial or hereditary risk. Eur J Surg Oncol. 2008;34(5):501-7. Exclusion: wrong population. [pmid: 17555911].
Kabat GC, Heo M, Kamensky V, et al. Adult height in relation to risk of cancer in a cohort of Canadian women. Int J Cancer. 2013;132(5):1125-32. Exclusion: wrong outcomes. [pmid: 22753236].
Kacl GM, Liu P, Debatin JF, et al. Detection of breast cancer with conventional mammography and contrast-enhanced MR imaging. Eur Radiol. 1998;8(2):194-200. Exclusion: wrong intervention. [pmid: 9477265].
Kaida H, Ishibashi M, Fujii T, et al. Improved detection of breast cancer on FDG-PET cancer screening using breast positioning device. Ann Nucl Med. 2008;22(2):95-101. Exclusion: wrong intervention. [pmid: 18311533].
Kaiser JS, Helvie MA, Blacklaw RL, et al. Palpable breast thickening: role of mammography and US in cancer detection. Radiology. 2002;223(3):839-44. Exclusion: wrong population. [pmid: 12034957].
Kalager M, Haldorsen T, Bretthauer M, et al. Improved breast cancer survival following introduction of an organized mammography screening program among both screened and unscreened women: a population-based cohort study. Breast Cancer Res. 2009;11(4):R44. Exclusion: wrong comparison. [pmid: 19575807].
Kalager M, Zelen M, Langmark F, et al. Effect of screening mammography on breast-cancer mortality in Norway. N Engl J Med. 2010;363(13):1203-10. Exclusion: included in an included systematic review, not directly used. [pmid: 20860502].
Kalli S, Freer PE, Rafferty EA. Lesions of the skin and superficial tissue at breast MR imaging. Radiographics. 2010;30(7):1891-913. Exclusion: wrong publication type. [pmid: 21057126].
Kamineni A, Anderson ML, White E, et al. Body mass index, tumor characteristics, and prognosis following diagnosis of early-stage breast cancer in a mammographically screened population. Cancer Causes Control. 2013;24(2):305-12. Exclusion: wrong comparison. [pmid: 23224272].
Kandula NR, Wen M, Jacobs EA, et al. Low rates of colorectal, cervical, and breast cancer screening in Asian Americans compared with non-Hispanic whites: Cultural influences or access to care?. Cancer. 2006;107(1):184-92. Exclusion: wrong outcomes. [pmid: 16721803].
Kane KY, Lindbloom EJ, Stevermer JJ. Does mammography add any benefit to a thorough clinical breast examination (CBE)?. Journal of Family Practice. 2000;49(12):1078. Exclusion: wrong publication type. [pmid: 11132055].
Kann PE, Bradley C, Lane DS. Outcomes of recommendations for breast biopsies in women receiving mammograms from a county health van. Public Health Rep. 1998;113(1):71-4. Exclusion: wrong intervention. [pmid: 9475937].
Karssemeijer N, Hendriks JH. Computer-assisted reading of mammograms. Eur Radiol. 1997;7(5):743-8. Exclusion: wrong publication type. [pmid: 9166576].
Katalinic A, Bartel C, Raspe H, et al. Beyond mammography screening: quality assurance in breast cancer diagnosis (The QuaMaDi Project). Br J Cancer. 2007;96(1):157-61. Exclusion: wrong comparison. [pmid: 17179994].
Katapodi MC, Dodd MJ, Lee KA, et al. Underestimation of breast cancer risk: influence on screening behavior. Oncol Nurs Forum. 2009;36(3):306-14. Exclusion: studies outside of search dates. [pmid: 19403452].
Kauhava L, Immonen-Raiha P, Parvinen I, et al. Population-based mammography screening results in substantial savings in treatment costs for fatal breast cancer. Breast Cancer Res Treat. 2006;98(2):143-50. Exclusion: wrong outcomes. [pmid: 16538536].
Kavanagh AM, Cawson J, Byrnes GB, et al. Hormone replacement therapy, percent mammographic density, and sensitivity of mammography. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1060-4. Exclusion: wrong outcomes. [pmid: 15894653].
Kavanagh AM, Giles GG, Mitchell H, et al. The sensitivity, specificity, and positive predictive value of screening mammography and symptomatic status. J Med Screen. 2000;7(2):105-10. Exclusion: wrong population. [pmid: 11002452].
Kavanagh AM, Mitchell H, Giles GG. Hormone replacement therapy and accuracy of mammographic screening. Lancet. 2000;355(9200):270-4. Exclusion: studies outside of search dates. [pmid: 10675074].
Kawai M, Kuriyama S, Suzuki A, et al. Effect of screening mammography on breast cancer survival in comparison to other detection methods: a retrospective cohort study. Cancer Sci. 2009;100(8):1479-84. Exclusion: wrong population. [pmid: 19493274].
Keating NL, Kouri EM, He Y, et al. Effect of Massachusetts health insurance reform on mammography use and breast cancer stage at diagnosis. Cancer. 2013;119(2):250-8. Exclusion: wrong outcomes. [pmid: 22833148].
Keavey E, Phelan N, O'Connell AM, et al. Comparison of the clinical performance of three digital mammography systems in a breast cancer screening programme. Br J Radiol. 2012;85(1016):1123-7. Exclusion: wrong outcomes. [pmid: 22096222].
Keen JD. Promoting screening mammography: insight or uptake?. J Am Board Fam Med. 2010;23(6):775-82. Exclusion: wrong publication type. [pmid: 21057074].
Keen JD. Where is the evidence: does computer-aided overdiagnosis save lives?. Radiology. 2010;254(3):989. Exclusion: wrong publication type. [pmid: 20177111].
Keen JD, Keen JE. How does age affect baseline screening mammography performance measures? A decision model. BMC Med Inform Decis Mak. 2008;8:40. Exclusion: wrong study design for key question. [pmid: 18803871].
Keen JD, Keen JE. What is the point: will screening mammography save my life?. BMC Med Inform Decis Mak. 2009;9:18. Exclusion: wrong study design for key question. [pmid: 19341448].
Kelly KM, Dean J, Comulada WS, et al. Breast cancer detection using automated whole breast ultrasound and mammography in radiographically dense breasts. Eur Radiol. 2010;20(3):734-42. Exclusion: wrong comparison. [pmid: 19727744].
Kennedy DA, Lee T, Seely D. A comparative review of thermography as a breast cancer screening technique. Integ Cancer Ther. 2009;8(1):9-16. Exclusion: review not meeting inclusion criteria.
Kennedy G, Markert M, Alexander JR, et al. Predictive value of BI-RADS classification for breast imaging in women under age 50. Breast Cancer Res Treat. 2011;130(3):819-23. Exclusion: wrong outcomes. [pmid: 21748292].
Kenney PJ, Ellison MC. Ductal lavage in the screening of high-risk women. Curr Womens Health Rep. 2003;3(2):151-5. Exclusion: wrong publication type. [pmid: 12628085].
Kerlikowske K. Efficacy of screening mammography among women aged 40 to 49 years and 50 to 69 years: comparison of relative and absolute benefit. J Natl Cancer Inst. Monographs. 1997;(22):79-86. Exclusion: review not meeting inclusion criteria.
Kerlikowske K. How do personal characteristics affect sensitivity and specificity of mammography?. Nat Clin Pract Oncol. 2005;2(1):16-7. Exclusion: wrong publication type. [pmid: 16264848].
Kerlikowske K. Screening mammography in women less than age 50 years. Curr Opin Obstet Gynecol. 2012;24(1):38-43. Exclusion: review not meeting inclusion criteria. [pmid: 22037165].
Kerlikowske K, Barclay J. Outcomes of modern screening mammography. J Natl Cancer Inst. Monographs. 1997;(22):105-11. Exclusion: review not meeting inclusion criteria.
Kerlikowske K, Creasman J, Leung JWT, et al. Differences in screening mammography outcomes among White, Chinese, and Filipino women. Arch Intern Med. 2005;165(16):1862-8. Exclusion: wrong comparison. [pmid: 16157830].
Kerlikowske K, Grady D, Barclay J, et al. Effect of age, breast density, and family history on the sensitivity of first screening mammography. JAMA. 1996;276(1):33-8. Exclusion: wrong comparison. [pmid: 8667536].
Kerlikowske K, Grady D, Barclay J, et al. Likelihood ratios for modern screening mammography. Risk of breast cancer based on age and mammographic interpretation. JAMA. 1996;276(1):39-43. Exclusion: wrong outcomes. [pmid: 8667537].
Kerlikowske K, Grady D, Rubin SM, et al. Efficacy of screening mammography. A meta-analysis. JAMA. 1995;273(2):149-54. Exclusion: review not meeting inclusion criteria. [pmid: 7799496].
Kerlikowske K, Hubbard RA, Miglioretti DL, et al. Comparative effectiveness of digital versus film-screen mammography in community practice in the United States: a cohort study. [Summary for patients in Ann Intern Med 2011 Oct 18;155(8):I30; PMID: 22007060]. Ann Intern Med. 2011;155(8):493-502. Exclusion: wrong comparison. [pmid: 22007043].
Kerlikowske K, Ichikawa L, Miglioretti DL, et al. Longitudinal measurement of clinical mammographic breast density to improve estimation of breast cancer risk. J Natl Cancer Inst. 2007;99(5):386-95. Exclusion: wrong outcomes. [pmid: 17341730].
Kerlikowske K, Salzmann P, Phillips KA, et al. Continuing screening mammography in women aged 70 to 79 years: impact on life expectancy and cost-effectiveness. JAMA. 1999;282(22):2156-63. Exclusion: wrong study design for key question. [pmid: 10591338].
Kerlikowske K, Smith-Bindman R, Abraham LA, et al. Breast cancer yield for screening mammographic examinations with recommendation for short-interval follow-up. Radiology. 2005;234(3):684-92. Exclusion: wrong intervention. [pmid: 15734926].
Kerlikowske K, Walker R, Miglioretti DL, et al. Obesity, mammography use and accuracy, and advanced breast cancer risk. J Natl Cancer Inst. 2008;100(23):1724-33. Exclusion: wrong comparison. [pmid: 19033562].
Kerner JF, Mandelblatt JS, Silliman RA, et al. Screening mammography and breast cancer treatment patterns in older women. Breast Cancer Res Treat. 2001;69(1):81-91. Exclusion: wrong outcomes. [pmid: 11759831].
Khanna R, Bhanegaonkar A, Colsher P, et al. Breast cancer screening, incidence, and mortality in West Virginia. W V Med J. 2009;105. Spec No:24-32. Exclusion: wrong intervention.
Khoo LAL, Taylor P, Given-Wilson RM. Computer-aided detection in the United Kingdom National Breast Screening Programme: prospective study. Radiology. 2005;237(2):444-9. Exclusion: wrong intervention. [pmid: 16244252].
Kiely BE, Hossack LK, Shadbolt CL, et al. Practicalities of developing a breast magnetic resonance imaging screening service for women at high risk for breast cancer. ANZ J Surg. 2011;81(10):688-93. Exclusion: wrong population. [pmid: 22295308].
Kim EK, Ko KH, Oh KK, et al. Clinical application of the BI-RADS final assessment to breast sonography in conjunction with mammography. AJR Am J Roentgenol. 2008;190(5):1209-15. Exclusion: wrong intervention. [pmid: 18430833].
Kim SH, Kang BJ, Choi BG, et al. Radiologists' performance for detecting lesions and the interobserver variability of automated whole breast ultrasound. Korean J Radiol. 2013;14(2):154-63. Exclusion: wrong outcomes. [pmid: 23482698].
Kim SJ, Chang JM, Cho N, et al. Outcome of breast lesions detected at screening ultrasonography. Eur J Radiol. 2012;81(11):3229-33. Exclusion: wrong comparison. [pmid: 22591758].
Kim SJ, Moon WK, Cho N, et al. Computer-aided detection in digital mammography: comparison of craniocaudal, mediolateral oblique, and mediolateral views. Radiology. 2006;241(3):695-701. Exclusion: wrong intervention. [pmid: 17114620].
Kim SJ, Moon WK, Cho N, et al. Computer-aided detection in full-field digital mammography: sensitivity and reproducibility in serial examinations. Radiology. 2008;246(1):71-80. Exclusion: wrong intervention. [pmid: 18096530].
Kim SJ, Moon WK, Kim S-Y, et al. Comparison of two software versions of a commercially available computer-aided detection (CAD) system for detecting breast cancer. Acta Radiol. 2010;51(5):482-90. Exclusion: wrong comparison. [pmid: 20429765].
Kim SJ, Moon WK, Seong MH, et al. Computer-aided detection in digital mammography: false-positive marks and their reproducibility in negative mammograms. Acta Radiol. 2009;50(9):999-1004. Exclusion: wrong outcomes. [pmid: 19863409].
Kim WH, Moon WK, Kim SJ, et al. Ultrasonographic assessment of breast density. Breast Cancer Res Treat. 2013;138(3):851-9. Exclusion: wrong outcomes. [pmid: 23568482].
Kimmick G, Muss HB. Breast cancer in older women. Clin Geriatr Med. 1997;13(2):265-82. Exclusion: review not meeting inclusion criteria. [pmid: 9115451].
Kingston N, Thomas I, Johns L, et al. Assessing the amount of unscheduled screening (“contamination”) in the control arm of the UK “Age” Trial. Cancer Epidemiol Biomarkers Prev. 2010;19(4):1132-6. Exclusion: wrong outcomes. [pmid: 20233850].
Kini VR, Vicini FA, Victor SJ, et al. Impact of the mode of detection on outcome in breast cancer patients treated with breast-conserving therapy. Am J Clin Oncol. 1999;22(5):429-35. Exclusion: wrong study design for key question. [pmid: 10521052].
Kitchen PR, Cawson JN, Winch KL, et al. Characteristics and treatment of breast cancers 10 mm or less detected by a mammographic screening programme. Aust N Z J Surg. 1998;68(1):45-9. Exclusion: wrong study design for key question. [pmid: 9440456].
Kitchen PRB, Cawson JN, Moore SE, et al. Margins and outcome of screen-detected breast cancer with extensive in situ component. ANZ J Surg. 2006;76(7):591-5. Exclusion: wrong comparison. [pmid: 16813624].
Kleit AN, Ruiz JF. False positive mammograms and detection controlled estimation. Health Serv Res. 2003;38(4):1207-28. Exclusion: wrong study design for key question. [pmid: 12968824].
Klemi PJ, Parvinen I, Pylkkanen L, et al. Significant improvement in breast cancer survival through population-based mammography screening. Breast. 2003;12(5):308-13. Exclusion: wrong comparison. [pmid: 14659145].
Klemi PJ, Toikkanen S, Rasanen O, et al. Mammography screening interval and the frequency of interval cancers in a population-based screening. Br J Cancer. 1997;75(5):762-6. Exclusion: wrong outcomes. [pmid: 9043038].
Klompenhouwer E, Duijm LM, Voogd A, et al. Re-attendance at biennial screening mammography following a repeated false positive recall. Breast Cancer Res Treat. 2014;145(2):429-37. Exclusion: wrong outcomes. [pmid: 24748569].
Kmietowicz Z. Mammography reduces risk of breast cancer death by 28%, study finds. BMJ. 2014;348:g4062. Exclusion: wrong publication type. [pmid: 24943498].
Ko ES, Han B-K, Kim SM, et al. Comparison of new and established full-field digital mammography systems in diagnostic performance. Korean J Radiol. 2013;14(2):164-70. Exclusion: wrong comparison. [pmid: 23482833].
Ko JM, Nicholas MJ, Mendel JB, et al. Prospective assessment of computer-aided detection in interpretation of screening mammography. AJR Am J Roentgenol. 2006;187(6):1483-91. Exclusion: wrong outcomes. [pmid: 17114541].
Kobetz E, Mendoza AD, Barton B, et al. Mammography use among Haitian women in Miami, Florida: an opportunity for intervention. J Immigr Minor Health. 2010;12(3):418-21. Exclusion: wrong outcomes. [pmid: 18841475].
Kok DL, Chang J-H, Erbas B, et al. Urban-rural differences in the management of screen-detected invasive breast cancer and ductal carcinoma in situ in victoria. ANZ J Surg. 2006;76(11):996-1001. Exclusion: wrong outcomes. [pmid: 17054549].
Kolb TM, Lichy J, Newhouse JH. Comparison of the performance of screening mammography, physical examination, and breast US and evaluation of factors that influence them: an analysis of 27,825 patient evaluations. Radiology. 2002;225(1):165-75. Exclusion: wrong outcomes. [pmid: 12355001].
Kollias J, Sibbering DM, Blamey RW, et al. Screening women aged less than 50 years with a family history of breast cancer. Eur J Cancer. 1998;34(6):878-83. Exclusion: wrong comparison. [pmid: 9797701].
Kong CY, Lee JM, McMahon PM, et al. Using radiation risk models in cancer screening simulations: important assumptions and effects on outcome projections. Radiology. 2012;262(3):977-84. Exclusion: wrong study design for key question. [pmid: 22357897].
Konski A. Clinical and economic outcomes analyses of women developing breast cancer in a managed care organization. Am J Clin Oncol. 2005;28(1):51-7. Exclusion: wrong outcomes. [pmid: 15685035].
Kontos D, Bakic PR, Carton A-K, et al. Parenchymal texture analysis in digital breast tomosynthesis for breast cancer risk estimation: a preliminary study. Acad Radiol. 2009;16(3):283-98. Exclusion: wrong outcomes. [pmid: 19201357].
Kopans DB. Arguments against mammography screening continue to be based on faulty science. Oncologist. 2014;19(2):107-12. Exclusion: wrong publication type. [pmid: 24536051].
Kopans DB. Basic physics and doubts about relationship between mammographically determined tissue density and breast cancer risk. Radiology. 2008;246(2):348-53. Exclusion: wrong publication type. [pmid: 18227535].
Kopans DB. Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2002;94(2):580-1. author reply 1-3. Exclusion: wrong publication type. [pmid: 11900247].
Kopans DB. The Canadian Screening Program: A Different Perspective. AJR Am J Roentgenol. 1990;155(4):748-9. Exclusion: wrong publication type.
Kopans DB. Defending mammography screening amid claims of overdiagnosis. Breast Dis. 2014;25(1):25-7. Exclusion: wrong publication type.
Kopans DB. The most recent breast cancer screening controversy about whether mammographic screening benefits women at any age: nonsense and nonscience. AJR Am J Roentgenol. 2003;180(1):21-6. Exclusion: wrong publication type. [pmid: 12490471].
Kopans DB. Re: Detection of ductal carcinoma in situ in women undergoing screening mammography. J Natl Cancer Inst. 2003;95(6):487. author reply -8. Exclusion: wrong publication type. [pmid: 12644544].
Kopans DB. Screening mammography for women age 40 to 49 years. Ann Intern Med. 2007;147(10):740-1. author reply 1. Exclusion: wrong publication type. [pmid: 18025452].
Kopans DB. Updated results of the trials of screening mammography. Surg Oncol Clin N Am. 1997;6(2):233-63. Exclusion: review not meeting inclusion criteria. [pmid: 9115494].
Kopans DB, Feig SA. The Canadian National Breast Screening Study: a critical review. AJR Am J Roentgenol. 1993;161(4):755-60. Exclusion: wrong publication type. [pmid: 8372752].
Kopans DB, Halpern E, Hulka CA. Statistical power in breast cancer screening trials and mortality reduction among women 40-49 years of age with particular emphasis on the National Breast Screening Study of Canada. Cancer. 1994;74(4):1196-203. Exclusion: wrong publication type. [pmid: 8055437].
Kopans DB, Moore RH, McCarthy KA, et al. Biasing the Interpretation of Mammography Screening Data by Age Grouping: Nothing Changes Abruptly at Age 50. Breast J. 1998;4(3):139-45. Exclusion: wrong outcomes.
Kopans DB, Smith RA, Duffy SW. Mammographic screening and “overdiagnosis”. Radiology. 2011;260(3):616-20. Exclusion: wrong publication type. [pmid: 21846757].
Korde LA, Calzone KA, Zujewski J. Assessing breast cancer risk: genetic factors are not the whole story. Postgrad Med. 2004;116(4):6-8. Exclusion: wrong publication type. [pmid: 15510590].
Korn JE, Bar-Cohen A. Breast cancer screening in Minnesota. The role of physicians. Minn Med. 1996;79(10):26-9. Exclusion: wrong outcomes. [pmid: 8937051].
Kornguth PJ, Rimer BK, Conaway MR, et al. Impact of patient-controlled compression on the mammography experience. Radiology. 1993;186(1):99-102. Exclusion: included in an included systematic review, not directly used. [pmid: 8416595].
Kosters JP, Gotzsche PC. Regular self-examination or clinical examination for early detection of breast cancer. Cochrane Database Syst Rev. 2008;1. Exclusion: wrong outcomes.
Kosters PJ, Gotzsche PC. Regular self-examination or clinical examination for early detection of breast cancer. Cochrane Database Syst Rev. 2009;(4). Exclusion: wrong intervention.
Kotsianos-Hermle D, Hiltawsky KM, Wirth S, et al. Analysis of 107 breast lesions with automated 3D ultrasound and comparison with mammography and manual ultrasound. Eur J Radiol. 2009;71(1):109-15. Exclusion: wrong intervention. [pmid: 18468829].
Kotsianos-Hermle D, Wirth S, Fischer T, et al. First clinical use of a standardized three-dimensional ultrasound for breast imaging. Eur J Radiol. 2009;71(1):102-8. Exclusion: wrong intervention. [pmid: 18479867].
Kriege M, Brekelmans CTM, Boetes C, et al. Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. 2004;351(5):427-37. Exclusion: wrong population. [pmid: 15282350].
Kriege M, Brekelmans CTM, Boetes C, et al. Differences between first and subsequent rounds of the MRISC breast cancer screening program for women with a familial or genetic predisposition. Cancer. 2006;106(11):2318-26. Exclusion: wrong population. [pmid: 16615112].
Krishnaiah PB, Nunes NL, Safranek S. FPIN's clinical inquiries. Screening mammography for reducing breast cancer mortality. Am Fam Physician. 2012;85(2):176-83. Exclusion: wrong publication type. [pmid: 22335218].
Kritz-Silverstein D, Schneider DL, Sandwell J. Breast cancer and bone mass in older women: is bone density prescreening for mammography useful?. Osteoporos Int. 2006;17(8):1196-201. Exclusion: wrong outcomes. [pmid: 16699738].
Kroenke K. Are the harms of false-positive screening test results minimal or meaningful?. JAMA Intern Med. 2014;174(6):961-3. Exclusion: wrong publication type. [pmid: 24756378].
Krupinski EA. Computer-aided detection in clinical environment: benefits and challenges for radiologists. Radiology. 2004;231(1):7-9. Exclusion: wrong publication type. [pmid: 15054153].
Kuhl CK, Schild HH. Dynamic image interpretation of MRI of the breast. J Magn Reson Imaging. 2000;12(6):965-74. Exclusion: review not meeting inclusion criteria. [pmid: 11105038].
Kuhl CK, Schmutzler RK, Leutner CC, et al. Breast MR imaging screening in 192 women proved or suspected to be carriers of a breast cancer susceptibility gene: preliminary results. Radiology. 2000;215(1):267-79. Exclusion: wrong population. [pmid: 10751498].
Kuhl CK, Schrading S, Leutner CC, et al. Mammography, breast ultrasound, and magnetic resonance imaging for surveillance of women at high familial risk for breast cancer. J Clin Oncol. 2005;23(33):8469-76. Exclusion: wrong population. [pmid: 16293877].
Kuo S-J, Chen TH-H, Yen AM-F, et al. Optimal two-stage breast cancer screening for countries with intermediate or low incidence of breast cancer. J Eval Clin Pract. 2010;16(6):1345-52. Exclusion: wrong study design for key question. [pmid: 20738471].
Kuroki Y, Nasu K, Kuroki S, et al. Diffusion-weighted imaging of breast cancer with the sensitivity encoding technique: analysis of the apparent diffusion coefficient value. Magn Reson Med Sci. 2004;3(2):79-85. Exclusion: wrong intervention. [pmid: 16093623].
Kurz KD, Steinhaus D, Klar V, et al. Assessment of three different software systems in the evaluation of dynamic MRI of the breast. Eur J Radiol. 2009;69(2):300-7. Exclusion: wrong outcomes. [pmid: 18060715].
Kusano AS, Trichopoulos D, Terry KL, et al. A prospective study of breast size and premenopausal breast cancer incidence. Int J Cancer. 2006;118(8):2031-4. Exclusion: wrong outcomes. [pmid: 16284954].
Kwek BH, Lau TN, Ng FC, et al. Non-consensual double reading in the Singapore Breast Screening Project: benefits and limitations. Ann Acad Med Singapore. 2003;32(4):438-41. Exclusion: wrong outcomes. [pmid: 12968545].
Kwong A, Cheung PSY, Wong AYW, et al. The acceptance and feasibility of breast cancer screening in the East. Breast. 2008;17(1):42-50. Exclusion: wrong comparison. [pmid: 17720500].
La Guardia M, Giammanco M. Breast cancer and obesity. Panminerva Med. 2001;43(2):123-33. Exclusion: review not meeting inclusion criteria. [pmid: 11449184].
LaCroix AZ, Chlebowski RT, Manson JE, et al. Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy: a randomized controlled trial. JAMA. 2011;305(13):1305-14. Exclusion: wrong intervention. [pmid: 21467283].
Lagerlund M, Sontrop JM, Zackrisson S. Psychosocial factors and attendance at a population-based mammography screening program in a cohort of Swedish women. BMC Womens Health. 2014;14(1):33. Exclusion: wrong outcomes. [pmid: 24565263].
Lahmann PH, Hoffmann K, Allen N, et al. Body size and breast cancer risk: findings from the European Prospective Investigation into Cancer And Nutrition (EPIC). Int J Cancer. 2004;111(5):762-71. Exclusion: wrong outcomes. [pmid: 15252848].
Lahmann PH, Lissner L, Berglund G. Breast cancer risk in overweight postmenopausal women. Cancer Epidemiol Biomarkers Prev. 2004;13(8):1414. Exclusion: wrong publication type. [pmid: 15298968].
Lahmann PH, Lissner L, Gullberg B, et al. A prospective study of adiposity and postmenopausal breast cancer risk: the Malmö Diet and Cancer Study. Int J Cancer. 2003;103(2):246-52. Exclusion: wrong comparison. [pmid: 12455040].
Lahmann PH, Schulz M, Hoffmann K, et al. Long-term weight change and breast cancer risk: the European prospective investigation into cancer and nutrition (EPIC). Br J Cancer. 2005;93(5):582-9. Exclusion: wrong outcomes. [pmid: 16136032].
Lai MS, Yen MF, Kuo HS, et al. Efficacy of breast-cancer screening for female relatives of breast-cancer-index cases: Taiwan multicentre cancer screening (TAMCAS). Int J Cancer. 1998;78(1):21-6. Exclusion: wrong population. [pmid: 9724089].
Lai Y-C, Huang Y-S, Wang D-W, et al. Computer-aided diagnosis for 3-d power Doppler breast ultrasound. Ultrasound Med Biol. 2013;39(4):555-67. Exclusion: wrong outcomes. [pmid: 23384464].
Lajous M, Lazcano-Ponce E, Hernandez-Avila M, et al. Folate, vitamin B(6), and vitamin B(12) intake and the risk of breast cancer among Mexican women. Cancer Epidemiol Biomarkers Prev. 2006;15(3):443-8. Exclusion: wrong outcomes. [pmid: 16537699].
Lambah A, Dixon J. Breast cancer: detection and management. Practitioner. 2000;244(1615):884-6. Exclusion: wrong publication type. [pmid: 11116736].
Lambertz CK. Pre-medication with Acetaminophen for Screening Mammography. Gonzaga University. 1998. Book. Exclusion: included in an included systematic review, not directly used.
Lambertz CK, Johnson CJ, Montgomery PG, et al. Premedication to reduce discomfort during screening mammography. Radiology. 2008;248(3):765-72. Exclusion: studies outside of search dates. [pmid: 18647845].
Lampic C, Thurfjell E, Bergh J, et al. Short- and long-term anxiety and depression in women recalled after breast cancer screening. Eur J Cancer. 1990). 2001;37(4):463-9. Exclusion: studies outside of search dates. [pmid: 11267855].
Lampic C, Thurfjell E, Bergh J, et al. Short- and long-term anxiety and depression in women recalled after breast cancer screening. Eur J Cancer. 2001;37(4):463-9. Exclusion: included in an included systematic review, not directly used. [pmid: 11267855].
Lampic C, Thurfjell E, Sjödén PO. The influence of a false-positive mammogram on a woman's subsequent behaviour for detecting breast cancer. Eur J Cancer. 2003;39(12):1730-7. Exclusion: included in an included systematic review, not directly used. [pmid: 12888368].
Lane DS, Messina CR. Current perspectives on physician barriers to breast cancer screening. J Am Board Fam Pract. 1999;12(1):8-15. Exclusion: wrong outcomes. [pmid: 10050638].
Lansdorp-Vogelaar I, Gulati R, Mariotto AB, et al. Personalizing age of cancer screening cessation based on comorbid conditions: model estimates of harms and benefits. [Summary for patients in Ann Intern Med. 2014 Jul 15;161(2). doi: 10.7326/P14-9023; PMID: 25023262]. Ann Intern Med. 2014;161(2):104-12. Exclusion: wrong study design for key question. [pmid: 25023249].
Lantz PM, Ubel PA. The use of life expectancy in cancer screening guidelines. Moving with caution from model-based evidence to evidence-based guidelines. J Gen Intern Med. 2005;20(6):552-3. Exclusion: wrong publication type. [pmid: 15987335].
Larsson SC, Bergkvist L, Wolk A. Glycemic load, glycemic index and breast cancer risk in a prospective cohort of Swedish women. Int J Cancer. 2009;125(1):153-7. Exclusion: wrong outcomes. [pmid: 19319984].
Larsson SC, Mantzoros CS, Wolk A. Diabetes mellitus and risk of breast cancer: a meta-analysis. Int J Cancer. 2007;121(4):856-62. Exclusion: wrong population. [pmid: 17397032].
Law J, Faulkner K. Concerning the relationship between benefit and radiation risk, and cancers detected and induced, in a breast screening programme. Br J Radiol. 2002;75(896):678-84. Exclusion: wrong study design for key question. [pmid: 12153942].
Law J, Faulkner K. Radiation benefit and risk at the assessment stage of the UK breast screening programme. Br J Radiol. 2006;79:479-82. Exclusion: wrong study design for key question. [pmid: 16714749].
Lazarus E, Mainiero MB, Gareen IF. Effect of referring physician specialty and practice type on referral for image-guided breast biopsy. J Am Coll Radiol. 2005;2(6):488-93. Exclusion: wrong intervention. [pmid: 17411865].
Leconte I, Feger C, Galant C, et al. Mammography and subsequent whole-breast sonography of nonpalpable breast cancers: the importance of radiologic breast density. AJR Am J Roentgenol. 2003;180(6):1675-9. Exclusion: wrong intervention. [pmid: 12760942].
Lee A, Chang J, Lim W, et al. Effectiveness of breast-specific gamma imaging (BSGI) for breast cancer in Korea: a comparative study. Breast J. 2012;18(5):453-8. Exclusion: wrong intervention. [pmid: 22897514].
Lee CH. Problem solving MR imaging of the breast. Radiol Clin North Am. 2004;42(5):919-34. Exclusion: wrong publication type. [pmid: 15337425].
Lee CH, Weinreb JC. The use of magnetic resonance imaging in breast cancer screening. J Am Coll Radiol. 2004;1(3):176-82. Exclusion: wrong publication type. [pmid: 17411555].
Lee H-J, Kim E-K, Kim MJ, et al. Observer variability of Breast Imaging Reporting and Data System (BI-RADS) for breast ultrasound. Eur J Radiol. 2008;65(2):293-8. Exclusion: wrong outcomes. [pmid: 17531417].
Lee S, Zelen M. A stochastic model for predicting the mortality of breast cancer. J Natl Cancer Inst. Monographs. 2006;(36):79-86. Exclusion: wrong study design for key question.
Lee SJ, Boscardin WJ, Stijacic-Cenzer I, et al. Time lag to benefit after screening for breast and colorectal cancer: meta-analysis of survival data from the United States, Sweden, United Kingdom, and Denmark. BMJ. 2013;346:e8441. Exclusion: wrong outcomes. [pmid: 23299842].
Lee SY, Jeong SH, Kim YN, et al. Cost-effective mammography screening in Korea: high incidence of breast cancer in young women. Cancer Sci. 2009;100(6):1105-11. Exclusion: wrong outcomes. [pmid: 19320639].
Lees A, Gabos A, Jenkins H. Investigations for staging and follow-up of breast cancer patients. Cancer Prev Control. 1997;1(2):157-60. Exclusion: wrong population. [pmid: 9765740].
Leff DR, Warren OJ, Enfield LC, et al. Diffuse optical imaging of the healthy and diseased breast: a systematic review. Breast Cancer Res Treat. 2008;108(1):9-22. Exclusion: review not meeting inclusion criteria. [pmid: 17468951].
Legler J, Meissner HI, Coyne C, et al. The effectiveness of interventions to promote mammography among women with historically lower rates of screening. Cancer Epidemiol Biomarkers Prev. 2002;11(1):59-71. Exclusion: wrong outcomes. [pmid: 11815402].
Legorreta AP, Brooks RJ, Leibowitz AN, et al. Cost of breast cancer treatment. A 4-year longitudinal study. Arch Intern Med. 1996;156(19):2197-201. Exclusion: wrong outcomes. [pmid: 8885818].
Legorreta AP, Chernicoff HO, Trinh JB, et al. Diagnosis, clinical staging, and treatment of breast cancer: a retrospective multiyear study of a large controlled population. Am J Clin Oncol. 2004;27(2):185-90. Exclusion: wrong population. [pmid: 15057159].
Lehman C, Holt S, Peacock S, et al. Use of the American College of Radiology BI-RADS guidelines by community radiologists: concordance of assessments and recommendations assigned to screening mammograms. AJR Am J Roentgenol. 2002;179(1):15-20. Exclusion: wrong outcomes. [pmid: 12076896].
Lehman CD. Clinical indications: what is the evidence?. Eur J Radiol. Suppl 1. 2012;81:S82-4. Exclusion: review not meeting inclusion criteria. [pmid: 23083615].
Lehman CD. Role of MRI in screening women at high risk for breast cancer. J Magn Reson Imaging. 2006;24(5):964-70. Exclusion: review not meeting inclusion criteria. [pmid: 17036340].
Lehman CD. Screening MRI for women at high risk for breast cancer. Semin Ultrasound CT MR. 2006;27(4):333-8. Exclusion: review not meeting inclusion criteria. [pmid: 16916001].
Lehman CD, Blume JD, DeMartini WB, et al. Accuracy and interpretation time of computer-aided detection among novice and experienced breast MRI readers. AJR Am J Roentgenol. 2013;200(6):W683-9. Exclusion: wrong outcomes. [pmid: 23701102].
Lehman CD, Isaacs C, Schnall MD, et al. Cancer yield of mammography, MR, and US in high-risk women: prospective multi-institution breast cancer screening study. Radiology. 2007;244(2):381-8. Exclusion: wrong population. [pmid: 17641362].
Lehtimaki T, Lundin M, Linder N, et al. Long-term prognosis of breast cancer detected by mammography screening or other methods. Breast Cancer Res. 2011;13(6):R134. Exclusion: wrong comparison. [pmid: 22204661].
Leinsinger GL, Friedl L, Tiling R, et al. Comparison of dynamic MR imaging of the breast and sestamibi scintimammography for evaluation of indeterminate mammographic lesions. Eur Radiol. 2001;11(10):2050-7. Exclusion: wrong intervention. [pmid: 11702141].
Leitch AM. Breast cancer: screening and early detection. Tex Med. 2001;97(2):74-8. Exclusion: review not meeting inclusion criteria. [pmid: 11233064].
Leivo T, Sintonen H, Tuominen R, et al. The cost-effectiveness of nationwide breast carcinoma screening in Finland, 1987-1992. Cancer. 1999;86(4):638-46. Exclusion: wrong outcomes. [pmid: 10440691].
Lemon SC, Zapka JG, Clemow L, et al. Mammography screening after breast cancer diagnosis in a first degree female relative: age group differences (United States). Cancer Causes Control. 2006;17(8):1053-65. Exclusion: wrong population. [pmid: 16933056].
Lenner P, Jonsson H. Excess mortality from breast cancer in relation to mammography screening in northern Sweden. J Med Screen. 1997;4(1):6-9. Exclusion: wrong outcomes. [pmid: 9200054].
Lenz S. Breast ultrasound in office gynecology--ten years of experience. Ultraschall Med. Suppl 1. 2011;32:S3-7. Exclusion: wrong outcomes. [pmid: 20938894].
Leonard BE, Leonard VF. Mammogram and diagnostic X-rays--evidence of protective Bystander, Adaptive Response (AR) radio-protection and AR retention at high dose levels. Int J Radiat Biol. 2008;84(11):885-99. Exclusion: wrong outcomes. [pmid: 19016137].
Le-Petross CH, Bidaut L, Yang WT. Evolving role of imaging modalities in inflammatory breast cancer. Semin Oncol. 2008;35(1):51-63. Exclusion: wrong publication type. [pmid: 18308146].
Lerman C, Trock B, Rimer BK, et al. Psychological and behavioral implications of abnormal mammograms. Ann Intern Med. 1991;114(8):657-61. Exclusion: studies outside of search dates. [pmid: 2003712].
Lerman C, Trock B, Rimer BK, et al. Psychological and behavioral implications of abnormal mammograms. Ann Intern Med. 1991;114(8):657-61. Exclusion: included in an included systematic review, not directly used. [pmid: 2003712].
Lerman C, Trock B, Rimer BK, et al. Psychological side effects of breast cancer screening. Health Psychol. 1991;10(4):259-67. Exclusion: studies outside of search dates. [pmid: 1915212].
Lester J. Breast cancer in 2007: incidence, risk assessment, and risk reduction strategies. Clin J Oncol Nurs. 2007;11(5):619-22. Exclusion: wrong publication type. [pmid: 17962169].
Letton AH, Mason EM, Ramshaw B. Twenty-year follow-up breast screening project. J Med Assoc Ga. 1996;85(1):31-2. Exclusion: wrong study design for key question. [pmid: 8583185].
Letton AH, Mason EM, Ramshaw BJ. Twenty-year review of a breast cancer screening project. Ninety-five percent survival of patients with nonpalpable cancers. Cancer. 1996;77(1):104-6. Exclusion: studies outside of search dates. [pmid: 8630914].
Leung GM, Lam TH, Hedley AJ. Screening mammography re-evaluated. Lancet. 2000;355(9205):750-1. author reply 2. Exclusion: wrong publication type. [pmid: 10703825].
Leung GM, Lam T-H, Thach TQ, et al. Will screening mammography in the East do more harm than good?. Am J Public Health. 2002;92(11):1841-6. Exclusion: review not meeting inclusion criteria. [pmid: 12406818].
Leung JWT. Screening mammography reduces morbidity of breast cancer treatment. AJR Am J Roentgenol. 2005;184(5):1508-9. Exclusion: wrong publication type. [pmid: 15855106].
Leung JWT, Margolin FR, Dee KE, et al. Performance parameters for screening and diagnostic mammography in a community practice: are there differences between specialists and general radiologists?. AJR Am J Roentgenol. 2007;188(1):236-41. Exclusion: wrong outcomes. [pmid: 17179372].
Levman JED, Causer P, Warner E, et al. Effect of the enhancement threshold on the computer-aided detection of breast cancer using MRI. Acad Radiol. 2009;16(9):1064-9. Exclusion: wrong outcomes. [pmid: 19515584].
Levman JED, Martel AL. A margin sharpness measurement for the diagnosis of breast cancer from magnetic resonance imaging examinations. Acad Radiol. 2011;18(12):1577-81. Exclusion: wrong intervention. [pmid: 21958601].
Lewin JM, D'Orsi CJ, Hendrick RE, et al. Clinical comparison of full-field digital mammography and screen-film mammography for detection of breast cancer. AJR Am J Roentgenol. 2002;179(3):671-7. Exclusion: wrong comparison. [pmid: 12185042].
Lewin JM, Hendrick RE, D'Orsi CJ, et al. Comparison of full-field digital mammography with screen-film mammography for cancer detection: results of 4,945 paired examinations. Radiology. 2001;218(3):873-80. Exclusion: wrong comparison. [pmid: 11230669].
Li CI, Littman AJ, White E. Relationship between age maximum height is attained, age at menarche, and age at first full-term birth and breast cancer risk. Cancer Epidemiol Biomarkers Prev. 2007;16(10):2144-9. Exclusion: wrong outcomes. [pmid: 17932363].
Li CI, Stanford JL, Daling JR. Anthropometric variables in relation to risk of breast cancer in middle-aged women. Int J Epidemiol. 2000;29(2):208-13. Exclusion: wrong intervention. [pmid: 10817115].
Li H, Giger ML, Huo Z, et al. Computerized analysis of mammographic parenchymal patterns for assessing breast cancer risk: effect of ROI size and location. Med Phys. 2004;31(3):549-55. Exclusion: wrong outcomes. [pmid: 15070253].
Lian M, Jeffe DB, Schootman M. Racial and geographic differences in mammography screening in St. Louis City: a multilevel study. J Urban Health. 2008;85(5):677-92. Exclusion: wrong outcomes. [pmid: 18622709].
Liberman L, Freeman HP, Chandra S, et al. Carcinoma detection at the breast examination center of Harlem. Cancer. 2002;95(1):8-14. Exclusion: wrong comparison. [pmid: 12115310].
Liberman L, Mason G, Morris EA, et al. Does size matter? Positive predictive value of MRI-detected breast lesions as a function of lesion size. AJR Am J Roentgenol. 2006;186(2):426-30. Exclusion: wrong intervention. [pmid: 16423948].
Liberman M, Sampalis F, Mulder DS, et al. Breast cancer diagnosis by scintimammography: A meta-analysis and review of the literature. Breast Cancer Res Treat. 2003;80(1):115-26. Exclusion: wrong intervention. [pmid: 12889605].
Libstug AR, Moravan V, Aitken SE. Results from the Ontario breast screening program, 1990-1995. J Med Screen. 1998;5(2):73-80. Exclusion: wrong comparison. [pmid: 9718525].
Lickley HL. Primary breast cancer in the elderly. Can J Surg. 1997;40(5):341-51. Exclusion: wrong publication type. [pmid: 9336523].
Lidbrink E, Elfving J, Frisell J, et al. Neglected aspects of false positive findings of mammography in breast cancer screening: Analysis of false positive cases from the Stockholm trial. Br Med J. 1996;312(7026):273-6. Exclusion: wrong outcomes. [pmid: 8611781].
Lidbrink E, Elfwing J, Frisell J, et al. Neglected aspects of false positive findings of mammography in breast cancer screening: analysis of false positive cases from the Stockholm trial. [see comments]. Br Med J. 1996;312:273-6. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 8611781].
Lidbrink E, Frisell J, Brandberg Y, et al. Nonattendance in the Stockholm mammography screening trial: Relative Mortality and reasons for nonattendance. Breast Cancer Res Treat. 1995;35(3):267-75. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 7579497].
Lidbrink E, Levi L, Pettersson I, et al. Single-view screening mammography: psychological, endocrine and immunological effects of recalling for a complete three-view examination. Eur J Cancer. 1995;31(6):932-3. Exclusion: included in an included systematic review, not directly used. [pmid: 7646925].
Lind DS. Breast cancer testing: what is appropriate?. J Surg Oncol. 2002;81(3):111-2. Exclusion: wrong publication type. [pmid: 12407719].
Linda A, Zuiani C, Londero V, et al. Outcome of initially only magnetic resonance mammography-detected findings with and without correlate at second-look sonography: distribution according to patient history of breast cancer and lesion size. Breast. 2008;17(1):51-7. Exclusion: wrong intervention. [pmid: 17709249].
Lindfors KK, McGahan MC, Rosenquist CJ, et al. Computer-aided detection of breast cancer: a cost-effectiveness study. [Erratum appears in Radiology. 2007 Jan;242(1):320]. Radiology. 2006;239(3):710-7. Exclusion: wrong outcomes. [pmid: 16569787].
Lindgren A, Pukkala E, Tuomilehto J, et al. Incidence of breast cancer among postmenopausal, hypertensive women. Int J Cancer. 2007;121(3):641-4. Exclusion: wrong comparison. [pmid: 17372911].
Linver MN, Paster SB. Mammography outcomes in a practice setting by age: prognostic factors, sensitivity, and positive biopsy rate. J Natl Cancer Inst. Monographs. 1997;(22):113-7. Exclusion: wrong outcomes.
Lipasti S, Anttila A, Pamilo M. Mammographic findings of women recalled for diagnostic work-up in digital versus screen-film mammography in a population-based screening program. Acta Radiol. 2010;51(5):491-7. Exclusion: wrong comparison. [pmid: 20429762].
Lipkus IM, Halabi S, Strigo TS, et al. The impact of abnormal mammograms on psychosocial outcomes and subsequent screening. Psychooncology. 2000;9(5):402-10. Exclusion: studies outside of search dates. [pmid: 11038478].
Lisby MD. Screening mammography in women 40 to 49 years of age. Am Fam Physician. 2004;70(9):1750-2. Exclusion: wrong publication type. [pmid: 15554494].
Litherland JC, Evans AJ, Wilson AR. The effect of hormone replacement therapy on recall rate in the National Health Service Breast Screening Programme. Clin Radiol. 1997;52(4):276-9. Exclusion: wrong outcomes. [pmid: 9112944].
Litherland JC, Stallard S, Hole D, et al. The effect of hormone replacement therapy on the sensitivity of screening mammograms. Clin Radiol. 1999;54(5):285-8. Exclusion: wrong outcomes. [pmid: 10362232].
Liu MJ, Hawk H, Gershman ST, et al. The effects of a National Breast and Cervical Cancer Early Detection Program on social disparities in breast cancer diagnosis and treatment in Massachusetts. Cancer Causes Control. 2005;16(1):27-33. Exclusion: wrong comparison. [pmid: 15750855].
Ljubicic N, Ivanda T, Strnad M, et al. The Croatian national breast cancer screening program--“mamma”. Breast J. 2011;17(1):106-8. Exclusion: wrong publication type. [pmid: 21155920].
Lo G, Cheung PSY. Use of magnetic resonance imaging for detecting clinically and mammographically occult ductal carcinoma in situ. Hong Kong Med J. 2008;14(3):229-32. Exclusion: wrong study design for key question. [pmid: 18525094].
Lobb R, Ayanian JZ, Allen JD, et al. Stage of breast cancer at diagnosis among low-income women with access to mammography. Cancer. 2010;116(23):5487-96. Exclusion: wrong comparison. [pmid: 21171232].
Localio AR, Zhou L, Norman SA. Measuring screening intensity in case-control studies of the efficacy of mammography. Am J Epidemiol. 2006;164(3):272-81. Exclusion: wrong study design for key question. [pmid: 16707653].
Lochner DM, Brubaker KL. Incidence of malignancy in hormone therapy users with indeterminate calcifications on mammogram. Am J Obstet Gynecol. 2006;194(1):82-5. Exclusion: wrong comparison. [pmid: 16389013].
Louwman WJ, van de Poll-Franse LV, Fracheboud J, et al. Impact of a programme of mass mammography screening for breast cancer on socio-economic variation in survival: a population-based study. Breast Cancer Res Treat. 2007;105(3):369-75. Exclusion: wrong population. [pmid: 17211536].
Louwman WJ, van Diest PJ, van Beek MWPM, et al. Trends in breast cancer aggressiveness before the introduction of mass screening in southeastern Netherlands 1975-1989. Breast Cancer Res Treat. 2002;73(3):199-206. Exclusion: wrong comparison. [pmid: 12160325].
Lowe JB, Balanda KP, Del Mar C, et al. Psychologic distress in women with abnormal findings in mass mammography screening. Cancer. 1999;85(5):1114-8. Exclusion: included in an included systematic review, not directly used. [pmid: 10091796].
Lowe JB, Balanda KP, Del Mar C, et al. Psychologic distress in women with abnormal findings in mass mammography screening. Cancer. 1999;85(5):1114-8. Exclusion: included in an included systematic review, not directly used. [pmid: 10091796].
Lowery JT, Byers T, Hokanson JE, et al. Complementary approaches to assessing risk factors for interval breast cancer. Cancer Causes Control. 2011;22(1):23-31. Exclusion: wrong outcomes. [pmid: 20978835].
Lui CY, Lam HS, Chan LK, et al. Opportunistic breast cancer screening in Hong Kong; a revisit of the Kwong Wah Hospital experience. Hong Kong Med J. 2007;13(2):106-13. Exclusion: wrong study design for key question. [pmid: 17406037].
Luke C, Priest K, Roder D. Changes in incidence of in situ and invasive breast cancer by histology type following mammography screening. Asian Pac J Cancer Prev. 2006;7(1):69-74. Exclusion: wrong population. [pmid: 16629519].
Lumachi F, Ermani M, Marzola MC, et al. Relationship between prognostic factors of breast cancer and 99mTc-sestamibi uptake in patients who underwent scintimammography: Multivariate analysis of causes of false-negative results. Breast. 2006;15(1):130-4. Exclusion: wrong comparison. [pmid: 15985369].
Lund E, Dumeaux V, Braaten T, et al. Cohort profile: The Norwegian Women and Cancer Study--NOWAC--Kvinner og kreft. Int J Epidemiol. 2008;37(1):36-41. Exclusion: wrong publication type. [pmid: 17644530].
Lund E, Mode N, Waaseth M, et al. Overdiagnosis of breast cancer in the Norwegian Breast Cancer Screening Program estimated by the Norwegian Women and Cancer cohort study. BMC Cancer. 2013;13:614. Exclusion: wrong outcomes. [pmid: 24377727].
Lynge E. Mammography screening for breast cancer in Copenhagen April 1991-March 1997. Mammography Screening Evaluation Group. APMIS Suppl. 1998;83:1-44. Exclusion: studies outside of search dates. [pmid: 9850674].
Lynge E, Braaten T, Njor SH, et al. Mammography activity in Norway 1983 to 2008. Acta Oncol. 2011;50(7):1062-7. Exclusion: studies outside of search dates. [pmid: 21830995].
Ma I, Dueck A, Gray R, et al. Clinical and self breast examination remain important in the era of modern screening. Ann Surg Oncol. 2012;19(5):1484-90. Exclusion: wrong publication type. [pmid: 22160521].
Madjar H, Sauerbrei W, Hansen L. Multivariate analysis of flow data in breast lesions and validation in a normal clinical setting. Ultraschall Med. 2011;32(5):511-7. Exclusion: wrong intervention. [pmid: 21080308].
Maes RM, Dronkers DJ, Hendriks JH, et al. Do non-specific minimal signs in a biennial mammographic breast cancer screening programme need further diagnostic assessment?. Br J Radiol. 1997;70:34-8. Exclusion: wrong comparison. [pmid: 9059292].
Magnus MC, Ping M, Shen MM, et al. Effectiveness of mammography screening in reducing breast cancer mortality in women aged 39-49 years: a meta-analysis. J Womens Health (Larchmt). 2011;20(6):845-52. Exclusion: review not meeting inclusion criteria. [pmid: 21413892].
Mahnken JD, Chan W, Freeman DH Jr., et al. Reducing the effects of lead-time bias, length bias and over-detection in evaluating screening mammography: a censored bivariate data approach. Stat Methods Med Res. 2008;17(6):643-63. Exclusion: wrong study design for key question. [pmid: 18445697].
Mahoney MC, Meganathan K. False positive marks on unsuspicious screening mammography with computer-aided detection. J Digit Imaging. 2011;24(5):772-7. Exclusion: wrong comparison. [pmid: 21547517].
Maidment AD. Digital mammography. Semin Roentgenol. 2003;38(3):216-30. Exclusion: review not meeting inclusion criteria. [pmid: 14513726].
Majek O, Danes J, Skovajsova M, et al. Breast cancer screening in the Czech Republic: time trends in performance indicators during the first seven years of the organised programme. BMC Public Health. 2011;11:288. Exclusion: wrong comparison. [pmid: 21554747].
Makela M, Saalasti-Koskinen U, Saarenmaa I, et al. The impact of an extension of breast cancer screening: update of Finohta's report 16/2000. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: wrong publication type.
Makretsov NA, Carter BA, Hayes MM. Mammography screening and indeterminate core biopsy diagnoses. Maturitas. 2012;73(3):177-9. Exclusion: wrong publication type. [pmid: 22902241].
Malich A, Fischer DR, Facius M, et al. Effect of breast density on computer aided detection. J Digit Imaging. 2005;18(3):227-33. Exclusion: wrong intervention. [pmid: 15827823].
Malich A, Marx C, Facius M, et al. Tumour detection rate of a new commercially available computer-aided detection system. Eur Radiol. 2001;11(12):2454-9. Exclusion: wrong outcomes. [pmid: 11734939].
Malmgren J, Atwood M, Kaplan H. Breast cancer detection method among 20- to 49-year-old patients at a community based cancer center: 1990-2008. Breast J. 2012;18(3):257-60. Exclusion: wrong population. [pmid: 22487162].
Malmgren JA, Atwood MK, Kaplan HG. Increase in mammography detected breast cancer over time at a community based regional cancer center: a longitudinal cohort study 1990-2005. BMC Cancer. 2008;8:131. Exclusion: wrong study design for key question. [pmid: 18471303].
Malmgren JA, Parikh J, Atwood MK, et al. Impact of mammography detection on the course of breast cancer in women aged 40-49 years. Radiology. 2012;262(3):797-806. Exclusion: wrong comparison. [pmid: 22357883].
Malmgren JA, Parikh J, Atwood MK, et al. Improved Prognosis of Women Aged 75 and Older with Mammography-detected Breast Cancer. Radiology. 2014. Exclusion: wrong comparison.
Mandelblatt J, Schechter CB, Lawrence W, et al. The SPECTRUM population model of the impact of screening and treatment on U.S. breast cancer trends from 1975 to 2000: principles and practice of the model methods. J Natl Cancer Inst. Monographs. 2006;(36):47-55. Exclusion: wrong study design for key question.
Mandelblatt J, van Ravesteyn N, Schechter C, et al. Which strategies reduce breast cancer mortality most? Collaborative modeling of optimal screening, treatment, and obesity prevention. Cancer. 2013;119(14):2541-8. Exclusion: wrong study design for key question. [pmid: 23625540].
Mandelblatt JS, Cronin KA, Bailey S, et al. Effects of mammography screening under different screening schedules: model estimates of potential benefits and harms. [Erratum appears in Ann Intern Med. 2010 Jan 19;152(2):136]. Ann Intern Med. 2009;151(10):738-47. Exclusion: wrong study design for key question. [pmid: 19920274].
Mandelblatt JS, Cronin KA, Berry DA, et al. Modeling the impact of population screening on breast cancer mortality in the United States. Breast. Suppl 3. 2011;20:S75-81. Exclusion: wrong study design for key question. [pmid: 22015298].
Mandelblatt JS, Schechter CB, Yabroff KR, et al. Toward optimal screening strategies for older women. Costs, benefits, and harms of breast cancer screening by age, biology, and health status. J Gen Intern Med. 2005;20(6):487-96. Exclusion: wrong outcomes. [pmid: 15987322].
Mandelblatt JS, Schechter CB, Yabroff KR, et al. Benefits and costs of interventions to improve breast cancer outcomes in African American women. J Clin Oncol. 2004;22(13):2554-66. Exclusion: wrong outcomes. [pmid: 15173213].
Mandelson MT, Oestreicher N, Porter PL, et al. Breast density as a predictor of mammographic detection: comparison of interval- and screen-detected cancers. J Natl Cancer Inst. 2000;92(13):1081-7. Exclusion: wrong comparison. [pmid: 10880551].
Manfrin E, Mariotto R, Remo A, et al. Is there still a role for fine-needle aspiration cytology in breast cancer screening? Experience of the Verona Mammographic Breast Cancer Screening Program with real-time integrated radiopathologic activity (1999-2004). Cancer. 2008;114(2):74-82. Exclusion: wrong outcomes. [pmid: 18306357].
Mann RM, Hoogeveen YL, Blickman JG, et al. MRI compared to conventional diagnostic work-up in the detection and evaluation of invasive lobular carcinoma of the breast: a review of existing literature. Breast Cancer Res Treat. 2008;107(1):1-14. Exclusion: wrong intervention. [pmid: 18043894].
Marchick J, Henson DE. Correlations between access to mammography and breast cancer stage at diagnosis. Cancer. 2005;103(8):1571-80. Exclusion: wrong outcomes. [pmid: 15772962].
Mariotto R, Brancato B, Bonetti F, et al. Real-time reading in mammography breast screening. Radiol Med (Torino). 2007;112(2):287-303. Exclusion: wrong outcomes. [pmid: 17361369].
Marquez Cruz MD, Marquez Calderon S. Diagnostic performance of digital mammography in breast cancer screening. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: wrong comparison.
Marshall T. Informed consent for mammography screening: modelling the risks and benefits for American women. Health Expect. 2005;8(4):295-305. Exclusion: wrong intervention. [pmid: 16266417].
Marshall T, Adab P. Informed consent for breast screening: what should we tell women?. J Med Screen. 2003;10(1):22-6. Exclusion: studies outside of search dates. [pmid: 12790312].
Martincich L, Faivre-Pierret M, Zechmann CM, et al. Multicenter, double-blind, randomized, intraindividual crossover comparison of gadobenate dimeglumine and gadopentetate dimeglumine for Breast MR imaging (DETECT Trial). Radiology. 2011;258(2):396-408. Exclusion: wrong intervention. [pmid: 21163915].
Marx C, Malich A, Facius M, et al. Are unnecessary follow-up procedures induced by computer-aided diagnosis (CAD) in mammography? Comparison of mammographic diagnosis with and without use of CAD. Eur J Radiol. 2004;51(1):66-72. Exclusion: wrong outcomes. [pmid: 15186887].
Maskarinec G, Nagata C, Shimizu H, et al. Comparison of mammographic densities and their determinants in women from Japan and Hawaii. [Erratum appears in Int J Cancer. 2003 May 10;104(6):800]. Int J Cancer. 2002;102(1):29-33. Exclusion: wrong study design for key question. [pmid: 12353230].
Maskarinec G, Pagano I, Chen Z, et al. Ethnic and geographic differences in mammographic density and their association with breast cancer incidence. Breast Cancer Res Treat. 2007;104(1):47-56. Exclusion: wrong study design for key question. [pmid: 17009106].
Maskarinec G, Pagano I, Lurie G, et al. A longitudinal investigation of mammographic density: the multiethnic cohort. Cancer Epidemiol Biomarkers Prev. 2006;15(4):732-9. Exclusion: wrong outcomes. [pmid: 16614116].
Maskarinec G, Wilkens L, Meng L. Mammography screening and the increase in breast cancer incidence in Hawaii. Cancer Epidemiol Biomarkers Prev. 1997;6(3):201-8. Exclusion: wrong study design for key question. [pmid: 9138664].
Maskarinec G, Williams AE, Carlin L. Mammographic densities in a one-year isoflavone intervention. Eur J Cancer Prev. 2003;12(2):165-9. Exclusion: wrong outcomes. [pmid: 12671541].
Masroor I. Prediction of benignity or malignancy of a lesion using BI-RADS. J Coll Physicians Surg Pak. 2005;15(11):686-8. Exclusion: wrong outcomes. [pmid: 16300702].
Massat NJ, Sasieni PD, Parmar D, et al. An ongoing case-control study to evaluate the NHS breast screening programme. BMC Cancer. 2013;13:596. Exclusion: wrong publication type. [pmid: 24330588].
Matcham NJ, Ridley NTF, Taylor SJ, et al. Breast screening: the use of consensus opinion for all recalls. Breast. 2004;13(3):184-7. Exclusion: wrong study design for key question. [pmid: 15177419].
Mathijssen IMJ, Strijdhorst H, Kiestra SK, et al. Added value of ultrasound in screening the clinically negative axilla in breast cancer. J Surg Oncol. 2006;94(5):364-7. Exclusion: wrong population. [pmid: 16967456].
Mattsson A, Leitz W, Rutqvist LE. Radiation risk and mammographic screening of women from 40 to 49 years of age: effect on breast cancer rates and years of life. Br J Cancer. 2000;82(1):220-6. Exclusion: wrong outcomes. [pmid: 10638993].
Mattsson P. Mammography-related breast pain is associated with migraine. Cephalalgia. 2009;29(6):616-23. Exclusion: wrong outcomes. [pmid: 19175612].
Maurice A, Evans DG, Affen J, et al. Surveillance of women at increased risk of breast cancer using mammography and clinical breast examination: further evidence of benefit. Int J Cancer. 2012;131(2):417-25. Exclusion: wrong population. [pmid: 21898384].
Mayor S. Five year survival rate of women whose cancer is detected by screening has risen to 96.4%. BMJ. 2008;336(7658):1398-9. Exclusion: wrong publication type. [pmid: 18566066].
Mayor S. Mammography screening has little or no effect on breast cancer deaths, Swedish data indicate. BMJ. 2012;345:e4847. Exclusion: wrong publication type. [pmid: 22804922].
Mayor S. Number of breast cancer cases detected by screening has doubled in a decade in England. BMJ. 2009;338:b414. Exclusion: wrong outcomes. [pmid: 19188233].
McBean AM, Yu X, Virnig BA. Screening mammography rate and predictors following treatment for colorectal cancer. J Cancer Surviv. 2009;3(1):12-20. Exclusion: wrong population. [pmid: 19224371].
McCann J, Duffy S, Day N, et al. Predicted long-term mortality reduction associated with the second round of breast screening in East Anglia. Br J Cancer. 2001;84(3):423-8. Exclusion: wrong study design for key question. [pmid: 11161411].
McCann J, Stockton D, Day N. Breast cancer in East Anglia: the impact of the breast screening programme on stage at diagnosis. J Med Screen. 1998;5(1):42-8. Exclusion: wrong outcomes. [pmid: 9575460].
McCann J, Stockton D, Godward S. Impact of false-positive mammography on subsequent screening attendance and risk of cancer. Breast Cancer Res. 2002;4(5):R11. Exclusion: included in an included systematic review, not directly used. [pmid: 12223128].
McCann J, Treasure P, Duffy S. Modelling the impact of detecting and treating ductal carcinoma in situ in a breast screening programme. J Med Screen. 2004;11(3):117-25. Exclusion: wrong study design for key question. [pmid: 15333269].
McCann J, Wait S, Seradour B, et al. A comparison of the performance and impact of breast cancer screening programmes in East Anglia, U.K. and Bouches du Rhone, France. Eur J Cancer. 1997;33(3):429-35. Exclusion: wrong outcomes. [pmid: 9155528].
McCarthy EP, Burns RB, Coughlin SS, et al. Mammography use helps to explain differences in breast cancer stage at diagnosis between older black and white women. Ann Intern Med. 1998;128(9):729-36. Exclusion: wrong outcomes. [pmid: 9556466].
McCarthy EP, Burns RB, Freund KM, et al. Mammography use, breast cancer stage at diagnosis, and survival among older women. J Am Geriatr Soc. 2000;48(10):1226-33. Exclusion: wrong population. [pmid: 11037009].
McCarty CA, Reding DJ, Commins J, et al. Alcohol, genetics and risk of breast cancer in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Breast Cancer Res Treat. 2012;133(2):785-92. Exclusion: wrong outcomes. [pmid: 22331481].
McCormack VA, dos Santos Silva I, De Stavola BL, et al. Fetal growth and subsequent risk of breast cancer: results from long term follow up of Swedish cohort. BMJ. 2003;326(7383):248. Exclusion: wrong outcomes. [pmid: 12560272].
McCormack VA, Perry N, Vinnicombe SJ, et al. Ethnic variations in mammographic density: a British multiethnic longitudinal study. Am J Epidemiol. 2008;168(4):412-21. Exclusion: wrong outcomes. [pmid: 18621673].
McCoy CB, Pereyra M, Metsch LR, et al. A community-based breast cancer screening program for medically underserved women: its effect on disease stage at diagnosis and on hazard of death. Rev Panam Salud Publica. 2004;15(3):160-7. Exclusion: wrong outcomes. [pmid: 15096288].
McDonald S, Saslow D, Alciati MH. Performance and reporting of clinical breast examination: a review of the literature. CA Cancer J Clin. 2004;54(6):345-61. Exclusion: wrong intervention. [pmid: 15537577].
McDougall JA, Li CI. Trends in distant-stage breast, colorectal, and prostate cancer incidence rates from 1992 to 2004: potential influences of screening and hormonal factors. Horm Cancer. 2010;1(1):55-62. Exclusion: wrong outcomes. [pmid: 21761350].
McElroy JA, Remington PL, Gangnon RE, et al. Identifying geographic disparities in the early detection of breast cancer using a geographic information system. Prev Chronic Dis. 2006;3(1):A10. Exclusion: wrong outcomes. [pmid: 16356363].
McGreevy JM, Loftus TJ. Outcomes evaluation for operative and nonoperative management of the abnormal mammogram. Am J Surg. 1998;175(1):69-72. Exclusion: wrong population. [pmid: 9445245].
McKenzie F, Ives A, Jeffreys M. Socio-economic inequalities in survival from screen-detected breast cancer in South West England: population-based cohort study. Eur J Public Health. 2012;22(3):418-22. Exclusion: wrong comparison. [pmid: 21891789].
McLaren CE, Chen W-P, Nie K, et al. Prediction of malignant breast lesions from MRI features: a comparison of artificial neural network and logistic regression techniques. Acad Radiol. 2009;16(7):842-51. Exclusion: wrong intervention. [pmid: 19409817].
McLaughlin JM, Anderson RT, Ferketich AK, et al. Effect on survival of longer intervals between confirmed diagnosis and treatment initiation among low-income women with breast cancer. J Clin Oncol. 2012;30(36):4493-500. Exclusion: wrong outcomes. [pmid: 23169521].
McPherson CP, Swenson KK, Jolitz G, et al. Survival of women ages 40-49 years with breast carcinoma according to method of detection. Cancer. 1997;79(10):1923-32. Exclusion: wrong comparison. [pmid: 9149019].
McPherson CP, Swenson KK, Lee MW. The effects of mammographic detection and comorbidity on the survival of older women with breast cancer. J Am Geriatr Soc. 2002;50(6):1061-8. Exclusion: wrong comparison. [pmid: 12110066].
McRae S. Screening mammography. Can J Rural Med. 2010;15(4):167. author reply 8. Exclusion: wrong publication type. [pmid: 20875318].
McTiernan A. Exercise and breast cancer--time to get moving?. N Engl J Med. 1997;336(18):1311-2. Exclusion: wrong publication type. [pmid: 9113936].
McTiernan A, Irwin M, Vongruenigen V. Weight, physical activity, diet, and prognosis in breast and gynecologic cancers. J Clin Oncol. 2010;28(26):4074-80. Exclusion: wrong population. [pmid: 20644095].
Medical Advisory S. Screening mammography for women aged 40 to 49 years at average risk for breast cancer: an evidence-based analysis. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: review not meeting inclusion criteria.
Medved M, Newstead GM, Abe H, et al. Clinical implementation of a multislice high spectral and spatial resolution-based MRI sequence to achieve unilateral full-breast coverage. Magn Reson Imaging. 2010;28(1):16-21. Exclusion: wrong intervention. [pmid: 19628350].
Meersman SC, Breen N, Pickle LW, et al. Access to mammography screening in a large urban population: a multi-level analysis. Cancer Causes Control. 2009;20(8):1469-82. Exclusion: wrong outcomes. [pmid: 19543987].
Meijnen P, Gilhuijs KG, Rutgers EJT. The effect of margins on the clinical management of ductal carcinoma in situ of the breast. J Surg Oncol. 2008;98(8):579-84. Exclusion: wrong publication type. [pmid: 19072848].
Meissner HI, Smith RA, Rimer BK, et al. Promoting cancer screening: Learning from experience. Cancer. 2004;101(5 Suppl):1107-17. Exclusion: wrong publication type. [pmid: 15316913].
Meldrum P, Turnbull D, Dobson HM, et al. Tailored written invitations for second round breast cancer screening: a randomised controlled trial. J Med Screen. 1994;1(4):245-8. Exclusion: included in an included systematic review, not directly used. [pmid: 8790529].
Mellemkjaer L, Bigaard J, Tjonneland A, et al. Body composition and breast cancer in postmenopausal women: a Danish prospective cohort study. Obesity (Silver Spring). 2006;14(10):1854-62. Exclusion: wrong outcomes. [pmid: 17062817].
Menashe I, Anderson WF, Jatoi I, et al. Underlying causes of the black-white racial disparity in breast cancer mortality: a population-based analysis. J Natl Cancer Inst. 2009;101(14):993-1000. Exclusion: wrong outcomes. [pmid: 19584327].
Mendez A, Cabanillas F, Echenique M, et al. Evaluation of Breast Imaging Reporting and Data System Category 3 mammograms and the use of stereotactic vacuum-assisted breast biopsy in a nonacademic community practice. Cancer. 2004;100(4):710-4. Exclusion: wrong outcomes. [pmid: 14770425].
Menes TS, Rosenberg R, Balch S, et al. Upgrade of high-risk breast lesions detected on mammography in the Breast Cancer Surveillance Consortium. Am J Surg. 2014;207(1):24-31. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 24112677].
Menna S, Di Virgilio MR, Burke P, et al. Diagnostic accuracy of commercial system for computer-assisted detection (CADx) as an adjunct to interpretation of mammograms. Radiol Med (Torino). 2005;110(4):334-40. Exclusion: wrong intervention. [pmid: 16292240].
Menvielle G, Kunst AE, van Gils CH, et al. The contribution of risk factors to the higher incidence of invasive and in situ breast cancers in women with higher levels of education in the European prospective investigation into cancer and nutrition. Am J Epidemiol. 2011;173(1):26-37. Exclusion: wrong outcomes. [pmid: 21084553].
Messecar DC. Mammography screening for older women with and without cognitive impairment. J Gerontol Nurs. 2000;26(4):14-24. quiz 52-3. Exclusion: wrong study design for key question. [pmid: 11272962].
Meystre-Agustoni G, Paccaud F, Jeannin A, et al. Anxiety in a cohort of Swiss women participating in a mammographic screening programme. J Med Screen. 2001;8(4):213-9. Exclusion: studies outside of search dates. [pmid: 11743038].
Michael M, Garzoli E, Reiner CS. Mammography, sonography and MRI for detection and characterization of invasive lobular carcinoma of the breast. Breast Dis. 2008;30:21-30. Exclusion: wrong intervention. [pmid: 19850992].
Michaelsen K, Krishnaswamy V, Pogue BW, et al. Near-infrared spectral tomography integrated with digital breast tomosynthesis: effects of tissue scattering on optical data acquisition design. Med Phys. 2012;39(7):4579-87. Exclusion: wrong outcomes. [pmid: 22830789].
Michaelson JS, Halpern E, Kopans DB. Breast cancer: computer simulation method for estimating optimal intervals for screening. Radiology. 1999;212(2):551-60. Exclusion: wrong study design for key question. [pmid: 10429717].
Michaelson JS, Satija S, Kopans D, et al. Gauging the impact of breast carcinoma screening in terms of tumor size and death rate. Cancer. 2003;98(10):2114-24. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 14601080].
Michell MJ. Breast cancer screening. Int J Clin Pract. 2001;55(8):531-5. Exclusion: wrong publication type. [pmid: 11695074].
Michell MJ, Iqbal A, Wasan RK, et al. A comparison of the accuracy of film-screen mammography, full-field digital mammography, and digital breast tomosynthesis. Clin Radiol. 2012;67(10):976-81. Exclusion: wrong comparison. [pmid: 22625656].
Michels KB, Terry KL, Eliassen AH, et al. Adult weight change and incidence of premenopausal breast cancer. Int J Cancer. 2012;130(4):902-9. Exclusion: wrong outcomes. [pmid: 21413008].
Michels KB, Terry KL, Willett WC. Longitudinal study on the role of body size in premenopausal breast cancer. Arch Intern Med. 2006;166(21):2395-402. Exclusion: wrong outcomes. [pmid: 17130395].
Michels KB, Xue F, Terry KL, et al. Longitudinal study of birthweight and the incidence of breast cancer in adulthood. Carcinogenesis. 2006;27(12):2464-8. Exclusion: wrong comparison. [pmid: 16777984].
Miglioretti DL, Gard CC, Carney PA, et al. When radiologists perform best: the learning curve in screening mammogram interpretation. Radiology. 2009;253(3):632-40. Exclusion: wrong outcomes. [pmid: 19789234].
Miglioretti DL, Rutter CM, Geller BM, et al. Effect of breast augmentation on the accuracy of mammography and cancer characteristics. JAMA. 2004;291(4):442-50. Exclusion: wrong comparison. [pmid: 14747501].
Miglioretti DL, Smith-Bindman R, Abraham L, et al. Radiologist characteristics associated with interpretive performance of diagnostic mammography. J Natl Cancer Inst. 2007;99(24):1854-63. Exclusion: wrong intervention. [pmid: 18073379].
Miglioretti DL, Walker R, Weaver DL, et al. Accuracy of screening mammography varies by week of menstrual cycle. Radiology. 2011;258(2):372-9. Exclusion: wrong outcomes. [pmid: 21131584].
Miller AB. Is mammography screening for breast cancer really not justifiable?. Recent Results Cancer Res. 2003;163:115-28. discussion 264-6. Exclusion: wrong publication type. [pmid: 12903848].
Miller AB. Organized breast cancer screening programs in Canada. CMAJ. 2000;163(9):1150-1. Exclusion: wrong publication type. [pmid: 11079061].
Miller AB. Overdiagnosis of breast cancer. Int J Cancer. 2013;133(11):2511. Exclusion: wrong publication type. [pmid: 23716268].
Miller AB, Baines CJ, Sickles EA. Canadian National Breast Screening Study. AJR Am J Roentgenol. 1990;155(5):1133-4. Exclusion: studies outside of search dates. [pmid: 2120947].
Miller AB, Baines CJ, To T. The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39-49 years at randomization. Cancer. 1998;83(1):186-90. Exclusion: wrong publication type. [pmid: 9655310].
Miller AB, Fletcher SW. Annual mammography screening did not reduce long-term breast cancer mortality in women 40 to 59 years of age. Ann Intern Med. 2014;160(10):JC7. Exclusion: wrong publication type.
Miller D, Livingstone V, Herbison P. Interventions for relieving the pain and discomfort of screening mammography. Cochrane Database Syst Rev. 2008;(1). CD002942. Exclusion: studies outside of search dates.
Miller D, Livingstone V, Herbison PG. Interventions for relieving the pain and discomfort of screening mammography. Cochrane Database Syst Rev. 2009;(1). Exclusion: review not meeting inclusion criteria.
Miller JC, Rafferty EA, Specht MC, et al. When is breast magnetic resonance imaging recommended for cancer detection?. J Am Coll Radiol. 2008;5(3):224-6. Exclusion: wrong publication type. [pmid: 18312973].
Miller JW, King JB, Ryerson AB, et al. Mammography use from 2000 to 2006: state-level trends with corresponding breast cancer incidence rates. AJR Am J Roentgenol. 2009;192(2):352-60. Exclusion: wrong study design for key question. [pmid: 19155394].
Miller M. Cancer incidence trends differ between Europe, United States. J Natl Cancer Inst. 2001;93(19):1444-5. Exclusion: wrong publication type. [pmid: 11584056].
Millet I, Pages E, Hoa D, et al. Pearls and pitfalls in breast MRI. Br J Radiol. 2012;85(1011):197-207. Exclusion: review not meeting inclusion criteria. [pmid: 22128131].
Milne ENC, Krupinski EA, Helvie MA, et al. Computer-aided detection of breast cancer. Radiology. 2004;233(2):615-6. author reply 6-7. Exclusion: wrong publication type. [pmid: 15516624].
Miltenburg GA, Peeters PH, Fracheboud J, et al. Seventeen-year evaluation of breast cancer screening: the DOM project, The Netherlands. Diagnostisch Onderzoek (investigation) Mammacarcinoom. Br J Cancer. 1998;78(7):962-5. Exclusion: wrong study design for key question. [pmid: 9764591].
Mincey BA, Perez EA. Advances in screening, diagnosis, and treatment of breast cancer. Mayo Clin Proc. 2004;79(6):810-6. Exclusion: review not meeting inclusion criteria. [pmid: 15182098].
Mink PJ, Shahar E, Rosamond WD, et al. Serum insulin and glucose levels and breast cancer incidence: the atherosclerosis risk in communities study. Am J Epidemiol. 2002;156(4):349-52. Exclusion: wrong outcomes. [pmid: 12181105].
Mitchell J, Lannin DR, Mathews HF, et al. Religious beliefs and breast cancer screening. J Womens Health (Larchmt). 2002;11(10):907-15. Exclusion: wrong outcomes. [pmid: 12626089].
Mittra I, Baum M, Thornton H, et al. Is clinical breast examination an acceptable alternative to mammographic screening?. BMJ. 2000;321(7268):1071-3. Exclusion: wrong publication type. [pmid: 11053185].
Mittra I, Mishra GA, Singh S, et al. A cluster randomized, controlled trial of breast and cervix cancer screening in Mumbai, India: methodology and interim results after three rounds of screening. Int J Cancer. 2010;126(4):976-84. Exclusion: wrong intervention. [pmid: 19697326].
Miyake K, Hayakawa K, Nishino M, et al. Benign or malignant?: differentiating breast lesions with computed tomography attenuation values on dynamic computed tomography mammography. J Comput Assist Tomogr. 2005;29(6):772-9. Exclusion: wrong intervention. [pmid: 16272850].
Miyake T, Shimazu K, Ohashi H, et al. Indication for sentinel lymph node biopsy for breast cancer when core biopsy shows ductal carcinoma in situ. Am J Surg. 2011;202(1):59-65. Exclusion: wrong intervention. [pmid: 21741518].
Mobley LR, Kuo T-MM, Watson L, et al. Geographic disparities in late-stage cancer diagnosis: multilevel factors and spatial interactions. Health Place. 2012;18(5):978-90. Exclusion: wrong outcomes. [pmid: 22789866].
Moin P, Deshpande R, Sayre J, et al. An observer study for a computer-aided reading protocol (CARP) in the screening environment for digital mammography. Acad Radiol. 2011;18(11):1420-9. Exclusion: wrong outcomes. [pmid: 21971259].
Moller B, Weedon-Fekjaer H, Hakulinen T, et al. The influence of mammographic screening on national trends in breast cancer incidence. Eur J Cancer Prev. 2005;14(2):117-28. Exclusion: wrong outcomes. [pmid: 15785315].
Monnin P, Bochud FO, Verdun FR. Using a NPWE model observer to assess suitable image quality for a digital mammography quality assurance programme. Radiat Prot Dosimetry. 2010;139(1-3):459-62. Exclusion: wrong outcomes. [pmid: 20395413].
Montella M, Buonanno M, Biondi E, et al. Changing patterns of breast cancer stage at diagnosis in southern italy: hospital data as indicators of progressive changes. Prev Med. 2000;30(2):174-7. Exclusion: wrong comparison. [pmid: 10656845].
Montella M, Schittulli F. Reduction in the number of women with advanced breast cancer stage at diagnosis in Italy. Eur J Cancer Prev. 2005;14(1):79-80. Exclusion: wrong publication type. [pmid: 15677900].
Montgomery M, McCrone SH. Psychological distress associated with the diagnostic phase for suspected breast cancer: systematic review. J Adv Nurs. 2010;66(11):2372-90. Exclusion: review not meeting inclusion criteria. [pmid: 21039773].
Monticciolo DL, Caplan LS. The American College of Radiology's BI-RADS 3 Classification in a Nationwide Screening Program: current assessment and comparison with earlier use. Breast J. 2004;10(2):106-10. Exclusion: wrong outcomes. [pmid: 15009036].
Moon JH, Kim HH, Shin HJ, et al. Supplemental use of optical diffusion breast imaging for differentiation between benign and malignant breast lesions. AJR Am J Roentgenol. 2011;197(3):732-9. Exclusion: wrong population. [pmid: 21862818].
Moon WK, Choi JW, Cho N, et al. Computer-aided analysis of ultrasound elasticity images for classification of benign and malignant breast masses. AJR Am J Roentgenol. 2010;195(6):1460-5. Exclusion: wrong intervention. [pmid: 21098210].
Moon WK, Shen Y-W, Huang C-S, et al. Comparative study of density analysis using automated whole breast ultrasound and MRI. Med Phys. 2011;38(1):382-9. Exclusion: wrong population. [pmid: 21361206].
Moore SG, Shenoy PJ, Fanucchi L, et al. Cost-effectiveness of MRI compared to mammography for breast cancer screening in a high risk population. BMC Health Serv Res. 2009;9:9. Exclusion: wrong outcomes. [pmid: 19144138].
Moorman PG, Jones BA, Millikan RC, et al. Race, anthropometric factors, and stage at diagnosis of breast cancer. Am J Epidemiol. 2001;153(3):284-91. Exclusion: wrong study design for key question. [pmid: 11157416].
Moraes PdC, Chala LF, Chang YS, et al. Observer variability in the application of morphologic and dynamic criteria according to the BI-RADS for MRI. Breast J. 2010;16(5):558-60. Exclusion: wrong publication type. [pmid: 20807220].
Moran CJ, Saranathan M, Nnewihe AN, et al. High resolution images of the breast. Eur J Radiol. Suppl 1. 2012;81:S101-3. Exclusion: wrong study design for key question. [pmid: 23083546].
Morimoto T, Okazaki M, Endo T. Current status and goals of mammographic screening for breast cancer in Japan. Breast Cancer. 2004;11(1):73-81. Exclusion: review not meeting inclusion criteria. [pmid: 14718797].
Morimoto T, Sasa M, Yamaguchi T, et al. Breast cancer screening by mammography in women aged under 50 years in Japan. Anticancer Res. 2000;20(5C):3689-94. Exclusion: wrong population. [pmid: 11268440].
Morimoto T, Sasa M, Yamaguchi T, et al. Effectiveness of mammographic screening for breast cancer in women aged over 50 years in Japan. Jpn J Cancer Res. 1997;88(8):778-84. Exclusion: wrong outcomes. [pmid: 9330610].
Morin RL, Maidment ADA. Digital mammography: coming of age. J Am Coll Radiol. 2005;2(9):798-801. Exclusion: wrong publication type. [pmid: 17411931].
Morland B, Lund Haheim L, Linnestad K. Mammography screening. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: review not meeting inclusion criteria.
Morrell S, Taylor R, Roder D, et al. Mammography screening and breast cancer mortality in Australia: an aggregate cohort study. J Med Screen. 2012;19(1):26-34. Exclusion: wrong study design for key question. [pmid: 22345322].
Morrow M. The certainties and the uncertainties of ductal carcinoma in situ. J Natl Cancer Inst. 2004;96(6):424-5. Exclusion: wrong publication type. [pmid: 15026460].
Morrow M. Magnetic resonance imaging in breast cancer: is seeing always believing?. Eur J Cancer. 2005;41(10):1368-9. Exclusion: wrong publication type. [pmid: 15913984].
Morrow M, Harris JR. More mastectomies: is this what patients really want?. J Clin Oncol. 2009;27(25):4038-40. Exclusion: wrong publication type. [pmid: 19635996].
Mortensen PB. Breast cancer risk in psychiatric patients. Am J Psychiatry. 1997;154(4):589. author reply -90. Exclusion: wrong publication type. [pmid: 9090367].
Moskowitz M. Guidelines for screening for breast cancer: Is a revision in order?. Radiol Clin North Am. 1992;30(1):221-33. Exclusion: wrong publication type. [pmid: 1732929].
Moss S. Screening women aged 40-49 years. Prev Med. 2011;53(3):105-7. Exclusion: wrong publication type. [pmid: 21704647].
Moss S. A trial to study the effect on breast cancer mortality of annual mammographic screening in women starting at age 40. J Med Screen. 1999;6(3):144-8. Exclusion: wrong publication type. [pmid: 10572845].
Moss S, Thomas I, Evans A, et al. Randomised controlled trial of mammographic screening in women from age 40: results of screening in the first 10 years. Br J Cancer. 2005;92(5):949-54. Exclusion: studies outside of search dates. [pmid: 15726102].
Moss SM. Advances in screening for breast cancer. Cancer Treat Res. 1996;86:77-91. Exclusion: review not meeting inclusion criteria. [pmid: 8886439].
Moss SM, Blanks RG, Bennett RL. Is radiologists' volume of mammography reading related to accuracy? A critical review of the literature. Clin Radiol. 2005;60(6):623-6. Exclusion: review not meeting inclusion criteria. [pmid: 16038688].
Moss SM, Brown J, Garvican L, et al. Routine breast screening for women aged 65-69: results from evaluation of the demonstration sites. Br J Cancer. 2001;85(9):1289-94. Exclusion: wrong study design for key question. [pmid: 11720462].
Moss SM, Nyström L, Jonsson H, et al. The impact of mammographic screening on breast cancer mortality in Europe: a review of trend studies. J Med Screen. Suppl 1. 2012;19:26-32. Exclusion: review not meeting inclusion criteria. [pmid: 22972808].
Mou X, Chen X, Sun L, et al. The impact of calibration phantom errors on dual-energy digital mammography. Phys Med Biol. 2008;53(22):6321-36. Exclusion: wrong outcomes. [pmid: 18936520].
Mouchawar J, Taplin S, Ichikawa L, et al. Late-stage breast cancer among women with recent negative screening mammography: do clinical encounters offer opportunity for earlier detection?. J Natl Cancer Inst. Monographs. 2005;(35):39-46. Exclusion: wrong comparison.
Mountford CE, Stanwell P, Ramadan S. Breast MR imaging at 3.0 T. Radiology. 2008;248(1):319-20. author reply 20. Exclusion: wrong publication type. [pmid: 18566184].
Mousa NA, Crystal P, Wolfman WL, et al. Aromatase inhibitors and mammographic breast density in postmenopausal women receiving hormone therapy. Menopause. 2008;15(5):875-84. Exclusion: wrong outcomes. [pmid: 18480735].
Moy L, Elias K, Patel V, et al. Is breast MRI helpful in the evaluation of inconclusive mammographic findings?. AJR Am J Roentgenol. 2009;193(4):986-93. Exclusion: wrong intervention. [pmid: 19770320].
Moy L, Noz ME, Maguire GQ Jr., et al. Role of fusion of prone FDG-PET and magnetic resonance imaging of the breasts in the evaluation of breast cancer. Breast J. 2010;16(4):369-76. Exclusion: wrong outcomes. [pmid: 20443788].
Moy L, Ponzo F, Noz ME, et al. Improving specificity of breast MRI using prone PET and fused MRI and PET 3D volume datasets. J Nucl Med. 2007;48(4):528-37. Exclusion: wrong intervention. [pmid: 17401088].
Moyle P, Warren R. Screening women at moderate risk of breast cancer. Br J Hosp Med (Lond). 2007;68(11):584-8. Exclusion: review not meeting inclusion criteria. [pmid: 18087844].
Muir TM, Tresham J, Fritschi L, et al. Screening for breast cancer post reduction mammoplasty. [Erratum appears in Clin Radiol. 2010 Jun;65(6):498]. Clin Radiol. 2010;65(3):198-205. Exclusion: wrong outcomes. [pmid: 20152275].
Mukhtar TK, Yeates DR, Goldacre MJ. Breast cancer mortality trends in England and the assessment of the effectiveness of mammography screening: population-based study. J R Soc Med. 2013;106(6):234-42. Exclusion: wrong comparison. [pmid: 23761583].
Muller-Schimpfle M, Ohmenhauser K, Sand J, et al. Dynamic 3D-MR mammography: is there a benefit of sophisticated evaluation of enhancement curves for clinical routine?. J Magn Reson Imaging. 1997;7(1):236-40. Exclusion: wrong outcomes. [pmid: 9039622].
Mundy L, Braunack-Mayer A, Merlin T. The role of scintimammography in the diagnosis of breast cancer. (Structured abstract). Health Technology Assessment Database. 2014;(1). Exclusion: wrong intervention.
Murad M, Bari V. Ultrasound differentiation of benign versus malignant solid breast masses. J Coll Physicians Surg Pak. 2004;14(3):166-9. Exclusion: wrong outcomes. [pmid: 15228851].
Muramatsu C, Li Q, Schmidt RA, et al. Determination of similarity measures for pairs of mass lesions on mammograms by use of BI-RADS lesion descriptors and image features. Acad Radiol. 2009;16(4):443-9. Exclusion: wrong outcomes. [pmid: 19268856].
Murday V, Pears R, Ball J, et al. An audit of screening for familial breast cancer before 50 years in the South Thames Region - have we got it right?. Fam Cancer. 2004;3(1):29-34. Exclusion: wrong study design for key question. [pmid: 15131403].
Murthy NS, Agarwal UK, Chaudhry K, et al. A study on time trends in incidence of breast cancer - Indian scenario. Eur J Cancer Care (Engl). 2007;16(2):185-6. Exclusion: wrong study design for key question. [pmid: 17371429].
Mushlin AI, Kouides RW, Shapiro DE. Estimating the accuracy of screening mammography: a meta-analysis. Am J Prev Med. 1998;14(2):143-53. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 9631167].
Mussurakis S, Buckley DL, Coady AM, et al. Observer variability in the interpretation of contrast enhanced MRI of the breast. Br J Radiol. 1996;69(827):1009-16. Exclusion: wrong outcomes. [pmid: 8958017].
Muti P. Re: “Serum insulin and glucose levels and breast cancer incidence: the Atherosclerosis Risk in Communities Study”. Am J Epidemiol. 2003;158(6):607. author reply 8. Exclusion: wrong publication type. [pmid: 12965886].
Muti P, Quattrin T, Grant BJB, et al. Fasting glucose is a risk factor for breast cancer: a prospective study. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1361-8. Exclusion: wrong outcomes. [pmid: 12433712].
Muttalib M, Sinnett HD. Re: Power et al. Needle-localised biopsy of impalpable breast lesions: a novel adjunct to surgical technique and specimen mammography. Surg J R Coll Surg Edinb Irel 2004;2(6): 343-45. Surgeon. 2006;4(1):60. Exclusion: wrong publication type. [pmid: 16459504].
Myles JP, Nixon RM, Duffy SW, et al. Bayesian evaluation of breast cancer screening using data from two studies. Stat Med. 2003;22(10):1661-74. Exclusion: wrong outcomes. [pmid: 12720303].
Myles JP, Salmininen T, Duffy SW, et al. Prospective estimation of rates of change in mammographic parenchymal patterns: influence of age and of hormone replacement therapy. Breast. 2004;13(1):56-60. Exclusion: wrong outcomes. [pmid: 14759717].
Naderi T, Bahrampoor A. Determination of sensitivity and specificity of breast tumor diagnosis by primary health care providers (Behvarz) using clinical examination by obstetrician as a gold standard. J Obstet Gynaecol Res. 2003;29(2):59-62. Exclusion: wrong intervention. [pmid: 12755522].
Nakagawa T, Hara T, Fujita H, et al. Radial-searching contour extraction method based on a modified active contour model for mammographic masses. Radiol Phys Technol. 2008;1(2):151-61. Exclusion: wrong intervention. [pmid: 20821141].
Nakano S, Ohtsuka M, Mibu A, et al. Diagnostic imaging strategy for MDCT- or MRI-detected breast lesions: use of targeted sonography. BMC Medical Imaging. 2012;12:13. Exclusion: wrong intervention. [pmid: 22691539].
Nakano S, Yoshida M, Fujii K, et al. Real-time virtual sonography, a coordinated sonography and MRI system that uses magnetic navigation, improves the sonographic identification of enhancing lesions on breast MRI. Ultrasound Med Biol. 2012;38(1):42-9. Exclusion: wrong outcomes. [pmid: 22137178].
Narayanan D, Madsen KS, Kalinyak JE, et al. Interpretation of positron emission mammography and MRI by experienced breast imaging radiologists: performance and observer reproducibility. AJR Am J Roentgenol. 2011;196(4):971-81. Exclusion: wrong outcomes. [pmid: 21427351].
Narod SA. Age of diagnosis, tumor size, and survival after breast cancer: implications for mammographic screening. Breast Cancer Res Treat. 2011;128(1):259-66. Exclusion: wrong comparison. [pmid: 21203901].
Narod SA. Re: Canadian national breast screening study-2: 13-year results of a randomized trial in women aged 50-59 years. J Natl Cancer Inst. 2001;93(5):396-7. Exclusion: wrong publication type. [pmid: 11238702].
Nasseri K. Secular trends in the incidence of female breast cancer in the United States, 1973-1998. [Erratum appears in Breast J. 2004 Jul-Aug;10(4):380]. Breast J. 2004;10(2):129-35. Exclusion: wrong comparison. [pmid: 15009040].
National Cancer Institute. Cancer control research. U.S. National Institutes of Health. Available at: http://cancercontrol.cancer.gov/grants/abstract.asp?applid=6965060 (http://cancercontrol.cancer.gov/grants/abstract.asp?applid=). Exclusion: wrong publication type.
Nattinger AB. Older women, mammography, and mortality from breast cancer. Am J Med. 2000;108(2):174-5. Exclusion: wrong publication type. [pmid: 11126313].
Navarro AM, Senn KL, McNicholas LJ, et al. Por La Vida model intervention enhances use of cancer screening tests among Latinas. Am J Prev Med. 1998;15(1):32-41. Exclusion: wrong outcomes. [pmid: 9651636].
Nederend J, Duijm LE, Louwman MW, et al. Trends in surgery for screen-detected and interval breast cancers in a national screening programme. Br J Surg. 2014;101(8):949-58. Exclusion: wrong outcomes. [pmid: 24828281].
Nederend J, Duijm LE, Voogd AC, et al. Trends in incidence and detection of advanced breast cancer at biennial screening mammography in The Netherlands: a population based study. Breast Cancer Res. 2012;14(1):R10. Exclusion: wrong comparison. [pmid: 22230363].
Nederend J, Duijm LEM, Louwman MWJ, et al. Impact of transition from analog screening mammography to digital screening mammography on screening outcome in The Netherlands: a population-based study. Ann Oncol. 2012;23(12):3098-103. Exclusion: wrong comparison. [pmid: 22745215].
Neeser K, Szucs T, Bulliard J-L, et al. Cost-effectiveness analysis of a quality-controlled mammography screening program from the Swiss statutory health-care perspective: quantitative assessment of the most influential factors. Value Health. 2007;10(1):42-53. Exclusion: wrong comparison. [pmid: 17261115].
Nekhlyudov L, Li R, Fletcher SW. Informed decision making before initiating screening mammography: does it occur and does it make a difference?. Health Expect. 2008;11(4):366-75. Exclusion: studies outside of search dates. [pmid: 19076664].
Nelson R. MRI better than mammography for detection of breast cancer?. Lancet Oncol. 2004;5(9):520. Exclusion: wrong publication type. [pmid: 15384210].
Newman LA, Sabel M. Advances in breast cancer detection and management. Med Clin North Am. 2003;87(5):997-1028. Exclusion: review not meeting inclusion criteria. [pmid: 14621328].
Ng EH, Ng FC, Tan PH, et al. Results of intermediate measures from a population-based, randomized trial of mammographic screening prevalence and detection of breast carcinoma among Asian women: the Singapore Breast Screening Project. Cancer. 1998;82(8):1521-8. Exclusion: wrong population. [pmid: 9554530].
Ng EH, Ng FC, Tan PH, et al. Results of intermediate measures from a population-based, randomized trial of mammographic screening prevalence and detection of breast carcinoma among Asian women: the Singapore Breast Screening Project. [Erratum appears in Cancer 1998 Jul 1;83(1):191]. Cancer. 1998;82(8):1521-8. Exclusion: wrong outcomes. [pmid: 9554530].
Nickson C, Kavanagh AM. Tumour size at detection according to different measures of mammographic breast density. J Med Screen. 2009;16(3):140-6. Exclusion: wrong comparison. [pmid: 19805755].
Nickson C, Mason KE, English DR, et al. Mammographic screening and breast cancer mortality: a case-control study and meta-analysis. Cancer Epidemiol Biomarkers Prev. 2012;21(9):1479-88. Exclusion: wrong study design for key question. [pmid: 22956730].
Nickson C, Mason KE, Kavanagh AM. Breast cancer screening of women aged 70-74 years: results from a natural experiment across Australia. Breast Cancer Res Treat. 2014;143(2):367-72. Exclusion: wrong outcomes. [pmid: 24327331].
Nie K, Chen J-H, Yu HJ, et al. Quantitative analysis of lesion morphology and texture features for diagnostic prediction in breast MRI. Acad Radiol. 2008;15(12):1513-25. Exclusion: wrong population. [pmid: 19000868].
Nilsen TI, Vatten LJ. Adult height and risk of breast cancer: a possible effect of early nutrition. Br J Cancer. 2001;85(7):959-61. Exclusion: wrong outcomes. [pmid: 11592765].
Nishikawa RM, Acharyya S, Gatsonis C, et al. Comparison of soft-copy and hard-copy reading for full-field digital mammography. Radiology. 2009;251(1):41-9. Exclusion: wrong intervention. [pmid: 19332845].
Nishikawa RM, Schmidt RA, Linver MN, et al. Clinically missed cancer: how effectively can radiologists use computer-aided detection?. [Erratum appears in AJR Am J Roentgenol. 2012 May;198(5):1232]. AJR Am J Roentgenol. 2012;198(3):708-16. Exclusion: wrong intervention. [pmid: 22358014].
Nixon R, Prevost TC, Duffy SW, et al. Some random-effects models for the analysis of matched-cluster randomised trials: application to the Swedish two-county trial of breast-cancer screening. J Epidemiol Biostat. 2000;5(6):349-58. Exclusion: wrong study design for key question. [pmid: 11234739].
Nixon RM, Pharoah P, Tabár L, et al. Mammographic screening in women with a family history of breast cancer: some results from the Swedish two-county trial. Rev Epidemiol Sante Publique. 2000;48(4):325-31. Exclusion: wrong comparison. [pmid: 11011299].
Njor S, Nyström L, Moss S, et al. Breast cancer mortality in mammographic screening in Europe: a review of incidence-based mortality studies. J Med Screen. Suppl 1. 2012;19:33-41. Exclusion: review not meeting inclusion criteria. [pmid: 22972809].
Njor SH, Hallas J, Schwartz W, et al. Type of hormone therapy and risk of misclassification at mammography screening. Menopause. 2011;18(2):171-7. Exclusion: wrong comparison. [pmid: 20729766].
Njor SH, Olsen AH, Schwartz W, et al. Tumour size distribution in mammography screening. Breast. 2005;14(4):329-32. Exclusion: wrong comparison. [pmid: 16085241].
Njor SH, Pedersen AT, Schwartz W, et al. Minimizing misclassification of hormone users at mammography screening. Int J Cancer. 2009;124(9):2159-65. Exclusion: wrong comparison. [pmid: 19132752].
Noble M, Bruening W, Uhl S, et al. Computer-aided detection mammography for breast cancer screening: systematic review and meta-analysis. Arch Gynecol Obstet. 2009;279(6):881-90. Exclusion: wrong outcomes. [pmid: 19023581].
Norden T, Thurfjell E, Hasselgren M, et al. Mammographic screening for breast cancer. What cancers do we find?. Eur J Cancer. 1997;33(4):624-8. Exclusion: wrong comparison. [pmid: 9274445].
Norman SA, Daly MB, McCorkle R, et al. Breast cancer and mammography: an American Cancer Society profile of Philadelphia and Montgomery Counties. Cancer Pract. 1996;4(2):68-75. Exclusion: wrong publication type. [pmid: 8715443].
Norman SA, Localio AR, Zhou L, et al. Benefit of screening mammography in reducing the rate of late-stage breast cancer diagnoses (United States). Cancer Causes Control. 2006;17(7):921-9. Exclusion: wrong study design for key question. [pmid: 16841259].
Norman SA, Russell Localio A, Weber AL, et al. Protection of mammography screening against death from breast cancer in women aged 40-64 years. Cancer Causes Control. 2007;18(9):909-18. Exclusion: wrong study design for key question. [pmid: 17665313].
Northington L, Martin T, Walker JT, et al. Integrated community education model: breast health awareness to impact late-stage breast cancer. Clin J Oncol Nurs. 2011;15(4):387-92. Exclusion: wrong publication type. [pmid: 21810571].
Nuno T, Martinez ME, Harris R, et al. A Promotora-administered group education intervention to promote breast and cervical cancer screening in a rural community along the U.S.-Mexico border: A randomized controlled trial. Cancer Causes Control. 2011;22(3):367-74. Exclusion: wrong intervention. [pmid: 21184267].
Nusbaum NJ. Role of the clinical breast examination in breast cancer screening does this patient have breast cancer? Does this patient have breast cancer? Barton MB, Harris R, Fletcher SW JAMA 1999;282:1270-1280. J Am Geriatr Soc. 2001;49(7):991-2. Exclusion: wrong publication type. [pmid: 11527493].
Nyante SJ, Dallal CM, Gierach GL, et al. Risk factors for specific histopathological types of postmenopausal breast cancer in the NIH-AARP Diet and Health Study. Am J Epidemiol. 2013;178(3):359-71. Exclusion: wrong outcomes. [pmid: 23899816].
Nyström L, Larsson LG, Wall S, et al. An overview of the Swedish randomised mammography trials: total mortality pattern and the representivity of the study cohorts. J Med Screen. 1996;3(2):85-7. Exclusion: review not meeting inclusion criteria. [pmid: 8849766].
Obenauer S, Sohns C, Werner C, et al. Computer-aided detection in full-field digital mammography: detection in dependence of the BI-RADS categories. Breast J. 2006;12(1):16-9. Exclusion: wrong intervention. [pmid: 16409582].
Obenauer S, Sohns C, Werner C, et al. Impact of breast density on computer-aided detection in full-field digital mammography. J Digit Imaging. 2006;19(3):258-63. Exclusion: wrong intervention. [pmid: 16741664].
Oberaigner W, Buchberger W, Frede T, et al. Breast cancer incidence and mortality in Tyrol/Austria after fifteen years of opportunistic mammography screening. BMC Public Health. 2010;10:86. Exclusion: wrong study design for key question. [pmid: 20170536].
Obuchowski NA, Lieber ML, Powell KA. Data analysis for detection and localization of multiple abnormalities with application to mammography. Acad Radiol. 2000;7(7):516-25. Exclusion: wrong outcomes. [pmid: 10902960].
O'Connor MK, Li H, Rhodes DJ, et al. Comparison of radiation exposure and associated radiation-induced cancer risks from mammography and molecular imaging of the breast. Med Phys. 2010;37(12):6187-98. Exclusion: wrong comparison. [pmid: 21302775].
Oestreicher N, Lehman CD, Seger DJ, et al. The incremental contribution of clinical breast examination to invasive cancer detection in a mammography screening program. AJR Am J Roentgenol. 2005;184(2):428-32. Exclusion: wrong outcomes. [pmid: 15671358].
Oestreicher N, White E, Lehman CD, et al. Predictors of sensitivity of clinical breast examination (CBE). Breast Cancer Res Treat. 2002;76(1):73-81. Exclusion: studies outside of search dates. [pmid: 12408378].
Ohlinger R, Heyer H, Thomas A, et al. Non-palpable breast lesions in asymptomatic women: diagnostic value of initial ultrasonography and comparison with mammography. Anticancer Res. 2006;26(5B):3943-55. Exclusion: studies outside of search dates. [pmid: 17094426].
Ohnuki K. Mammographic screening for non-palpable breast cancer in Japan. Breast Cancer. 2005;12(4):258-66. Exclusion: wrong publication type. [pmid: 16286905].
Ohta T, Okamoto K, Kanemaki Y, et al. Use of ultrasonography as an alternative modality for first-line examination in detecting breast cancer in selected patients. Clin Breast Cancer. 2007;7(8):624-6. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 17592675].
Ohuchi N, Ishida T, Kawai M, et al. Randomized controlled trial on effectiveness of ultrasonography screening for breast cancer in women aged 40-49 (J-START): research design. Jpn J Clin Oncol. 2011;41(2):275-7. Exclusion: wrong publication type. [pmid: 21131295].
Okamoto H, Ogawara T, Arihara F, et al. Usefulness of ultrasonography combined with conventional physical examination in mass screening for breast cancer: a retrospective study of Yamanashi Health Care Center results from 1989 to 1994. Jpn J Cancer Res. 1996;87(3):317-23. Exclusion: studies outside of search dates. [pmid: 8613436].
Okunade AA, Karakus MC. Mortality from breast carcinoma among US women: the role and implications of socio-economics, heterogeneous insurance, screening mammography, and geography. Health Care Manag Sci. 2003;6(4):237-48. Exclusion: wrong study design for key question. [pmid: 14686630].
Oleske DM, Galvez A, Cobleigh MA, et al. Are tri-ethnic low-income women with breast cancer effective teachers of the importance of breast cancer screening to their first-degree relatives? Results from a randomized clinical trial. Breast J. 2007;13(1):19-27. Exclusion: wrong outcomes. [pmid: 17214789].
Olivotto IA, Gomi A, Bancej C, et al. Influence of delay to diagnosis on prognostic indicators of screen-detected breast carcinoma. Cancer. 2002;94(8):2143-50. Exclusion: studies outside of search dates. [pmid: 12001110].
Olivotto IA, Kan L, Coldman AJ. False positive rate of screening mammography. N Engl J Med. 1998;339:560. Exclusion: wrong publication type. [pmid: 9714619].
Olivotto IA, Kan L, d'Yachkova Y, et al. Ten years of breast screening in the Screening Mammography Program of British Columbia, 1988-97. J Med Screen. 2000;7(3):152-9. Exclusion: wrong comparison. [pmid: 11126165].
Olsen AH, Jensen A, Njor SH, et al. Breast cancer incidence after the start of mammography screening in Denmark. Br J Cancer. 2003;88(3):362-5. Exclusion: wrong study design for key question. [pmid: 12569377].
Olsen AH, Njor SH, Lynge E. Estimating the benefits of mammography screening: the impact of study design. Epidemiology. 2007;18(4):487-92. Exclusion: wrong study design for key question. [pmid: 17486020].
Olsen AH, Njor SH, Vejborg I, et al. Breast cancer mortality in Copenhagen after introduction of mammography screening: cohort study. BMJ. 2005;330(7485):220. Exclusion: included in an included systematic review, not directly used. [pmid: 15649904].
Olsen AH, Njor SH, Vejborg I, et al. A model for determining the effect of mammography service screening. Acta Oncol. 2005;44(2):120-8. Exclusion: wrong study design for key question. [pmid: 15788290].
Olsen O. Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2002;94(2):578-9. author reply 81-3. Exclusion: wrong publication type. [pmid: 11900244].
Olsen O, Gotzsche PC. Cochrane review on screening for breast cancer with mammography. [Erratum appears in Lancet. 2006 Feb 11;367(9509):474]. Lancet. 2001;358(9290):1340-2. Exclusion: wrong publication type. [pmid: 11684218].
Olson RA, Nichol A, Caron NR, et al. Effect of community population size on breast cancer screening, stage distribution, treatment use and outcomes. Can J Public Health. Revue Canadienne de Sante Publique. 2012;103(1):46-52. Exclusion: wrong outcomes. [pmid: 22338328].
Olsson A, Borgquist S, Butt S, et al. Tumour-related factors and prognosis in breast cancer detected by screening. Br J Surg. 2012;99(1):78-87. Exclusion: wrong population. [pmid: 22068957].
Olsson A, Garne JP, Tengrup I, et al. Body mass index and breast cancer survival in relation to the introduction of mammographic screening. Eur J Surg Oncol. 2009;35(12):1261-7. Exclusion: wrong comparison. [pmid: 19481409].
Olsson P, Armelius K, Nordahl G, et al. Women with false positive screening mammograms: how do they cope?. J Med Screen. 1999;6(2):89-93. Exclusion: studies outside of search dates. [pmid: 10444727].
Oluwole SF, Ali AO, Adu A, et al. Impact of a cancer screening program on breast cancer stage at diagnosis in a medically underserved urban community. J Am Coll Surg. 2003;196(2):180-8. Exclusion: wrong comparison. [pmid: 12595043].
O'Meara ES, Zhu W, Hubbard RA, et al. Mammographic screening interval in relation to tumor characteristics and false-positive risk by race/ethnicity and age. Cancer. 2013;119(22):3959-67. Exclusion: wrong outcomes. [pmid: 24037812].
Omer Z, Hwang E, Esserman L, et al. P5-15-01: Words Matter: Influence of DCIS Diagnosis Terminology on Patient Treatment Decisions. Cancer Res. 2011;71(24 Supplement). P5-15-01. Exclusion: wrong outcomes.
Ondrusova M, Muzik J, Durdik S, et al. Long-term trends in the development of the epidemiology of breast cancer in the Slovak and Czech Republic with reference to applied screening and international comparisons. Neoplasma. 2012;59(1):70-8. Exclusion: wrong comparison. [pmid: 22103899].
Onega T, Cook A, Kirlin B, et al. The influence of travel time on breast cancer characteristics, receipt of primary therapy, and surveillance mammography. Breast Cancer Res Treat. 2011;129(1):269-75. Exclusion: wrong comparison. [pmid: 21553117].
Onesti JK, Mangus BE, Helmer SD, et al. Breast cancer tumor size: correlation between magnetic resonance imaging and pathology measurements. Am J Surg. 2008;196(6):844-48. discussion 9-50. Exclusion: wrong population. [pmid: 19095098].
Ong G, Austoker J, Brett J. Breast screening: adverse psychological consequences one month after placing women on early recall because of a diagnostic uncertainty. A multicentre study. J Med Screen. 1997;4(3):158-68. Exclusion: included in an included systematic review, not directly used. [pmid: 9368874].
Onishi H, Masuda N, Takechi K, et al. Computed radiography-based mammography with 50-microm pixel size: intra-individual comparison with film-screen mammography for diagnosis of breast cancers. Acad Radiol. 2009;16(7):836-41. Exclusion: wrong intervention. [pmid: 19345121].
Onitilo AA, Engel JM, Liang H, et al. Mammography utilization: patient characteristics and breast cancer stage at diagnosis. AJR Am J Roentgenol. 2013;201(5):1057-63. Exclusion: wrong comparison. [pmid: 23952790].
Ooi CWL, Campbell ID, Kollias J, et al. National Breast Cancer Audit: overview of invasive breast cancer in New Zealand. N Z Med J. 2012;125(1359):7-16. Exclusion: wrong comparison. [pmid: 22932509].
O'Regan RM. Do tumors detected by mammography screening have a favorable prognosis?. JAMA. 2004;292(9):1062-3. Exclusion: wrong publication type. [pmid: 15339899].
Orel SG. High-resolution MR imaging for the detection, diagnosis, and staging of breast cancer. Radiographics. 1998;18(4):903-12. Exclusion: review not meeting inclusion criteria. [pmid: 9672975].
Orel SG. MR imaging of the breast. Radiol Clin North Am. 2000;38(4):899-913. Exclusion: review not meeting inclusion criteria. [pmid: 10943285].
Orel SG, Hochman MG, Schnall MD, et al. High-resolution MR imaging of the breast: clinical context. Radiographics. 1996;16(6):1385-401. Exclusion: review not meeting inclusion criteria. [pmid: 8946543].
Orguc S, Basara I, Coskun T. Diffusion-weighted MR imaging of the breast: comparison of apparent diffusion coefficient values of normal breast tissue with benign and malignant breast lesions. Singapore Med J. 2012;53(11):737-43. Exclusion: wrong outcomes. [pmid: 23192501].
Orlacchio A, Bolacchi F, Rotili A, et al. MR breast imaging: a comparative analysis of conventional and parallel imaging acquisition. Radiol Med (Torino). 2008;113(4):465-76. Exclusion: wrong comparison. [pmid: 18523845].
Orton M, Fitzpatrick R, Fuller A, et al. Factors affecting women's response to an invitation to attend for a second breast cancer screening examination. Br J Gen Pract. 1991;41(349):320-2. Exclusion: included in an included systematic review, not directly used. [pmid: 1777275].
Osako T, Iwase T, Takahashi K, et al. Diagnostic mammography and ultrasonography for palpable and nonpalpable breast cancer in women aged 30 to 39 years. Breast Cancer. 2007;14(3):255-9. Exclusion: wrong population. [pmid: 17690501].
Osako T, Takahashi K, Iwase T, et al. Diagnostic ultrasonography and mammography for invasive and noninvasive breast cancer in women aged 30 to 39 years. Breast Cancer. 2007;14(2):229-33. Exclusion: wrong population. [pmid: 17485910].
Osmun WE, Copeland J, Boisvert L. Mammography screening: how far is too far?. Rural Remote Health. 2013;13(1):2149. Exclusion: wrong outcomes. [pmid: 23406261].
Ostbye T, Greenberg GN, Taylor DH Jr., et al. Screening mammography and Pap tests among older American women 1996-2000: results from the Health and Retirement Study (HRS) and Asset and Health Dynamics Among the Oldest Old (AHEAD). Ann Fam Med. 2003;1(4):209-17. Exclusion: wrong outcomes. [pmid: 15055410].
O'Sullivan I, Sutton S, Dixon S, et al. False positive results do not have a negative effect on reattendance for subsequent breast screening. J Med Screen. 2001;8(3):145-8. Exclusion: included in an included systematic review, not directly used. [pmid: 11678554].
Otten JD, Fracheboud J, den Heeten GJ, et al. Likelihood of early detection of breast cancer in relation to false-positive risk in life-time mammographic screening: population-based cohort study. Ann Oncol. 2013;24(10):2501-6. Exclusion: wrong population. [pmid: 23788759].
Otten JDM, Broeders MJM, Fracheboud J, et al. Impressive time-related influence of the Dutch screening programme on breast cancer incidence and mortality, 1975-2006. Int J Cancer. 2008;123(8):1929-34. Exclusion: included in an included systematic review, not directly used. [pmid: 18688863].
Otto SJ, Fracheboud J, Looman CWN, et al. Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: a systematic review. Lancet. 2003;361(9367):1411-7. Exclusion: included in an included systematic review, not directly used. [pmid: 12727393].
Otto SJ, Fracheboud J, Verbeek ALM, et al. Mammography screening and risk of breast cancer death: a population-based case-control study. Cancer Epidemiol Biomarkers Prev. 2012;21(1):66-73. Exclusion: included in an included systematic review, not directly used. [pmid: 22147362].
Ouedraogo S, Dabakuyo TS, Gentil J, et al. Attending breast cancer screening alone does not explain the detection of tumours at an early stage. Eur J Cancer Prev. 2013;22(2):103-11. Exclusion: wrong study design for key question. [pmid: 22751208].
Ouedraogo S, Dabakuyo TS, Gentil J, et al. Population-based study of breast cancer screening in Cote d'Or (France): clinical implications and factors affecting screening round adequacy. [Erratum appears in Eur J Cancer Prev. 2012 Jan;21(1):109]. Eur J Cancer Prev. 2011;20(6):462-74. Exclusion: wrong outcomes. [pmid: 22025137].
Ozanne EM, Shieh Y, Barnes J, et al. Characterizing the impact of 25 years of DCIS treatment. Breast Cancer Res Treat. 2011;129(1):165-73. Exclusion: wrong intervention. [pmid: 21390494].
Paajanen H, Kyhala L, Varjo R, et al. Effect of screening mammography on the surgery of breast cancer in Finland: a population-based analysis during the years 1985-2004. Am Surg. 2006;72(2):167-71. Exclusion: wrong comparison. [pmid: 16536250].
Paakko E, Reinikainen H, Lindholm E-L, et al. Low-field versus high-field MRI in diagnosing breast disorders. Eur Radiol. 2005;15(7):1361-8. Exclusion: wrong intervention. [pmid: 15711841].
Paap E, Holland R, den Heeten GJ, et al. A remarkable reduction of breast cancer deaths in screened versus unscreened women: a case-referent study. Cancer Causes Control. 2010;21(10):1569-73. Exclusion: wrong study design for key question. [pmid: 20512656].
Paap E, Verbeek ALM, Puliti D, et al. Breast cancer screening case-control study design: impact on breast cancer mortality. Ann Oncol. 2011;22(4):863-9. Exclusion: wrong study design for key question. [pmid: 20924073].
Pace LE, Keating NL. A systematic assessment of benefits and risks to guide breast cancer screening decisions. JAMA. 2014;311(13):1327-35. Exclusion: review not meeting inclusion criteria. [pmid: 24691608].
Paci E, Alexander FE. Study design of randomized controlled clinical trials of breast cancer screening. J Natl Cancer Inst. Monographs. 1997;(22):21-5. Exclusion: wrong publication type. [pmid: 8978404].
Paci E, Broeders M, Hofvind S, et al. European breast cancer service screening outcomes: a first balance sheet of the benefits and harms. Cancer Epidemiol Biomarkers Prev. 2014;23(7):1159-63. Exclusion: review not meeting inclusion criteria. [pmid: 24991022].
Paci E, Coviello E, Miccinesi G, et al. Evaluation of service mammography screening impact in Italy. The contribution of hazard analysis. Eur J Cancer. 2008;44(6):858-65. Exclusion: wrong study design for key question. [pmid: 18359222].
Paci E, Duffy S. Overdiagnosis and overtreatment of breast cancer: overdiagnosis and overtreatment in service screening. Breast Cancer Res. 2005;7(6):266-70. Exclusion: studies outside of search dates. [pmid: 16457702].
Paci E, Duffy SW, Giorgi D, et al. Are breast cancer screening programmes increasing rates of mastectomy? Observational study. BMJ. 2002;325(7361):418. Exclusion: wrong outcomes. [pmid: 12193357].
Paci E, Duffy SW, Giorgi D, et al. Quantification of the effect of mammographic screening on fatal breast cancers: The Florence Programme 1990-96. Br J Cancer. 2002;87(1):65-9. Exclusion: wrong comparison. [pmid: 12085258].
Paci E, Giorgi D, Bianchi S, et al. Assessment of the early impact of the population-based breast cancer screening programme in Florence (Italy) using mortality and surrogate measures. Eur J Cancer. 2002;38(4):568-73. Exclusion: included in an included systematic review, not directly used. [pmid: 11872351].
Paci E, Group EW. Summary of the evidence of breast cancer service screening outcomes in Europe and first estimate of the benefit and harm balance sheet. J Med Screen. Suppl 1. 2012;19:5-13. Exclusion: review not meeting inclusion criteria. [pmid: 22972806].
Paci E, Pannelli F. Female breast cancer. Epidemiol Prev. 2004;28(2 Suppl):64-7. Exclusion: wrong publication type. [pmid: 15281608].
Paci E, Ponti A, Crocetti E, et al. Re: Role of detection method in predicting breast cancer survival: analysis of randomized screening trials. J Natl Cancer Inst. 2005;97(24):1853-4. author reply 4. Exclusion: wrong publication type. [pmid: 16368949].
Paci E, Zappa M. Re: Efficacy of breast cancer screening in the community according to risk level. J Natl Cancer Inst. 2005;97(22):1704. author reply -5. Exclusion: wrong publication type. [pmid: 16288126].
Paesmans M, Ameye L, Moreau M, et al. Breast cancer screening in the older woman: an effective way to reduce mortality?. Maturitas. 2010;66(3):263-7. Exclusion: review not meeting inclusion criteria. [pmid: 20451335].
Pagan JA, Brown CJ, Asch DA, et al. Health literacy and breast cancer screening among Mexican American women in South Texas. J Cancer Educ. 2012;27(1):132-7. Exclusion: wrong outcomes. [pmid: 21573944].
Page DL, Gray GF Jr. Pathology of mammographically discovered breast cancer. Clinical implications of size and histologic differentiation. Surg Oncol Clin N Am. 1997;6(2):335-42. Exclusion: review not meeting inclusion criteria. [pmid: 9115499].
Pai VR, Gregory NE, Swinford AE, et al. Ductal carcinoma in situ: computer-aided detection in screening mammography. Radiology. 2006;241(3):689-94. Exclusion: wrong intervention. [pmid: 17053200].
Paik S, Shak S, Tang G, et al. A Multigene Assay to Predict Recurrence of Tamoxifen-Treated, Node-Negative Breast Cancer. N Engl J Med. 2004;351(27):2817-26. Exclusion: wrong intervention. [pmid: 15591335].
Paik S, Tang G, Shak S, et al. Gene expression and benefit of chemotherapy in women with node-negative, estrogen receptor-positive breast cancer. J Clin Oncol. 2006;24(23):3726-34. Exclusion: wrong population. [pmid: 16720680].
Palka I, Kelemen G, Ormandi K, et al. Tumor characteristics in screen-detected and symptomatic breast cancers. Pathol Oncol Res. 2008;14(2):161-7. Exclusion: wrong outcomes. [pmid: 18347932].
Pande AR, Lohani B, Sayami P, et al. Predictive value of ultrasonography in the diagnosis of palpable breast lump. Kathmandu Univ Med J. 2003;1(2):78-84. Exclusion: wrong intervention.
Panetta K, Zhou Y, Agaian S, et al. Nonlinear unsharp masking for mammogram enhancement. IEEE Trans Inf Technol Biomed. 2011;15(6):918-28. Exclusion: wrong intervention. [pmid: 21843996].
Panizza P, Vigano S, Bonelli L, et al. Screening women at intermediate risk: harm or charm?. Eur J Radiol. Suppl 1. 2012;81:S116-7. Exclusion: wrong publication type. [pmid: 23083554].
Papadopoulos A, Fotiadis DI, Costaridou L. Improvement of microcalcification cluster detection in mammography utilizing image enhancement techniques. Comput Biol Med. 2008;38(10):1045-55. Exclusion: wrong study design for key question. [pmid: 18774128].
Papas MA, Klassen AC. Pain and discomfort associated with mammography among urban low-income African-American women. J Community Health. 2005;30(4):253-67. Exclusion: included in an included systematic review, not directly used. [pmid: 15989208].
Paquerault S, Samuelson FW, Petrick N, et al. Investigation of reading mode and relative sensitivity as factors that influence reader performance when using computer-aided detection software. Acad Radiol. 2009;16(9):1095-107. Exclusion: wrong intervention. [pmid: 19523855].
Paquette D, Snider J, Bouchard F, et al. Performance of screening mammography in organized programs in Canada in 1996. The Database Management Subcommittee to the National Committee for the Canadian Breast Cancer Screening Initiative. CMAJ. 2000;163(9):1133-8. Exclusion: wrong comparison. [pmid: 11079057].
Parikh JR. Breast imaging flow models. J Am Coll Radiol. 2004;1(4):265-9. Exclusion: wrong intervention. [pmid: 17411578].
Park JM, Yang L, Laroia A, et al. Missed and/or misinterpreted lesions in breast ultrasound: reasons and solutions. Can Assoc Radiol J. 2011;62(1):41-9. Exclusion: wrong study design for key question. [pmid: 20947291].
Parr N, Boyages J, Taylor R, et al. Projecting mammographic screens. J Med Screen. 2000;7(3):146-51. Exclusion: wrong study design for key question. [pmid: 11126164].
Parris T, Wakefield D, Frimmer H. Real world performance of screening breast ultrasound following enactment of Connecticut Bill 458. Breast J. 2013;19(1):64-70. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 23240937].
Parsian S, Rahbar H, Allison KH, et al. Nonmalignant breast lesions: ADCs of benign and high-risk subtypes assessed as false-positive at dynamic enhanced MR imaging. Radiology. 2012;265(3):696-706. Exclusion: wrong outcomes. [pmid: 23033500].
Partin MR, Casey-Paal AL, Slater JS, et al. Measuring mammography compliance: lessons learned from a survival analysis of screening behavior. Cancer Epidemiol Biomarkers Prev. 1998;7(8):681-7. Exclusion: wrong outcomes. [pmid: 9718220].
Partin MR, Slater JS, Caplan L. Randomized controlled trial of a repeat mammography intervention: effect of adherence definitions on results. Prev Med. 2005;41(3-4):734-40. Exclusion: wrong outcomes. [pmid: 16043216].
Partridge SC, DeMartini WB, Kurland BF, et al. Quantitative diffusion-weighted imaging as an adjunct to conventional breast MRI for improved positive predictive value. AJR Am J Roentgenol. 2009;193(6):1716-22. Exclusion: wrong intervention. [pmid: 19933670].
Partridge SC, Rahbar H, Murthy R, et al. Improved diagnostic accuracy of breast MRI through combined apparent diffusion coefficients and dynamic contrast-enhanced kinetics. Magn Reson Med. 2011;65(6):1759-67. Exclusion: wrong intervention. [pmid: 21254208].
Parvinen I, Helenius H, Pylkkanen L, et al. Service screening mammography reduces breast cancer mortality among elderly women in Turku. J Med Screen. 2006;13(1):34-40. Exclusion: included in an included systematic review, not directly used. [pmid: 16569304].
Paskett E, Tatum C, Rushing J, et al. Randomized trial of an intervention to improve mammography utilization among a triracial rural population of women. J Natl Cancer Inst. 2006;98(17):1226-37. Exclusion: wrong intervention. [pmid: 16954475].
Patani N, Mokbel K. The utility of MRI for the screening and staging of breast cancer. Int J Clin Pract. 2008;62(3):450-3. Exclusion: review not meeting inclusion criteria. [pmid: 18201177].
Patel MR, Whitman GJ. Negative mammograms in symptomatic patients with breast cancer. Acad Radiol. 1998;5(1):26-33. Exclusion: wrong population. [pmid: 9442204].
Payne JI, Caines JS, Gallant J, et al. A review of interval breast cancers diagnosed among participants of the Nova Scotia Breast Screening Program. Radiology. 2013;266(1):96-103. Exclusion: wrong outcomes. [pmid: 23169791].
Pediconi F, Catalano C, Roselli A, et al. The challenge of imaging dense breast parenchyma: is magnetic resonance mammography the technique of choice? A comparative study with x-ray mammography and whole-breast ultrasound. Invest Radiol. 2009;44(7):412-21. Exclusion: wrong intervention. [pmid: 19448554].
Pentecost MJ. Mammography and the risks of engagement. J Am Coll Radiol. 2004;1(11):797-9. Exclusion: wrong publication type. [pmid: 17411707].
Pereira RR Jr., Azevedo Marques PM, Honda MO, et al. Usefulness of texture analysis for computerized classification of breast lesions on mammograms. J Digit Imaging. 2007;20(3):248-55. Exclusion: wrong outcomes. [pmid: 17122993].
Perez-Fidalgo JA, Miranda J, Chirivella I, et al. Impact of a mammography screening programme on the breast cancer population of the Region of Valencia (Spain). Clin Transl Oncol. 2008;10(11):745-52. Exclusion: wrong comparison. [pmid: 19015071].
Perez-Gomez B, Ruiz F, Martinez I, et al. Women's features and inter-/intra-rater agreement on mammographic density assessment in full-field digital mammograms (DDM-SPAIN). [Erratum appears in Breast Cancer Res Treat. 2012 Dec;136(3):935]. Breast Cancer Res Treat. 2012;132(1):287-95. Exclusion: wrong outcomes. [pmid: 22042363].
Perrier A, Roy PM, Sanchez O, et al. Multidetector-row computed tomography in suspected pulmonary embolism. N Engl J Med. 2005;352(17):1760-8. Exclusion: wrong intervention. [pmid: 15858185].
Perry DK, Marable S, Darcy D. Breast cancer control report card: Rhode Island, 1999. Med Health R I. 1999;82(12):451-2. Exclusion: wrong publication type. [pmid: 10628144].
Perry NM, Patani N, Milner SE, et al. The impact of digital mammography on screening a young cohort of women for breast cancer in an urban specialist breast unit. Eur Radiol. 2011;21(4):676-82. Exclusion: wrong outcomes. [pmid: 20886340].
Peters NHGM, Borel Rinkes IHM, Zuithoff NPA, et al. Meta-analysis of MR imaging in the diagnosis of breast lesions. Radiology. 2008;246(1):116-24. Exclusion: wrong intervention. [pmid: 18024435].
Petrakis IE, Paraskakis S. Breast cancer in the elderly. Arch Gerontol Geriatr. 2010;50(2):179-84. Exclusion: wrong publication type. [pmid: 19409626].
Petralia G, Bonello L, Summers P, et al. Intraobserver and interobserver variability in the calculation of apparent diffusion coefficient (ADC) from diffusion-weighted magnetic resonance imaging (DW-MRI) of breast tumours. Radiol Med (Torino). 2011;116(3):466-76. Exclusion: wrong outcomes. [pmid: 21225368].
Petticrew MP, Sowden AJ, Lister-Sharp D, et al. False-negative results in screening programmes: systematic review of impact and implications. Health Technol Assess. 2000;4(5):1-120. Exclusion: review not meeting inclusion criteria. [pmid: 10859208].
Pharoah PDP, Sewell B, Fitzsimmons D, et al. Cost effectiveness of the NHS breast screening programme: life table model. [Erratum appears in BMJ. 2013;346:f3822]. BMJ. 2013;346:f2618. Exclusion: wrong study design for key question. [pmid: 23661112].
Phillips CE, Rothstein JD, Beaver K, et al. Patient navigation to increase mammography screening among inner city women. J Gen Intern Med. 2011;26(2):123-9. Exclusion: wrong intervention. [pmid: 20931294].
Phillips J, Smith ED. Breast cancer control and African American women: a review. Cancer Invest. 2001;19(3):273-80. Exclusion: review not meeting inclusion criteria. [pmid: 11338885].
Phillips N, Coldman A. Comparison of nonbreast cancer incidence, survival and mortality between breast screening program participants and nonparticipants. Int J Cancer. 2008;122(1):197-201. Exclusion: wrong outcomes. [pmid: 17721881].
Philpotts LE, Smith RA. Screening for breast cancer. Semin Roentgenol. 2003;38(1):19-33. Exclusion: wrong publication type. [pmid: 12698588].
Piccoli CW, Greer JG, Mitchell DG. Breast MR imaging for cancer detection and implant evaluation: potential pitfalls. Radiographics. 1996;16(1):63-75. Exclusion: review not meeting inclusion criteria. [pmid: 10946690].
Pickles MD, Turnbull LW. Breast MRI at 3.0 T in a high-risk familial breast cancer screening cohort: comparison with 1.5 T screening studies. Br J Radiol. 2012;85(1015):990-5. Exclusion: wrong population. [pmid: 22167509].
Pinker K, Grabner G, Bogner W, et al. A combined high temporal and high spatial resolution 3 Tesla MR imaging protocol for the assessment of breast lesions: initial results. Invest Radiol. 2009;44(9):553-8. Exclusion: wrong intervention. [pmid: 19652611].
Pisani P, Forman D. Declining mortality from breast cancer in Yorkshire, 1983-1998: extent and causes. Br J Cancer. 2004;90(3):652-6. Exclusion: wrong intervention. [pmid: 14760380].
Pisano E. Issues in breast cancer screening. Technol Cancer Res Treat. 2005;4(1):5-9. Exclusion: wrong publication type. [pmid: 15649082].
Pisano ED, Earp JA, Gallant TL. Screening mammography behavior after a false positive mammogram. Cancer Detect Prev. 1998;22(2):161-7. Exclusion: studies outside of search dates. [pmid: 9544437].
Pisano ED, Gatsonis C, Hendrick E, et al. Diagnostic performance of digital versus film mammography for breast-cancer screening. [Erratum appears in N Engl J Med. 2006 Oct 26;355(17):1840]. N Engl J Med. 2005;353(17):1773-83. Exclusion: wrong comparison. [pmid: 16169887].
Pisano ED, Hendrick RE, Yaffe MJ, et al. Diagnostic accuracy of digital versus film mammography: exploratory analysis of selected population subgroups in DMIST. Radiology. 2008;246(2):376-83. Exclusion: wrong intervention. [pmid: 18227537].
Pistolese CA, Ciarrapico AM, della Gatta F, et al. Inappropriateness of breast imaging: cost analysis. Radiol Med (Torino). 2013;118(6):984-94. Exclusion: wrong outcomes. [pmid: 23801396].
Pistolese CA, Perretta T, Cossu E, et al. Value of the correct diagnostic pathway through conventional imaging (mammography and ultrasound) in evaluating breast disease. Radiol Med (Torino). 2011;116(4):584-94. Exclusion: wrong outcomes. [pmid: 21431300].
Plecha D, Salem N, Kremer M, et al. Neglecting to screen women between 40 and 49 years old with mammography: what is the impact on treatment morbidity and potential risk reduction?. AJR American Journal of Roentgenology. 2014;202(2):282-8. Exclusion: wrong outcomes. [pmid: 24450666].
Pollan M, Pastor-Barriuso R, Ardanaz E, et al. Recent changes in breast cancer incidence in Spain, 1980-2004. J Natl Cancer Inst. 2009;101(22):1584-91. Exclusion: wrong comparison. [pmid: 19861303].
Pons-Vigués M, Puigpinós R, Cano-Serral G, et al. Breast cancer mortality in Barcelona following implementation of a city breast cancer-screening program. Cancer Detect Prev. 2008;32(2):162-7. Exclusion: included in an included systematic review, not directly used. [pmid: 18639990].
Ponti A, Lynge E, James T, et al. International variation in management of screen-detected ductal carcinoma in situ of the breast. Eur J Cancer. 2014;50(15):2695-704. Exclusion: wrong outcomes. [pmid: 25149183].
Ponti A, Mano MP, Distante V, et al. Audit system on quality of breast cancer diagnosis and treatment (QT): results from the survey on screen-detected lesions in Italy, 2004. Epidemiol Prev. 2007;31(2-3 Suppl 2):69-75. Exclusion: wrong study design for key question. [pmid: 17824364].
Ponti A, Mano MP, Distante V, et al. Audit system on Quality of breast cancer diagnosis and Treatment (QT): results from the survey on screen-detected lesions in Italy, 2003-2004. Epidemiol Prev. 2006;30(1 Suppl 3):59-63. Exclusion: wrong intervention. [pmid: 16937847].
Ponti A, Rosso S, Zanetti R, et al. Re: Breast cancer incidence, 1980-2006: combined roles of menopausal hormone therapy, screening mammography, and estrogen receptor status. J Natl Cancer Inst. 2007;99(23):1817-8. author reply 9. Exclusion: wrong publication type. [pmid: 18042935].
Ponzone R, Sismondi P, Baum M. Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2002;94(2):579-80. author reply 81-3. Exclusion: wrong publication type. [pmid: 11900246].
Poplack SP, Tosteson AN, Grove MR, et al. Mammography in 53,803 women from the New Hampshire mammography network. Radiology. 2000;217(3):832-40. Exclusion: wrong outcomes. [pmid: 11110951].
Poplack SP, Tosteson TD, Kogel CA, et al. Digital breast tomosynthesis: initial experience in 98 women with abnormal digital screening mammography. AJR Am J Roentgenol. 2007;189(3):616-23. Exclusion: studies outside of search dates. [pmid: 17715109].
Porter GJR, Evans AJ, Burrell HC, et al. Interval breast cancers: prognostic features and survival by subtype and time since screening. J Med Screen. 2006;13(3):115-22. Exclusion: wrong outcomes. [pmid: 17007651].
Porter PL, El-Bastawissi AY, Mandelson MT, et al. Breast tumor characteristics as predictors of mammographic detection: comparison of interval- and screen-detected cancers. J Natl Cancer Inst. 1999;91(23):2020-8. Exclusion: wrong comparison. [pmid: 10580027].
Poulos A, Rickard M. Compression in mammography and the perception of discomfort. Australas Radiol. 1997;41(3):247-52. Exclusion: included in an included systematic review, not directly used. [pmid: 9293675].
Powell KA, Obuchowski NA, Chilcote WA, et al. Film-screen versus digitized mammography: assessment of clinical equivalence. AJR Am J Roentgenol. 1999;173(4):889-94. Exclusion: wrong comparison. [pmid: 10511142].
Powles TJ, Diem SJ, Fabian CJ, et al. Breast cancer incidence in postmenopausal women with osteoporosis or low bone mass using arzoxifene. Breast Cancer Res Treat. 2012;134(1):299-306. Exclusion: wrong intervention. [pmid: 22484799].
Poynter JN, Inoue-Choi M, Ross JA, et al. Reproductive, lifestyle, and anthropometric risk factors for cancer in elderly women. Cancer Epidemiol Biomarkers Prev. 2013;22(4):681-7. Exclusion: wrong comparison. [pmid: 23429062].
Prasad SN, Houserkova D. A comparison of mammography and ultrasonography in the evaluation of breast masses. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2007;151(2):315-22. Exclusion: wrong population. [pmid: 18345271].
Prasad SN, Houserkova D, Campbell J. Breast imaging using 3D electrical impedence tomography. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2008;152(1):151-4. Exclusion: wrong outcomes. [pmid: 18795091].
Price ER, Hargreaves J, Lipson JA, et al. The California breast density information group: a collaborative response to the issues of breast density, breast cancer risk, and breast density notification legislation. Radiology. 2013;269(3):887-92. Exclusion: wrong publication type. [pmid: 24023072].
Price J, Chen SW. Screening for breast cancer with MRI: recent experience from the Australian Capital Territory. J Med Imaging Radiat Oncol. 2009;53(1):69-80. Exclusion: wrong population. [pmid: 19453531].
Printz C. Advanced cancer risk similar with biennial vs. annual mammography in women aged 50 to 74. Cancer. 2013;119(16):2949. Exclusion: wrong publication type.
Prionas ND, Lindfors KK, Ray S, et al. Contrast-enhanced dedicated breast CT: initial clinical experience. Radiology. 2010;256(3):714-23. Exclusion: wrong outcomes. [pmid: 20720067].
Prior P, Woodman CB, Wilson S, et al. Reliability of underlying incidence rates for estimating the effect and efficiency of screening for breast cancer. J Med Screen. 1996;3(3):119-22. Exclusion: wrong study design for key question. [pmid: 8946305].
Prizemin Y. Using “voting” in CAD for mammography to lower false-positive rates. Radiol Manage. 2010;32(1):13-5. Exclusion: wrong publication type. [pmid: 22279723].
Provenzano E, Pinder SE. Pre-operative diagnosis of breast cancer in screening: problems and pitfalls. Pathology. 2009;41(1):3-17. Exclusion: review not meeting inclusion criteria. [pmid: 19089735].
Puig-Vives M, Pollan M, Rue M, et al. Rapid increase in incidence of breast ductal carcinoma in situ in Girona, Spain 1983-2007. Breast. 2012;21(5):646-51. Exclusion: wrong outcomes. [pmid: 22340960].
Puliti D, Miccinesi G, Collina N, et al. Effectiveness of service screening: a case-control study to assess breast cancer mortality reduction. [Erratum appears in Br J Cancer. 2008 Nov 18;99(10):1756]. Br J Cancer. 2008;99(3):423-7. Exclusion: included in an included systematic review, not directly used. [pmid: 18665188].
Puliti D, Miccinesi G, Manneschi G, et al. Does an organised screening programme reduce the inequalities in breast cancer survival?. Ann Oncol. 2012;23(2):319-23. Exclusion: wrong outcomes. [pmid: 21515663].
Puliti D, Paci E. The other side of technology: risk of overdiagnosis of breast cancer with mammography screening. Fut Oncol. 2009;5(4):481-91. Exclusion: wrong publication type.
Qian W, Song D, Lei M, et al. Computer-aided mass detection based on ipsilateral multiview mammograms. Acad Radiol. 2007;14(5):530-8. Exclusion: wrong intervention. [pmid: 17434066].
Quek ST, Thng CH, Khoo JBK, et al. Radiologists' detection of mammographic abnormalities with and without a computer-aided detection system. Australas Radiol. 2003;47(3):257-60. Exclusion: wrong outcomes. [pmid: 12890245].
Raabe NK, Fossaa SD. Primary invasive breast carcinoma in Oslo 1980-1989. Incidence and delay. Acta Oncol. 1996;35(1):9-15. Exclusion: wrong outcomes. [pmid: 8619947].
Rack SK. Mammography screening: a current controversy. W V Med J. 2003;99(3):108-10. Exclusion: wrong publication type. [pmid: 14515434].
Rafferty EA, Park JM, Philpotts LE, et al. Assessing radiologist performance using combined digital mammography and breast tomosynthesis compared with digital mammography alone: results of a multicenter, multireader trial. Radiology. 2013;266(1):104-13. Exclusion: wrong outcomes. [pmid: 23169790].
Raftery J, Chorozoglou M. Possible net harms of breast cancer screening: updated modelling of Forrest report. BMJ. 2011;343:d7627. Exclusion: wrong study design for key question. [pmid: 22155336].
Rakha EA, El-Sayed ME, Reed J, et al. Screen-detected breast lesions with malignant needle core biopsy diagnoses and no malignancy identified in subsequent surgical excision specimens (potential false-positive diagnosis). Eur J Cancer. 2009;45(7):1162-7. Exclusion: wrong intervention. [pmid: 19121932].
Rakha EA, Lee AHS, Reed J, et al. Screen-detected malignant breast lesions diagnosed following benign (B2) or normal (B1) needle core biopsy diagnoses. Eur J Cancer. 2010;46(10):1835-40. Exclusion: wrong intervention. [pmid: 20392631].
Ramirez AJ, Westcombe AM, Burgess CC, et al. Factors predicting delayed presentation of symptomatic breast cancer: A systematic review. Lancet. 1999;353(9159):1127-31. Exclusion: wrong outcomes. [pmid: 10209975].
Randolph WM, Goodwin JS, Mahnken JD, et al. Regular mammography use is associated with elimination of age-related disparities in size and stage of breast cancer at diagnosis. Ann Intern Med. 2002;137(10):783-90. Exclusion: wrong population. [pmid: 12435214].
Raneta O, Bella V, Bellova L, et al. The use of electrical impedance tomography to the differential diagnosis of pathological mammographic/sonographic findings. Neoplasma. 2013;60(6):647-54. Exclusion: wrong intervention. [pmid: 23906299].
Rangayyan RM, Shen L, Shen Y, et al. Improvement of sensitivity of breast cancer diagnosis with adaptive neighborhood contrast enhancement of mammograms. IEEE Trans Inf Technol Biomed. 1997;1(3):161-70. Exclusion: wrong intervention. [pmid: 11020818].
Ranger B, Littrup PJ, Duric N, et al. Breast ultrasound tomography versus MRI for clinical display of anatomy and tumor rendering: preliminary results. AJR Am J Roentgenol. 2012;198(1):233-9. Exclusion: wrong intervention. [pmid: 22194502].
Rankin SC. MRI of the breast. Br J Radiol. 2000;73(872):806-18. Exclusion: wrong publication type. [pmid: 11026854].
Rao S, Latha PS, Ravi A, et al. Ductal carcinoma in a multiple fibroadenoma: diagnostic inaccuracies. J Cancer Res Ther. 2010;6(3):385-7. Exclusion: wrong study design for key question. [pmid: 21119286].
Rauscher GH, Hawley ST, Earp JAL. Baseline predictors of initiation vs. maintenance of regular mammography use among rural women. Prev Med. 2005;40(6):822-30. Exclusion: wrong comparison. [pmid: 15850884].
Ravert PK, Huffaker C. Breast cancer screening in women: An integrative literature review. J Am Acad Nurse Pract. 2010;22(12):668-73. Exclusion: review not meeting inclusion criteria. [pmid: 21129075].
Rayford CE 2nd, Zhou W, Chen Y. Breast tomosynthesis imaging configuration analysis. International Journal of Computational Biology & Drug Design. 2013;6(3):255-62. Exclusion: wrong outcomes. [pmid: 23900440].
Rayson D, Payne JI, Abdolell M, et al. Comparison of clinical-pathologic characteristics and outcomes of true interval and screen-detected invasive breast cancer among participants of a Canadian breast screening program: a nested case-control study. Clin Breast Cancer. 2011;11(1):27-32. Exclusion: wrong comparison. [pmid: 21421519].
Raza S, Chikarmane SA, Neilsen SS, et al. BI-RADS 3, 4, and 5 lesions: value of US in management--follow-up and outcome. Radiology. 2008;248(3):773-81. Exclusion: wrong population. [pmid: 18647850].
Redondo M, Funez R, Medina-Cano F, et al. Detection methods predict differences in biology and survival in breast cancer patients. BMC Cancer. 2012;12:604. Exclusion: wrong comparison. [pmid: 23244222].
Reeves MJ, Newcomb PA, Remington PL, et al. Body mass and breast cancer. Relationship between method of detection and stage of disease. Cancer. 1996;77(2):301-7. Exclusion: wrong outcomes. [pmid: 8625238].
Regentova E, Zhang L, Zheng J, et al. Detecting microcalcifications in digital mammograms using wavelet domain hidden Markov tree model. Conf Proc IEEE Eng Med Biol Soc. 2006;1:1972-5. Exclusion: wrong outcomes. [pmid: 17945686].
Reinikainen H, Rissanen T, Paivansalo M, et al. B-mode, power Doppler and contrast-enhanced power Doppler ultrasonography in the diagnosis of breast tumors. Acta Radiol. 2001;42(1):106-13. Exclusion: wrong population. [pmid: 11167342].
Reiser I, Nishikawa RM, Giger ML, et al. Computerized detection of mass lesions in digital breast tomosynthesis images using two- and three dimensional radial gradient index segmentation. Technol Cancer Res Treat. 2004;3(5):437-41. Exclusion: wrong intervention. [pmid: 15453808].
Retsky M, Demicheli R, Hrushesky W. Breast cancer screening for women aged 40-49 years: screening may not be the benign process usually thought. J Natl Cancer Inst. 2001;93(20):1572. Exclusion: wrong publication type. [pmid: 11604483].
Rettig B, Horton M. Breast cancer in Nebraska: recent trends in incidence, mortality, and screening. Nebr Med J. 1996;81(3):63-9. Exclusion: wrong outcomes.
Rhodes DJ, Hruska CB, Phillips SW, et al. Dedicated dual-head gamma imaging for breast cancer screening in women with mammographically dense breasts. Radiology. 2011;258(1):106-18. Exclusion: wrong intervention. [pmid: 21045179].
Ricci P, Cantisani V, Ballesio L, et al. Benign and malignant breast lesions: efficacy of real time contrast-enhanced ultrasound vs. magnetic resonance imaging. Ultraschall Med. 2007;28(1):57-62. Exclusion: wrong outcomes. [pmid: 17304413].
Richardson A, Wells JE. Breast cancer screening: the effect of self selection for screening on comparisons of randomised controlled trials. J Med Screen. 1997;4(1):16-8. Exclusion: wrong outcomes. [pmid: 9200056].
Richardson LC, Schulman J, Sever LE, et al. Early-stage breast cancer treatment among medically underserved women diagnosed in a national screening program, 1992-1995. Breast Cancer Res Treat. 2001;69(2):133-42. Exclusion: wrong comparison. [pmid: 11759819].
Rickard M, Donnellan M. Diagnosis of small sized invasive breast cancer by an Australian mammography screening service: surrogate end-points for mortality reduction. Aust N Z J Surg. 1998;68(6):415-8. Exclusion: wrong comparison. [pmid: 9623460].
Rickard M, Taylor R, Page A, et al. Cancer detection and mammogram volume of radiologists in a population-based screening programme. Breast. 2006;15(1):39-43. Exclusion: wrong outcomes. [pmid: 16005226].
Rickard MT, Taylor RJ, Fazli MA, et al. Interval breast cancers in an Australian mammographic screening program. Med J Aust. 1998;169(4):184-7. Exclusion: wrong comparison. [pmid: 9734574].
Riedl CC, Ponhold L, Flory D, et al. Magnetic resonance imaging of the breast improves detection of invasive cancer, preinvasive cancer, and premalignant lesions during surveillance of women at high risk for breast cancer. Clin Cancer Res. 2007;13(20):6144-52. Exclusion: wrong population. [pmid: 17947480].
Rijnsburger AJ, van Oortmarssen GJ, Boer R, et al. Mammography benefit in the Canadian National Breast Screening Study-2: a model evaluation. Int J Cancer. 2004;110(5):756-62. Exclusion: wrong study design for key question. [pmid: 15146566].
Rimer BK, Bluman LG. The psychosocial consequences of mammography. J Natl Cancer Inst. 1997;(22):131-8. Exclusion: wrong publication type.
Rimer BK, Lipscomb J. Enhancing the use of mammography: effectiveness and cost. Eff Clin Pract. 2000;3(5):250-5. Exclusion: wrong publication type. [pmid: 11185331].
Ringash J, Canadian Task Force on Preventive Health C. Preventive health care, 2001 update: screening mammography among women aged 40-49 years at average risk of breast cancer. CMAJ. 2001;164(4):469-76. Exclusion: review not meeting inclusion criteria. [pmid: 11233866].
Ripping TM, Verbeek ALM, van der Waal D, et al. Immediate and delayed effects of mammographic screening on breast cancer mortality and incidence in birth cohorts. Br J Cancer. 2013;109(9):2467-71. Exclusion: wrong comparison. [pmid: 24113141].
Robbins AS, Clarke CA. Re: Declines in invasive breast cancer and use of postmenopausal hormone therapy in a screening mammography population. J Natl Cancer Inst. 2007;99(23):1815. author reply 6-7. Exclusion: wrong publication type. [pmid: 18042938].
Roberts-Klein S, Iuanow E, Slanetz PJ. Avoiding pitfalls in mammographic interpretation. Can Assoc Radiol J. 2011;62(1):50-9. Exclusion: wrong publication type. [pmid: 20832240].
Robinson JI, Crane CE, King JM, et al. The South Australian Breast X-Ray Service: results from a statewide mammographic screening programme. Br J Cancer. 1996;73(6):837-42. Exclusion: wrong comparison. [pmid: 8611391].
Robsahm TE, Tretli S. Weak associations between sociodemographic factors and breast cancer: possible effects of early detection. Eur J Cancer Prev. 2005;14(1):7-12. Exclusion: wrong outcomes. [pmid: 15677890].
Rockhill B, Spiegelman D, Byrne C, et al. Validation of the Gail et al. model of breast cancer risk prediction and implications for chemoprevention. J Natl Cancer Inst. 2001;93(5):358-66. Exclusion: wrong outcomes. [pmid: 11238697].
Roder D, Houssami N, Farshid G, et al. Population screening and intensity of screening are associated with reduced breast cancer mortality: evidence of efficacy of mammography screening in Australia. Breast Cancer Res Treat. 2008;108(3):409-16. Exclusion: wrong study design for key question. [pmid: 18351455].
Roder D, Webster F, Zorbas H, et al. Breast screening and breast cancer survival in Aboriginal and Torres Strait Islander women of Australia. Asian Pac J Cancer Prev. 2012;13(1):147-55. Exclusion: wrong outcomes. [pmid: 22502658].
Rodger A, Kavanagh AM. Outcome measures of an Australian breast-screening program. Med J Aust. 1998;169(4):179-80. Exclusion: wrong publication type. [pmid: 9734571].
Rodrigues PS, Giraldi GA, Provenzano M, et al. A new methodology based on q-entropy for breast lesion classification in 3-D ultrasound images. Conf Proc IEEE Eng Med Biol Soc. 2006;1:1048-51. Exclusion: wrong study design for key question. [pmid: 17945617].
Roelofs AAJ, Karssemeijer N, Wedekind N, et al. Importance of comparison of current and prior mammograms in breast cancer screening. Radiology. 2007;242(1):70-7. Exclusion: wrong outcomes. [pmid: 17185661].
Roelofs AAJ, van Woudenberg S, Otten JDM, et al. Effect of soft-copy display supported by CAD on mammography screening performance. Eur Radiol. 2006;16(1):45-52. Exclusion: wrong intervention. [pmid: 16132926].
Roen EL, Roubidoux MA, Joe AI, et al. Adherence to screening mammography among American Indian women of the Northern Plains. Breast Cancer Res Treat. 2013;139(3):897-905. Exclusion: wrong outcomes. [pmid: 23749344].
Rohan TE, Jain M, Howe GR, et al. A cohort study of dietary carotenoids and lung cancer risk in women (Canada). Cancer Causes Control. 2002;13(3):231-7. Exclusion: wrong outcomes. [pmid: 12020104].
Rojas-Dominguez A, Nandi AK. Development of tolerant features for characterization of masses in mammograms. Comput Biol Med. 2009;39(8):678-88. Exclusion: wrong study design for key question. [pmid: 19524221].
Rolnick SJ, O'Connor PJ, Jackson JM, et al. Early- and late-stage breast cancer in a managed care setting in relation to mammography screening. Cancer Detect Prev. 1998;22(6):495-8. Exclusion: wrong study design for key question. [pmid: 9824371].
Roman M, Hubbard RA, Sebuodegard S, et al. The cumulative risk of false-positive results in the Norwegian Breast Cancer Screening Program: updated results. Cancer. 2013;119(22):3952-8. Exclusion: wrong study design for key question. [pmid: 23963877].
Roman R, Sala M, De La Vega M, et al. Effect of false-positives and women's characteristics on long-term adherence to breast cancer screening. Breast Cancer Res Treat. 2011;130(2):543-52. Exclusion: wrong outcomes. [pmid: 21617920].
Roman R, Sala M, Salas D, et al. Effect of protocol-related variables and women's characteristics on the cumulative false-positive risk in breast cancer screening. Ann Oncol. 2012;23(1):104-11. Exclusion: wrong outcomes. [pmid: 21430183].
Romero C, Varela C, Munoz E, et al. Impact on breast cancer diagnosis in a multidisciplinary unit after the incorporation of mammography digitalization and computer-aided detection systems. [Erratum appears in AJR Am J Roentgenol. 2012 Jan;198(1):2]. AJR Am J Roentgenol. 2011;197(6):1492-7. Exclusion: wrong outcomes. [pmid: 22109307].
Romero Castellano C, Varela Nunez C, Cuena Boy R, et al. Impact of mammographic breast density on computer-assisted detection (CAD) in a breast imaging department. Radiologia. 2011;53(5):456-61. Exclusion: wrong intervention. [pmid: 21641624].
Rominger MB, Sax EV, Figiel JH, et al. Occurrence and positive predictive value of additional nonmass findings for risk stratification of breast microcalcifications in mammography. Can Assoc Radiol J. 2013;64(4):333-8. Exclusion: wrong outcomes. [pmid: 23298860].
Rong XJ, Shaw CC, Johnston DA, et al. Microcalcification detectability for four mammographic detectors: flat-panel, CCD, CR, and screen/film). Med Phys. 2002;29(9):2052-61. Exclusion: wrong intervention. [pmid: 12349926].
Roque AC, Andre TCSS. Mammography and computerized decision systems: a review. Ann N Y Acad Sci. 2002;980:83-94. Exclusion: review not meeting inclusion criteria. [pmid: 12594083].
Rosen EL, Sickles E, Keating D. Ability of mammography to reveal nonpalpable breast cancer in women with palpable breast masses. AJR Am J Roentgenol. 1999;172(2):309-12. Exclusion: wrong population. [pmid: 9930773].
Rosen S, Weintraub N. The efficacy of performing screening mammograms in the frail elderly population. J Am Med Dir Assoc. 2006;7(4):230-3. Exclusion: wrong publication type. [pmid: 16698509].
Rosenberg RD, Hunt WC, Williamson MR, et al. Effects of age, breast density, ethnicity, and estrogen replacement therapy on screening mammographic sensitivity and cancer stage at diagnosis: review of 183,134 screening mammograms in Albuquerque, New Mexico. Radiology. 1998;209(2):511-8. Exclusion: wrong comparison. [pmid: 9807581].
Rosenberg RD, Yankaskas BC, Abraham LA, et al. Performance benchmarks for screening mammography. Radiology. 2006;241(1):55-66. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 16990671].
Rostgaard K, Vaeth M, Holst H, et al. Age-period-cohort modelling of breast cancer incidence in the Nordic countries. Stat Med. 2001;20(1):47-61. Exclusion: wrong study design for key question. [pmid: 11135347].
Roth EB, Jeffe DB, Margenthaler JA, et al. Method of breast cancer presentation and depressed mood 1 year after diagnosis in women with locally advanced disease. Ann Surg Oncol. 2009;16(6):1637-41. Exclusion: wrong population. [pmid: 19360452].
Rothschild J, Lourenco AP, Mainiero MB. Screening mammography recall rate: does practice site matter?. Radiology. 2013;269(2):348-53. Exclusion: wrong outcomes. [pmid: 23884734].
Roubidoux MA, Wilson TE, Orange RJ, et al. Breast cancer in women who undergo screening mammography: relationship of hormone replacement therapy to stage and detection method. Radiology. 1998;208(3):725-8. Exclusion: wrong comparison. [pmid: 9722852].
Rouse HC, Ussher S, Kavanagh AM, et al. Examining the sensitivity of ultrasound-guided large core biopsy for invasive breast carcinoma in a population screening programme. J Med Imaging Radiat Oncol. 2013;57(4):435-43. Exclusion: wrong outcomes. [pmid: 23870339].
Royak-Schaler R, Chen S, Zang E, et al. Does access to screening through health maintenance organization membership translate into improved breast cancer outcomes for African American patients?. J Am Med Womens Assoc. 2003;58(3):154-6. Exclusion: wrong comparison. [pmid: 12948106].
Ruamsup S, Wiratkapun C, Wibulpolprasert B, et al. A comparison between short-interval and regular-interval follow-up for BI-RADS category 3 lesions. Singapore Med J. 2010;51(2):120-5. Exclusion: wrong outcomes. [pmid: 20358150].
Rue M, Vilaprinyo E, Lee S, et al. Effectiveness of early detection on breast cancer mortality reduction in Catalonia (Spain). BMC Cancer. 2009;9:326. Exclusion: wrong study design for key question. [pmid: 19754959].
Rutter CM, Taplin S. Assessing mammographers' accuracy. A comparison of clinical and test performance. J Clin Epidemiol. 2000;53(5):443-50. Exclusion: wrong outcomes. [pmid: 10812315].
Rutter DR, Calnan M, Field S, et al. Predicting reattendance in the second round of the UK National Breast Screening Programme: A prospective 3-year longitudinal analysis. Breast. 1997;6(3):120-5. Exclusion: included in an included systematic review, not directly used.
Saadatmand S, Tilanus-Linthorst MMA, Rutgers EJT, et al. Cost-effectiveness of screening women with familial risk for breast cancer with magnetic resonance imaging. J Natl Cancer Inst. 2013;105(17):1314-21. Exclusion: wrong population. [pmid: 23940285].
Saarenmaa I, Salminen T, Geiger U, et al. The effect of age and density of the breast on the sensitivity of breast cancer diagnostic by mammography and ultasonography. Breast Cancer Res Treat. 2001;67(2):117-23. Exclusion: wrong intervention. [pmid: 11519860].
Sadigh G, Carlos RC, Neal CH, et al. Ultrasonographic differentiation of malignant from benign breast lesions: a meta-analytic comparison of elasticity and BIRADS scoring. Breast Cancer Res Treat. 2012;133(1):23-35. Exclusion: review not meeting inclusion criteria. [pmid: 22057974].
Sadjadi A, Hislop TG, Bajdik C, et al. Comparison of breast cancer survival in two populations: Ardabil, Iran and British Columbia, Canada. BMC Cancer. 2009;9:381. Exclusion: wrong outcomes. [pmid: 19863791].
Sadler GR, Beerman PR, Lee K, et al. Promoting breast cancer screening among Asian American women: the Asian grocery store-based cancer education program. J Cancer Educ. 2012;27(4):612-7. Exclusion: wrong outcomes. [pmid: 23055131].
Sadler GR, Ko CM, Wu P, et al. A cluster randomized controlled trial to increase breast cancer screening among African American women: the black cosmetologists promoting health program. J Natl Med Assoc. 2011;103(8):735-45. Exclusion: wrong outcomes. [pmid: 22046851].
Sagen A, Kaaresen R, Sandvik L, et al. Upper limb physical function and adverse effects after breast cancer surgery: a prospective 2.5-year follow-up study and preoperative measures. Arch Phys Med Rehabil. 2014;95(5):875-81. Exclusion: wrong comparison. [pmid: 24389401].
Sahiner B, Chan HP, Petrick N, et al. Improvement of mammographic mass characterization using spiculation meausures and morphological features. Med Phys. 2001;28(7):1455-65. Exclusion: wrong outcomes. [pmid: 11488579].
Sahiner B, Chan H-P, Hadjiiski LM, et al. Multi-modality CADx: ROC study of the effect on radiologists' accuracy in characterizing breast masses on mammograms and 3D ultrasound images. Acad Radiol. 2009;16(7):810-8. Exclusion: wrong outcomes. [pmid: 19375953].
Sahiner B, Chan H-P, Roubidoux MA, et al. Malignant and benign breast masses on 3D US volumetric images: effect of computer-aided diagnosis on radiologist accuracy. Radiology. 2007;242(3):716-24. Exclusion: wrong intervention. [pmid: 17244717].
Sahiner B, Chan H-P, Roubidoux MA, et al. Computerized characterization of breast masses on three-dimensional ultrasound volumes. Med Phys. 2004;31(4):744-54. Exclusion: wrong intervention. [pmid: 15124991].
Sala M, Comas M, Macia F, et al. Implementation of digital mammography in a population-based breast cancer screening program: effect of screening round on recall rate and cancer detection. Radiology. 2009;252(1):31-9. Exclusion: wrong comparison. [pmid: 19420316].
Sala M, Salas D, Belvis F, et al. Reduction in false-positive results after introduction of digital mammography: analysis from four population-based breast cancer screening programs in Spain. [Erratum appears in Radiology. 2011 Jul;260(1):308]. Radiology. 2011;258(2):388-95. Exclusion: wrong comparison. [pmid: 21273520].
Salas D, Ibanez J, Roman R, et al. Effect of start age of breast cancer screening mammography on the risk of false-positive results. Prev Med. 2011;53(1-2):76-81. Exclusion: wrong outcomes. [pmid: 21575653].
Salz T, Richman AR, Brewer NT. Meta-analyses of the effect of false-positive mammograms on generic and specific psychosocial outcomes. Psychooncology. 2010;19(10):1026-34. Exclusion: review not meeting inclusion criteria. [pmid: 20882572].
Salzmann P, Kerlikowske K, Phillips K. Cost-effectiveness of extending screening mammography guidelines to include women 40 to 49 years of age. [Erratum appears in Ann Intern Med 1998 May 15;128(10):878]. Ann Intern Med. 1997;127(11):955-65. Exclusion: wrong outcomes. [pmid: 9412300].
Samei E, Poolla A, Ulissey MJ, et al. Digital mammography: comparative performance of color LCD and monochrome CRT displays. Acad Radiol. 2007;14(5):539-46. Exclusion: wrong outcomes. [pmid: 17434067].
Samei E, Saunders RS Jr., Baker JA, et al. Digital mammography: effects of reduced radiation dose on diagnostic performance. Radiology. 2007;243(2):396-404. Exclusion: wrong intervention. [pmid: 17356178].
Samnakay N, Tinning J, Ives A, et al. Rates for mastectomy are lower in women attending a breast-screening programme. ANZ J Surg. 2005;75(11):936-9. Exclusion: wrong outcomes. [pmid: 16336381].
Sampalis FS, Denis R, Picard D, et al. International prospective evaluation of scintimammography with (99m)technetium sestamibi. Am J Surg. 2003;185(6):544-9. Exclusion: wrong intervention. [pmid: 12781883].
Samulski M, Hupse R, Boetes C, et al. Using computer-aided detection in mammography as a decision support. Eur Radiol. 2010;20(10):2323-30. Exclusion: wrong intervention. [pmid: 20532890].
Samulski M, Karssemeijer N. Optimizing Case-based detection performance in a multiview CAD system for mammography. IEEE Trans Med Imaging. 2011;30(4):1001-9. Exclusion: wrong intervention. [pmid: 21233045].
Sanchez Gomez S, Torres Tabanera M, Vega Bolivar A, et al. Impact of a CAD system in a screen-film mammography screening program: a prospective study. Eur J Radiol. 2011;80(3):e317-21. Exclusion: wrong intervention. [pmid: 20863639].
Sanders MA, Roland L, Sahoo S. Clinical implications of subcategorizing BI-RADS 4 breast lesions associated with microcalcification: a radiology-pathology correlation study. Breast J. 2010;16(1):28-31. Exclusion: wrong outcomes. [pmid: 19929890].
Sanderson M, Daling JR, Doody DR, et al. Perinatal factors and mortality from breast cancer. Cancer Epidemiol Biomarkers Prev. 2006;15(10):1984-7. Exclusion: wrong outcomes. [pmid: 17035409].
Sandin B, Chorot P, Valiente RM, et al. Adverse psychological effects in women attending a second-stage breast cancer screening. Journal of psychosomatic research. 2002;52(5):303-9. Exclusion: studies outside of search dates. [pmid: 12023127].
Sandin B, Chorot P, Valiente RM, et al. Adverse psychological effects in women attending a second-stage breast cancer screening. Journal of psychosomatic research. 2002;52(5):303-9. Exclusion: included in an included systematic review, not directly used. [pmid: 12023127].
Sandstrom-Wakeling SK, Nied L, Gambino K, et al. The importance of mammography screening in elderly women. Nurse Pract. 2003;28(5):50-3. Exclusion: wrong study design for key question. [pmid: 12792269].
Sankaranarayanan R, Ramadas K, Thara S, et al. Clinical breast examination: preliminary results from a cluster randomized controlled trial in India. J Natl Cancer Inst. 2011;103(19):1476-80. Exclusion: wrong intervention. [pmid: 21862730].
Sardanelli F. MultiHance for dynamic MR imaging of the breast. Eur Radiol. Suppl 7. 2004;14:O65-70. discussion O84-5. Exclusion: wrong outcomes. [pmid: 15503379].
Sardanelli F, Fausto A, Iozzelli A, et al. Dynamic breast magnetic resonance imaging. Effect of changing the region of interest on early enhancement using 2D and 3D techniques. J Comput Assist Tomogr. 2004;28(5):642-6. Exclusion: wrong outcomes. [pmid: 15480038].
Sarkeala T. Performance and effectiveness of organised breast cancer screening in Finland. Acta Oncol. 2008;47(8):1618. Exclusion: wrong publication type. [pmid: 18759146].
Sarkeala T, Anttila A, Saarenmaa I, et al. Validity of process indicators of screening for breast cancer to predict mortality reduction. J Med Screen. 2005;12(1):33-7. Exclusion: wrong outcomes. [pmid: 15814017].
Sarkeala T, Heinavaara S, Anttila A. Breast cancer mortality with varying invitational policies in organised mammography. Br J Cancer. 2008;98(3):641-5. Exclusion: included in an included systematic review, not directly used. [pmid: 18231108].
Sarkeala T, Heinavaara S, Anttila A. Organised mammography screening reduces breast cancer mortality: a cohort study from Finland. Int J Cancer. 2008;122(3):614-9. Exclusion: wrong comparison. [pmid: 17847022].
Sarkissyan M, Wu Y, Vadgama JV. Obesity is associated with breast cancer in African-American women but not Hispanic women in South Los Angeles. Cancer. 2011;117(16):3814-23. Exclusion: wrong outcomes. [pmid: 21305540].
Sassi F, Luft HS, Guadagnoli E. Reducing racial/ethnic disparities in female breast cancer: screening rates and stage at diagnosis. Am J Public Health. 2006;96(12):2165-72. Exclusion: wrong comparison. [pmid: 17077392].
Satake H, Nishio A, Ikeda M, et al. Predictive value for malignancy of suspicious breast masses of BI-RADS categories 4 and 5 using ultrasound elastography and MR diffusion-weighted imaging. AJR Am J Roentgenol. 2011;196(1):202-9. Exclusion: wrong outcomes. [pmid: 21178068].
Sauer T, Young K, Thoresen SO. Fine needle aspiration cytology in the work-up of mammographic and ultrasonographic findings in breast cancer screening: an attempt at differentiating in situ and invasive carcinoma. Cytopathology. 2002;13(2):101-10. Exclusion: wrong comparison. [pmid: 11952748].
Saunders RS Jr., Samei E, Lo JY, et al. Can compression be reduced for breast tomosynthesis? Monte carlo study on mass and microcalcification conspicuity in tomosynthesis. Radiology. 2009;251(3):673-82. Exclusion: wrong outcomes. [pmid: 19474373].
Sauven P, Bishop H, Patnick J, et al. The National Health Service Breast Screening Programme and British Association of Surgical Oncology audit of quality assurance in breast screening 1996-2001. Br J Surg. 2003;90(1):82-7. Exclusion: wrong outcomes. [pmid: 12520580].
Savoca CJ. Re: “Technology evaluation center assessment synopsis: use of magnetic resonance imaging to avoid a biopsy in women with suspicious primary breast lesions”. J Am Coll Radiol. 2005;2(10):869. author reply -70. Exclusion: wrong publication type. [pmid: 17411953].
Sayegh RA, Slanetz PJ. Breast density, hormones, and screening mammography: should women be less concerned?. Menopause. 2009;16(6):1085-6. Exclusion: wrong study design for key question. [pmid: 19724240].
Scaf-Klomp W, Sanderman R, van de Wiel HB, et al. Distressed or relieved? Psychological side effects of breast cancer screening in The Netherlands. J Epidemiol Community Health. 1997;51(6):705-10. Exclusion: studies outside of search dates. [pmid: 9519137].
Schell MJ, Yankaskas BC, Ballard-Barbash R, et al. Evidence-based target recall rates for screening mammography. Radiology. 2007;243(3):681-9. Exclusion: wrong outcomes. [pmid: 17517927].
Schilling K. Positron emission mammography: better than magnetic resonance mammography?. Eur J Radiol. Suppl 1. 2012;81:S139-41. Exclusion: wrong outcomes. [pmid: 23083565].
Schleicher UM, Ammon J. Mode of breast cancer detection: a study from the German part of the Maas-Rhine-EUREGIO. Eur J Cancer Prev. Suppl 1. 1998;7:S41-6. Exclusion: wrong intervention. [pmid: 10866035].
Schmitz AC, Peters NHGM, Veldhuis WB, et al. Contrast-enhanced 3.0-T breast MRI for characterization of breast lesions: increased specificity by using vascular maps. Eur Radiol. 2008;18(2):355-64. Exclusion: wrong outcomes. [pmid: 17882425].
Schnall M, Orel S. Breast MR imaging in the diagnostic setting. Magn Reson Imaging Clin N Am. 2006;14(3):329-37. Exclusion: wrong intervention. [pmid: 17098174].
Schnall MD. Application of magnetic resonance imaging to early detection of breast cancer. Breast Cancer Res. 2001;3(1):17-21. Exclusion: review not meeting inclusion criteria. [pmid: 11300101].
Schnall MD. Breast MR imaging. Radiol Clin North Am. 2003;41(1):43-50. Exclusion: wrong publication type. [pmid: 12630684].
Schnall MD, Blume J, Bluemke DA, et al. Diagnostic architectural and dynamic features at breast MR imaging: multicenter study. Radiology. 2006;238(1):42-53. Exclusion: wrong outcomes. [pmid: 16373758].
Schnur JB, Montgomery GH, Hallquist MN, et al. Anticipatory psychological distress in women scheduled for diagnostic and curative breast cancer surgery. Int J Behav Med. 2008;15(1):21-8. Exclusion: wrong outcomes. [pmid: 18444017].
Schonberg MA, Breslau ES, McCarthy EP. Targeting of mammography screening according to life expectancy in women aged 75 and older. J Am Geriatr Soc. 2013;61(3):388-95. Exclusion: wrong outcomes. [pmid: 23414437].
Schonberg MA, McCarthy EP, Davis RB, et al. Breast cancer screening in women aged 80 and older: results from a national survey. J Am Geriatr Soc. 2004;52(10):1688-95. Exclusion: wrong outcomes. [pmid: 15450046].
Schootman M, Fuortes LJ. Breast and cervical carcinoma: the correlation of activity limitations and rurality with screening, disease incidence, and mortality. Cancer. 1999;86(6):1087-94. Exclusion: wrong outcomes. [pmid: 10491538].
Schootman M, Fuortes LJ. Early indicators of the effect of a breast cancer screening program for low-income women. Cancer Detect Prev. 2001;25(2):138-46. Exclusion: wrong study design for key question. [pmid: 11341349].
Schootman M, Jeffe D, Reschke A, et al. The full potential of breast cancer screening use to reduce mortality has not yet been realized in the United States. Breast Cancer Res Treat. 2004;85(3):219-22. Exclusion: wrong study design for key question. [pmid: 15111759].
Schootman M, Jeffe DB, Lian M, et al. Surveillance mammography and the risk of death among elderly breast cancer patients. Breast Cancer Res Treat. 2008;111(3):489-96. Exclusion: wrong population. [pmid: 17957465].
Schootman M, Lian M, Deshpande AD, et al. Temporal trends in area socioeconomic disparities in breast-cancer incidence and mortality, 1988-2005. Breast Cancer Res Treat. 2010;122(2):533-43. Exclusion: wrong comparison. [pmid: 20054637].
Schootman M, Walker MS, Jeffe DB, et al. Breast cancer screening and incidence in communities with a high proportion of uninsured. Am J Prev Med. 2007;33(5):379-86. Exclusion: wrong outcomes. [pmid: 17950403].
Schott G, Reichel M, Junkermann H, et al. Retrospective quantification of background incidence and stage distribution of breast cancer for the mammography screening pilot project in Wiesbaden, Germany. J Cancer Res Clin Oncol. 2008;134(1):29-35. Exclusion: wrong outcomes. [pmid: 17602243].
Schousboe JT, Kerlikowske K, Loh A, et al. Personalizing mammography by breast density and other risk factors for breast cancer: analysis of health benefits and cost-effectiveness. Ann Intern Med. 2011;155(1):10-20. Exclusion: wrong outcomes. [pmid: 21727289].
Schouten LJ, de Rijke JM, Huveneers JAM, et al. Rising incidence of breast cancer after completion of the first prevalent round of the breast cancer screening programme. J Med Screen. 2002;9(3):120-4. Exclusion: wrong outcomes. [pmid: 12370323].
Schouten LJ, de Rijke JM, Schlangen JT, et al. Evaluation of the effect of breast cancer screening by record linkage with the cancer registry, The Netherlands. J Med Screen. 1998;5(1):37-41. Exclusion: wrong comparison. [pmid: 9575459].
Schroen AM, Wobbes T, van der Sluis RF. Infiltrating lobular carcinoma of the breast detected by screening. Br J Surg. 1998;85(3):390-2. Exclusion: wrong intervention. [pmid: 9529500].
Schwartz LM, Woloshin S, Sox HC, et al. US women's attitudes to false positive mammography results and detection of ductal carcinoma in situ: cross sectional survey. BMJ. 2000;320(7250):1635-40. Exclusion: wrong study design for key question. [pmid: 10856064].
Scinto JD, Gill TM, Grady JN, et al. Screening mammography: Is it suitably targeted to older women who are most likely to benefit?. J Am Geriatr Soc. 2001;49(8):1101-4. Exclusion: wrong outcomes. [pmid: 11555074].
Scotland NHSQI. Comparison of digital mammography and film screen mammography. 2004. Exclusion: wrong outcomes.
Sechopoulos I, Suryanarayanan S, Vedantham S, et al. Radiation dose to organs and tissues from mammography: Monte Carlo and phantom study. Radiology. 2008;246(2):434-43. Exclusion: wrong population. [pmid: 18056857].
Seemayer CA, Breuer E, Kroll G, et al. Incidence and tumour stages of breast cancer in the region of Aachen, Germany. Eur J Cancer Care (Engl). 2002;11(1):16-24. Exclusion: wrong outcomes. [pmid: 11966831].
Seidenwurm D, Rosenberg R. Quality of life and diagnostic imaging outcomes. J Am Coll Radiol. 2010;7(4):265-8. Exclusion: wrong study design for key question. [pmid: 20362941].
Seigneurin A, Exbrayat C, Labarere J, et al. Comparison of interval breast cancer rates for two-versus single-view screening mammography: a population-based study. Breast. 2009;18(5):284-8. Exclusion: wrong outcomes. [pmid: 19713113].
Seigneurin A, Exbrayat C, Labarere J, et al. Association of diagnostic work-up with subsequent attendance in a breast cancer screening program for false-positive cases. Breast Cancer Res Treat. 2011;127(1):221-8. Exclusion: wrong outcomes. [pmid: 20809364].
Seiler S, Lenkinski RE. Dedicated PET device for breast PET and MRI/PET correlations. Eur J Radiol. Suppl 1. 2012;81:S149-50. Exclusion: wrong publication type. [pmid: 23083569].
Sekine K, Tsunoda-Shimizu H, Kikuchi M, et al. DCIS showing architectural distortion on the screening mammogram - comparison of mammographic and pathological findings. Breast Cancer. 2007;14(3):281-4. Exclusion: wrong outcomes. [pmid: 17690505].
Selinko VL, Middleton LP, Dempsey PJ. Role of sonography in diagnosing and staging invasive lobular carcinoma. J Clin Ultrasound. 2004;32(7):323-32. Exclusion: wrong population. [pmid: 15293298].
Sellers TA, King RA, Cerhan JR, et al. Fifty-year follow-up of cancer incidence in a historical cohort of Minnesota breast cancer families. Cancer Epidemiol Biomarkers Prev. 1999;8(12):1051-7. Exclusion: wrong population. [pmid: 10613336].
Semiglazov VF, Manikhas AG, Moiseenko VM, et al. Results of a prospective randomized investigation [Russia (St.Petersburg)/WHO] to evaluate the significance of self-examination for the early detection of breast cancer. Vopr Onkol. 2003;49(4):434-41. Exclusion: wrong outcomes. [pmid: 14569932].
Semiglazov VF, Moiseyenko VM, Bavli JL, et al. The role of breast self-examination in early breast cancer detection (results of the 5-years USSR/WHO randomized study in Leningrad). Eur J Epidemiol. 1992;8(4):498-502. Exclusion: studies outside of search dates. [pmid: 1397215].
Sener SF, Winchester DJ, Winchester DP, et al. Survival rates for breast cancers detected in a community service screening mammogram program. Am J Surg. 2006;191(3):406-9. Exclusion: wrong comparison. [pmid: 16490556].
Sener SF, Winchester DJ, Winchester DP, et al. Spectrum of mammographically detected breast cancers. Am Surg. 1999;65(8):731-5. discussion 5-6. Exclusion: wrong outcomes. [pmid: 10432082].
Sennerstam RB, Wiksell H, Schassburger K-U, et al. Breast cancer and clinical outcome among women over 60 years of age: a plead for more screening and alternative treatments. Anal Quant Cytol Histol. 2012;34(4):189-94. Exclusion: wrong comparison.
Sentis M. Imaging diagnosis of young women with breast cancer. Breast Cancer Res Treat. Suppl 1. 2010;123:11-3. Exclusion: review not meeting inclusion criteria. [pmid: 20711665].
Seo BK, Pisano ED, Kuzmiak CM, et al. The positive predictive value for diagnosis of breast cancer full-field digital mammography versus film-screen mammography in the diagnostic mammographic population. Acad Radiol. 2006;13(10):1229-35. Exclusion: wrong outcomes. [pmid: 16979072].
Seppanen J, Heinavaara S, Anttila A, et al. Effects of different phases of an invitational screening program on breast cancer incidence. Int J Cancer. 2006;119(4):920-4. Exclusion: wrong study design for key question. [pmid: 16550598].
Seppanen J, Heinavaara S, Hakulinen T. Influence of alternative mammographic screening scenarios on breast cancer incidence predictions (Finland). Cancer Causes Control. 2006;17(9):1135-44. Exclusion: wrong outcomes. [pmid: 17006719].
Seppanen J, Heinavaara S, Hakulinen T. Predicting impacts of mass-screening policy changes on breast cancer mortality. Stat Med. 2008;27(25):5235-51. Exclusion: wrong outcomes. [pmid: 18613224].
Seradour B, Allemand H, Weill A, et al. Changes by age in breast cancer incidence, mammography screening and hormone therapy use in France from 2000 to 2006. Bull Cancer. 2009;96(4):E1-6. Exclusion: wrong outcomes. [pmid: 19435691].
Seradour B, Esteve J, Heid P, et al. Hormone replacement therapy and screening mammography: analysis of the results in the Bouches du Rhone programme. J Med Screen. 1999;6(2):99-102. Exclusion: wrong comparison. [pmid: 10444729].
Setti E, Trecate G, Ferrari M, et al. Breast magnetic resonance imaging: a computer-based analysis of enhancement curves. J Digit Imaging. 2001;14(2 Suppl 1):226-8. Exclusion: wrong study design for key question. [pmid: 11442107].
Setz-Pels W, Duijm LEM, Coebergh JW, et al. Re-attendance after false-positive screening mammography: a population-based study in the Netherlands. Br J Cancer. 2013;109(8):2044-50. Exclusion: wrong outcomes. [pmid: 24052045].
Setz-Pels W, Duijm LEM, Louwman MWJ, et al. Characteristics and screening outcome of women referred twice at screening mammography. Eur Radiol. 2012;22(12):2624-32. Exclusion: wrong population. [pmid: 22696156].
Shapiro S. Determining the efficacy of breast cancer screening. Cancer. 1989;63(10):1873-80. Exclusion: studies outside of search dates. [pmid: 2649218].
Shapiro S, Strax P, Venet L, et al. Proceedings: Changes in 5-year breast cancer mortality in a breast cancer screening program. Proceedings National Cancer Conference. 1972;7:663-78. Exclusion: studies outside of search dates. [pmid: 4764931].
Shaw CM, Flanagan FL, Fenlon HM, et al. Consensus review of discordant findings maximizes cancer detection rate in double-reader screening mammography: Irish National Breast Screening Program experience. Radiology. 2009;250(2):354-62. Exclusion: wrong comparison. [pmid: 19188311].
Shen W-C, Chang R-F, Moon WK, et al. Breast ultrasound computer-aided diagnosis using BI-RADS features. Acad Radiol. 2007;14(8):928-39. Exclusion: wrong intervention. [pmid: 17659238].
Shen Y, Parmigiani G. A model-based comparison of breast cancer screening strategies: mammograms and clinical breast examinations. Cancer Epidemiol Biomarkers Prev. 2005;14(2):529-32. Exclusion: wrong study design for key question. [pmid: 15734983].
Shen Y, Yang Y, Inoue LYT, et al. Role of detection method in predicting breast cancer survival: analysis of randomized screening trials. J Natl Cancer Inst. 2005;97(16):1195-203. Exclusion: review not meeting inclusion criteria. [pmid: 16106024].
Shen Y, Zelen M. Screening sensitivity and sojourn time from breast cancer early detection clinical trials: mammograms and physical examinations. J Clin Oncol. 2001;19(15):3490-9. Exclusion: review not meeting inclusion criteria. [pmid: 11481355].
Shile PE, Pilgram TK. Variability in the interpretation of screening mammograms by US radiologists. Acad Radiol. 1996;3(10):879-81. discussion 81-2. Exclusion: wrong publication type. [pmid: 8923909].
Shimada M, Senoo A, Hayashi S, et al. Assessment of breast cancer with dynamic gadolinium-enhanced MR imaging combined with magnetization transfer contrast using a newly developed breast surface coil for the supine position. Radiat Med. 1997;15(2):85-90. Exclusion: wrong intervention. [pmid: 9192432].
Shin HJ, Kim HH, Cha JH, et al. Automated ultrasound of the breast for diagnosis: interobserver agreement on lesion detection and characterization. AJR Am J Roentgenol. 2011;197(3):747-54. Exclusion: wrong intervention. [pmid: 21862820].
Shrestha S, Poulos A. The effect of verbal information on the experience of discomfort in mammography. Radiography. 2001;7(4):271-7. Exclusion: included in an included systematic review, not directly used.
Sickles E, D'Orsi C. ACR BI-RADS Follow-up and outcome monitoring. ACR BI-RADS Atlas: Breast Imaging Data Reporting System. 2013:17. Exclusion: wrong publication type.
Sickles EA. Breast cancer screening outcomes in women ages 40-49: clinical experience with service screening using modern mammography. J Natl Cancer Inst. Monographs. 1997;(22):99-104. Exclusion: wrong publication type.
Sickles EA. Quality assurance. How to audit your own mammography practice. Radiol Clin North Am. 1992;30(1):265-75. Exclusion: wrong publication type. [pmid: 1732933].
Sickles EA. The use of breast imaging to screen women at high risk for cancer. Radiol Clin North Am. 2010;48(5):859-78. Exclusion: wrong study design for key question. [pmid: 20868890].
Sickles EA, Miglioretti DL, Ballard-Barbash R, et al. Performance benchmarks for diagnostic mammography. Radiology. 2005;235(3):775-90. Exclusion: wrong intervention. [pmid: 15914475].
Siegal EC, Angelakis EJ, Hartman A. Can peer review contribute to earlier detection of breast cancer? A quality initiative to learn from false-negative mammograms. Breast J. 2008;14(4):330-4. Exclusion: wrong intervention. [pmid: 18540960].
Sihto H, Lundin J, Lehtimaki T, et al. Molecular subtypes of breast cancers detected in mammography screening and outside of screening. Clin Cancer Res. 2008;14(13):4103-10. Exclusion: wrong comparison. [pmid: 18593987].
Sim LSJ, Hendriks JHCL, Bult P, et al. US correlation for MRI-detected breast lesions in women with familial risk of breast cancer. Clin Radiol. 2005;60(7):801-6. Exclusion: wrong population. [pmid: 15978891].
Simpson WL Jr., Hermann G, Rausch DR, et al. Ultrasound detection of nonpalpable mammographically occult malignancy. Can Assoc Radiol J. 2008;59(2):70-6. Exclusion: wrong comparison. [pmid: 18533395].
Sinclair N, Littenberg B, Geller B, et al. Accuracy of screening mammography in older women. AJR Am J Roentgenol. 2011;197(5):1268-73. Exclusion: wrong comparison. [pmid: 22021524].
Singh S, Kumar V, Verma HK, et al. SVM based system for classification of microcalcifications in digital mammograms. Conf Proc IEEE Eng Med Biol Soc. 2006;1:4747-50. Exclusion: wrong intervention. [pmid: 17945853].
Singh V, Saunders C, Wylie L, et al. New diagnostic techniques for breast cancer detection. Fut Oncol. 2008;4(4):501-13. Exclusion: wrong publication type.
Singhal H, O'Malley FP, Tweedie E, et al. Axillary node dissection in patients with breast cancer diagnosed through the Ontario Breast Screening Program: a need for minimally invasive techniques. Can J Surg. 1997;40(5):377-82. Exclusion: wrong study design for key question. [pmid: 9336528].
Singletary SE. New approaches to surgery for breast cancer. Endocr Relat Cancer. 2001;8(4):265-86. Exclusion: review not meeting inclusion criteria. [pmid: 11733225].
Sjolin M, Maerker M. Effects of information on and reflection of women's pain experience during mammography. Vard i Norden. 1994;14(1):11-5. Exclusion: included in an included systematic review, not directly used. [pmid: 7941212].
Skaane P. The additional value of US to mammography in the diagnosis of breast cancer. A prospective study. Acta Radiol. 1999;40(5):486-90. Exclusion: wrong comparison. [pmid: 10485236].
Skaane P. Nationwide mammography screening registers: the best way to go for mortality evaluation - but there is no free lunch. Acta Radiol. 2011;52(3):235. Exclusion: wrong publication type. [pmid: 21498355].
Skaane P. Studies comparing screen-film mammography and full-field digital mammography in breast cancer screening: updated review. Acta Radiol. 2009;50(1):3-14. Exclusion: review not meeting inclusion criteria. [pmid: 19037825].
Skaane P. Ultrasonography as adjunct to mammography in the evaluation of breast tumors. Acta Radiol Suppl. 1999;420:1-47. Exclusion: wrong intervention. [pmid: 10693544].
Skaane P, Balleyguier C, Diekmann F, et al. Breast lesion detection and classification: comparison of screen-film mammography and full-field digital mammography with soft-copy reading--observer performance study. Radiology. 2005;237(1):37-44. Exclusion: wrong comparison. [pmid: 16100086].
Skaane P, Bandos AI, Gullien R, et al. Prospective trial comparing full-field digital mammography (FFDM) versus combined FFDM and tomosynthesis in a population-based screening programme using independent double reading with arbitration. Eur Radiol. 2013;23(8):2061-71. Exclusion: wrong outcomes. [pmid: 23553585].
Skaane P, Engedal K, Skjennald A. Interobserver variation in the interpretation of breast imaging. Comparison of mammography, ultrasonography, and both combined in the interpretation of palpable noncalcified breast masses. Acta Radiol. 1997;38(4 Pt 1):497-502. Exclusion: wrong outcomes. [pmid: 9240666].
Skaane P, Hofvind S, Skjennald A. Randomized trial of screen-film versus full-field digital mammography with soft-copy reading in population-based screening program: follow-up and final results of Oslo II study. Radiology. 2007;244(3):708-17. Exclusion: wrong comparison. [pmid: 17709826].
Skaane P, Kshirsagar A, Hofvind S, et al. Mammography screening using independent double reading with consensus: is there a potential benefit for computer-aided detection?. Acta Radiol. 2012;53(3):241-8. Exclusion: wrong intervention. [pmid: 22287148].
Skaane P, Kshirsagar A, Stapleton S, et al. Effect of computer-aided detection on independent double reading of paired screen-film and full-field digital screening mammograms. AJR Am J Roentgenol. 2007;188(2):377-84. Exclusion: wrong comparison. [pmid: 17242245].
Skaane P, Skjennald A. Screen-film mammography versus full-field digital mammography with soft-copy reading: randomized trial in a population-based screening program--the Oslo II Study. Radiology. 2004;232(1):197-204. Exclusion: wrong comparison. [pmid: 15155893].
Skandarajah AR, Mann GB. The role of magnetic resonance imaging in early breast cancer. Asia Pac J Clin Oncol. 2012;8(1):24-30. Exclusion: wrong intervention. [pmid: 22369441].
Smart CR, Byrne C, Smith RA, et al. Twenty-year follow-up of the breast cancers diagnosed during the Breast Cancer Detection Demonstration Project. CA Cancer J Clin. 1997;47(3):134-49. Exclusion: wrong comparison. [pmid: 9152171].
Smith CL, Kricker A, Armstrong BK. Breast cancer mortality trends in Australia: 1921 to 1994. [Erratum appears in Med J Aust 1998 Mar 2;168(5):225]. Med J Aust. 1998;168(1):11-4. Exclusion: wrong study design for key question. [pmid: 9451388].
Smith-Bindman R, Chu P, Miglioretti DL, et al. Physician predictors of mammographic accuracy. J Natl Cancer Inst. 2005;97(5):358-67. Exclusion: wrong outcomes. [pmid: 15741572].
Smith-Bindman R, Kerlikowske K. Is there a downside to elderly women undergoing screening mammography?. J Natl Cancer Inst. 1998;90(18):1322-3. Exclusion: wrong publication type. [pmid: 9747859].
Smith-Bindman R, Kerlikowske K, Gebretsadik T, et al. Is screening mammography effective in elderly women?. Am J Med. 2000;108(2):112-9. Exclusion: wrong comparison. [pmid: 11126304].
Sohlich RE, Sickles EA, Burnside ES, et al. Interpreting data from audits when screening and diagnostic mammography outcomes are combined. AJR Am J Roentgenol. 2002;178(3):681-6. Exclusion: wrong outcomes. [pmid: 11856698].
Sohn Y-M, Kim MJ, Kim E-K, et al. Sonographic elastography combined with conventional sonography: how much is it helpful for diagnostic performance?. J Ultrasound Med. 2009;28(4):413-20. Exclusion: wrong intervention. [pmid: 19321669].
Sohn Y-M, Kim MJ, Kwak JY, et al. Breast ultrasonography in young Asian women: analyses of BI-RADS final assessment category according to symptoms. Acta Radiol. 2011;52(1):35-40. Exclusion: wrong population. [pmid: 21498323].
Solin LJ, Fourquet A, Vicini FA, et al. Mammographically detected ductal carcinoma in situ of the breast treated with breast-conserving surgery and definitive breast irradiation: long-term outcome and prognostic significance of patient age and margin status. Int J Radiat Oncol Biol Phys. 2001;50(4):991-1002. Exclusion: wrong intervention. [pmid: 11429227].
Solin LJ, Gray R, Baehner FL, et al. A multigene expression assay to predict local recurrence risk for ductal carcinoma in situ of the breast. J Natl Cancer Inst. 2013;105(10):701-10. Exclusion: wrong intervention. [pmid: 23641039].
Solin LJ, McCormick B, Recht A, et al. Mammographically detected, clinically occult ductal carcinoma in situ treated with breast-conserving surgery and definitive breast irradiation. Cancer J Sci Am. 1996;2(3):158-65. Exclusion: wrong population. [pmid: 9166516].
Solin LJ, Schultz DJ, Hanchak NA, et al. Patterns of treatment for older women with newly diagnosed breast carcinoma. Am J Clin Oncol. 1999;22(2):107-13. Exclusion: wrong outcomes. [pmid: 10199441].
Solin LJ, Schultz DJ, Kessler HB, et al. Downstaging of Breast Carcinomas in Older Women Associated with Mammographic Screening. Breast J. 1999;5(2):94-100. Exclusion: wrong intervention. [pmid: 11348266].
Song E, Jiang L, Jin R, et al. Breast mass segmentation in mammography using plane fitting and dynamic programming. Acad Radiol. 2009;16(7):826-35. Exclusion: wrong intervention. [pmid: 19362024].
Song L, Fletcher R. Breast cancer rescreening in low-income women. Am J Prev Med. 1998;15(2):128-33. Exclusion: wrong outcomes. [pmid: 9713668].
Sontag L, Axelrod DE. Evaluation of pathways for progression of heterogeneous breast tumors. J Theor Biol. 2005;232(2):179-89. Exclusion: wrong study design for key question. [pmid: 15530488].
Sorelli PG, Cosgrove DO, Svensson WE, et al. Can contrast-enhanced sonography distinguish benign from malignant breast masses?. J Clin Ultrasound. 2010;38(4):177-81. Exclusion: wrong outcomes. [pmid: 20146214].
Souza FH, Wendland EM, Rosa MI, et al. Is full-field digital mammography more accurate than screen-film mammography in overall population screening? A systematic review and meta-analysis. Breast. 2013;22(3):217-24. Exclusion: review not meeting inclusion criteria. [pmid: 23489759].
Sox H. Screening mammography for younger women: back to basics. Ann Intern Med. 2002;137(5 Part 1):361-2. Exclusion: wrong publication type. [pmid: 12204022].
Spanu A, Sanna D, Chessa F, et al. The clinical impact of breast scintigraphy acquired with a breast specific-camera (BSGC) in the diagnosis of breast cancer: incremental value versus mammography. Int J Oncol. 2012;41(2):483-9. Exclusion: wrong intervention. [pmid: 22641247].
Spencer DB, Potter JE, Chung MA, et al. Mammographic screening and disease presentation of breast cancer patients who die of disease. Breast J. 2004;10(4):298-303. Exclusion: wrong outcomes. [pmid: 15239787].
Spillane AJ, Kennedy CW, Gillett DJ, et al. Screen-detected breast cancer compared to symptomatic presentation: an analysis of surgical treatment and end-points of effective mammographic screening. ANZ J Surg. 2001;71(7):398-402. Exclusion: wrong comparison. [pmid: 11450913].
Sprague BL, Trentham-Dietz A, Burnside ES. Socioeconomic disparities in the decline in invasive breast cancer incidence. Breast Cancer Res Treat. 2010;122(3):873-8. Exclusion: wrong outcomes. [pmid: 20087648].
Spratt JS, Gaines BM, Aaron WS, et al. What are the benefits and costs of screening mammograms on Kentucky women aged 40-49?. J Surg Oncol. 1996;63(2):71-6. Exclusion: wrong publication type. [pmid: 8888797].
Stang A, Kaab-Sanyal V, Hense H-W, et al. Effect of mammography screening on surgical treatment for breast cancer: a nationwide analysis of hospitalization rates in Germany 2005-2009. Eur J Epidemiol. 2013;28(8):689-96. Exclusion: wrong outcomes. [pmid: 23775424].
Stefanick ML, Anderson GL, Margolis KL, et al. Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. 2006;295(14):1647-57. Exclusion: wrong intervention. [pmid: 16609086].
Steinemann SK, Chun MBJ, Huynh DH, et al. Breast cancer worry among women awaiting mammography: is it unfounded? Does prior counseling help?. Hawaii Med J. 2011;70(7):149-50. Exclusion: wrong intervention. [pmid: 21886303].
Sterns EE. Relation between clinical and mammographic diagnosis of breast problems and the cancer/biopsy rate. Can J Surg. 1996;39(2):128-32. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 8769923].
Stoblen F, Landt S, Stelkens-Gebhardt R, et al. First evaluation of the diagnostic accuracy of an automated 3D ultrasound system in a breast screening setting. Anticancer Res. 2011;31(8):2569-74. Exclusion: wrong outcomes. [pmid: 21778306].
Stout NK, Rosenberg MA, Trentham-Dietz A, et al. Retrospective cost-effectiveness analysis of screening mammography. J Natl Cancer Inst. 2006;98(11):774-82. Exclusion: wrong outcomes. [pmid: 16757702].
Stoutjesdijk MJ, Futterer JJ, Boetes C, et al. Variability in the description of morphologic and contrast enhancement characteristics of breast lesions on magnetic resonance imaging. Invest Radiol. 2005;40(6):355-62. Exclusion: wrong outcomes. [pmid: 15905722].
Strigel RM, Eby PR, Demartini WB, et al. Frequency, upgrade rates, and characteristics of high-risk lesions initially identified with breast MRI. AJR Am J Roentgenol. 2010;195(3):792-8. Exclusion: wrong outcomes. [pmid: 20729462].
Suhrke P, Maehlen J, Schlichting E, et al. Effect of mammography screening on surgical treatment for breast cancer in Norway: comparative analysis of cancer registry data. BMJ. 2011;343:d4692. Exclusion: wrong study design for key question. [pmid: 21914765].
Sun J, Chapman J, Gordon R, et al. Survival from primary breast cancer after routine clinical use of mammography. Breast J. 2002;8(4):199-208. Exclusion: wrong study design for key question. [pmid: 12100111].
Suzuki A, Kuriyama S, Kawai M, et al. Age-specific interval breast cancers in Japan: estimation of the proper sensitivity of screening using a population-based cancer registry. Cancer Sci. 2008;99(11):2264-7. Exclusion: wrong outcomes. [pmid: 18795941].
Suzuki R, Iwasaki M, Yamamoto S, et al. Leisure-time physical activity and breast cancer risk defined by estrogen and progesterone receptor status--the Japan Public Health Center-based Prospective Study. Prev Med. 2011;52(3-4):227-33. Exclusion: wrong outcomes. [pmid: 21295062].
Suzuki R, Ye W, Rylander-Rudqvist T, et al. Alcohol and postmenopausal breast cancer risk defined by estrogen and progesterone receptor status: a prospective cohort study. J Natl Cancer Inst. 2005;97(21):1601-8. Exclusion: wrong outcomes. [pmid: 16264180].
Svahn T, Andersson I, Chakraborty D, et al. The diagnostic accuracy of dual-view digital mammography, single-view breast tomosynthesis and a dual-view combination of breast tomosynthesis and digital mammography in a free-response observer performance study. Radiat Prot Dosimetry. 2010;139(1-3):113-7. Exclusion: wrong outcomes. [pmid: 20228048].
Svane G, Azavedo E, Lindman K, et al. Clinical experience of photon counting breast tomosynthesis: comparison with traditional mammography. Acta Radiol. 2011;52(2):134-42. Exclusion: wrong population. [pmid: 21498340].
Svartbo B, Bygren LO, Bucht G, et al. False-negative cases of breast cancer deaths in mammography screening evaluations. Breast J. 2003;9(2):142-3. Exclusion: wrong publication type. [pmid: 12603393].
Svensson WE, Pandian AJ, Hashimoto H. The use of breast ultrasound color Doppler vascular pattern morphology improves diagnostic sensitivity with minimal change in specificity. Ultraschall Med. 2010;31(5):466-74. Exclusion: wrong outcomes. [pmid: 20094978].
Swedish Organised Service Screening Evaluation G. Effect of mammographic service screening on stage at presentation of breast cancers in Sweden. Cancer. 2007;109(11):2205-12. Exclusion: wrong study design for key question. [pmid: 17471486].
Swedish Organised Service Screening Evaluation Group. Reduction in breast cancer mortality from organized service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiol Biomarkers Prev. 2006;15(1):45-51. Exclusion: included in an included systematic review, not directly used. [pmid: 16434585].
Sylvester PA, Vipond MN, Kutt E, et al. A comparative audit of prevalent, incident and interval cancers in the Avon breast screening programme. Ann R Coll Surg Engl. 1997;79(4):272-5. Exclusion: wrong comparison. [pmid: 9244071].
Tabár L, Chen HH, Duffy SW, et al. Primary and adjuvant therapy, prognostic factors and survival in 1053 breast cancers diagnosed in a trial of mammography screening. Jpn J Clin Oncol. 1999;29(12):608-16. Exclusion: wrong population. [pmid: 10721943].
Tabár L, Dean PB. Mammography and breast cancer: the new era. Int J Gynaecol Obstet. 2003;82(3):319-26. Exclusion: wrong publication type. [pmid: 14499978].
Tabár L, Duffy SW, Burhenne LW. New Swedish breast cancer detection results for women aged 40-49. Cancer. 1993;72(4 Suppl):1437-48. Exclusion: studies outside of search dates. [pmid: 8339236].
Tabár L, Duffy SW, Chen HH. Re: Quantitative interpretation of age-specific mortality reductions from the Swedish Breast Cancer-Screening Trials. J Natl Cancer Inst. 1996;88(1):52-5. Exclusion: wrong publication type. [pmid: 8847728].
Tabár L, Duffy SW, Krusemo UB. Detection method, tumour size and node metastases in breast cancers diagnosed during a trial of breast cancer screening. Eur J Cancer Clin Oncol. 1987;23(7):959-62. Exclusion: studies outside of search dates. [pmid: 3311769].
Tabár L, Duffy SW, Yen MF, et al. All-cause mortality among breast cancer patients in a screening trial: support for breast cancer mortality as an end point. J Med Screen. 2002;9(4):159-62. Exclusion: studies outside of search dates. [pmid: 12518005].
Tabár L, Fagerberg G, Day NE, et al. The Swedish two-county trial of mammographic screening for breast cancer: recent results on mortality and tumor characteristics. Pathologie-biologie. 1992;39(9):846. Exclusion: studies outside of search dates. [pmid: 1538900].
Tabár L, Gad A, Holmberg L, et al. Significant reduction in advanced breast cancer. Results of the first seven years of mammography screening in Kopparberg, Sweden. Diagn Imaging Clin Med. 1985;54(3-4):158-64. Exclusion: studies outside of search dates. [pmid: 3896614].
Tabár L, Larsson LG. Breast-cancer screening with mammography in women aged 40-49 years. Int J Cancer. 1996;68(6):693-9. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 8980168].
Tabár L, Vitak B, Chen HH, et al. Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2001;91(9):1724-31. Exclusion: wrong comparison. [pmid: 11335897].
Tabár L, Vitak B, Yen MFA, et al. Number needed to screen: lives saved over 20 years of follow-up in mammographic screening. J Med Screen. 2004;11(3):126-9. Exclusion: wrong outcomes. [pmid: 15333270].
Taghipour S, Banjevic D, Miller AB, et al. Parameter estimates for invasive breast cancer progression in the Canadian National Breast Screening Study. Br J Cancer. 2013;108(3):542-8. Exclusion: wrong outcomes. [pmid: 23322203].
Taib NA, Yip CH, Low WY. Recognising symptoms of breast cancer as a reason for delayed presentation in Asian women--the psycho-socio-cultural model for breast symptom appraisal: opportunities for intervention. Asian Pac J Cancer Prev. 2011;12(6):1601-8. Exclusion: wrong outcomes. [pmid: 22126506].
Takei H, Iino Y, Horiguchi J, et al. Age-dependent characteristics of screen-detected patients with breast cancer. Anticancer Res. 1998;18(4B):2833-6. Exclusion: wrong population. [pmid: 9713470].
Tamer R, Voti L, Fleming LE, et al. A feasibility study of the evaluation of the Florida breast cancer early detection program using the statewide cancer registry. Breast Cancer Res Treat. 2003;81(3):187-94. Exclusion: wrong study design for key question. [pmid: 14620914].
Tan A, Freeman DH Jr., Goodwin JS, et al. Variation in false-positive rates of mammography reading among 1067 radiologists: a population-based assessment. Breast Cancer Res Treat. 2006;100(3):309-18. Exclusion: wrong intervention. [pmid: 16819566].
Tan A, Kuo YF, Elting LS, et al. Refining physician quality indicators for screening mammography in older women: distinguishing appropriate use from overuse. J Am Geriatr Soc. 2013;61(3):380-7. Exclusion: wrong outcomes. [pmid: 23452077].
Tan T, Platel B, Huisman H, et al. Computer-aided lesion diagnosis in automated 3-D breast ultrasound using coronal spiculation. IEEE Trans Med Imaging. 2012;31(5):1034-42. Exclusion: wrong study design for key question. [pmid: 22271831].
Tange UB, Jensen MB, Vejborg IMM, et al. Clinical impact of introduction of mammography screening in a non-screening country with special reference to the Copenhagen service mammography screening programme. Scand J Surg. 2002;91(3):293-303. Exclusion: wrong outcomes. [pmid: 12449474].
Taplin SH, Abraham L, Geller BM, et al. Effect of previous benign breast biopsy on the interpretive performance of subsequent screening mammography. J Natl Cancer Inst. 2010;102(14):1040-51. Exclusion: wrong outcomes. [pmid: 20601590].
Taplin SH, Ichikawa L, Buist DSM, et al. Evaluating organized breast cancer screening implementation: the prevention of late-stage disease?. Cancer Epidemiol Biomarkers Prev. 2004;13(2):225-34. Exclusion: wrong study design for key question. [pmid: 14973097].
Taplin SH, Ichikawa L, Yood MU, et al. Reason for late-stage breast cancer: absence of screening or detection, or breakdown in follow-up?. J Natl Cancer Inst. 2004;96(20):1518-27. Exclusion: wrong comparison. [pmid: 15494602].
Taplin SH, Mandelson MT, Anderman C, et al. Mammography diffusion and trends in late-stage breast cancer: evaluating outcomes in a population. Cancer Epidemiol Biomarkers Prev. 1997;6(8):625-31. Exclusion: wrong outcomes. [pmid: 9264276].
Taplin SH, Rutter CM, Lehman CD. Testing the effect of computer-assisted detection on interpretive performance in screening mammography. AJR Am J Roentgenol. 2006;187(6):1475-82. Exclusion: wrong intervention. [pmid: 17114540].
Tarone RE. The excess of patients with advanced breast cancer in young women screened with mammography in the Canadian National Breast Screening Study. Cancer. 1995;75(4):997-1003. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 7842421].
Taslidere E, Cohen FS, Georgiou G. Classification of the stages of hyperplasia in breast ducts by analyzing different depths and segmentation of ultrasound breast scans into ductal areas. Conf Proc IEEE Eng Med Biol Soc. 2006;1:2396-9. Exclusion: wrong outcomes. [pmid: 17946958].
Tavakoli B, Zhu Q. Depth-correction algorithm that improves optical quantification of large breast lesions imaged by diffuse optical tomography. J Biomed Opt. 2011;16(5):056002. Exclusion: wrong intervention. [pmid: 21639570].
Taves DH, McCurdy LI, Sparrow RK. The relative diagnostic impact of screening mammography and physical examination. Can Assoc Radiol J. 1996;47(4):257-9. Exclusion: wrong outcomes. [pmid: 8696991].
Taylor KJW, Merritt C, Piccoli C, et al. Ultrasound as a complement to mammography and breast examination to characterize breast masses. Ultrasound Med Biol. 2002;28(1):19-26. Exclusion: wrong intervention. [pmid: 11879948].
Taylor R, Boyages J. Estimating risk of breast cancer from population incidence affected by widespread mammographic screening. J Med Screen. 2001;8(2):73-6. Exclusion: wrong study design for key question. [pmid: 11480447].
Taylor R, Morrell S, Estoesta J, et al. Mammography screening and breast cancer mortality in New South Wales, Australia. Cancer Causes Control. 2004;15(6):543-50. Exclusion: wrong comparison. [pmid: 15280633].
Taylor R, Page A, Bampton D, et al. Age-specific interval breast cancers in New South Wales and meta-analysis of studies of women aged 40-49 years. J Med Screen. 2004;11(4):199-206. Exclusion: wrong outcomes. [pmid: 15563775].
Taylor R, Supramaniam R, Rickard M, et al. Interval breast cancers in New South Wales, Australia, and comparisons with trials and other mammographic screening programmes. J Med Screen. 2002;9(1):20-5. Exclusion: wrong outcomes. [pmid: 11943793].
Teertstra HJ, Loo CE, van den Bosch MAAJ, et al. Breast tomosynthesis in clinical practice: initial results. Eur Radiol. 2010;20(1):16-24. Exclusion: wrong intervention. [pmid: 19657655].
The JS, Schilling KJ, Hoffmeister JW, et al. Detection of breast cancer with full-field digital mammography and computer-aided detection. AJR Am J Roentgenol. 2009;192(2):337-40. Exclusion: wrong intervention. [pmid: 19155392].
Thibault F, Balleyguier C, Tardivon A, et al. Contrast enhanced spectral mammography: better than MRI?. Eur J Radiol. Suppl 1. 2012;81:S162-4. Exclusion: wrong comparison. [pmid: 23083575].
Thibault F, Dromain C, Breucq C, et al. Digital breast tomosynthesis versus mammography and breast ultrasound: a multireader performance study. Eur Radiol. 2013;23(9):2441-9. Exclusion: wrong outcomes. [pmid: 23673573].
Thibault F, Meunier M, Klijanienko J, et al. Diagnostic accuracy of sonography and combined sonographic assessment and sonographically guided cytology in nonpalpable solid breast lesions. J Clin Ultrasound. 2000;28(8):387-98. Exclusion: wrong population. [pmid: 10993966].
Thomas CM. Assessing the effect of hormone replacement therapy on the performance of screening mammography. Radiology. 1999;213(3):926-7. Exclusion: wrong publication type. [pmid: 10580977].
Thomassin-Naggara I, Trop I, Lalonde L, et al. Tips and techniques in breast MRI. Diagn Interv Imaging. 2012;93(11):828-39. Exclusion: wrong comparison. [pmid: 23084072].
Thornton H. Effect of population-based screening on breast cancer mortality. Lancet. 2012;379(9823):1296-7. author reply 8. Exclusion: wrong publication type. [pmid: 22483023].
Threlfall AG, Collins S, Woodman CBJ. Impact of NHS breast screening on advanced disease and mortality from breast cancer in the North West of England. Br J Cancer. 2003;89(1):77-80. Exclusion: wrong comparison. [pmid: 12838304].
Thurfjell E, Thurfjell MG, Egge E, et al. Sensitivity and specificity of computer-assisted breast cancer detection in mammography screening. Acta Radiol. 1998;39(4):384-8. Exclusion: wrong intervention. [pmid: 9685824].
Thurfjell EL, Lindgren JA. Breast cancer survival rates with mammographic screening: similar favorable survival rates for women younger and those older than 50 years. Radiology. 1996;201(2):421-6. Exclusion: wrong comparison. [pmid: 8888234].
Thurfjell MG. Aspects in mammographic screening. Detection, prediction, recurrence and prognosis. Acta Radiol Suppl. 2001;42(424):1-22. Exclusion: wrong intervention. [pmid: 12040855].
Thurfjell MG, Vitak B, Azavedo E, et al. Effect on sensitivity and specificity of mammography screening with or without comparison of old mammograms. Acta Radiol. 2000;41(1):52-6. Exclusion: wrong outcomes. [pmid: 10665871].
Tian N, Goovaerts P, Zhan FB, et al. Identifying risk factors for disparities in breast cancer mortality among African-American and Hispanic women. Womens Health Issues. 2012;22(3):e267-76. Exclusion: wrong outcomes. [pmid: 22265181].
Tice JA, Cummings SR, Smith-Bindman R, et al. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337-47. Exclusion: wrong intervention. [pmid: 18316752].
Tice JA, O'Meara ES, Weaver DL, et al. Benign breast disease, mammographic breast density, and the risk of breast cancer. J Natl Cancer Inst. 2013;105(14):1043-9. Exclusion: wrong intervention. [pmid: 23744877].
Tilanus-Linthorst MM, Bartels CC, Obdeijn AI, et al. Earlier detection of breast cancer by surveillance of women at familial risk. Eur J Cancer. 2000;36(4):514-9. Exclusion: wrong intervention. [pmid: 10717529].
Tilanus-Linthorst MM, Obdeijn IM, Bartels KC, et al. First experiences in screening women at high risk for breast cancer with MR imaging. Breast Cancer Res Treat. 2000;63(1):53-60. Exclusion: wrong population. [pmid: 11079159].
Timberg P, Baath M, Andersson I, et al. Visibility of microcalcification clusters and masses in breast tomosynthesis image volumes and digital mammography: a 4AFC human observer study. Med Phys. 2012;39(5):2431-7. Exclusion: wrong population. [pmid: 22559613].
Timmers JM, den Heeten GJ, Adang EM, et al. Dutch digital breast cancer screening: implications for breast cancer care. Eur J Public Health. 2012;22(6):925-9. Exclusion: wrong outcomes. [pmid: 22158996].
Timp S, Karssemeijer N. A new 2D segmentation method based on dynamic programming applied to computer aided detection in mammography. Med Phys. 2004;31(5):958-71. Exclusion: wrong intervention. [pmid: 15191279].
Timp S, Varela C, Karssemeijer N. Computer-aided diagnosis with temporal analysis to improve radiologists' interpretation of mammographic mass lesions. IEEE Trans Inf Technol Biomed. 2010;14(3):803-8. Exclusion: wrong intervention. [pmid: 20403792].
Tingberg A, Fornvik D, Mattsson S, et al. Breast cancer screening with tomosynthesis--initial experiences. Radiat Prot Dosimetry. 2011;147(1-2):180-3. Exclusion: review not meeting inclusion criteria. [pmid: 21733859].
Tohno E, Ueno E. Current improvements in breast ultrasound, with a special focus on elastography. Breast Cancer. 2008;15(3):200-4. Exclusion: review not meeting inclusion criteria. [pmid: 18484155].
Tohno E, Umemoto T, Sasaki K, et al. Effect of adding screening ultrasonography to screening mammography on patient recall and cancer detection rates: a retrospective study in Japan. Eur J Radiol. 2013;82(8):1227-30. Exclusion: wrong population. [pmid: 23465737].
Tornberg S, Kemetli L, Ascunce N, et al. A pooled analysis of interval cancer rates in six European countries. Eur J Cancer Prev. 2010;19(2):87-93. Exclusion: wrong comparison. [pmid: 20010429].
Tornberg S, Kemetli L, Lynge E, et al. Breast cancer incidence and mortality in the Nordic capitals, 1970-1998. Trends related to mammography screening programmes. Acta Oncol. 2006;45(5):528-35. Exclusion: wrong publication type. [pmid: 16864165].
Torres-Mejia G, De Stavola B, Allen DS, et al. Mammographic features and subsequent risk of breast cancer: a comparison of qualitative and quantitative evaluations in the Guernsey prospective studies. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1052-9. Exclusion: wrong outcomes. [pmid: 15894652].
Tortosa R, Ramos M, Villaescusa JI, et al. Analysis of the radiological detriment for premenopausal women in a breast early detection program during 2008. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:900-2. Exclusion: wrong intervention. [pmid: 19963982].
Tosteson ANA, Stout NK, Fryback DG, et al. Cost-effectiveness of digital mammography breast cancer screening. Ann Intern Med. 2008;148(1):1-10. Exclusion: wrong outcomes. [pmid: 18166758].
Tourassi GD, Ike R 3rd, Singh S, et al. Evaluating the effect of image preprocessing on an information-theoretic CAD system in mammography. Acad Radiol. 2008;15(5):626-34. Exclusion: wrong intervention. [pmid: 18423320].
Tourassi GD, Vargas-Voracek R, Catarious DM Jr., et al. Computer-assisted detection of mammographic masses: a template matching scheme based on mutual information. Med Phys. 2003;30(8):2123-30. Exclusion: wrong intervention. [pmid: 12945977].
Tozaki M. Interpretation of breast MRI: correlation of kinetic and morphological parameters with pathological findings. Magn Reson Med Sci. 2004;3(4):189-97. Exclusion: wrong comparison. [pmid: 16093637].
Trecate G, Vergnaghi D, Manoukian S, et al. MRI in the early detection of breast cancer in women with high genetic risk. Tumori. 2006;92(6):517-23. Exclusion: wrong population. [pmid: 17260493].
Tseng HS, Wu HK, Chen ST, et al. Speckle reduction imaging of breast ultrasound does not improve the diagnostic performance of morphology-based CAD System. J Clin Ultrasound. 2012;40(1):1-6. Exclusion: wrong intervention. [pmid: 22086841].
Tuncbilek I, Ozdemir A, Gultekin S, et al. Clinical outcome assessment in mammography: an audit of 7,506 screening and diagnostic mammography examinations. Diagn Interv Radiol. 2007;13(4):183-7. Exclusion: wrong comparison. [pmid: 18092288].
Turchetti D, Mangone L, Negri R, et al. Changes in breast cancer incidence and stage distribution in Modena, Italy: the effect of a mammographic screening program. Cancer Causes Control. 2002;13(8):729-34. Exclusion: wrong comparison. [pmid: 12420951].
Tuttle TM, Jarosek S, Habermann EB, et al. Increasing rates of contralateral prophylactic mastectomy among patients with ductal carcinoma in situ. J Clin Oncol. 2009;27(9):1362-7. Exclusion: wrong outcomes. [pmid: 19224844].
Tweedie E, Tonkin K, Kerkvliet N, et al. Biologic characteristics of breast cancer detected by mammography and by palpation in a screening program: a pilot study. Clin Invest Med. 1997;20(5):300-7. Exclusion: wrong comparison. [pmid: 9336655].
Tyndel S, Austoker J, Henderson BJ, et al. What is the psychological impact of mammographic screening on younger women with a family history of breast cancer? Findings from a prospective cohort study by the PIMMS Management Group. J Clin Oncol. 2007;25(25):3823-30. Exclusion: studies outside of search dates. [pmid: 17761970].
Uematsu T, Kasami M. High-spatial-resolution 3-T breast MRI of nonmasslike enhancement lesions: an analysis of their features as significant predictors of malignancy. AJR Am J Roentgenol. 2012;198(5):1223-30. Exclusion: wrong intervention. [pmid: 22528918].
Uhry Z, Hedelin G, Colonna M, et al. Modelling the effect of breast cancer screening on related mortality using French data. Cancer epidemiol. 2011;35(3):235-42. Exclusion: wrong outcomes. [pmid: 21159568].
Urban N. Developing measures of mammography performance. Med Care. 2002;40(6 Suppl):III86-8. Exclusion: wrong publication type. [pmid: 12064762].
Utzon-Frank N, Vejborg I, von Euler-Chelpin M, et al. Balancing sensitivity and specificity: sixteen year's of experience from the mammography screening programme in Copenhagen, Denmark. Cancer epidemiol. 2011;35(5):393-8. Exclusion: wrong outcomes. [pmid: 21239242].
Vacek PM, Geller BM. A prospective study of breast cancer risk using routine mammographic breast density measurements. Cancer Epidemiol Biomarkers Prev. 2004;13(5):715-22. Exclusion: wrong comparison. [pmid: 15159301].
Vacek PM, Skelly JM, Geller BM. Breast cancer risk assessment in women aged 70 and older. Breast Cancer Res Treat. 2011;130(1):291-9. Exclusion: wrong comparison. [pmid: 21604157].
van Breest Smallenburg V, Duijm LEM, den Heeten GJ, et al. Two-view versus single-view mammography at subsequent screening in a region of the Dutch breast screening programme. Eur J Radiol. 2012;81(9):2189-94. Exclusion: wrong intervention. [pmid: 21906898].
van Breest Smallenburg V, Duijm LEM, Voogd AC, et al. Lower sensitivity of screening mammography after previous benign breast surgery. Int J Cancer. 2012;130(1):122-8. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 21328339].
van den Biggelaar FJHM, Kessels AGH, van Engelshoven JMA, et al. Computer-aided detection in full-field digital mammography in a clinical population: performance of radiologist and technologists. Breast Cancer Res Treat. 2010;120(2):499-506. Exclusion: wrong outcomes. [pmid: 19418215].
van den Biggelaar FJHM, Kessels AGH, van Engelshoven JMA, et al. Strategies for digital mammography interpretation in a clinical patient population. Int J Cancer. 2009;125(12):2923-9. Exclusion: wrong study design for key question. [pmid: 19672861].
van den Biggelaar FJHM, Nelemans PJ, Flobbe K. Performance of radiographers in mammogram interpretation: a systematic review. Breast. 2008;17(1):85-90. Exclusion: wrong outcomes. [pmid: 17764941].
van der Steeg AFW, Keyzer-Dekker CMG, De Vries J, et al. Effect of abnormal screening mammogram on quality of life. Br J Surg. 2011;98(4):537-42. Exclusion: wrong study design for key question. [pmid: 21656719].
van Dijck J, Verbeek A, Hendriks J, et al. Mammographic screening after the age of 65 years: early outcomes in the Nijmegen programme. Br J Cancer. 1996;74(11):1838-42. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 8956803].
van Dijck JA, Broeders MJ, Verbeek AL. Mammographic screening in older women. Is it worthwhile?. Drugs Aging. 1997;10(2):69-79. Exclusion: review not meeting inclusion criteria. [pmid: 9061265].
Van Dijck JA, Verbeek AL, Beex LV, et al. Breast-cancer mortality in a non-randomized trial on mammographic screening in women over age 65. Int J Cancer. 1997;70(2):164-8. Exclusion: wrong comparison. [pmid: 9009155].
Van Dijck JA, Verbeek AL, Beex LV, et al. Mammographic screening after the age of 65 years: evidence for a reduction in breast cancer mortality. Int J Cancer. 1996;66(6):727-31. Exclusion: wrong comparison. [pmid: 8647640].
Van Dijck JAAM, Verbeek ALM, Hendriks JHCL, et al. The current detectability of breast cancer in a mammographic screening program: A review of the previous mammograms of interval and screen-detected cancers. Cancer. 1993;72(6):1933-8. Exclusion: wrong comparison. [pmid: 8364871].
van Gils CH, Otten JD, Hendriks JH, et al. High mammographic breast density and its implications for the early detection of breast cancer. J Med Screen. 1999;6(4):200-4. Exclusion: wrong study design for key question. [pmid: 10693066].
van Gils CH, Otten JD, Verbeek AL, et al. Mammographic breast density and risk of breast cancer: masking bias or causality?. Eur J Epidemiol. 1998;14(4):315-20. Exclusion: wrong study design for key question. [pmid: 9690746].
van Gils CH, Otten JD, Verbeek AL, et al. Effect of mammographic breast density on breast cancer screening performance: a study in Nijmegen, The Netherlands. J Epidemiol Community Health. 1998;52(4):267-71. Exclusion: wrong study design for key question. [pmid: 9616416].
van Gils CH, Veldhuis WB, Peeters PHM. Tailored breast cancer screening with ultrasound and MRI?. Ned Tijdschr Geneeskd. 2012;156(37):A5313. Exclusion: wrong comparison. [pmid: 22971434].
Van Luijt P HE, Fracheboud J, Broeders MJM, Wesseling J, Den Heeten GJ, De Koning HJ. DCIS distribution of grades in 5,126 screened and non-screened women and estimated risk of overdiagnosis in breast cancer screening: A model of progression. Eur J Cancer. 2014;50(19). Exclusion: wrong publication type.
van Luijt PA, Fracheboud J, Heijnsdijk EAM, et al. Nation-wide data on screening performance during the transition to digital mammography: observations in 6 million screens. Eur J Cancer. 2013;49(16):3517-25. Exclusion: wrong outcomes. [pmid: 23871248].
Van Ongeval C, Bosmans H, Van Steen A. Current challenges of full field digital mammography. Radiat Prot Dosimetry. 2005;117(1-3):148-53. Exclusion: review not meeting inclusion criteria. [pmid: 16461520].
van Ravesteyn NT, Heijnsdijk EAM, Draisma G, et al. Prediction of higher mortality reduction for the UK Breast Screening Frequency Trial: a model-based approach on screening intervals. Br J Cancer. 2011;105(7):1082-8. Exclusion: wrong study design for key question. [pmid: 21863031].
van Ravesteyn NT, Miglioretti DL, Stout NK, et al. Tipping the balance of benefits and harms to favor screening mammography starting at age 40 years: a comparative modeling study of risk. Ann Intern Med. 2012;156(9):609-17. Exclusion: wrong study design for key question. [pmid: 22547470].
van Schie G, Wallis MG, Leifland K, et al. Mass detection in reconstructed digital breast tomosynthesis volumes with a computer-aided detection system trained on 2D mammograms. Med Phys. 2013;40(4):041902. Exclusion: wrong population. [pmid: 23556896].
van Schoor G, Moss SM, Otten JDM, et al. Effective biennial mammographic screening in women aged 40-49. Eur J Cancer. 2010;46(18):3137-40. Exclusion: wrong study design for key question. [pmid: 21036034].
van Schoor G, Moss SM, Otten JDM, et al. Increasingly strong reduction in breast cancer mortality due to screening. Br J Cancer. 2011;104(6):910-4. Exclusion: included in an included systematic review, not directly used. [pmid: 21343930].
van Schoor G, Paap E, Broeders MJM, et al. Residual confounding after adjustment for age: a minor issue in breast cancer screening effectiveness. Eur J Epidemiol. 2011;26(8):585-8. Exclusion: wrong study design for key question. [pmid: 21519892].
van Veen WA, Knottnerus JA. The evidence to support mammography screening. Neth J Med. 2002;60(5):200-6. Exclusion: review not meeting inclusion criteria. [pmid: 12365475].
Varas X, Leborgne JH, Leborgne F, et al. Revisiting the mammographic follow-up of BI-RADS category 3 lesions. AJR Am J Roentgenol. 2002;179(3):691-5. Exclusion: wrong population. [pmid: 12185047].
Venkatesan A, Chu P, Kerlikowske K, et al. Positive predictive value of specific mammographic findings according to reader and patient variables. Radiology. 2009;250(3):648-57. Exclusion: wrong outcomes. [pmid: 19164116].
Venturini E, Losio C, Panizza P, et al. Tailored breast cancer screening program with microdose mammography, US, and MR Imaging: short-term results of a pilot study in 40-49-year-old women. Radiology. 2013;268(2):347-55. Exclusion: wrong comparison. [pmid: 23579052].
Verenhitach BD, Elias S, Patrocinio AC, et al. Evaluation of the clinical efficacy of minimally invasive procedures for breast cancer screening at a teaching hospital. J Clin Pathol. 2011;64(10):858-61. Exclusion: wrong intervention. [pmid: 21666140].
Vernacchia FS, Pena ZG. Digital mammography: its impact on recall rates and cancer detection rates in a small community-based radiology practice. AJR Am J Roentgenol. 2009;193(2):582-5. Exclusion: wrong outcomes. [pmid: 19620459].
Vernet MdM, Checa MA, Macia F, et al. Influence of hormone replacement therapy on the accuracy of screening mammography. Breast J. 2006;12(2):154-8. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 16509841].
Vetter M, Huang DJ, Bosshard G, et al. Breast cancer in women 80 years of age and older: a comprehensive analysis of an underreported entity. Acta Oncol. 2013;52(1):57-65. Exclusion: wrong population. [pmid: 23083423].
Vettorazzi M, Stocco C, Chirico A, et al. Quality control of mammography screening in the Veneto Region. Evaluation of four programs at a local health unit level--analysis of the frequency and diagnostic pattern of interval cancers. Tumori. 2006;92(1):1-5. Exclusion: wrong outcomes. [pmid: 16683376].
Vicini FA, Lacerna MD, Goldstein NS, et al. Ductal carcinoma in situ detected in the mammographic era: an analysis of clinical, pathologic, and treatment-related factors affecting outcome with breast-conserving therapy. Int J Radiat Oncol Biol Phys. 1997;39(3):627-35. Exclusion: wrong intervention. [pmid: 9336142].
Vigeland E, Klaasen H, Klingen TA, et al. Full-field digital mammography compared to screen film mammography in the prevalent round of a population-based screening programme: the Vestfold County Study. Eur Radiol. 2008;18(1):183-91. Exclusion: wrong comparison. [pmid: 17680246].
Vinnicombe S, Pinto Pereira SM, McCormack VA, et al. Full-field digital versus screen-film mammography: comparison within the UK breast screening program and systematic review of published data. Radiology. 2009;251(2):347-58. Exclusion: wrong comparison. [pmid: 19401569].
Vitak B. Invasive interval cancers in the Östergötland Mammographic Screening Programme: radiological analysis. Eur Radiol. 1998;8(4):639-46. Exclusion: wrong outcomes. [pmid: 9569340].
Vitak B, Olsen KE, Manson JC, et al. Tumour characteristics and survival in patients with invasive interval breast cancer classified according to mammographic findings at the latest screening: a comparison of true interval and missed interval cancers. Eur Radiol. 1999;9(3):460-9. Exclusion: wrong outcomes. [pmid: 10087117].
Vitak B, Stal O, Manson JC, et al. Interval cancers and cancers in non-attenders in the Östergötland Mammographic Screening Programme. Duration between screening and diagnosis, S-phase fraction and distant recurrence. Eur J Cancer. 1997;33(9):1453-60. Exclusion: wrong outcomes. [pmid: 9337689].
Vogel VG. Epidemiology, genetics, and risk evaluation of postmenopausal women at risk of breast cancer. Menopause. 2008;15(4 Suppl):782-9. Exclusion: wrong intervention. [pmid: 18596599].
von Euler-Chelpin M, Risor LM, Thorsted BL, et al. Risk of breast cancer after false-positive test results in screening mammography. J Natl Cancer Inst. 2012;104(9):682-9. Exclusion: wrong outcomes. [pmid: 22491228].
Voogd AC, Coebergh JWW. Mortality reduction by breast-cancer screening. Lancet. 2003;362(9379):245-6. Exclusion: wrong publication type. [pmid: 12885492].
Vutuc C, Haidinger G, Waldhoer T. Prevalence of self-reported screening mammography and impact on breast cancer mortality in Austria. Wien Klin Wochenschr. 1998;110(13-14):485-90. Exclusion: wrong study design for key question. [pmid: 9746962].
Vutuc C, Waldhoer T, Klimont J, et al. Survival of women with breast cancer in Austria by age, stage and period of diagnosis. Wien Klin Wochenschr. 2002;114(12):438-42. Exclusion: wrong population. [pmid: 12422577].
Wai ES, D'Yachkova Y, Olivotto IA, et al. Comparison of 1- and 2-year screening intervals for women undergoing screening mammography. Br J Cancer. 2005;92(5):961-6. Exclusion: wrong study design for key question. [pmid: 15714210].
Waldherr C, Cerny P, Altermatt HJ, et al. Value of one-view breast tomosynthesis versus two-view mammography in diagnostic workup of women with clinical signs and symptoms and in women recalled from screening. AJR Am J Roentgenol. 2013;200(1):226-31. Exclusion: wrong intervention. [pmid: 23255766].
Wallis MG, Cheung S, Kearins O, et al. Non-operative diagnosis--effect on repeat-operation rates in the UK breast screening programme. Eur Radiol. 2009;19(2):318-23. Exclusion: wrong outcomes. [pmid: 18751983].
Wallis MG, Moa E, Zanca F, et al. Two-view and single-view tomosynthesis versus full-field digital mammography: high-resolution X-ray imaging observer study. Radiology. 2012;262(3):788-96. Exclusion: wrong outcomes. [pmid: 22274840].
Walter LC, Covinsky KE. Cancer screening in elderly patients: a framework for individualized decision making. JAMA. 2001;285(21):2750-6. Exclusion: wrong publication type. [pmid: 11386931].
Walter LC, Eng C, Covinsky KE. Screening mammography for frail older women: what are the burdens?. J Gen Intern Med. 2001;16(11):779-84. Exclusion: wrong comparison. [pmid: 11722693].
Walter LC, Schonberg MA. Screening mammography in older women: A review. JAMA. 2014;311(13):1336-47. Exclusion: review not meeting inclusion criteria. [pmid: 24691609].
Wanebo HJ, Cole B, Chung M, et al. Is surgical management compromised in elderly patients with breast cancer?. Ann Surg. 1997;225(5):579-86. discussion 86-9. Exclusion: wrong outcomes. [pmid: 9193185].
Wang H, Karesen R, Hervik A, et al. Mammography screening in Norway: results from the first screening round in four counties and cost-effectiveness of a modeled nationwide screening. Cancer Causes Control. 2001;12(1):39-45. Exclusion: wrong comparison. [pmid: 11227924].
Wang HC, Chen DR, Kao CH, et al. Detecting breast cancer in mammographically dense breasts: comparing technetium-99m tetrofosmin mammoscintigraphy and ultrasonography. Cancer Invest. 2002;20(7-8):932-8. Exclusion: wrong intervention. [pmid: 12449724].
Wang J, Chang KJ, Kuo WH, et al. Efficacy of mammographic evaluation of breast cancer in women less than 40 years of age: experience from a single medical center in Taiwan. J Formos Med Assoc. 2007;106(9):736-47. Exclusion: wrong population. [pmid: 17908663].
Wang T, Wang K, Yao Q, et al. Prospective study on combination of electrical impedance scanning and ultrasound in estimating risk of development of breast cancer in young women. Cancer Invest. 2010;28(3):295-303. Exclusion: wrong population. [pmid: 19857040].
Wang ZL, Xu JH, Li JL, et al. Comparison of automated breast volume scanning to hand-held ultrasound and mammography. [Erratum appears in Radiol Med. 2012 Dec;117(8):1443 Note: Xw, Jian Hong [corrected to Xu, Jian Hong]]. Radiol Med (Torino). 2012;117(8):1287-93. Exclusion: wrong intervention. [pmid: 22744341].
Ward J. Population-based mammographic screening: does ‘informed choice’ require any less than full disclosure to individuals of benefits, harms, limitations and consequences?. Aust N Z J Public Health. 1999;23(3):301-4. Exclusion: wrong study design for key question. [pmid: 10388176].
Ward JE, Young JM, Jelfs P. Population-based cancer control: where is the greatest benefit from proven strategies to ‘regain’ years of life lost prematurely?. Aust N Z J Public Health. 1999;23(5):538-40. Exclusion: wrong study design for key question. [pmid: 10575780].
Warner E. Clinical practice. Breast-cancer screening. N Engl J Med. 2011;365(11):1025-32. Exclusion: review not meeting inclusion criteria. [pmid: 21916640].
Warner E, Messersmith H, Causer P, et al. Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. Ann Intern Med. 2008;148(9):671-9. Exclusion: wrong intervention. [pmid: 18458280].
Warren RM, Duffy S. A comparison of the effectiveness of 28 kV (grid) versus 25 kV (no grid) mammographic techniques for breast screening. Br J Radiol. 1997;70(838):1022-7. Exclusion: wrong intervention. [pmid: 9404206].
Warren RML, Crawley A. Is breast MRI ever useful in a mammographic screening programme?. Clin Radiol. 2002;57(12):1090-7. Exclusion: wrong population. [pmid: 12475534].
Warren RML, Pointon L, Caines R, et al. What is the recall rate of breast MRI when used for screening asymptomatic women at high risk?. Magn Reson Imaging. 2002;20(7):557-65. Exclusion: wrong population. [pmid: 12413602].
Warwick J, Tabár L, Vitak B, et al. Time-dependent effects on survival in breast carcinoma: results of 20 years of follow-up from the Swedish Two-County Study. Cancer. 2004;100(7):1331-6. Exclusion: wrong population. [pmid: 15042664].
Wazer DE, Gage I, Homer MJ, et al. Age-related differences in patients with nonpalpable breast carcinomas. Cancer. 1996;78(7):1432-7. Exclusion: wrong study design for key question. [pmid: 8839548].
Weaver DL, Rosenberg RD, Barlow WE, et al. Pathologic findings from the Breast Cancer Surveillance Consortium: population-based outcomes in women undergoing biopsy after screening mammography. Cancer. 2006;106(4):732-42. Exclusion: wrong comparison. [pmid: 16411214].
Webb LJ, Samei E, Lo JY, et al. Comparative performance of multiview stereoscopic and mammographic display modalities for breast lesion detection. Med Phys. 2011;38(4):1972-80. Exclusion: wrong outcomes. [pmid: 21626930].
Webb ML, Cady B, Michaelson JS, et al. A failure analysis of invasive breast cancer: Most deaths from disease occur in women not regularly screened. Cancer. 2014;120(18):2839-46. Exclusion: wrong comparison. [pmid: 24018987].
Weedon-Fekjaer H, Lindqvist BH, Vatten LJ, et al. Estimating mean sojourn time and screening sensitivity using questionnaire data on time since previous screening. J Med Screen. 2008;15(2):83-90. Exclusion: wrong study design for key question. [pmid: 18573776].
Weedon-Fekjaer H, Vatten LJ, Aalen OO, et al. Estimating mean sojourn time and screening test sensitivity in breast cancer mammography screening: new results. J Med Screen. 2005;12(4):172-8. Exclusion: wrong study design for key question. [pmid: 16417693].
Wei J, Chan HP, Helvie MA, et al. Correlation between mammographic density and volumetric fibroglandular tissue estimated on breast MR images. Med Phys. 2004;31(4):933-42. Exclusion: wrong study design for key question. [pmid: 15125012].
Wei J, Chan HP, Zhou C, et al. Computer-aided detection of breast masses: four-view strategy for screening mammography. Med Phys. 2011;38(4):1867-76. Exclusion: wrong intervention. [pmid: 21626920].
Wei J, Hadjiiski LM, Sahiner B, et al. Computer-aided detection systems for breast masses: comparison of performances on full-field digital mammograms and digitized screen-film mammograms. Acad Radiol. 2007;14(6):659-69. Exclusion: wrong outcomes. [pmid: 17502255].
Weigel S, Biesheuvel C, Berkemeyer S, et al. Digital mammography screening: how many breast cancers are additionally detected by bilateral ultrasound examination during assessment?. Eur Radiol. 2013;23(3):684-91. Exclusion: wrong intervention. [pmid: 23052645].
Weigel S, Decker T, Korsching E, et al. Minimal invasive biopsy results of “uncertain malignant potential” in digital mammography screening: high prevalence but also high predictive value for malignancy. Fortschr Geb Rontgenstr Nuklearmed. 2011;183(8):743-8. Exclusion: wrong outcomes.
Weigel S, Decker T, Korsching E, et al. Calcifications in digital mammographic screening: improvement of early detection of invasive breast cancers?. Radiology. 2010;255(3):738-45. Exclusion: wrong intervention. [pmid: 20501713].
Weigert J, Steenbergen S. The connecticut experiment: the role of ultrasound in the screening of women with dense breasts. Breast J. 2012;18(6):517-22. Exclusion: wrong study design for key question. [pmid: 23009208].
Weinstein SP, Localio AR, Conant EF, et al. Multimodality screening of high-risk women: a prospective cohort study. J Clin Oncol. 2009;27(36):6124-8. Exclusion: wrong population. [pmid: 19884532].
Welch HG, Fisher ES. Diagnostic testing following screening mammography in the elderly. J Natl Cancer Inst. 1998;90(18):1389-92. Exclusion: studies outside of search dates. [pmid: 9747869].
Welch HG, Frankel BA. Likelihood that a woman with screen-detected breast cancer has had her “life saved” by that screening. Arch Intern Med. 2011;171(22):2043-6. Exclusion: wrong study design for key question. [pmid: 22025097].
Wenkel E, Geppert C, Schulz-Wendtland R, et al. Diffusion weighted imaging in breast MRI: comparison of two different pulse sequences. Acad Radiol. 2007;14(9):1077-83. Exclusion: wrong intervention. [pmid: 17707315].
Whittemore AS. Re: Reason for late-stage breast cancer: absence of screening or detection, or breakdown in follow-up?. J Natl Cancer Inst. 2005;97(5):400. author reply -1. Exclusion: wrong publication type. [pmid: 15741577].
Whyte K. Breast lumps and mammograms. Aust Fam Physician. 1999;28(8):831. Exclusion: wrong publication type. [pmid: 10495537].
Wilkerson BF, Schooff M. Screening mammography may not be effective at any age. J Fam Pract. 2000;49(4):302. Exclusion: wrong outcomes. [pmid: 10778833].
Wilkinson JE. Effect of mammography on breast cancer mortality. Am Fam Physician. 2011;84(11):1225-7. Exclusion: wrong publication type. [pmid: 22150654].
Williams TC, DeMartini WB, Partridge SC, et al. Breast MR imaging: computer-aided evaluation program for discriminating benign from malignant lesions. Radiology. 2007;244(1):94-103. Exclusion: wrong intervention. [pmid: 17507720].
Wilson AR. Contrast-enhanced breast ultrasound. The clinical context. Eur Radiol. Suppl 3. 2001;11:E35-40. Exclusion: wrong publication type. [pmid: 11793051].
Wiratkapun C, Bunyapaiboonsri W, Wibulpolprasert B, et al. Biopsy rate and positive predictive value for breast cancer in BI-RADS category 4 breast lesions. J Med Assoc Thai. 2010;93(7):830-7. Exclusion: wrong population. [pmid: 20649064].
Wishart GC, Greenberg DC, Britton PD, et al. Screen-detected vs symptomatic breast cancer: is improved survival due to stage migration alone?. Br J Cancer. 2008;98(11):1741-4. Exclusion: wrong comparison. [pmid: 18506175].
Witt J. The effect of information in the utilization of preventive health-care strategies: an application to breast cancer. Health Econ. 2008;17(6):721-31. Exclusion: wrong outcomes. [pmid: 17990287].
Wojcik BE, Spinks MK, Stein CR. Effects of screening mammography on the comparative survival rates of African American, white, and Hispanic beneficiaries of a comprehensive health care system. Breast J. 2003;9(3):175-83. Exclusion: wrong comparison. [pmid: 12752625].
Wolf R, Quan G, Calhoun K, et al. Efficiency of Core Biopsy for BI-RADS-5 Breast Lesions. Breast J. 2008;14(5):471-5. Exclusion: wrong intervention. [pmid: 18821933].
Wood C. Computer Aided Detection (CAD) for breast MRI. Technol Cancer Res Treat. 2005;4(1):49-53. Exclusion: wrong intervention. [pmid: 15649087].
Wright H, Listinsky J, Rim A, et al. Magnetic resonance imaging as a diagnostic tool for breast cancer in premenopausal women. Am J Surg. 2005;190(4):572-5. Exclusion: wrong study design for key question. [pmid: 16164923].
Wright IA, Pugh ND, Lyons K, et al. Power Doppler in breast tumours: a comparison with conventional colour Doppler imaging. Eur J Ultrasound. 1998;7(3):175-81. Exclusion: wrong intervention. [pmid: 9700212].
Wright JR, Whelan TJ, McCready DR, et al. Management of ductal carcinoma in situ of the breast. Provincial Breast Cancer Disease Site Group. Cancer Prev Control. 1998;2(6):312-9. Exclusion: wrong outcomes. [pmid: 10470463].
Wu D, Rosner GL, Broemeling LD. Bayesian inference for the lead time in periodic cancer screening. Biometrics. 2007;63(3):873-80. Exclusion: wrong study design for key question. [pmid: 17825017].
Wu JCY, Anttila A, Yen AMF, et al. Evaluation of breast cancer service screening programme with a Bayesian approach: mortality analysis in a Finnish region. Breast Cancer Res Treat. 2010;121(3):671-8. Exclusion: wrong study design for key question. [pmid: 19890708].
Wu MH, Chou YC, Yu JC, et al. Hormonal and body-size factors in relation to breast cancer risk: a prospective study of 11,889 women in a low-incidence area. Ann Epidemiol. 2006;16(3):223-9. Exclusion: wrong comparison. [pmid: 15996484].
Wu WJ, Moon WK. Ultrasound breast tumor image computer-aided diagnosis with texture and morphological features. Acad Radiol. 2008;15(7):873-80. Exclusion: wrong study design for key question. [pmid: 18572123].
Wu X, Yan A, Liu H. X-ray phase-shifts-based method of volumetric breast density measurement. Med Phys. 2012;39(7):4239-44. Exclusion: wrong study design for key question. [pmid: 22830757].
Wu Y, Weissfeld JL, Weinberg GB, et al. Screening mammography and late-stage breast cancer: a population-based study. Prev Med. 1999;28(6):572-8. Exclusion: wrong comparison. [pmid: 10404555].
Xu JL, Fagerstrom RM, Prorok PC. Estimation of post-lead-time survival under dependence between lead-time and post-lead-time survival. Stat Med. 1999;18(2):155-62. Exclusion: wrong study design for key question. [pmid: 10028136].
Xu JL, Fagerstrom RM, Prorok PC, et al. Estimating the cumulative risk of a false-positive test in a repeated screening program. Biometrics. 2004;60(3):651-60. Exclusion: wrong study design for key question. [pmid: 15339287].
Xu W, Vnenchak P, Smucny J. Screening mammography in women aged 70 to 79 years. Journal of Family Practice. 2000;49(3):266-7. Exclusion: wrong study design for key question. [pmid: 10735487].
Yabroff KR, Harlan LC, Clegg LX, et al. Is mode of breast cancer detection associated with cancer treatment in the United States?. Cancer. 2008;112(5):1011-9. Exclusion: wrong population. [pmid: 18189297].
Yabuuchi H, Matsuo Y, Sunami S, et al. Detection of non-palpable breast cancer in asymptomatic women by using unenhanced diffusion-weighted and T2-weighted MR imaging: comparison with mammography and dynamic contrast-enhanced MR imaging. Eur Radiol. 2011;21(1):11-7. Exclusion: wrong comparison. [pmid: 20640898].
Yaffe MJ, Barnes GT, Orton CG. Point/Counterpoint. Film mammography for breast cancer screening in younger women is no longer appropriate because of the demonstrated superiority of digital mammography for this age group. Med Phys. 2006;33(11):3979-82. Exclusion: wrong publication type. [pmid: 17153375].
Yaffe MJ, Pritchard KI. Overdiagnosing overdiagnosis. Oncologist. 2014;19(2):103-6. Exclusion: wrong publication type. [pmid: 24536050].
Yamaguchi K, Schacht D, Newstead GM, et al. Breast cancer detected on an incident (second or subsequent) round of screening MRI: MRI features of false-negative cases. AJR Am J Roentgenol. 2013;201(5):1155-63. Exclusion: wrong intervention. [pmid: 24147491].
Yang HC, Chang CH, Huang SW, et al. Correlations among acoustic, texture and morphological features for breast ultrasound CAD. Ultrason Imaging. 2008;30(4):228-36. Exclusion: wrong study design for key question. [pmid: 19507676].
Yang MC, Huang CS, Chen JH, et al. Whole breast lesion detection using naive bayes classifier for portable ultrasound. Ultrasound Med Biol. 2012;38(11):1870-80. Exclusion: wrong intervention. [pmid: 22975038].
Yang SK, Moon WK, Cho N, et al. Screening mammography-detected cancers: sensitivity of a computer-aided detection system applied to full-field digital mammograms. Radiology. 2007;244(1):104-11. Exclusion: wrong intervention. [pmid: 17507722].
Yang W, Zhang S, Chen Y, et al. Shape symmetry analysis of breast tumors on ultrasound images. Comput Biol Med. 2009;39(3):231-8. Exclusion: wrong outcomes. [pmid: 19178908].
Yang WT, Lam WW, Cheung H, et al. Sonographic, magnetic resonance imaging, and mammographic assessments of preoperative size of breast cancer. J Ultrasound Med. 1997;16(12):791-7. Exclusion: wrong population. [pmid: 9401992].
Yankaskas BC, Cleveland RJ, Schell MJ, et al. Association of recall rates with sensitivity and positive predictive values of screening mammography. AJR Am J Roentgenol. 2001;177(3):543-9. Exclusion: no original data to include; publication or dataset with longer followup, more complete data, or same data already included in review. [pmid: 11517044].
Yankaskas BC, Gill KS. Diagnostic mammography performance and race: outcomes in Black and White women. Cancer. 2005;104(12):2671-81. Exclusion: wrong intervention. [pmid: 16288489].
Yankaskas BC, May RC, Matuszewski J, et al. Effect of observing change from comparison mammograms on performance of screening mammography in a large community-based population. Radiology. 2011;261(3):762-70. Exclusion: wrong outcomes. [pmid: 22031709].
Yankaskas BC, Taplin SH, Ichikawa L, et al. Association between mammography timing and measures of screening performance in the United States. Radiology. 2005;234(2):363-73. Exclusion: wrong outcomes. [pmid: 15670994].
Yasmeen S, Hubbard RA, Romano PS, et al. Risk of advanced-stage breast cancer among older women with comorbidities. Cancer Epidemiol Biomarkers Prev. 2012;21(9):1510-9. Exclusion: wrong comparison. [pmid: 22744339].
Yasmeen S, Romano PS, Pettinger M, et al. Frequency and predictive value of a mammographic recommendation for short-interval follow-up. J Natl Cancer Inst. 2003;95(6):429-36. Exclusion: wrong outcomes. [pmid: 12644536].
Yasmeen S, Xing G, Morris C, et al. Comorbidities and mammography use interact to explain racial/ethnic disparities in breast cancer stage at diagnosis. Cancer. 2011;117(14):3252-61. Exclusion: wrong comparison. [pmid: 21246529].
Yassin MM, Peel ALG, Thompson WD, et al. Does screen-detected breast cancer have better survival than symptomatic breast cancer?. Asian J Surg. 2003;26(2):101-7. Exclusion: wrong comparison. [pmid: 12732494].
Yasunaga H, Ide H, Imamura T, et al. Women's anxieties caused by false positives in mammography screening: A contingent valuation survey. Breast Cancer Res Treat. 2007;101(1):59-64. Exclusion: studies outside of search dates. [pmid: 16821083].
Yee KM. Cancer: Screening mammo cuts incidence of late-stage cancer. 2014. Exclusion: wrong publication type.
Yeh ED. Breast magnetic resonance imaging: current clinical indications. Magn Reson Imaging Clin N Am. 2010;18(2):155-69. Exclusion: wrong study design for key question. [pmid: 20494303].
Yin XX, Ng BWH, Ramamohanarao K, et al. Exploiting sparsity and low-rank structure for the recovery of multi-slice breast MRIs with reduced sampling error. Med Biol Eng Comput. 2012;50(9):991-1000. Exclusion: wrong outcomes. [pmid: 22644257].
Yokoe T, Iino Y, Maemura M, et al. Efficacy of mammography for detecting early breast cancer in women under 50. Anticancer Res. 1998;18(6B):4709-11. Exclusion: wrong study design for key question. [pmid: 9891545].
Yong LC, Brown CC, Schatzkin A, et al. Prospective study of relative weight and risk of breast cancer: the Breast Cancer Detection Demonstration Project follow-up study, 1979 to 1987-1989. Am J Epidemiol. 1996;143(10):985-95. Exclusion: wrong comparison. [pmid: 8629617].
Yoon JH, Kim MH, Kim EK, et al. Interobserver variability of ultrasound elastography: how it affects the diagnosis of breast lesions. AJR Am J Roentgenol. 2011;196(3):730-6. Exclusion: wrong intervention. [pmid: 21343520].
Yoshida M, Kondo K, Tada T. The relation between the cancer screening rate and the cancer mortality rate in Japan. J Med Invest. 2010;57(3-4):251-9. Exclusion: wrong study design for key question. [pmid: 20847525].
Youk JH, Kim EK. Supplementary screening sonography in mammographically dense breast: pros and cons. Korean J Radiol. 2010;11(6):589-93. Exclusion: wrong publication type. [pmid: 21076583].
Young RF, Schwartz K, Booza J. Medical barriers to mammography screening of African American women in a high cancer mortality area: implications for cancer educators and health providers. J Cancer Educ. 2011;26(2):262-9. Exclusion: wrong study design for key question. [pmid: 21210272].
Yu J, Park A, Morris E, et al. MRI screening in a clinic population with a family history of breast cancer. Ann Surg Oncol. 2008;15(2):452-61. Exclusion: wrong population. [pmid: 18026801].
Yu X, McBean AM, Virnig BA. Physician visits, patient comorbidities, and mammography use among elderly colorectal cancer survivors. J Cancer Surviv. 2007;1(4):275-82. Exclusion: wrong population. [pmid: 18648962].
Yucesoy C, Oktay NA, Ozturk E, et al. Pathologic assessment of non-palpable probably benign breast masses at sonography: can instant intervention be avoided and is follow-up adequate?. JBR-BTR. 2010;93(5):242-6. Exclusion: wrong population. [pmid: 21179983].
Zackrisson S, Andersson I, Manjer J, et al. Non-attendance in breast cancer screening is associated with unfavourable socio-economic circumstances and advanced carcinoma. Int J Cancer. 2004;108(5):754-60. Exclusion: wrong outcomes. [pmid: 14696103].
Zahl PH, Jorgensen KJ, Gotzsche PC. Overestimated lead times in cancer screening has led to substantial underestimation of overdiagnosis. Br J Cancer. 2013;109(7):2014-9. Exclusion: wrong study design for key question. [pmid: 23963144].
Zahl PH, Gotzsche PC, Maehlen J. Natural history of breast cancers detected in the Swedish mammography screening programme: a cohort study. Lancet Oncol. 2011;12(12):1118-24. Exclusion: wrong outcomes. [pmid: 21996169].
Zahl PH, Jorgensen KJ, Maehlen J, et al. Biases in estimates of overdetection due to mammography screening. Lancet Oncol. 2008;9(3):199-201. author reply -2. Exclusion: wrong publication type. [pmid: 18308246].
Zahl PH, Maehlen J. Constant relative survival rates in Sweden and Norway when adjusting for screening-related overdiagnosis. Int J Cancer. 2007;120(10):2279. author reply 80. Exclusion: wrong publication type. [pmid: 17230530].
Zahl PH, Suhrke P, Jorgensen KJ. Overdiagnosis of breast cancer in Norway: what have the authors adjusted for?. Int J Cancer. 2013;133(11):2754-5. Exclusion: wrong publication type. [pmid: 23650050].
Zamora LI, Forastero C, Guirado D, et al. A Monte Carlo tool to study the mortality reduction due to breast screening programs. Med Phys. 2012;39(12):7215-23. Exclusion: wrong study design for key question. [pmid: 23231272].
Zappa M, Federici A. Introduction. J Med Screen. 2012;19(suppl 1):3-4. Exclusion: wrong publication type. [pmid: 22972805].
Zelle SG, Nyarko KM, Bosu WK, et al. Costs, effects and cost-effectiveness of breast cancer control in Ghana. Trop Med Int Health. 2012;17(8):1031-43. Exclusion: wrong outcomes. [pmid: 22809238].
Zhang B, Ferrence R, Cohen J, et al. Smoking cessation and lung cancer mortality in a cohort of middle-aged Canadian women. Ann Epidemiol. 2005;15(4):302-9. Exclusion: wrong outcomes. [pmid: 15780778].
Zhang S, Ivy JS, Diehl KM, et al. The association of breast density with breast cancer mortality in African American and white women screened in community practice. Breast Cancer Res Treat. 2013;137(1):273-83. Exclusion: wrong comparison. [pmid: 23143213].
Zografos GC, Zagouri F, Sergentanis TN, et al. Is zero underestimation feasible? Extended Vacuum-Assisted Breast Biopsy in solid lesions - a blind study. World J Surg Oncol. 2007;5:53. Exclusion: wrong intervention. [pmid: 17501997].
Zonderland HM, Pope TL Jr., Nieborg AJ. The positive predictive value of the breast imaging reporting and data system (BI-RADS) as a method of quality assessment in breast imaging in a hospital population. Eur Radiol. 2004;14(10):1743-50. Exclusion: wrong comparison. [pmid: 15243715].
Zotov V, Shyyan R, Program PBCA. Introduction of breast cancer screening in Chernihiv Oblast in the Ukraine: report of a PATH Breast Cancer Assistance Program experience. Breast J. Suppl 2. 2003;9:S75-80. Exclusion: wrong study design for key question. [pmid: 12713500].
Zwahlen M, Bopp M, Probst-Hensch NM. Mammography screening in Switzerland: limited evidence from limited data. Swiss Med Wkly. 2004;134(21-22):295-306. Exclusion: wrong study design for key question. [pmid: 15243841].
Zwiggelaar R, Parr TC, Schumm JE, et al. Model-based detection of spiculated lesions in mammograms. Med Image Anal. 1999;3(1):39-62. Exclusion: wrong publication type. [pmid: 10709696].
Zysk AM, Brankov JG, Wernick MN, et al. Adaptation of a clustered lumpy background model for task-based image quality assessment in x-ray phase-contrast mammography. Med Phys. 2012;39(2):906-11. Exclusion: wrong outcomes. [pmid: 22320800].

## Appendix A5 Quality Rating Criteria

### Randomized, Controlled Trials (RCTs) and Cohort Studies1,2

#### Criteria

- Initial assembly of comparable groups:
  ○ for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat is lacking.

### Case Control Studies1,2

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

#### Definition of ratings based on criteria above

Good: | Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
Fair: | Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
Poor: | Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

### Systematic Reviews2-5

#### Criteria

- Search dates reported?
- Search methods reported?
- Comprehensive search?
- Inclusion criteria reported?
- Selection bias avoided?
- Validity criteria reported?
- Validity assessed appropriately?
- Methods used to combine studies reported?
- Findings combined appropriately?
- Conclusions supported by data?

#### Definitions of ratings based on above criteria

Good: | Meets all criteria: reports comprehensive and reproducible search methods and results; reports pre-defined criteria to select studies and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.
Fair: | Studies will be graded fair if they fail to meet one or more of the above criteria, but the limitations are not judged as being major.
Poor: | Studies will be graded poor if they have a major limitation in one or more of the above criteria.

### References

1 U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. July. 2008. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. September 18, 2014.
2 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
3 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006. Available at: http://www.nice.org.uk/About/What-we-do/Our-Programmes/NICE-guidance/NICE-guidelines/NICE-clinical-guidelines.
4 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-1278. September 18, 2014. [pmid: 1834807].
5 Shea BJ, Hamel C, Wells GA, Bouter LM, Kristjansson E, Grimshaw J, Henry DA, Boers M. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. 2009;62(10):1013-1023. [pmid: 19230606].

## Appendix A6 Details of the Breast Cancer Surveillance Consortium

### Breast Cancer Surveillance Consortium

In 1994 the National Cancer Institute (NCI) established the Breast Cancer Surveillance Consortium (BCSC) to study breast cancer screening practices in the United States, with the recognition that results from controlled clinical trials of mammography may differ from the results of community screening practices. Each of the Consortium's breast imaging registries collects population-based screening and diagnostic mammography data and links it to state or regional cancer registries. The following BCSC registries contributed data to this report: the Carolina Mammography Registry (North Carolina), Group Health Cooperative (Seattle Puget Sound region), New Hampshire Mammography Network, San Francisco Mammography Registry, and Vermont Breast Cancer Surveillance System. Mammography data are also linked to pathology databases, which include benign as well as malignant outcomes. A comparison of women represented in the BCSC against 2000 Census data shows that Consortium sites are located in counties that contain slightly more than 5 percent of the U.S. population, and represent the population in important sociodemographic respects.1

Currently, the Consortium's database contains information on 10.7 million mammography examinations (including 2.6 million digital), 2.5 million women, and 130,000 breast cancer cases. Information on the distribution of key variables, mammographic data, characteristics of cases, and screening performance, among others, are detailed on the BCSC website: http://breastscreening.cancer.gov/data/. Data are pooled at a central Statistical Coordinating Center.

Registries and the Coordinating Center received institutional review board approval for active or passive consenting processes or a waiver of consent to enroll participants, link data, and perform analysis. All procedures were Health Insurance Portability and Accountability Act compliant, and registries and the coordinating center received a federal Certificate of Confidentiality and other protections for the identities of women, physicians, and facilities.

BCSC data include screening as well as diagnostic mammography. Screening mammography examinations are those designated as such by the ordering provider or radiologist performed more than 9 months after a previous imaging examination in women without a history of breast cancer or breast augmentation. Unilateral exams are excluded. Mammography information includes breast density, Breast Imaging Reporting And Data System (BI-RADS) assessment score, and recommendations for further work-up. In addition, prior to each mammography examination, a woman fills out a questionnaire that includes demographic and medical history information, including previous mammography information. Each screening mammography examination is given initial BI-RADS score based on the screening views only, which categorizes it as “positive” or “negative.” In our analysis, an initial score of 0, 4, 5, or 3 with a recommendation for immediate work-up is considered positive, whereas a score of 1, 2 or 3 without a recommendation for immediate work-up is negative.

In this report, BCSC data from 2003 to 2011 are included to examine the 1) frequency of recommendations for additional imaging and biopsy procedures resulting from positive screening mammography, 2) potential adverse effects of mammography screening, 3) incidence of ductal carcinoma in situ and invasive cancers detected by mammography screening; and 4) differences in outcomes between groups based on age, risk factors, and time since last mammography screening. Information for women under age 40 years or who have histories of breast augmentation or previous breast cancer diagnosis has been excluded.

### References

1 National Cancer Institute. Breast Cancer Surveillance Consortium: Evaluating Screening Performance in Practice. NIH Publication No. 04-5490. Bethesda, MD. National Cancer Institute, National Institutes of Health, U.S. Department of Health and Human Services. April. 2004. Available at: http://breastscreening.cancer.gov/espp.pdf. September 18, 2014.
2 National Cancer Institute. Breast Cancer Surveillance Consortium Fact Sheet. Bethesda, MD. National Cancer Institute, National Institutes of Health, U.S. Department of Health and Human Services. September. 2013. Available at: http://breastscreening.cancer.gov/about/bcsc_fact_sheet.pdf. September 18 2014.

## Appendix A7 List of Peer Reviewers

### Expert Reviewers

Joann G. Elmore, MD, MPH Professor of Medicine, Adjunct Professor of Epidemiology, University of Washington, Seattle, WA

Laura Esserman, MD, MBA Director, UCSF Carol Franc Buck Breast Care Center, Professor of Surgery and Radiology, University of California, San Francisco, CA

W. Phil Evans, MD Clinical Professor of Radiology; Director, UT Southwestern Center for Breast Care, University of Texas Southwestern Medical Center, Dallas, TX

Suzanne W. Fletcher, MD, MSc Professor emerita, Department of Population medicine, Harvard medical School and Harvard Pilgrim Health Care Institute, Cambridge, MA

Karla Kerlikowske, MD Professor of Medicine and Epidemiology and biostatistics, University of California, San Francisco, CA

Anthony B. Miller, MD, FRCP, FRCP(C), FACE, FFPHM Professor Emeritus, Dalla Lana School of Public Health, University of Toronto, Toronto, ON, Canada

Edward A. Sickles, MD Professor Emeritus of Radiology, UCSF School of Medicine, San Francisco, CA

### Federal Reviewer

Barnett (Barry) Kramer, MD, MPH Director, Division of Cancer prevention, National Cancer Institute, Rockville, MD

## Appendix A8 List of Studies in the Included Systematic Reviews

### Key Question 1 What is the effectiveness of routine mammography screening in reducing breast cancer–specific and all-cause mortality, and how does it differ by age, risk factor, and screening interval?

#### Broeders et al, 2012

Allgood PC, Warwick J, Warren RML, et al. A case-control study of the impact of the East Anglian breast screening programme on breast cancer mortality. Br J Cancer. 2008;98(1):206-9. [pmid: 18059396].
Anttila A, Koskela J, Hakama M. Programme sensitivity and effectiveness of mammography service screening in Helsinki, Finland. J Med Screen. 2002;9(4):153-8. [pmid: 12518004].
Anttila A, Sarkeala T, Hakulinen T, et al. Impacts of the Finnish service screening programme on breast cancer rates. BMC Public Health. 2008;8.
Ascunce EN, Moreno-Iribas C, Urtiaga AB, et al. Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 2007;14(1):14-20. [pmid: 17362566].
Autier P, Boniol M, Gavin A, et al. Breast cancer mortality in neighbouring European countries with different levels of screening but similar access to treatment: Trend analysis of WHO mortality database. BMJ. 2011;343(7818).
Autier P, Boniol M, LaVecchia C, et al. Disparities in breast cancer mortality trends between 30 European countries: Retrospective trend analysis of WHO mortality database. BMJ. 2010;341(7768):335.
Baker SG, Kramer BS, Prorok PC. Comparing cancer mortality rates before-and-after a change in availability of screening in different regions: Extension of the paired availability design. BMC Med Res Methodol. 2004;4:1-24.
Barchielli A, Paci E. Trends in breast cancer mortality, incidence, and survival, and mammographic screening in Tuscany, Italy. Cancer Causes Control. 2001;12(3):249-55. [pmid: 11405330].
Blanks RG, Moss SM, McGahan CE, et al. Effect of NHS breast screening programme on mortality from breast cancer in England and Wales, 1990-8: Comparison of observed with predicted mortality. Br Med J. 2000;321(7262):665. [pmid: 10987769].
Botha JL, Bray F, Sankila R, et al. Breast cancer incidence and mortality trends in 16 European countries. Eur J Cancer. 2003;39(12):1718-29. [pmid: 12888367].
Broeders MJM, Verbeek ALM, Straatman H, et al. Repeated mammographic screening reduces breast cancer mortality along the continuum of age. J Med Screen. 2002;9(4):163-7. [pmid: 12518006].
Cabanes A, Vidal E, Pérez-Gómez B, et al. Age-specific breast, uterine and ovarian cancer mortality trends in Spain: Changes from 1980 to 2006. Cancer Epidemiol. 2009;33(3-4):169-75. [pmid: 19766076].
Chen LS, Yen AMF, Duffy SW, et al. Computer-aided system of evaluation for population-based all-in-one service screening (CASE-PASS): From study design to outcome analysis with bias adjustment. Ann Epidemiol. 2010;20(10):786-96. [pmid: 20816316].
Duffy SW, Tabár L, Chen HH, et al. The impact of organized mammography service screening on breast carcinoma mortality in seven Swedish Counties: A collaborative evaluation. Cancer. 2002;95(3):458-69. [pmid: 12209737].
Duffy SW, Tabar L, Olsen AH, et al. Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J Med Screen. 2010;17(1):25-30. [pmid: 20356942].
Fielder HM, Warwick J, Brook D, et al. A case-control study to estimate the impact on breast cancer death of the breast screening programme in Wales. J Med Screen. 2004;11(4):194-8. [pmid: 15563774].
Gabe R, Tryggvadóttir L, Sigfússon BF, et al. A case-control study to estimate the impact of the icelandic population-based mammography screening program on breast cancer death. Acta radiol. 2007;48(9):948-55. [pmid: 18080359].
Gorini G, Zappa M, Miccinesi G, et al. Breast cancer mortality trends in two areas of the province of Florence, Italy, where screening programmes started in the 1970s and 1990s. Br J Cancer. 2004;90(9):1780-3. [pmid: 15150601].
Hakama M, Pukkala E, Heikkila M, et al. Effectiveness of the public health policy for breast cancer screening in Finland: Population based cohort study. Br Med J. 1997;314(7084):864-7. [pmid: 9093096].
Haukka J, Byrnes G, Boniol M, et al. Trends in breast cancer mortality in Sweden before and after implementation of mammography screening. PLoS One. 2011;6(9).
Jonsson H, Bordás P, Wallin H, et al. Service screening with mammography in Northern Sweden: Effects on breast cancer mortality - An update. J Med Screen. 2007;14(2):87-93. [pmid: 17626708].
Jonsson H, Nyström L, Törnberg S, et al. Service screening with mammography of women aged 50-69 years in sweden: Effects on mortality from breast cancer. J Med Screen. 2001;8(3):152-60. [pmid: 11678556].
Jonsson H, Nyström L, Törnberg S, et al. Service screening with mammography. Long-term effects on breast cancer mortality in the county of Gävleborg, Sweden. Breast. 2003;12(3):183-93. [pmid: 14659325].
Jørgensen KJ, Zahl PH, Gøtzsche PC. Breast cancer mortality in organised mammography screening in Denmark: Comparative study. BMJ. 2010;340(7750):797.
Kalager M, Zelen M, Langmark F, et al. Effect of screening mammography on breast-cancer mortality in Norway. N Engl J Med. 2010;363(13):1203-10. [pmid: 20860502].
Olsen AH, Njor SH, Vejborg I, et al. Breast cancer mortality in Copenhagen after introduction of mammography screening: Cohort study. Br Med J. 2005;330(7485):220-2. [pmid: 15649904].
Otten JDM, Broeders MJM, Fracheboud J, et al. Impressive time-related influence of the Dutch screening programme on breast cancer incidence and mortality, 1975-2006. Int J Cancer. 2008;123(8):1929-34. [pmid: 18688863].
Otto SJ, Fracheboud J, Looman CWN, et al. Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: A systematic review. Lancet. 2003;361(9367):1411-7. [pmid: 12727393].
Otto SJ, Fracheboud J, Verbeek ALM, et al. Mammography screening and risk of breast cancer death: A population-based case - Control study. Cancer Epidemiol Biomarkers Prev. 2012;21(1):66-73. [pmid: 22147362].
Paap E, Holland R, Heeten GJD, et al. A remarkable reduction of breast cancer deaths in screened versus unscreened women: A case-referent study. Cancer Causes Control. 2010;21(10):1569-73. [pmid: 20512656].
Paci E, Duffy SW, Giorgi D, et al. Quantification of the effect of mammographic screening on fatal breast cancers: The Florence Programme 1990-96. Br J Cancer. 2002;87(1):65-9. [pmid: 12085258].
Paci E, Giorgi D, Bianchi S, et al. Assessment of the early impact of the population-based breast cancer screening programme in Florence (Italy) using mortality and surrogate measures. Eur J Cancer. 2002;38(4):568-73. [pmid: 11872351].
Parvinen I, Helenius H, Pylkkänen L, et al. Service screening mammography reduces breast cancer mortality among elderly women in Turku. J Med Screen. 2006;13(1):34-40. [pmid: 16569304].
Pons-Vigués M, Puigpinós R, Cano-Serral G, et al. Breast cancer mortality in Barcelona following implementation of a city breast cancer-screening program. Cancer Detect Prev. 2008;32(2):162-7. [pmid: 18639990].
Puliti D, Miccinesi G, Collina N, et al. Effectiveness of service screening: A case-control study to assess breast cancer mortality reduction. Br J Cancer. 2008;99(3):423-7. [pmid: 18665188].
Quinn M, Allen E. Changes in incidence of and mortality from breast cancer in England and Wales since introduction of screening. Br Med J. 1995;311(7017):1391-5. [pmid: 8520272].
Sarkeala T, Heinävaara S, Anttila A. Breast cancer mortality with varying invitational policies in organised mammography. Br J Cancer. 2008;98(3):641-5. [pmid: 18231108].
Sarkeala T, Heinävaara S, Anttila A. Organised mammography screening reduces breast cancer mortality: A cohort study from Finland. Int J Cancer. 2008;122(3):614-9. [pmid: 17847022].
Swedish Organised Service Screening Evaluation G. Reduction in breast cancer mortality from organized service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiol Biomarkers Prev. 2006;15(1):45-51. [pmid: 16434585].
Tabár L, Vitak B, Tonychen HH, et al. Beyond randomized controlled trials: Organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2001;91(9):1724-31. [pmid: 11335897].
Törnberg S, Kemetli L, Lynge E, et al. Breast cancer incidence and mortality in the Nordic capitals, 1970-1998. Trends related to mammography screening programmes. Acta Oncol. 2006;45(5):528-35. [pmid: 16864165].
Ugarte MD, Goicoa T, Etxeberria J, et al. Age-specific spatio-temporal patterns of female breast cancer mortality in Spain (1975-2005). Ann Epidemiol. 2010;20(12):906-16. [pmid: 21074105].
Van Schoor G, Moss SM, Otten JDM, et al. Increasingly strong reduction in breast cancer mortality due to screening. Br J Cancer. 2011;104(6):910-4. [pmid: 21343930].
Wu JCY, Anttila A, Yen AMF, et al. Evaluation of breast cancer service screening programme with a Bayesian approach: Mortality analysis in a Finnish region. Breast Cancer Res Treat. 2010;121(3):671-8. [pmid: 19890708].

#### Harris et al, 2011

Anttila A, Koskela J, Hakama M. Programme sensitivity and effectiveness of mammography service screening in Helsinki, Finland. J Med Screen. 2002;9(4):153-8. [pmid: 12518004].
Ascunce EN, Moreno-Iribas C, Urtiaga AB, et al. Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 2007;14(1):14-20. [pmid: 17362566].
Broeders MJM, Peer PGM, Straatman H, et al. Diverging breast cancer mortality rates in relation to screening? A comparison of Nijmegen to Arnhem and the Netherlands, 1969-1997. Int J Cancer. 2001;92(2):303-8. [pmid: 11291061].
Duffy SW, Tabar L, Olsen AH, et al. Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J Med Screen. 2010;17(1):25-30. [pmid: 20356942].
Garne JP, Aspegren K, Balldin G, et al. Increasing incidence of and declining mortality from breast carcinoma: Trends in Malmo, Sweden, 1961-1992. Cancer. 1997;79(1):69-74. [pmid: 8988728].
Gorini G, Zappa M, Miccinesi G, et al. Breast cancer mortality trends in two areas of the province of Florence, Italy, where screening programmes started in the 1970s and 1990s. Br J Cancer. 2004;90(9):1780-3. [pmid: 15150601].
Jonsson H, Bordás P, Wallin H, et al. Service screening with mammography in Northern Sweden: Effects on breast cancer mortality - An update. J Med Screen. 2007;14(2):87-93. [pmid: 17626708].
Jonsson H, Nyström L, Törnberg S, et al. Service screening with mammography of women aged 50-69 years in sweden: Effects on mortality from breast cancer. J Med Screen. 2001;8(3):152-60. [pmid: 11678556].
Jonsson H, Nyström L, Törnberg S, et al. Service screening with mammography. Long-term effects on breast cancer mortality in the county of Gävleborg, Sweden. Breast. 2003;12(3):183-93. [pmid: 14659325].
Jorgensen KJ, Zahl PH, Gotzsche PC. Breast cancer mortality in organized mammography screening in Denmark: comparative study. BMJ. 2010:340.
Olsen AH, Njor SH, Lynge E. Estimating the benefits of mammography screening: The impact of study design. Epidemiology. 2007;18(4):487-92. [pmid: 17486020].
Olsen AH, Njor SH, Vejborg I, et al. Breast cancer mortality in Copenhagen after introduction of mammography screening: Cohort study. Br Med J. 2005;330(7485):220-2. [pmid: 15649904].
Otto SJ, Fracheboud J, Looman CWN, et al. Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: A systematic review. Lancet. 2003;361(9367):1411-7. [pmid: 12727393].
Parvinen I, Helenius H, Pylkkänen L, et al. Service screening mammography reduces breast cancer mortality among elderly women in Turku. J Med Screen. 2006;13(1):34-40. [pmid: 16569304].
Sarkeala T, Heinävaara S, Anttila A. Organised mammography screening reduces breast cancer mortality: A cohort study from Finland. Int J Cancer. 2008;122(3):614-9. [pmid: 17847022].
Swedish Organised Service Screening Evaluation G. Reduction in breast cancer mortality from organized service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiol Biomarkers Prev. 2006;15(1):45-51. [pmid: 16434585].
Tabar L, Yen MF, Vitak B, et al. Mammography service screening and mortality in breast cancer patients: 20-year follow-up before and after introduction of screening. Lancet. 2003;361(9367):1405-10. [pmid: 12727392].
Törnberg S, Kemetli L, Lynge E, et al. Breast cancer incidence and mortality in the Nordic capitals, 1970-1998. Trends related to mammography screening programmes. Acta Oncol. 2006;45(5):528-35. [pmid: 16864165].

#### Moss et al, 2012

Ascunce EN, Moreno-Iribas C, Urtiaga AB, et al. Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 2007;14(1):14-20. [pmid: 17362566].
Autier P, Boniol M, Gavin A, et al. Breast cancer mortality in neighbouring European countries with different levels of screening but similar access to treatment: Trend analysis of WHO mortality database. BMJ. 2011;343:7818.
Autier P, Boniol M, LaVecchia C, et al. Disparities in breast cancer mortality trends between 30 European countries: Retrospective trend analysis of WHO mortality database. BMJ. 2010;341(7768):335.
Barchielli A, Paci E. Trends in breast cancer mortality, incidence, and survival, and mammographic screening in Tuscany, Italy. Cancer Causes Control. 2001;12(3):249-55. [pmid: 11405330].
Blanks RG, Moss SM, McGahan CE, et al. Effect of NHS breast screening programme on mortality from breast cancer in England and Wales, 1990-8: Comparison of observed with predicted mortality. Br Med J. 2000;321(7262):665. [pmid: 10987769].
Botha JL, Bray F, Sankila R, et al. Breast cancer incidence and mortality trends in 16 European countries. Eur J Cancer. 2003;39(12):1718-29. [pmid: 12888367].
Cabanes A, Vidal E, Pérez-Gómez B, et al. Age-specific breast, uterine and ovarian cancer mortality trends in Spain: Changes from 1980 to 2006. Cancer Epidemiol. 2009;33(3-4):169-75. [pmid: 19766076].
Duffy SW, Tabar L, Olsen AH, et al. Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J Med Screen. 2010;17(1):25-30. [pmid: 20356942].
Gorini G, Zappa M, Miccinesi G, et al. Breast cancer mortality trends in two areas of the province of Florence, Italy, where screening programmes started in the 1970s and 1990s. Br J Cancer. 2004;90(9):1780-3. [pmid: 15150601].
Haukka J, Byrnes G, Boniol M, et al. Trends in breast cancer mortality in Sweden before and after implementation of mammography screening. PLoS One. 2011;6(9).
Jørgensen KJ, Zahl PH, Gøtzsche PC. Breast cancer mortality in organised mammography screening in Denmark: Comparative study. BMJ. 2010;340(7750):797.
Otten JDM, Broeders MJM, Fracheboud J, et al. Impressive time-related influence of the Dutch screening programme on breast cancer incidence and mortality, 1975-2006. Int J Cancer. 2008;123(8):1929-34. [pmid: 18688863].
Otto SJ, Fracheboud J, Looman CWN, et al. Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: A systematic review. Lancet. 2003;361(9367):1411-7. [pmid: 12727393].
Pons-Vigués M, Puigpinós R, Cano-Serral G, et al. Breast cancer mortality in Barcelona following implementation of a city breast cancer-screening program. Cancer Detect Prev. 2008;32(2):162-7. [pmid: 18639990].
Quinn M, Allen E. Changes in incidence of and mortality from breast cancer in England and Wales since introduction of screening. Br Med J. 1995;311(7017):1391-5. [pmid: 8520272].
Törnberg S, Kemetli L, Lynge E, et al. Breast cancer incidence and mortality in the Nordic capitals, 1970-1998. Trends related to mammography screening programmes. Acta Oncol. 2006;45(5):528-35. [pmid: 16864165].
Ugarte MD, Goicoa T, Etxeberria J, et al. Age-specific spatio-temporal patterns of female breast cancer mortality in Spain (1975-2005). Ann Epidemiol. 2010;20(12):906-16. [pmid: 21074105].

#### Njor et al, 2012

Anttila A, Koskela J, Hakama M. Programme sensitivity and effectiveness of mammography service screening in Helsinki, Finland. J Med Screen. 2002;9(4):153-8. [pmid: 12518004].
Anttila A, Sarkeala T, Hakulinen T, et al. Impacts of the Finnish service screening programme on breast cancer rates. BMC Public Health. 2008:8. [pmid: 18184424].
Ascunce EN, Moreno-Iribas C, Urtiaga AB, et al. Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 2007;14(1):14-20. [pmid: 17362566].
Baker SG, Kramer BS, Prorok PC. Comparing breast cancer mortality rates before-and-after a change in availability of screening in different regions: Extension of the paired availability design. BMC Med Res Methodol. 2004;4:12-20. [pmid: 15149551].
Chen LS, Yen AMF, Duffy SW, et al. Computer-aided system of evaluation for population-based all-in-one service screening (CASE-PASS): From study design to outcome analysis with bias adjustment. Ann Epidemiol. 2010;20(10):786-96. [pmid: 20816316].
Duffy SW, Tabár L, Chen HH, et al. The impact of organized mammography service screening on breast carcinoma mortality in seven Swedish Counties: A collaborative evaluation. Cancer. 2002;95(3):458-69. [pmid: 12209737].
Hakama M, Pukkala E, Heikkila M, et al. Effectiveness of the public health policy for breast cancer screening in Finland: Population based cohort study. Br Med J. 1997;314(7084):864-7. [pmid: 9093096].
Jonsson H, Bordás P, Wallin H, et al. Service screening with mammography in Northern Sweden: Effects on breast cancer mortality - An update. J Med Screen. 2007;14(2):87-93. [pmid: 17626708].
Jonsson H, Nyström L, Törnberg S, et al. Service screening with mammography of women aged 50-69 years in sweden: Effects on mortality from breast cancer. J Med Screen. 2001;8(3):152-60. [pmid: 11678556].
Jonsson H, Nyström L, Törnberg S, et al. Service screening with mammography. Long-term effects on breast cancer mortality in the county of Gävleborg, Sweden. Breast. 2003;12(3):183-93. [pmid: 14659325].
Kalager M, Zelen M, Langmark F, et al. Effect of screening mammography on breast-cancer mortality in Norway. N Engl J Med. 2010;363(13):1203-10. [pmid: 20860502].
Olsen AH, Njor SH, Vejborg I, et al. Breast cancer mortality in Copenhagen after introduction of mammography screening: Cohort study. Br Med J. 2005;330(7485):220-2. [pmid: 15649904].
Paci E, Duffy SW, Giorgi D, et al. Quantification of the effect of mammographic screening on fatal breast cancers: The Florence Programme 1990-96. Br J Cancer. 2002;87(1):65-9. [pmid: 12085258].
Paci E, Giorgi D, Bianchi S, et al. Assessment of the early impact of the population-based breast cancer screening programme in Florence (Italy) using mortality and surrogate measures. Eur J Cancer. 2002;38(4):568-73. [pmid: 11872351].
Parvinen I, Helenius H, Pylkkänen L, et al. Service screening mammography reduces breast cancer mortality among elderly women in Turku. J Med Screen. 2006;13(1):34-40. [pmid: 16569304].
Sarkeala T, Heinävaara S, Anttila A. Breast cancer mortality with varying invitational policies in organised mammography. Br J Cancer. 2008;98(3):641-5. [pmid: 18231108].
Sarkeala T, Heinävaara S, Anttila A. Organised mammography screening reduces breast cancer mortality: A cohort study from Finland. Int J Cancer. 2008;122(3):614-9. [pmid: 17847022].
Swedish Organised Service Screening Evaluation G. Reduction in breast cancer mortality from organized service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiology, Biomarkers & Prevention. 2006;15(1):45-51.
Tabár L, Vitak B, Tonychen HH, et al. Beyond randomized controlled trials: Organized mammographic screening substantially reduces breast carcinoma mortality. Cancer. 2001;91(9):1724-31. [pmid: 11335897].
Wu JCY, Anttila A, Yen AMF, et al. Evaluation of breast cancer service screening programme with a Bayesian approach: Mortality analysis in a Finnish region. Breast Cancer Res Treat. 2010;121(3):671-8. [pmid: 19890708].

### Key Question 5 What are the harms of routine mammography screening, and how do they differ by age, risk factor, and screening interval?

#### Psychological Harms

##### Bond et al, 2013

Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. [pmid: 11873891].
Brett J, Austoker J, Ong G. Do women who undergo further investigation for breast screening suffer adverse psychological consequences? A multi-centre follow-up study comparing different breast screening result groups five months after their last breast screening appointment. J Public Health Med. 1998;20(4):396-403. [pmid: 9923945].
Bull AR, Cambell MJ. Assessment of the physiological impact of a breast screening programme. Br J Radiol. 1991;64(762):510-5. [pmid: 2070180].
Ellman R, Angeli N, Christians A, et al. Psychiatric morbidity associated with screening for breast cancer. Br J Cancer. 1989;60(5):781-4. [pmid: 2803955].
McCann J, Stockton D, Godward S. Impact of false-positive mammography on subsequent screening attendance and risk of cancer. Breast Cancer Res. 2002;4(5).
Meldrum P, Turnbull D, Dobson HM, et al. Tailored written invitations for second round breast cancer screening: a randomised controlled trial. J Med Screen. 1994;1(4):245-8. [pmid: 8790529].
Ong G, Austoker J, Brett J. Breast screening: Adverse psychological consequences one month after placing women on early recall because of a diagnostic uncertainty. A multicentre study. J Med Screen. 1997;4(3):158-68. [pmid: 9368874].
Orton M, Fitzpatrick R, Fuller A, et al. Factors affecting women's response to an invitation to attend for a second breast cancer screening examination. Br J Gen Pract. 1991;41(349):320-2. [pmid: 1777275].
O'Sullivan I, Sutton S, Dixon S, et al. False positive results do not have a negative effect on reattendance for subsequent breast screening. J Med Screen. 2001;8(3):145-8. [pmid: 11678554].

##### Hafslund and Nortvedt, 2009

Absetz P, Aro AR, Sutton SR. Experience with breast cancer, pre-screening perceived susceptibility and the psychological impact of screening. Psychooncology. 2003;12(4):305-18. [pmid: 12748969].
Aro AR, Pilvikki Absetz S, Van Elderen TM, et al. False-positive findings in mammography screening induces short-term distress - Breast cancer-specific concern prevails longer. Eur J Cancer. 2000;36(9):1089-97. [pmid: 10854941].
Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. [pmid: 11873891].
Brett J, Austoker J. Development and validation of the EBS: A measure to assess women's experience at all stages of the breast screening process. J Public Health. 2004;26(1):79-83.
Gilbert FJ, Cordiner CM, Affleck IR, et al. Breast screening: The psychological sequelae of false-positive recall in women with and without a family history of breast cancer. Eur J Cancer. 1998;34(13):2010-4. [pmid: 10070302].
Hislop TG, Harris SR, Jackson J, et al. Satisfaction and anxiety for women during investigation of an abnormal screening mammogram. Breast Cancer Res Treat. 2002;76(3):245-54. [pmid: 12462385].
Johnston K, Brown J, Gerard K, et al. Valuing temporary and chronic health states associated with breast screening. Soc Sci Med. 1998;47(2):213-22. [pmid: 9720640].
Lampic C, Thurfjell E, Bergh J, et al. Short- and long-term anxiety and depression in women recalled after breast cancer screening. Eur J Cancer. 2001;37(4):463-9. [pmid: 11267855].
Lampic C, Thurfjell E, Sjödén PO. The influence of a false-positive mammogram on a woman's subsequent behaviour for detecting breast cancer. Eur J Cancer. 2003;39(12):1730-7. [pmid: 12888368].
Lipkus IM, Halabi S, Strigo TS, et al. The impact of abnormal mammograms on psychosocial outcomes and subsequent screening. Psychooncology. 2000;9(5):402-10. [pmid: 11038478].
Lowe JB, Balanda KP, Del Mar C, et al. Psychologic distress in women with abnormal findings in mass mammography screening. Cancer. 1999;85(5):1114-8. [pmid: 10091796].
Meystre-Agustoni G, Paccaud F, Jeannin A, et al. Anxiety in a cohort of Swiss women participating in a mammographic screening programme. J Med Screen. 2001;8(4):213-9. [pmid: 11743038].
Pineault P. Breast cancer screening: women's experiences of waiting for further testing. Oncol Nurs Forum. 2007;34(4):847-53. [pmid: 17723985].
Sandin B, Chorot P, Valiente RM, et al. Adverse psychological effects in women attending a second-stage breast cancer screening. J Psychosom Res. 2002;52(5):303-9. [pmid: 12023127].
Scaf-Klomp W, Sanderman R, Van De Wiel HBM, et al. Distressed or relieved? Psychological side effects of breast cancer screening in the Netherlands. J Epidemiol Community Health. 1997;51(6):705-10. [pmid: 9519137].
Sutton S, Saidi G, Bickler G, et al. Does routine screening for breast cancer raise anxiety? Results from a three wave prospective study in England. J Epidemiol Community Health. 1995;49(4):413-8. [pmid: 7650466].
Swanson V, McIntosh IB, Power KG, et al. The psychological effects of breast screening in terms of patients' perceived health anxieties. Br J Clin Pract. 1996;50(3):129-35. [pmid: 8733330].

##### Brewer et al, 2007

Aro AR, Pilvikki Absetz S, Van Elderen TM, et al. False-positive findings in mammography screening induces short-term distress - Breast cancer-specific concern prevails longer. Eur J Cancer. 2000;36(9):1089-97. [pmid: 10854941].
Barton MB, Morley DS, Moore S, et al. Decreasing women's anxieties after abnormal mammograms: A controlled trial. J Natl Cancer Inst. 2004;96(7):529-38. [pmid: 15069115].
Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. [pmid: 11873891].
Brett J, Austoker J, Ong G. Do women who undergo further investigation for breast screening suffer adverse psychological consequences? A multi-centre follow-up study comparing different breast screening result groups five months after their last breast screening appointment. J Public Health Med. 1998;20(4):396-403. [pmid: 9923945].
Bull AR, Cambell MJ. Assessment of the physiological impact of a breast screening programme. Br J Radiol. 1991;64(762):510-5. [pmid: 2070180].
Burman ML, Taplin SH, Herta DF, et al. Effect of false-positive mammograms on interval breast cancer screening in a health maintenance organization. Ann Intern Med. 1999;131(1):1-6. [pmid: 10391809].
Chiarelli AM, Moravan V, Halapy E, et al. False-positive result and reattendance in the Ontario Breast Screening Program. J Med Screen. 2003;10(3):129-33. [pmid: 14561264].
Cockburn J, Staples M, Hurley SF, et al. Psychological consequences of screening mammography. J Med Screen. 1994;1(1):7-12. [pmid: 8790480].
Ellman R, Angeli N, Christians A, et al. Psychiatric morbidity associated with screening for breast cancer. Br J Cancer. 1989;60(5):781-4. [pmid: 2803955].
Gram IT, Lund E, Slenker SE. Quality of life following a false positive mammogram. Br J Cancer. 1990;62(6):1018-22. [pmid: 2257206].
Hofvind SSH, Wang H, Thoresen S. The Norwegian breast cancer screening program: Re-attendance related to the women's experiences, intentions and previous screening result. Cancer Causes Control. 2003;14(4):391-8. [pmid: 12846372].
Jatoi I, Zhu K, Shah M, et al. Psychological distress in U.S. women who have experienced false-positive mammograms. Breast Cancer Res Treat. 2006;100(2):191-200. [pmid: 16773439].
Johnson MM, Hislop TG, Kan L, et al. Compliance with the screening mammography program of British Columbia: Will she return?. Can J Public Health. 1996;87(3):176-80. [pmid: 8771920].
Lampic C, Thurfjell E, Bergh J, et al. Short- and long-term anxiety and depression in women recalled after breast cancer screening. Eur J Cancer. 2001;37(4):463-9. [pmid: 11267855].
Lampic C, Thurfjell E, Sjödén PO. The influence of a false-positive mammogram on a woman's subsequent behaviour for detecting breast cancer. Eur J Cancer. 2003;39(12):1730-7. [pmid: 12888368].
Lerman C, Trock B, Rimer BK, et al. Psychological and behavioral implications of abnormal mammograms. Ann Intern Med. 1991;114(8):657-61. [pmid: 2003712].
Lerman C, Trock B, Rimer BK, et al. Psychological side effects of breast cancer screening. Health Psychol. 1991;10(4):259-67. [pmid: 1915212].
Lipkus IM, Halabi S, Strigo TS, et al. The impact of abnormal mammograms on psychosocial outcomes and subsequent screening. Psychooncology. 2000;9(5):402-10. [pmid: 11038478].
McCann J, Stockton D, Godward S. Impact of false-positive mammography on subsequent screening attendance and risk of cancer. Breast Cancer Res. 2002;4(5).
Meystre-Agustoni G, Paccaud F, Jeannin A, et al. Anxiety in a cohort of Swiss women participating in a mammographic screening programme. J Med Screen. 2001;8(4):213-9. [pmid: 11743038].
Olsson P, Armelius K, Nordahl G, et al. Women with false positive screening mammograms: How do they cope?. J Med Screen. 1999;6(2):89-93. [pmid: 10444727].
Ong G, Austoker J, Brett J. Breast screening: Adverse psychological consequences one month after placing women on early recall because of a diagnostic uncertainty. A multicentre study. J Med Screen. 1997;4(3):158-68. [pmid: 9368874].
O'Sullivan I, Sutton S, Dixon S, et al. False positive results do not have a negative effect on reattendance for subsequent breast screening. J Med Screen. 2001;8(3):145-8. [pmid: 11678554].
Pinckney RG, Geller BM, Burman M, et al. Effect of false-positive mammograms on return for subsequent screening mammography. Am J Med. 2003;114(2):120-5. [pmid: 12586231].
Pisano ED, Earp J, Schell M, et al. Screening behavior of women after a false-positive mammogram. Radiology. 1998;208(1):245-9. [pmid: 9646820].
Sandin B, Chorot P, Valiente RM, et al. Adverse psychological effects in women attending a second-stage breast cancer screening. J Psychosom Res. 2002;52(5):303-9. [pmid: 12023127].
Scaf-Klomp W, Sanderman R, Van De Wiel HBM, et al. Distressed or relieved? Psychological side effects of breast cancer screening in the Netherlands. J Epidemiol Community Health. 1997;51(6):705-10. [pmid: 9519137].

##### Brett et al, 2005

Absetz P, Aro AR, Sutton SR. Experience with breast cancer, pre-screening perceived susceptibility and the psychological impact of screening. Psychooncology. 2003;12(4):305-18. [pmid: 12748969].
Aro AR, Pilvikki Absetz S, Van Elderen TM, et al. False-positive findings in mammography screening induces short-term distress - Breast cancer-specific concern prevails longer. Eur J Cancer. 2000;36(9):1089-97. [pmid: 10854941].
Austoker J, Ong G. Written information needs of women who are recalled for further investigation of breast screening: results of a multicentre study. J Med Screen. 1994;1(4):238-44. [pmid: 8790528].
Baines CJ, To T, Wall C. Women's attitudes to screening after participation in the National breast screening study. A questionnaire survey. Cancer. 1990;65(7):1663-9. [pmid: 2311075].
Bakker DA, Lightfoot NE, Steggles S, et al. The experience and satisfaction of women attending breast cancer screening. Oncol Nurs Forum. 1998;25(1):115-21. [pmid: 9460779].
Barton MB, Moore S, Polk S, et al. Increased patient concern after false-positive mammograms: Clinician documentation and subsequent ambulatory visits. J Gen Intern Med. 2001;16(3):150-6. [pmid: 11318909].
Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. [pmid: 11873891].
Brett J, Austoker J, Ong G. Do women who undergo further investigation for breast screening suffer adverse psychological consequences? A multi-centre follow-up study comparing different breast screening result groups five months after their last breast screening appointment. J Public Health Med. 1998;20(4):396-403. [pmid: 9923945].
Bull AR, Cambell MJ. Assessment of the physiological impact of a breast screening programme. Br J Radiol. 1991;64(762):510-5. [pmid: 2070180].
Chen CC, David A, Thompson K, et al. Coping strategies and psychiatric morbidity in women attending breast assessment clinics. J Psychosom Res. 1996;40(3):265-70. [pmid: 8861122].
Cockburn J, De Luise T, Hurley S, et al. Development and validation of the PCQ: A questionnaire to measure the psychological consequences of screening mammography. Soc Sci Med. 1992;34(10):1129-34. [pmid: 1641674].
Cockburn J, Staples M, Hurley SF, et al. Psychological consequences of screening mammography. J Med Screen. 1994;1(1):7-12. [pmid: 8790480].
Dean C, Roberts MM, French K, et al. Psychiatric morbidity after screening for breast cancer. J Epidemiol Community Health. 1986;40(1):71-5. [pmid: 3711771].
Dolan NC, Feinglass J, Priyanath A, et al. Measuring satisfaction with mammography results reporting. J Gen Intern Med. 2001;16(3):157-62. [pmid: 11318910].
Donato F, Bollani A, Spiazzi R, et al. Factors associated with non-participation of women in a breast cancer screening programme in a town in northern Italy. J Epidemiol Community Health. 1991;45(1):59-64. [pmid: 2045747].
Drossaert CHC, Boer H, Seydel ER. Does mammographic screening and a negative result affect attitudes towards future breast screening?. J Med Screen. 2001;8(4):204-12. [pmid: 11743037].
Drossaert CHC, Boer H, Seydel ER. Monitoring women's experiences during three rounds of breast cancer screening: Results from a longitudinal study. J Med Screen. 2002;9(4):168-75. [pmid: 12518007].
Eardley A, Elkind A. A pilot study of attendance for breast cancer screening. Soc Sci Med. 1990;30(6):693-9. [pmid: 2315738].
Ekeberg Ø, Skjauff H, Kåresen R. Screening for breast cancer is associated with a low degree of psychological distress. Breast. 2001;10(1):20-4. [pmid: 14965553].
Ellman R, Angeli N, Christians A, et al. Psychiatric morbidity associated with screening for breast cancer. Br J Cancer. 1989;60(5):781-4. [pmid: 2803955].
Fallofield LJ, Rodway A, Baum M. What are the psychological factors influencing attendance, non-attendance and re-attendance at a breast screening centre?. J R Soc Med. 1990;83(9):547-51. [pmid: 2213798].
Gilbert FJ, Cordiner CM, Affleck IR, et al. Breast screening: The psychological sequelae of false-positive recall in women with and without a family history of breast cancer. Eur J Cancer. 1998;34(13):2010-4. [pmid: 10070302].
Gram IT, Lund E, Slenker SE. Quality of life following a false positive mammogram. Br J Cancer. 1990;62(6):1018-22. [pmid: 2257206].
Haas J, Kaplan C, McMillan A, et al. Does timely assessment affect the anxiety associated with an abnormal mammogram result?. J Womens Health Gend Based Med. 2001;10(6):599-605. [pmid: 11559457].
Kelly P, Winslow EH. Needle wire localization for nonpalpable breast lesions: sensations, anxiety levels, and informational needs. Oncol Nurs Forum. 1996;23(4):639-45. [pmid: 8735322].
Lampic C, Thurfjell E, Bergh J, et al. Short- and long-term anxiety and depression in women recalled after breast cancer screening. Eur J Cancer. 2001;37(4):463-9. [pmid: 11267855].
Lampic C, Thurfjell E, Sjödén PO. The influence of a false-positive mammogram on a woman's subsequent behaviour for detecting breast cancer. Eur J Cancer. 2003;39(12):1730-7. [pmid: 12888368].
Lerman C, Rimer B, Trock B, et al. Factors associated with repeat adherence to breast cancer screening. Prev Med. 1990;19(3):279-90. [pmid: 2377590].
Lerman C, Trock B, Rimer BK, et al. Psychological and behavioral implications of abnormal mammograms. Ann Intern Med. 1991;114(8):657-61. [pmid: 2003712].
Lidbrink E, Levi L, Pettersson I, et al. Single-view screening mammography: psychological, endocrine and immunological effects of recalling for a complete three-view examination. Eur J Cancer. 1995;31(6):932-3. [pmid: 7646925].
Lightfoot NE, Steggles S, Barker D, et al. The short-term psychological impact of organised breast cancer screening. Curr Oncol. 1994;1:206-11.
Lindfors KK, O'Connor J, Parker RA. False-positive screening mammograms: Effect of immediate versus later work-up on patient stress. Radiology. 2001;218(1):247-53. [pmid: 11152810].
Loken K, Steine S, Laerum E. Mammography: Influence of departmental practice and women's characteristics on patient satisfaction: Comparison of six departments in Norway. Qual Health Care. 1998;7(3):136-41. [pmid: 10185139].
Lowe JB, Balanda KP, Del Mar C, et al. Psychologic distress in women with abnormal findings in mass mammography screening. Cancer. 1999;85(5):1114-8. [pmid: 10091796].
Maclean U, Sinfield D, Klein S, et al. Women who decline breast screening. J Epidemiol Community Health. 1984;38(4):278-83. [pmid: 6512479].
Mainiero MB, Schepps B, Clements NC, et al. Mammography-related anxiety: Effect of preprocedural patient education. Womens Health Issues. 2001;11(2):110-5. [pmid: 11275514].
Marshall G. A comparative study of re-attenders and non-re-attenders for second triennial national breast screening programme appointments. J Public Health Med. 1994;16(1):79-86. [pmid: 8037957].
McNoe B, Richardson AK, Elwood JM. Factors affecting participation in mammography screening. N Z Med J. 1996;109(1030):359-61. [pmid: 8890861].
Meystre-Agustoni G, Paccaud F, Jeannin A, et al. Anxiety in a cohort of Swiss women participating in a mammographic screening programme. J Med Screen. 2001;8(4):213-9. [pmid: 11743038].
Michielutte R, Dignan MB, Smith BL. Psychosocial factors associated with the use of breast cancer screening by women age 60 years or over. Health Educ Behav. 1999;26(5):625-47. [pmid: 10533169].
Nielsen CC. Women's use of mammographic screening: the role of information, cues, and reinforcement. Conn Med. 1990;54(7):374-7. [pmid: 2394097].
Ong G, Austoker J. Recalling women for further investigation of breast screening: Women's experiences at the clinic and afterwards. J Public Health Med. 1997;19(1):29-36. [pmid: 9138214].
Ong G, Austoker J, Brett J. Breast screening: Adverse psychological consequences one month after placing women on early recall because of a diagnostic uncertainty. A multicentre study. J Med Screen. 1997;4(3):158-68. [pmid: 9368874].
Sandin B, Chorot P, Valiente RM, et al. Adverse psychological effects in women attending a second-stage breast cancer screening. J Psychosom Res. 2002;52(5):303-9. [pmid: 12023127].
Scaf-Klomp W, Sanderman R, Van De Wiel HBM, et al. Distressed or relieved? Psychological side effects of breast cancer screening in the Netherlands. J Epidemiol Community Health. 1997;51(6):705-10. [pmid: 9519137].
Stein JA, Fox SA, Murata PJ. The influence of ethnicity, socioeconomic status, and psychological barriers on use of mammography. J Health Soc Behav. 1991;32(2):101-13. [pmid: 1861047].
Sutton S, Saidi G, Bickler G, et al. Does routine screening for breast cancer raise anxiety? Results from a three wave prospective study in England. J Epidemiol Community Health. 1995;49(4):413-8. [pmid: 7650466].
Swanson V, McIntosh IB, Power KG, et al. The psychological effects of breast screening in terms of patients' perceived health anxieties. Br J Clin Pract. 1996;50(3):129-35. [pmid: 8733330].
Thorne SE, Harris SR, Hislop TG, et al. The experience of waiting for diagnosis after an abnormal mammogram. Breast J. 1999;5(1):42-51. [pmid: 11348255].
Walker LG, Cordiner CM, Gilbert FJ, et al. How distressing is attendance for routine breast screening?. Psychooncology. 1994;3(4):299-304.
Walter LC, Eng C, Covinsky KE. Screening mammography for frail older women: What are the burdens?. J Gen Intern Med. 2001;16(11):779-84. [pmid: 11722693].
Weller A, Hener T. Invasiveness of medical procedures and state anxiety in women. Behav Med. 1993;19(2):60-5. [pmid: 8280963].

#### Pain from Mammography

##### Whelehan et al, 2013

Aro AR, Absetz-Ylöstalo P, Eerola T, et al. Pain and discomfort during mammography. Eur J Cancer. 1996;32(10):1674-9. [pmid: 8983273].
Bennett IC, Robert DA, Osborne JM, et al. Discomfort during mammography: A survey of women attending a breast screening center. Breast Dis. 1994;7(1):35-41.
Conlon M, Lightfoot N, Bissett R, et al. Predictors of re-attendance at an organised breast screening centre. Curr Oncol. 1998;5(2):85-90.
Drossaert CHC, Boer H, Seydel ER. Health education to improve repeat participation in the Dutch breast cancer screening programme: Evaluation of a leaflet tailored to previous participants. Patient Educ Couns. 1996;28(2):121-31. [pmid: 8852086].
Drossaert CHC, Boer H, Seydel ER. Does mammographic screening and a negative result affect attitudes towards future breast screening?. J Med Screen. 2001;8(4):204-12. [pmid: 11743037].
Drossaert CHC, Boer H, Seydel ER. Monitoring women's experiences during three rounds of breast cancer screening: Results from a longitudinal study. J Med Screen. 2002;9(4):168-75. [pmid: 12518007].
Dullum JR, Lewis EC, Mayer JA. Rates and correlates of discomfort associated with mammography. Radiology. 2000;214(2):547-52. [pmid: 10671609].
Edwards SA, Chiarelli AM, Ritvo P, et al. Satisfaction with initial screen and compliance with biennial breast screening at centers with and without nurses. Cancer Nurs. 2011;34(4):293-301. [pmid: 21681146].
Elwood M, McNoe B, Smith I, et al. Once is enough - Why some women do not continue to participate in a breast cancer screening programme. N Z Med J. 1998;111(1066):180-3. [pmid: 9640316].
Hofvind SSH, Wang H, Thoresen S. The Norwegian breast cancer screening program: Re-attendance related to the women's experiences, intentions and previous screening result. Cancer Causes Control. 2003;14(4):391-8. [pmid: 12846372].
Keemers-Gels ME, Groenendijk RPR, Van Den Heuvel JHM, et al. Pain experienced by women attending breast cancer screening. Breast Cancer Res Treat. 2000;60(3):235-40. [pmid: 10930111].
Marshall G. A comparative study of re-attenders and non-re-attenders for second triennial national breast screening programme appointments. J Public Health Med. 1994;16(1):79-86. [pmid: 8037957].
Mullai N, Murugesan N, Burton L, et al. Risk of non-compliance due to patient discomfort during screening mammogram. J Clin Oncol. 2009;27(15 SUPPL. 1):1522. [pmid: 19171704].
Orton M, Fitzpatrick R, Fuller A, et al. Factors affecting women's response to an invitation to attend for a second breast cancer screening examination. Br J Gen Pract. 1991;41(349):320-2. [pmid: 1777275].
Papas MA, Klassen AC. Pain and discomfort associated with mammography among urban low-income African-American women. J Community Health. 2005;30(4):253-67. [pmid: 15989208].
Peipins LA, Shapiro JA, Bobo JK, et al. Impact of women's experiences during mammography on adherence to rescreening (United States). Cancer Causes Control. 2006;17(4):439-47. [pmid: 16596296].
Rutter DR, Calnan M, Field S, et al. Predicting reattendance in the second round of the UK National Breast Screening Programme: A prospective 3-year longitudinal analysis. Breast. 1997;6(3):120-5.
Scaf-Klomp W, Van Sonderen E, Van Den Heuvel W. Compliance after 17 years of breast cancer screening: Factors associated with reattendance for periodic breast screening. Eur J Public Health. 1997;7(2):182-7.
Tsai HW, Twu NF, Ko CC, et al. Compliance with screening mammography and breast sonography of young Asian women. Eur J Obstet Gynecol Reprod Biol. 2011;157(1):89-93. [pmid: 21439713].
Yankaskas BC, Dickens P, Michael Bowling J, et al. Barriers to adherence to screening mammography among women with disabilities. Am J Public Health. 2010;100(5):947-53. [pmid: 19834002].

##### Armstrong et al, 2007

Aro AR, Absetz-Ylöstalo P, Eerola T, et al. Pain and discomfort during mammography. Eur J Cancer. 1996;32(10):1674-9. [pmid: 8983273].
Bakker DA, Lightfoot NE, Steggles S, et al. The experience and satisfaction of women attending breast cancer screening. Oncol Nurs Forum. 1998;25(1):115-21. [pmid: 9460779].
Baskin-Smith J, Miaskowski C, Dibble SL, et al. Perceptions of the mammography experience. Cancer Nurs. 1995;18(1):47-52. [pmid: 7866976].
Brew MD, Billings JD, Chisholm RJ. Mammography and breast pain. Australas Radiol. 1989;33(4):335-6. [pmid: 2633733].
Bruyninckx E, Mortelmans D, Van Goethem M, et al. Risk factors of pain in mammographic screening. Soc Sci Med. 1999;49(7):933-41. [pmid: 10468397].
Cockburn J, Cawson J, Hill D, et al. An analysis of reported discomfort caused by mammographic X-ray amongst attenders at an Australian pilot breast screening program. Australas Radiol. 1992;36(2):115-9. [pmid: 1520168].
Dibble SL, Israel J, Nussey B, et al. Mammography with breast cushions. Womens Health Issues. 2005;15(2):55-63. [pmid: 15767195].
Domar AD, Eyvazzadeh A, Allen S, et al. Relaxation techniques for reducing pain and anxiety during screening mammography. AJR Am J Roentgenol. 2005;184(2):445-7. [pmid: 15671361].
Dullum JR, Lewis EC, Mayer JA. Rates and correlates of discomfort associated with mammography. Radiology. 2000;214(2):547-52. [pmid: 10671609].
Jackson VP, Lex AM, Smith DJ. Patient discomfort during screen-film mammography. Radiology. 1988;168(2):421-3. [pmid: 3393659].
Kashikar-Zuck S, Keefe FJ, Kornguth P, et al. Pain coping and the pain experience during mammography: A preliminary study. Pain. 1997;73(2):165-72. [pmid: 9415502].
Keemers-Gels ME, Groenendijk RPR, Van Den Heuvel JHM, et al. Pain experienced by women attending breast cancer screening. Breast Cancer Res Treat. 2000;60(3):235-40. [pmid: 10930111].
Kornguth PJ, Keefe FJ, Wright KR, et al. Mammography pain in women treated conservatively for breast cancer. J Pain. 2000;1(4):268-74. [pmid: 14622609].
Leaney BJ, Martin M. Breast pain associated with mammographic compression. Australas Radiol. 1992;36(2):120-3. [pmid: 1520169].
Markle L, Roux S, Sayre JW. Reduction of discomfort during mammography utilizing a radiolucent cushioning pad. Breast J. 2004;10(4):345-9. [pmid: 15239794].
Nielsen BB, Miaskowski C, Dibble SL, et al. Pain and discomfort associated with film-screen mammography. J Natl Cancer Inst. 1991;83(23):1754-6. [pmid: 1770555].
Roworth MA, McIlwaine GM, Wallace AM. Women's views of the Scottish Breast Screening Programme: A national consumer opinion survey. Public Health. 1993;107(3):185-92. [pmid: 8511238].
Rutter DR, Calnan M, Vaile MSB, et al. Discomfort and pain during mammography: Description, prediction, and prevention. Br Med J. 1992;305(6851):443-5. [pmid: 1392955].
Sapir R, Patlas M, Strano SD, et al. Does mammography hurt?. J Pain Symptom Manage. 2003;25(1):53-63. [pmid: 12565189].
Sharp PC, Michielutte R, Freimanis R, et al. Reported pain following mammography screening. Arch Intern Med. 2003;163(7):833-6. [pmid: 12695274].
Stomper PC, Kopans DB, Sadowsky NL, et al. Is mammography painful? A multicenter patient survey. Arch Intern Med. 1988;148(3):521-4. [pmid: 3341852].
Walter LC, Eng C, Covinsky KE. Screening mammography for frail older women: What are the burdens?. J Gen Intern Med. 2001;16(11):779-84. [pmid: 11722693].

##### Miller et al, 2008

Alimoglu E, Alimoglu MK, Kabaalioglu A, et al. Mammography-related pain and anxiety. Tani Girisim Radyol. 2004;10(3):213-7. [pmid: 15470624].
Dibble SL, Israel J, Nussey B, et al. Mammography with breast cushions. Womens Health Issues. 2005;15(2):55-63. [pmid: 15767195].
Kornguth PJ, Rimer BK, Conaway MR, et al. Impact of patient-controlled compression on the mammography experience. Radiology. 1993;186(1):99-102. [pmid: 8416595].
Lambertz CK. Pre-medication with Acetaminophen for Screening Mammography. Gonzaga University. 1998.
Poulos A, Rickard M. Compression in mammography and the perception of discomfort. Australas Radiol. 1997;41(3):247-52. [pmid: 9293675].
Shrestha S, Poulos A. The effect of verbal information on the experience of discomfort in mammography. Radiography. 2001;7(4):271-7.
Sjolin M, Maerker M. Effects of information on and reflection of women's pain experience during mammography. Vard Nord Utveckl Forsk. 1994;14(1):11-5. [pmid: 7941212].

#### Overdiagnosis

##### Marmot et al, 2013

Gøtzsche PC, Nielsen M. Screening for breast cancer with mammography. Cochrane database of systematic reviews (Online). 2011:1.
Miller AB, To T, Baines CJ, et al. Canadian National Breast Screening Study-2: 13-year results of a randomized trial in women aged 50-59 years. J Natl Cancer Inst. 2000;92(18):1490-9. [pmid: 10995804].
Miller AB, To T, Baines CJ, et al. The Canadian National Breast Screening Study-1: breast cancer mortality after 11 to 16 years of follow-up. A randomized screening trial of mammography in women age 40 to 49 years. Ann Intern Med. 2002;137(5 Part 1):305-12. [pmid: 12204013].
Nyström L, Andersson I, Bjurstam N, et al. Long-term effects of mammography screening: Updated overview of the Swedish randomised trials. Lancet. 2002;359(9310):909-19. [pmid: 11918907].
Tabár L, Vitak B, Chen THH, et al. Swedish two-county trial: Impact of mammographic screening on breast cancer mortality during 3 decades. Radiology. 2011;260(3):658-63. [pmid: 21712474].
Zackrisson S, Andersson I, Janzon L, et al. Rate of over-diagnosis of breast cancer 15 years after end of Malmö mammographic screening trial: follow-up study. BMJ. 2006;332(7543):689-92. [pmid: 16517548].

##### Moss, 2005

Alexander FE, Anderson TJ, Brown HK, et al. The Edinburgh randomised trial of breast cancer screening: results after 10 years of follow-up. Br J Cancer. 1994;70(3):542-8. [pmid: 8080744].
Andersson I, Aspegren K, Janzon L, et al. Mammographic screening and mortality from breast cancer: The Malmo mammographic screening trial. Br Med J. 1988;297(6654):943-8. [pmid: 3142562].
Frisell J, Lidbrink E, Hellström L, et al. Followup after 11 years - Update of mortality results in the Stockholm mammographic screening trial. Breast Cancer Res Treat. 1997;45(3):263-70. [pmid: 9386870].
Miller AB, Baines CJ, To T, et al. Canadian National Breast Screening Study: 2. Breast cancer detection and death rates among women aged 50 to 59 years. CMAJ. 1992;147(10):1477-88. [pmid: 1423088].
Miller AB, Baines CJ, To T, et al. Canadian National Breast Screening Study: 1. Breast cancer detection and death rates among women aged 40 to 49 years. CMAJ. 1992;147(10):1459-76. [pmid: 1423087].
Miller AB, To T, Baines CJ, et al. Canadian national breast screening study-2: 13-Year results of a randomized trial in women aged 50-59 years. J Natl Cancer Inst. 2000;92(18):1490-9. [pmid: 10995804].
Shapiro S, Venet W, Strax P, et al. Ten- to fourteen-year effect of screening on breast cancer mortality. J Natl Cancer Inst. 1982;69(2):349-55. [pmid: 6955542].
Tabár L, Gad A, Holmberg LH, et al. Reduction in mortality from breast cancer after mass screening with mammography. Randomised Trial from the Breast Cancer Screening Working Group of the Swedish National Board of Health and Welfare. The Lancet. 1985;325(8433):829-32.

##### Puliti et al, 2012

De Gelder R, Heijnsdijk EAM, Van Ravesteyn NT, et al. Interpreting overdiagnosis estimates in population-based mammography screening. Epidemiologic Reviews. 2011;33(1):111-21. [pmid: 21709144].
Duffy SW, Tabar L, Olsen AH, et al. Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J Med Screen. 2010;17(1):25-30. [pmid: 20356942].
Jonsson H, Johansson R, Lenner P. Increased incidence of invasive breast cancer after the introduction of service screening with mammography in Sweden. Int J Cancer. 2005;117(5):842-7. [pmid: 15957172].
Jørgensen KJ, Gøtzsche PC. Overdiagnosis in publicly organised mammography screening programmes: Systematic review of incidence trends. BMJ. 2009:339.
Jørgensen KJ, Zahl PH, Gøtzsche PC. Overdiagnosis in organised mammography screening in Denmark. A comparative study. BMC Women's Health. 2009:9. [pmid: 19379514].
Martinez-Alonso M, Vilaprinyo E, Marcos-Gragera R, et al. Breast cancer incidence and overdiagnosis in Catalonia (Spain). Breast Cancer Research. 2010;12:4.
Olsen AH, Agbaje OF, Myles JP, et al. Overdiagnosis, sojourn time, and sensitivity in the Copenhagen mammography screening program. Breast J. 2006;12(4):338-42. [pmid: 16848843].
Paci E, Miccinesi G, Puliti D, et al. Estimate of overdiagnosis of breast cancer due to mammography after adjustment for lead time. A service screening study in Italy. Breast Cancer Research. 2006;8:6.
Paci E, Warwick J, Falini P, et al. Overdiagnosis in screening: Is the increase in breast cancer incidence rates a cause for concern?. J Med Screen. 2004;11(1):23-7. [pmid: 15006110].
Peeters PHM, Verbeek ALM, Straatman H, et al. Evaluation of overdiagnosis of breast cancer in screening with mammography: Results of the Nijmegen programmme. International Journal of Epidemiology. 1989;18(2):295-9. [pmid: 2788627].
Puliti D, Zappa M, Miccinesi G, et al. An estimate of overdiagnosis 15 years after the start of mammographic screening in Florence. Eur J Cancer. 2009;45(18):3166-71. [pmid: 19879130].
Waller M, Moss S, Watson J, et al. The effect of mammographic screening and hormone replacement therapy use on breast cancer incidence in England and Wales. Cancer Epidemiol Biomarkers Prev. 2007;16(11):2257-61. [pmid: 18006913].
Zahl PH, Strand BH, Mæshlen J. Incidence of breast cancer in Norway and Sweden during introduction of nationwide screening: Prospective cohort study. Br Med J. 2004;328(7445):921-4. [pmid: 15013948].