# References

1 U.S. Preventive Services Task Force. Recommendation Statement: Screening for Iron Deficiency Anemia—Including Supplementation for Children and Pregnant Women. Rockville, MD. U.S. Preventive Services Task Force. 2006.
2 Griffin IJ, Abrams SA. Iron and breastfeeding. Pediatr Clin North Am. 2001;48(2):401-3. [pmid: 11339160].
3 Centers for Disease Control and Prevention. Recommendations to prevent and control iron deficiency in the United States. MMWR. 1998;47(RR-3):1-36. [pmid: 9563847].
4 Centers for Disease Control and Prevention. CDC criteria for anemia in children and childbearing-aged women. MMWR. 1989;38(22):400-4. [pmid: 2542755].
5 World Health Organization. Iron Deficiency Anaemia: Assessment, Prevention, and Control. A Guide for Programme Managers. Geneva. World Health Organization. 2001. Accessed at http://www.who.int/nutrition/publications/en/ida_assessment_prevention_control.pdf.
6 Institute of Medicine, Committee on the Prevention, Detection, and Management of Iron Deficiency Anemia Among U.S. Children and Women of Childbearing Age. Iron Deficiency Anemia: Recommended Guidelines for the Prevention, Detection, and Management Among U.S. Children and Women of Childbearing Age. Washington, DC. National Academies Press. 1993.
7 Van Den Broek NR, Letsky EA, White SA, Shenkin A. Iron status in pregnant women: which measurements are valid?. Br J Haematol. 1998;103:817-24. [pmid: 9858238].
8 Krishnamurti L. Iron-deficiency anemia. McInerny TK, editor. American Academy of Pediatrics Textbook of Pediatric Care. Elk Grove Village, IL. American Academy of Pediatrics. 2009.
9 Scholl TO. Iron status during pregnancy: setting the stage for mother and infant. Am J Clin Nutr. 2005;81(5):1218S-22S. [pmid: 15883455].
10 Mei Z, Cogswell ME, Looker AC, et al. Assessment of iron status in US pregnant women from the National Health and Nutrition Examination Survey (NHANES), 1999-2006. Am J Clin Nutr. 2011;93(6):1312-20. [pmid: 21430118].
11 Centers for Disease Control and Prevention. Iron deficiency--United States, 1999-2000. MMWR. 2002;51(40):897-9. [pmid: 12418542].
12 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin No. 95: anemia in pregnancy. Obstet Gynecol. 2008;112(1):201-7. [pmid: 18591330].
13 Bodnar LM, Cogswell ME, Scanlon KS. Low income postpartum women are at risk of iron deficiency. J Nutr. 2002;132(8):2298-302. [pmid: 12163678].
14 Bodnar LM, Cogswell ME, McDonald T. Have we forgotten the significance of postpartum iron deficiency?. Am J Obstet Gynecol. 2005;193(1):36-44. [pmid: 16021056].
15 Bodnar LM, Siega-Riz AM, Cogswell ME. High prepregnancy BMI increases the risk of postpartum anemia. Obes Res. 2004;12(6):941-8. [pmid: 15229333].
16 Neymotin F, Sen U. Iron and obesity in females in the United States. Obesity (Silver Spring). 2011;19(1):191-9. [pmid: 20467417].
17 Hoffman R, Benz E, Silberstein L, et al. Hematology: Basic Principles and Practice. 6th ed. Philadephia, PA. Elsevier Saunders. 2012.
18 Scholl TO, Hediger ML, Fischer RL, Shearer JW. Anemia vs iron deficiency: increased risk of preterm delivery in a prospective study. Am J Clin Nutr. 1992;55(5):985-8. [pmid: 1570808].
19 Murphy JF, O'Riordan J, Newcombe RG, et al. Relation of haemoglobin levels in first and second trimesters to outcome of pregnancy. Lancet. 1986;1(8488):992-5. [pmid: 2871331].
20 Zhou LM, Yang WW, Hua JZ, et al. Relation of hemoglobin measured at different times in pregnancy to preterm birth and low birth weight in Shanghai, China. Am J Epidemiol. 1998;148(10):998-1006. [pmid: 9829872].
21 Klebanoff MA, Shiono PH, Selby JV, et al. Anemia and spontaneous preterm birth. Am J Obstet Gynecol. 1991;164(1 Pt 1):59-63. [pmid: 1986627].
22 Lu ZM, Goldenberg RL, Cliver SP, et al. The relationship between maternal hematocrit and pregnancy outcome. Obstet Gynecol. 1991;77(2):190-4. [pmid: 1988879].
23 Singh K, Fong YF, Arulkumaran S. Anaemia in pregnancy--a cross-sectional study in Singapore. Eur J Clin Nutr. 1998;52(1):65-70. [pmid: 9481535].
24 Scholl TO, Hediger ML. Anemia and iron-deficiency anemia: compilation of data on pregnancy outcome. Am J Clin Nutr. 1994;59(2 Suppl):492S-500S. [pmid: 8304287].
25 Peña-Rosas JP, De-Regil LM, Dowswell T, Viteri FE. Intermittent oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2012;(7). CD009997.
26 Peña-Rosas JP, Viteri FE. Effects and safety of preventive oral iron or iron+folic acid supplementation for women during pregnancy. Cochrane Database Syst Rev. 2009;(4). CD004736.
27 Reveiz L, Gyte GM, Cuervo LG, Casasbuenas A. Treatments for iron-deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2011;(10). CD003094.
28 Cuervo LG, Mahomed K. Treatments for iron deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2001;(2). CD003094.
29 Goddard AF, James MW, McIntyre AS, et al. Guidelines for the management of iron deficiency anaemia. Gut. 2011;60(10):1309-16. [pmid: 21561874].
30 Short M. Iron deficiency anemia: evaluation and management. Am Fam Physician. 2013;87(2):98-104. [pmid: 23317073].
31 Al RA, Unlubilgin E, Kandemir O, et al. Intravenous versus oral iron for treatment of anemia in pregnancy: a randomized trial. Obstet Gynecol. 2005;106(6):1335-40. [pmid: 16319260].
32 Department of Veteran Affairs, Department of Defense. VA/DoD Clinical Practice Guideline for Management of Pregnancy. Washington, DC. Department of Veteran Affairs, Department of Defense. 2009. Accessed at http://www.healthquality.va.gov/guidelines/WH/up/.
33 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Iron Deficiency Anemia. Leawood, KS. American Academy of Family Physicians. 2006. Accessed at http://www.aafp.org/patient-care/clinical-recommendations/all/iron-deficiency-anemia.html.
34 World Health Organization. Guideline: Daily Iron and Folic Acid Supplementation in Pregnant Women. Geneva. World Health Organization. 2012.
35 Casanova BF, Sammel MD, Macones GA. Development of a clinical prediction rule for iron deficiency anemia in pregnancy. Am J Obstet Gynecol. 2005;193(2):460-6. [pmid: 16098871].
36 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2008. Accessed at http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
37 U.S. Preventive Services Task Force. Screening for iron deficiency anemia, including iron prophylaxis. Guide to Clinical Preventive Services. 2nd ed. Baltimore, MD. Williams & Wilkins. 1996.
38 Oregon Evidence-based Practice Center. Screening for Iron Deficiency Anemia in Childhood and Pregnancy: Update of the 1996 U.S. Preventive Services Task Force Review. Evidence Synthesis No. 40. AHRQ Publication No. 06-0590-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2006.
39 McDonagh M, Blazina I, Dana T, Cantor A, Bougatsos C. Routine Iron Supplementation and Screening for Iron Deficiency Anemia in Children Ages 6 to 24 Months: A Systematic Review to Update the U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 122. AHRQ Publication No.13-05187-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2015.
40 United Nations Development Programme. Human Development Index (HDI). New York, NY. United Nations Development Programme. 2014. Accessed at http://hdr.undp.org/en/statistics/.
41 Slaven RE. Best evidence synthesis: an intelligent alternative to meta-analysis. J Clin Epidemiol. 1995;48(1):9-18. [pmid: 7853053].
42 Makrides M, Crowther CA, Gibson RA, et al. Efficacy and tolerability of low-dose iron supplements during pregnancy: a randomized controlled trial. Am J Clin Nutr. 2003;78(1):145-53. [pmid: 12816784].
43 Barton DP, Joy MT, Lappin TR, et al. Maternal erythropoietin in singleton pregnancies: a randomized trial on the effect of oral hematinic supplementation. Am J Obstet Gynecol. 1994;170(3):896-901. [pmid: 8141223].
44 Chan KK, Chan BC, Lam KF, et al. Iron supplement in pregnancy and development of gestational diabetes--a randomised placebo-controlled trial. BJOG. 2009;116(6):789-97. [pmid: 19432567].
45 Meier PR, Nickerson HJ, Olson KA, et al. Prevention of iron deficiency anemia in adolescent and adult pregnancies. Clin Med Res. 2003;1(1):29-36. [pmid: 15931282].
46 Ziaei S, Norrozi M, Faghihzadeh S, Jafarbegloo E. A randomised placebo-controlled trial to determine the effect of iron supplementation on pregnancy outcome in pregnant women with haemoglobin ≥13.2 g/dl. BJOG. 2007;114(6):684-8. [pmid: 17516958].
47 Cogswell ME, Parvanta I, Ickes L, et al. Iron supplementation during pregnancy, anemia, and birth weight: a randomized controlled trial. Am J Clin Nutr. 2003;78(4):773-81. [pmid: 14522736].
48 Siega-Riz AM, Hartzema AG, Turnbull C, et al. The effects of prophylactic iron given in prenatal supplements on iron status and birth outcomes: a randomized controlled trial. Am J Obstet Gynecol. 2006;194(2):512-9. [pmid: 16458655].
49 Falahi E, Akbari S, Ebrahimzade F, Gargari BP. Impact of prophylactic iron supplementation in healthy pregnant women on maternal iron status and birth outcome. Food Nutr Bull. 2011;32(3):213-7. [pmid: 22073795].
50 Milman N, Agger AO, Nielsen OJ. Iron status markers and serum erythropoietin in 120 mothers and newborn infants. Effect of iron supplementation in normal pregnancy. Acta Obstet Gynecol Scand. 1994;73(3):200-4. [pmid: 8122498].
51 Ziaei S, Mehrnia M, Faghihzadeh S. Iron status markers in nonanemic pregnant women with and without iron supplementation. Int J Gynaecol Obstet. 2008;100(2):130-2. [pmid: 17977537].
52 Eskeland B, Malterud K, Ulvik RJ, Hunskaar S. Iron supplementation in pregnancy: is less enough? A randomized, placebo controlled trial of low dose iron supplementation with and without heme iron. Acta Obstet Gynecol Scand. 1997;76(9):822-8. [pmid: 9351406].
53 Romslo I, Haram K, Sagen N, Augensen K. Iron requirement in normal pregnancy as assessed by serum ferritin, serum transferrin saturation and erythrocyte protoporphyrin determinations. Br J Obstet Gynaecol. 1983;90(2):101-7. [pmid: 6824608].
54 Zhou SJ, Gibson RA, Makrides M. Routine iron supplementation in pregnancy has no effect on iron status of children at six months and four years of age. J Pediatr. 2007;151(4):438-40. [pmid: 17889086].
55 Milman N, Agger AO, Nielsen OJ. Iron supplementation during pregnancy. Effect on iron status markers, serum erythropoietin and human placental lactogen. A placebo controlled study in 207 Danish women. Dan Med Bull. 1991;38(6):471-6. [pmid: 1802636].
56 Bloxam DL, Williams NR, Waskett RJ, et al. Maternal zinc during oral iron supplementation in pregnancy: a preliminary study. Clin Sci (Lond). 1989;76(1):59-65. [pmid: 2920535].
57 Butler EB. Effect of iron and folic acid on red cell and plasma volume in pregnancy. J Obstet Gynaecol Br Commonw. 1968;75(5):497-510. [pmid: 5742694].
58 Buytaert G, Wallenburg HC, van Eijck HG, Buytaert P. Iron supplementation during pregnancy. Eur J Obstet Gynecol Reprod Biol. 1983;15(1):11-6. [pmid: 6884561].
59 Cantlie GS, De Leeuw NK, Lowenstein L. Iron and folate nutrition in a group of private obstetrical patients. Am J Clin Nutr. 1971;24(6):637-41. [pmid: 5581003].
60 Chisholm M. A controlled clinical trial of prophylactic folic acid and iron in pregnancy. BJOG. 1966;73(2):191-6.
61 Dawson EB, McGanity WJ. Protection of maternal iron stores in pregnancy. J Reprod Med. 1987;32(6 Suppl):478-87. [pmid: 3612641].
62 Dawson EB, Albers J, McGanity WJ. Serum zinc changes due to iron supplementation in teen-age pregnancy. Am J Clin Nutr. 1989;50(4):848-52. [pmid: 2801591].
63 Fleming AF, Martin JD, Hahnel R, Westlake AJ. Effects of iron and folic acid antenatal supplements on maternal haematology and fetal wellbeing. Med J Aust. 1974;2(12):429-36. [pmid: 4431344].
64 Harvey LJ, Dainty JR, Hollands WJ, et al. Effect of high-dose iron supplements on fractional zinc absorption and status in pregnant women. Am J Clin Nutr. 2007;85(1):131-6. [pmid: 17209188].
65 Holly RG. Anemia in pregnancy. Obstet Gynecol. 1955;5(4):562-8. [pmid: 14370701].
66 Lee JI, Lee JA, Lim HS. Effect of time of initiation and dose of prenatal iron and folic acid supplementation on iron and folate nutriture of Korean women during pregnancy. Am J Clin Nutr. 2005;82(4):843-9. [pmid: 16210715].
67 Pritchard JA, Hunt CF. A comparison of the hematologic responses following the routine prenatal administration of intramuscular and oral iron. Surg Gynecol Obstet. 1958;106(5):516-8. [pmid: 13556464].
68 Puolakka J, Janne O, Pakarinen A, et al. Serum ferritin as a measure of iron stores during and after normal pregnancy with and without iron supplements. Acta Obstet Gynecol Scand Suppl. 1980;95:43-51. [pmid: 6935911].
69 Svanberg B, Arvidsson B, Norrby A, et al. Absorption of supplemental iron during pregnancy: a longitudinal study with repeated bone-marrow studies and absorption measurements. Acta Obstet Gynecol Scand Suppl. 1975;48:87-108. [pmid: 1062910].
70 Taylor DJ, Mallen C, McDougall N, Lind T. Effect of iron supplementation on serum ferritin levels during and after pregnancy. Br J Obstet Gynaecol. 1982;89(12):1011-7. [pmid: 7171510].
71 Van Eijk HG, Kroos MJ, Hoogendoorn GA, Wallenburg HC. Serum ferritin and iron stores during pregnancy. Clin Chim Acta. 1978;83(1-2):81-91. [pmid: 620471].
72 Symonds EM, Radden HS, Cellier KM. Controlled-release iron therapy in pregnancy. Aust N Z J Obstet Gynaecol. 1969;9(1):21-5. [pmid: 4890375].
73 Zittoun J, Blot I, Hill C, et al. Iron supplements versus placebo during pregnancy: its effects on iron and folate status on mothers and newborns. Ann Nutr Metab. 1983;27(4):320-7. [pmid: 6881917].
74 Haider BA, Olofin I, Wang M, et al. Anaemia, prenatal iron use, and risk of adverse pregnancy outcomes: a systematic review and meta-analysis. BMJ. 2013;346:f3443. [pmid: 23794316].