# Discussion

## Summary of Review Findings

The evidence reviewed in this update is summarized in Table 5. Newer evidence identified for this review was consistent with findings from the previous USPSTF reviews,37,38 which demonstrated that iron supplementation is often effective in improving maternal hematological indexes and that supplementation may result in a lower incidence of iron deficiency anemia and iron deficiency during pregnancy and at delivery but has limited effect for improving clinical outcomes for the mother, fetus, or infant.

Table 5 Summary of Evidence

Routine Iron Supplementation in Pregnant Women

Main Findings From Prior USPSTF Reviews | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality^a^
Key Question 1. What are the benefits of routine iron supplementation in pregnant women on maternal and infant health outcomes?
Clinical outcomes, maternal
Limited evidence exists demonstrating improved clinical outcomes | 5 RCTs | Outcomes mostly reported as ad hoc events; variable doses of iron supplements | Mostly consistent | Studies limited to those conducted in U.S.-applicable countries and populations | 1 trial reported no differences in quality of life between iron-supplemented pregnant women and those receiving placebo. 5 trials reported rates of Cesarean delivery, with 4 finding no difference in rates between supplemented women and placebo. 1 trial found significantly fewer Cesarean deliveries in women receiving iron supplementation. | Poor
Clinical outcomes, infant
Infant mortality
Limited evidence; 1 trial reported fewer infant deaths in the selective supplementation group | 4 trials | Outcomes mostly reported as ad hoc events; variable doses of iron supplements | Consistent | 1 trial conducted in Iran | 4 trials reported no association between maternal iron supplementation and infant mortality. | Poor
Preterm delivery
Limited evidence shows no effect on pregnancy outcomes | 4 RCTs | Variable doses of iron supplements | Consistent | No issues | 4 studies found no association between prenatal iron supplementation and the incidence of preterm delivery. | Fair
Length of gestation
Limited evidence shows no effect on pregnancy outcomes | 6 RCTs | Variable doses of iron supplements | Consistent | No issues | 6 trials reported no association between length of gestation and iron supplementation. All studies reported normal gestational ages of between 38 and 40 weeks for both supplemented and placebo groups. | Fair
Small for gestational age
No studies | 4 RCTs | Variable doses of iron supplements | Inconsistent | No issues | 4 trials reported inconsistent findings for infants who were small for gestational age. 1 study reported no difference between supplementation and placebo groups, 2 trials reported fewer small for gestational age infants among the supplementation group, and 1 trial found that women not receiving supplementation had fewer small for gestational age infants. | Fair
Low birthweight
Limited evidence shows no effect on pregnancy outcomes | 6 RCTs | Variable doses of iron supplements | Some inconsistency | No issues | 1 study reported a significant reduction in the rate of low birthweight (<2,500 g) among infants exposed to prenatal iron supplementation (4.3% vs. 16.7%; p=0.003). 5 studies found no association. | Fair
Apgar score
No studies | 5 RCTs | Variable doses of iron supplements | Consistent | No issues | 4 studies found no association in Apgar scores at 1 and 5 minutes in infants exposed to prenatal iron supplements vs. placebo. | Fair
Intermediate outcomes, maternal
Iron supplements are effective in improving maternal hematological indexes | 12 RCTs for intermediate outcomes | Variable doses of iron supplements | Mostly consistent | Studies limited to those conducted in U.S.-applicable countries and populations | 12 trials reported mostly improvement in maternal hematological indexes with variable doses of iron supplementation vs. placebo, but inconsistent associations between iron supplements and the incidence of maternal iron deficiency or anemia. Pooled analysis of 4 trials reporting a lower incidence of iron deficiency anemia at term (2 statistically significant and 2 with no difference) resulted in a statistically significant difference between groups favoring supplementation (20–66 mg iron daily) (4 trials; RR, 0.29 [95% CI, 0.17 to 0.49]; I^2^=0%). The clinical significance of these findings remains unclear. | Fair
Intermediate outcomes, infant
Infant iron outcomes not assessed | 1 followup study | No issues | Not applicable | No issues | A followup study to the good-quality Australian trial, in which mothers were randomly allocated to receive 20 mg of elemental iron supplementation daily starting at 20 weeks' gestation until delivery, reported child hematological outcomes and found no differences in iron status of children at age 6 months. | Poor
Key Question 2. What are the harms of routine iron supplementation in pregnant women?
Reversible gastrointestinal symptoms associated with iron use | 10 RCTs | Outcomes mostly reported as ad hoc events; variable doses of iron supplements | Some inconsistency | No issues | 10 trials included in Key Question 1 assessed variable harms of routine iron supplementation in pregnant women, although none of the harms were serious or associated with long-term significance, and there were mostly no significant differences between groups. Most reported harms included transient treatment effects, such as nausea, constipation, and diarrhea. Findings on rates of maternal hypertension were inconsistent. 6 trials found no difference in nonadherence to supplementation vs. placebo between groups; however, 1 trial had lower nonadherence in the supplementation group than the placebo group. | Poor

a “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; RR=relative risk.

Screening for Iron Deficiency Anemia in Pregnant Women

Main Findings From Prior USPSTF Reviews | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality^a^
Key Question 1. What are the benefits of screening for iron deficiency anemia in asymptomatic pregnant women on maternal and infant health outcomes?
No studies | No studies | No studies | No studies | No studies | No studies | No studies
Key Question 2. What are the harms of screening for iron deficiency anemia in pregnant women?
No studies | No studies | No studies | No studies | No studies | No studies | No studies
Key Question 3. What are benefits of treatment of iron deficiency anemia in pregnant women on maternal and infant health outcomes?
Iron supplements are effective in improving maternal hematological indexes but limited evidence exists demonstrating improved clinical outcomes | No studies | No studies | No studies | No studies | No studies | No studies
Key Question 4. What are the harms of iron treatment in pregnant women?
Reversible gastrointestinal symptoms associated with iron use | No studies | No studies | No studies | No studies | No studies | No studies
Key Question 5. In pregnant women with iron deficiency, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?
Not previously reviewed | No studies | No studies | No studies | No studies | No studies | No studies

a “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; RR=relative risk.

This update includes 11 trials that reported various clinical outcomes of iron supplementation trials in women and infants. One trial reported no differences in quality of life between pregnant women receiving iron supplementation and those receiving placebo. Trials of prenatal iron supplementation found no clear effect on gestational age, infant Apgar score, preterm birth, or infant mortality; however, infant mortality was not a prespecified outcome. Findings were inconsistent among studies that reported an effect of maternal iron supplementation on rates of Cesarean delivery, infants born small for gestational age, and infants with low birthweight. It is important to note that the strength of this evidence is reduced by the small number of trials reporting these outcomes (five trials reporting on premature birth, small for gestational age, and Cesarean delivery) and the possibility that the current studies lack adequate sample size to identify important differences.

The strongest evidence supporting the benefit of supplementation on hematological outcomes was from a good-quality randomized Australian trial of pregnant women at average risk for anemia42 that reported improvements in some maternal hematological parameters. Eleven other good- or fair-quality trials43-53 supported the evidence that maternal iron supplementation may improve hematological parameters or reduce the incidence of iron deficiency anemia, but the clinical significance of these findings remains unclear. One followup study of maternal iron supplementation during pregnancy reported no differences in child iron status at age 6 months.54 No studies reported serious harms or accidental overdose as a result of supplementation.

No trial evaluated screening or harms of screening for iron deficiency anemia in pregnant women. One older study evaluated the effectiveness and harms of treatment of iron deficiency anemia on intermediate outcomes during pregnancy but was of poor quality. One older poor-quality study reported that change in maternal iron status improved maternal hematological indexes but did not affect perinatal outcomes; therefore, evidence on the relationship between improvement in maternal iron status and maternal or infant clinical outcomes remains sparse.

Other published reviews in this topic area include a 2013 systematic review and meta-analysis that included trials and observational studies that did not meet our inclusion criteria because of the country in which it was conducted, quality, and high statistical heterogeneity, even when analysis was limited to high-quality trials (I^2^=97%).74 Therefore, analysis of these results has limited applicability to our review.

## Limitations

We excluded non–English-language articles, which could result in language bias, although we identified none that would have met inclusion criteria. We could not formally assess for publication bias with graphical or statistical methods because of the small number of studies and differences in study design, populations, and outcomes assessed. We included some trials from countries that may not be directly generalizable to the United States because of differences in nutritional status, resources, infrastructure, and other factors (Hong Kong, Iran); however, all were rated as at least “high” on the United Nations Human Development Index.40

## Emerging Issues

The incidence of iron deficiency anemia in the United States has remained essentially unchanged over the past decades, and screening and supplementation in asymptomatic, pregnant women are common. There are very few new studies or emerging issues at this time. However, further elucidating the possible influence of iron supplementation on Cesarean delivery rates could be an area of interest in the United States.

## Relevance for Priority Populations

We did not identify any studies that identified specific issues or risk factors or that reported subgroup data for priority populations, including racial or ethnic minorities. However, two of the included iron supplementation trials conducted in the United States primarily included women eligible for the Special Supplemental Nutrition Program for Women, Infants, and Children47,48 or a population that was more than 50 percent black.48 While one of these studies found a significantly higher percentage of small for gestational age (6.8% vs. 17.7%; p=0.014) and low birthweight infants (4.3% vs. 16.7%; p=0.003) in the placebo groups, the other study48 found no differences between groups in clinical outcomes. Regarding iron levels, no differences between groups at the third trimester timepoint reached statistical significance. Both of these studies ended the placebo phase of the trial at 28 weeks' gestation, after which all women in the study received routine iron supplementation, therefore limiting the interpretation of trial results.

## Future Research

Research is needed to identify the long-term effects of iron supplementation during pregnancy. Infants exposed to prenatal iron supplementation should continue to be followed to help identify unexpected or emerging long-term benefits or harms from maternal supplementation. Research is also needed to understand the clinical significance of the short-term improvement in maternal hematological outcomes following prenatal iron supplementation. The influence of supplementation dose and timing could also be better studied. Additional trials with sufficient sample sizes would strengthen conclusions regarding infant and maternal harms of iron supplementation during pregnancy.

## Conclusions

In summary, the use of iron supplementation during pregnancy appears to be effective at improving maternal hematological indexes and may reduce the incidence of iron deficiency anemia and iron deficiency in the short term, although the definition of these conditions during pregnancy is imprecise. Routine supplementation is not associated with significant short-term maternal harms, but there is no clear benefit on infant birth outcomes, including Apgar score, preterm birth, or infant mortality. More research is needed to fully understand the short- and long-term clinical effects of routine iron supplementation during pregnancy in women and infants, including the effects on rates of Cesarean delivery, small for gestational age infants, and low birthweight infants. There is no new evidence on the use of prenatal screening for iron deficiency anemia. More research is needed to establish the effects of treatment of pregnant women with iron deficiency anemia on maternal and infant clinical outcomes, as well as the association between improvements in iron status measures and clinical outcomes.