# Results

## Routine Iron Supplementation in Pregnant Women

### Key Question 1 What Are the Benefits of Routine Iron Supplementation in Pregnant Women on Maternal and Infant Health Outcomes?

#### Summary

Eleven trials of routine iron supplementation in pregnant women reported clinical outcomes for women and infants. One trial reported no differences in quality of life between women receiving iron supplementation and those receiving placebo.42 Five trials of maternal iron supplementation reported inconsistent findings for rates of Cesarean delivery42-46 and having an infant born small for gestational age (three studies)44,47,48 or with low birthweight (six studies).42,43,45,47-49 Evidence from these studies demonstrates that exposure to maternal iron supplementation does not affect infant gestational age, Apgar scores, preterm birth, or infant mortality. Studies were methodologically heterogeneous and possibly underpowered.

Twelve good- or fair-quality trials reported some improvement in maternal hematological indexes with variable doses and duration of iron supplementation versus placebo measured at different timepoints during pregnancy, although half of the studies had findings that were not statistically significant. Four of these trials reported a lower incidence of maternal iron deficiency anemia at term with variable supplemental dosing (20 to 66 mg iron daily). While two reported statistically significant differences and two did not, pooling these findings resulted in a statistically significant difference between groups favoring supplementation (four trials; 4% (15/389) vs. 15% (55/373); RR, 0.29 (95% CI, 0.17 to 0.49); I^2^=0%).42,45,49,50 The results are from the same trials mentioned above that reported clinical outcomes. The clinical significance of these hematological findings remains unclear.

The prior USPSTF reviews37,38 found that iron supplementation is effective in improving hematological indexes in anemic pregnant women but found limited evidence to demonstrate improved clinical outcomes for the mother, fetus, or newborn.

#### Evidence

We identified 12 trials (in 14 publications) of good42,46,51,54 and fair quality43-45,47-50,52,53,55 that compared the effects of routine iron supplementation versus no supplementation in pregnant women (Tables 2 and 3; Appendixes B1 and B2). Three studies were conducted in the United States, three in Iran, and the others in Hong Kong, Australia, or Europe. Sample sizes ranged from 45 to 1,164 participants, although only two studies had more than 500 participants. Most studies reported that women with seriously low hematological indexes at baseline were excluded from the study and received treatment.42-48,51,52 Several studies also reported providing treatment if indexes dropped too low during the course of the study.42,44-46,51,52 The majority of enrolled women were in their 20s (one study included adolescents45), and participants were mostly white or black or race was not reported. Two of the three studies conducted in the United States47,48 were of women at higher risk for anemia based on reported risk factors (e.g., 100% eligible for the Special Supplemental Nutrition Program for Women, Infants, and Children, >50% black race, 24% to 44% with parity >2). All other included studies were of women at average risk for anemia; however, risk factors were not always reported, and no studies stratified results by risk groups.

Table 2 Infant Birth Outcomes

Study, Year Country N Quality | Iron Supplement Dose and Formulation, Initiation | Risk Factors Reported | Supplementation vs. Control
Study, Year Country N Quality | Iron Supplement Dose and Formulation, Initiation | Risk Factors Reported | Apgar Score | Preterm Delivery^a^ | Length of Gestation | Small for Gestational Age^b^ | Birthweight | Low Birthweight^c^ | Infant Mortality
Barton 1994^43^ Ireland N=97 Fair | 120 mg elemental iron daily starting at 14 weeks' gestation | Race: NR (Ireland) Nulliparous: 45%–47% | | | | | | <2,700 g: 9.4% vs. 15.9%; p=0.34 | 1.9% vs. 0%; p=0.57
Chan 2009^44^ Hong Kong N=1,164 Fair | 60 mg elemental iron daily starting at <16 weeks' gestation | Race: NR (Hong Kong) Parity ≥2: 0.50% vs. 0.18% BMI: 20.8 vs. 21.0 kg/m^2^ | Score at 1 min: 8.8 vs. 8.8; p=NS Score at 5 min: 9.8 vs. 9.7; p=NS | 6.4% vs. 6.8%; p=0.85 | 39 vs. 39 weeks; p=0.322 | 3.6% vs. 7.5%; p=0.013 | 3,247.3 vs. 3,151.9 g; p=0.001
Cogswell 2003^47^ U.S. N=275 Fair | 30 mg elemental iron daily starting at <20 weeks' gestation | Race: 56%–57% white, 24%–26% black, 16–17% Hispanic Parity ≥2: 31% vs. 24% ≤High school education: 73%–76% SES: 100% eligible for WIC | | 12.8% vs. 12.5%; p=0.944 | 38.9 vs. 38.3 weeks; p=0.05 | 6.8% vs. 17.7%; p=0.014 | 3,277 vs. 3,072 g; p=0.010 | 4.3% vs. 16.7%; p=0.003
Eskeland 1997^52^ Norway N=90 Fair | 27 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Norway) BMI: 22–23 kg/m^2^ Parity ≥2: 0%–10% Single: 3%–17% Low education: 3%–10% | | | | | 3,690 vs. 3,620 vs. 3,610 g; p=NS^d^
Falahi 2011^49^ Iran N=148 Fair | 60 mg elemental iron daily starting at <20 weeks' gestation | Race: NR (Iran) BMI: 24–25 kg/m^2^ | | 3% vs. 6.8%; p=NS | 38.9 vs. 38.8 weeks; p=NS | | 3,310 vs. 3,270 g; p=NS | 3% vs. 6.8%; p=NS
Makrides 2003^42^ Australia N=430 Good | 20 mg elemental iron daily starting at 20 weeks' gestation | Race: 95% white, 0.9%–3.3% Aboriginal, 1.4%–2.3% Asian Multiparous: 52%–53% BMI: 26 kg/m^2^ Highest level of education: 12%–15% year <10, 27%–28% year 11, 28%–33% year 12, 5%–8% trade certificate or diploma, 21% tertiary degree | Score <7 at 5 min: 1.4% vs. 1.5%; p=NS | | 39 vs. 39 weeks; p=NS | | 3,406 vs. 3,449 g; p=NS | 5.4% vs. 4.2%; p=NS | 0.5% (1 case) vs. 0%; p=NS (infant born at 22 weeks with bilateral intrauterine pneumonia)
Meier 2003^45^ U.S. N=111 Fair | 60 mg elemental iron daily starting at 1st prenatal visit | Race: NR (Wisconsin) Private group practice | Score <7 at 1 min: Adolescents: 30% vs. 25%; p=NS Adults: 29.7% vs. 16.7%; p=NS | | Adolescents: 39.9 vs. 39.8 weeks; p=NS Adults: 39.2 vs. 39.5 weeks; p=NS | | | Adolescents: 0% vs. 0%; p=NS Adults: 5.4% vs. 2.9%; p=NS | 0% vs. 0%; p=NS
Milman 1994^50^ Denmark N=120 Fair | 66 mg elemental iron daily starting at 14–16 weeks' gestation | Race: NR (Denmark) | | | | | 3,350 vs. 3,450 g; p>0.5 (median)
Romslo 1983^53^ Norway N=45 Fair | 200 mg elemental iron daily starting within 10 weeks' gestation | Race: NR (Norway) | 1-min score: 8.7 vs. 8.8; p=NR 5-min score: 9.0 vs. 9.0; p=NR | | 39.9 vs. 39.5 weeks; p=NR | | 3,546 vs. 3,510 g; p=NR
Siega-Riz 2006^48^ U.S. N=429 Fair | 30 mg elemental iron daily starting at <20 weeks' gestation | Race: 58%–65% black, 31%–37% white Single: 75% Parity ≥2: 44% vs. 41% SES: 100% eligible for WIC | | 7.5% vs. 13.9%; p=0.05 | 39.1 vs. 39.0 weeks; p=0.43 | 10.8% vs. 15.5%; p=0.22 | 3,325 vs. 3,217 g; p=0.03 | 4.8% vs. 9.5%; p=0.09
Ziaei 2007^46^ Iran N=727 Good | 50 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Iran) BMI: 24 kg/m^2^ Parity: 1.7 | Score at 10 min: 9.9 vs. 9.8; p=NS | | | 15% vs. 10%; p=0.035 | | | 0.8% vs. 1.7%; p=NS

a <37 weeks' gestation.

b <10th percentile of birthweight for gestational age.

c <2,500 g.

d Heme-iron supplemented group vs. nonheme-iron supplemented group vs. placebo group.

Note: Bolded p-values show a significant difference.

Abbreviations: BMI=body mass index; NR=not reported; NS=not significant; SES=socioeconomic status; WIC= Special Supplemental Nutrition Program for Women, Infants, and Children.

Table 3 Maternal Hematological Outcomes

Study, Year Country N, Quality | Timepoint | Iron Supplement Dose, Formulation, Initiation | Risk Factors Reported | Supplementation vs. Control
Study, Year Country N, Quality | Timepoint | Iron Supplement Dose, Formulation, Initiation | Risk Factors Reported | Hemoglobin | Serum Ferritin | MCV | Iron Deficiency^a^ | Anemia^b^ | Iron Deficiency Anemia^c^
3rd trimester
Siega-Riz 2006^48^ U.S. N=429 Fair | 26–29 weeks (end of RCT phase) | 30 mg elemental iron daily starting at <20 weeks' gestation | Race: 58%–65% black, 31%–37% white Single: 75% Parity ≥2: 44% vs. 41% SES: 100% eligible for WIC | 114 vs. 114 g/L; p=0.81 | 22.0 vs. 20.3 μg/L; p=0.48 | | 53% vs. 65%; p=0.08^d^ | 21% vs. 19%; p=0.65 | 10% vs. 15%^e^; p=0.23
Cogswell 2003^47^ U.S. N=275 Fair | 28 weeks (end of RCT phase) | 30 mg elemental iron daily starting at <20 weeks' gestation | Race: 56%–57% white, 24%–26% black, 16%–17% Hispanic Parity ≥2: 31% vs. 24% ≤High school education: 73%–76% SES: 100% eligible for WIC | 117 vs. 116 g/L; p=0.499 | 7.4 vs. 7.4 μg/L; p=0.985 | 90.8 vs. 90.3 fL; p=0.443 | 56.4% vs. 65.1%; p=0.214 | 19.8% vs. 26.7%; p=0.251 | 12.7% vs. 20.9%; p=0.123
Falahi 2011^49^ Khorramabad City, Iran N=148 Fair | 28 weeks | 60 mg elemental iron daily starting at <20 weeks' gestation | Race: NR (Iran) BMI: 24–25 kg/m^2^ | | | | | | 1.4% vs. 3.8%; p<0.05
Ziaei 2007^46^ Tehran, Iran N=727 Good | 3rd trimester | 50 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Iran) BMI: 24 kg/m^2^ Parity: 1.7 | 138 vs. 125 g/L; p<0.001
Barton 1994^43^ Ireland N=97 Fair | 36 weeks | 120 mg elemental iron daily starting at 14 weeks' gestation | Race: NR (Ireland) Nulliparous: 45%–47% | 135 vs. 126 g/L; p=0.043 (adjusted for smoking, p=0.25) | 32.6 vs. 12.8 μg/L; p=0.04
Eskeland 1997^52^ Norway N=90 Fair | 38 weeks | 27 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Norway) BMI: 22–23 kg/m^2^ Parity ≥2: 0%–10% Single: 3%–17% Low education: 3%–10% | | | | 29% vs. 52% vs. 85%; p<0.001 for A vs. C and p<0.05 for B vs. C^e^
At term
Meier 2003^45^ U.S. N=111 Fair | Delivery, 36–40 weeks, stratified by age group | 60 mg elemental iron daily starting at 1st prenatal visit | Race: NR (Wisconsin) Private group practice | Adolescents: 122 vs. 115 g/L; p=0.024 Adults: 121 vs. 117 g/L; p=0.135 | Adolescents: 12.0 vs. 6.2 μg/L; p=0.010 Adults: 12.9 vs. 7.6 μg/L; p=0.027 | | | | Adolescents: 5% vs. 29%; p=0.14 Adults: 10.5% vs. 22.2%; p=0.26
Romslo 1983^53^ Norway N=45 Fair | 37–40 weeks | 200 mg elemental iron daily starting within 10 weeks' gestation | Race: NR (Norway) | 126 vs. 113 g/L; p=NR | 24.0 vs. 6.0 μg/L; p=NR | | 0% vs. 65.2%; p=0.02
Barton 1994^43^ Ireland N=97 Fair | 40 weeks | 120 mg elemental iron daily starting at 14 weeks' gestation | Race: NR (Ireland) Nulliparous: 45%–47% | 137 vs. 120 g/L; p<0.001 | | | | “No patients were withdrawn from the study due to anemia”
Chan 2009^44^ Hong Kong N=1,164 Fair | Delivery | 60 mg elemental iron daily starting at <16 weeks' gestation | Race: NR (Hong Kong) Parity ≥2: 0.50 vs. 0.18% BMI: 20.8 vs. 21.0 kg/m^2^ | 122 vs. 118 g/L; p<0.001 | 30.0 vs. 24.9 μg/L; p<0.003
Falahi 2011^49^ Khorramabad City, Iran N=148 Fair | Delivery | 60 mg elemental iron daily starting at <20 weeks' gestation | Race: NR (Iran) BMI: 24–25 kg/m^2^ | 123 vs. 121 g/L; p=NS | 28.1 vs. 22.1 μg/L; p=NS | | 9.5% vs. 28.2%; p<0.05 | | 0% vs. 0%; p=NS
Makrides 2003^42^ Australia N=430 Good | Delivery | 20 mg elemental iron daily starting at 20 weeks' gestation | Race: 95% white, 0.9%–3.3% Aboriginal, 1.4%–2.3% Asian Multiparous: 52%–53% BMI: 26 kg/m^2^ Highest level of education: 12%–15% year <10, 27%–28% year 11, 28%–33% year 12, 5%–8% trade certificate or diploma, 21% tertiary degree | 127 vs. 120 g/L; RR, 6.9 (95% CI, 4.4 to 9.3) | 21 vs. 14 μg/L; RR, 7.1 (95% CI, 4 to 10.2) | | 35% vs. 58%; RR, 0.60 (95% CI, 0.48 to 0.76) | 7% vs. 16%; RR, 0.45 (95% CI, 0.25 to 0.82) | 3% vs. 11%; RR, 0.28 (95% CI, 0.12 to 0.68)
Milman 1994^50^ Denmark N=120 Fair | Term | 66 mg elemental iron daily starting at 14–16 weeks' gestation | Race: NR (Denmark) | 127 vs. 116 g/L; p<0.0001 | 22 vs. 14 μg/L; p<0.0001 | | | | 0% vs. 17.5%; p=0.03
Ziaei 2008^51^ Iran (location NR) N=205 Good | Delivery | 50 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Iran) BMI: 24 kg/m^2^ Parity: 1.6–1.7 Educational level: 7%–11% primary school, 77%–83% high school, 10%–12% university | 139 vs. 128 g/L; p<0.0001 | 26.2 vs. 19.1 μg/L; p<0.0001
Postpartum
Eskeland 1997^52^ Norway N=90 Fair | 1 week postpartum | 27 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Norway) BMI: 22–23 kg/m^2^ Parity ≥2: 0%–10% Single: 3%–17% Low education: 3%–10% | | | | | 11.5% vs. 20.7%; p=0.25
Eskeland 1997^52^ Norway N=90 Fair | 6-10 weeks postpartum | 27 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Norway) BMI: 22–23 kg/m^2^ Parity ≥2: 0%–10% Single: 3%–17% Low education: 3%–10% | | | | 8% vs. 27% vs. 52%; p<0.01 for A vs. C; p=NS for others^f^
Eskeland 1997^52^ Norway N=90 Fair | 24 weeks postpartum | 27 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Norway) BMI: 22–23 kg/m^2^ Parity ≥2: 0%–10% Single: 3%–17% Low education: 3%–10% | | | | 4% vs. 17% vs. 51%; p<0.001 for A vs. C and p<0.05 for B vs. C^f^
Makrides 2003^42^ Australia N=430 Good | 6 months postpartum | 20 mg elemental iron daily starting at 20 weeks' gestation | Race: 95% white, 0.9%–3.3% Aboriginal, 1.4%–2.3% Asian Multiparous: 52%–53% BMI: 26 kg/m^2^ Highest level of education: 12%–15% year <10, 27%–28% year 11, 28%–33% year 12, 5%–8% trade certificate or diploma, 21% tertiary degree | 135 vs. 134 g/L; RR, 1.6 (95% CI, −0.1 to 3.3) | 34 vs. 26 μg/L; RR, 7.9 (95% CI, 3.5 to 12.3) | | 16% vs. 29%; RR, 0.57 (95% CI, 0.38 to 0.84) | 3.7% vs. 4.5%; RR, 0.82 (95% CI, 0.30 to 2.21) | 2.6% vs. 1.7%; RR, 1.55 (95% CI, 0.38 to 6.40)
Ziaei 2008^51^ Iran (location NR) N=205 Good | 6 weeks postpartum | 50 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Iran) BMI: 24 kg/m^2^ Parity: 1.6–1.7 Educational level: 7%–11% primary school, 77%–83% high school, 10%–12% university | 133 vs. 126 g/L; p<0.0001 | 21.7 vs. 18.5 μg/L; p<0.0001

a Serum ferritin <12 μg/L.

b Hemoglobin <110 g/L.

c Hemoglobin <110 g/L and serum ferritin <12 μg/L.

d Serum ferritin <20 μg/L.

e Hemoglobin <110 g/L and serum ferritin <20 μg/L.

f Heme-iron supplemented group (A) vs. nonheme-iron supplemented group (B) vs. placebo group (C).

Note: Bolded p-values and relative risks show a significant difference.

Abbreviations: BMI=body mass index; CI=confidence interval; MCV=mean corpuscular volume; NR=not reported; NS=not significant; RCT=randomized, controlled trial; RR=relative risk; SES=socioeconomic status; WIC= Special Supplemental Nutrition Program for Women, Infants, and Children.

The timing of supplementation varied from the first prenatal visit up to 20 weeks' gestation and continued until delivery. However, in two of the studies conducted in the United States, participants in the placebo group were reassigned to supplementation at 26 to 29 weeks' gestation (therefore, results up to that time period are included in this report).47,48 Outcomes were measured during the third trimester, at delivery, or included a short duration of followup into the postpartum period. Supplement dosing ranged from 20 to 200 mg of elemental iron daily. Adherence, usually based on pill counts or an equation involving pill counts, ranged from 54 to 98 percent and mostly did not differ between groups in the seven studies that reported it; however, adherence data were not available for all included participants.42,44,45,47,48,52,53

Five studies (in six publications) reported power or sample size calculations.42,44,46-48,54 Two studies were powered to detect a reduction in the rate of anemia—one from 30 to 15 percent (Δ, 15%)47 and the other from 25 to 15 percent (Δ, 10%).48 One of these studies was also powered to detect between-group differences of 0.407 times the standard deviation of birthweight and gestational age.47 One study was powered to detect reductions in the rates of iron deficiency anemia (from 11.5% to 3%; Δ, 8.5%) and iron deficiency (from 30% to 15%; Δ, 15%), as well as an increase in the rate of gastrointestinal adverse effects (from 10% to 20%; Δ, 10%).42 The sample size of one study was calculated to detect a 7-percent difference in the proportion of infants born small for gestational age,46 and another study enrolled enough patients to detect an increase from 10 to 15 percent (Δ, 5%) in the incidence of gestational diabetes.44

Given the heterogeneity of supplementation dosing, duration, timing of initiation, and timing of followup in these studies, we pooled results for selected outcomes. We excluded 16 poor-quality studies56-71 for this Key Question because of the availability of good- and fair-quality trials. The poor-quality studies suffered from high loss to followup, small sample sizes, and other methodological flaws, including poor reporting of statistical methods.

#### Clinical Outcomes—Maternal

One good-quality Australian trial (n=430) reported quality of life as a secondary outcome and found no differences between women receiving iron supplementation and those receiving placebo in any of the eight Short-Form 36 health concepts (physical functioning, role-physical, bodily pain, general health, vitality, social functioning, role-emotional, and general mental health) at 36 weeks' gestation, 6 weeks postpartum, or 6 months postpartum (specific data only displayed in a figure in the article).42

Although Cesarean delivery may occur for a variety of indications, including elective reasons, and there is no known causal relationship between iron deficiency anemia and Cesarean delivery, it is typically considered a clinical outcome in pregnancy and was reported in five trials as an ad hoc event.42-46 These trials of women likely at average risk for anemia compared pregnant women receiving iron supplementation with those not receiving supplementation; Cesarean delivery rates ranged from 7.6 to 26 percent in the supplementation group and 9.1 to 33 percent in the placebo group.42-46 One large (n=1,164) fair-quality trial conducted in Hong Kong found a significant reduction in the rate of Cesarean delivery in women receiving 60 mg elemental iron daily versus placebo (25.2% vs. 33.1%; odds ratio, 0.58 [95% CI, 0.37 to 0.89]; p=0.008).44 However, four smaller fair- and good-quality trials conducted in Australia (n=430), the United States (n=111), Ireland (N=97), and Iran (n=727) demonstrated no effect on Cesarean delivery rates in women receiving supplementation (20 to 120 mg elemental iron) versus placebo (23.6% vs. 22.0%;42 16% vs. 19%;45 7.6% vs. 9.1%;43 and 26% vs. 23%,46 respectively).

No other maternal clinical outcomes were reported.

#### Clinical Outcomes—Infant

Eleven trials of good42,46 and fair quality43-45,47-50,52,53 reported infant birth outcomes, including infant mortality, preterm delivery, length of gestation, small for gestational age, birthweight, and Apgar scores (Table 2). Details are described below.

Infant mortality. Four trials42,43,45,46 anecdotally reported no effect of prenatal iron supplements on infant mortality, with rates ranging from 0 to 1.9 percent in the supplementation group and 0 to 1.7 percent in the placebo group, although this was not a prespecified outcome in these studies. All trials were of pregnant women at average risk for anemia. One good-quality Iranian trial reported a perinatal mortality rate of 0.8 percent (3/370) in the supplementation group and 1.7 percent (6/357) in the placebo group (p-value reported as nonsignificant).46 A good-quality Australian trial reported one case of an infant born at 22 weeks with bilateral intrauterine pneumonia in the supplementation group,42 a fair-quality Irish trial reported one unexplained death at 37 weeks' gestation in the supplementation group,43 and a U.S. trial reported no infant deaths.45

Preterm delivery. Four fair-quality trials conducted in Hong Kong, the United States, and Iran reported rates of preterm delivery (defined as delivery before 37 weeks), ranging from 3 to 12.8 percent in the supplementation group and 6.8 to 13.9 percent in the placebo group.44,47-49 As with the prior USPSTF report, these trials found no difference in rates of preterm delivery between women exposed to routine prenatal iron supplementation versus placebo (6.4% vs. 6.8%; p=0.85;^44^ 3% vs. 6.8%; p=not significant [NS];49 12.8% vs. 12.5%; p=0.944;^47^ and 7.5% vs. 13.9%; p=0.05^48^). Note that the two trials conducted in the United States (last two results listed) were of women at increased risk for iron deficiency.

Pooled estimates from two studies44,49 with similar supplemental dosing (60 mg elemental iron) demonstrate a nonsignificant reduction in the incidence of preterm birth in the supplementation groups (RR, 0.88 [95% CI, 0.55 to 1.42]; I^2^=0%) (Appendix C1).

Length of gestation. Six fair-quality trials and one good-quality trial conducted in Hong Kong, Norway, the United States (three trials), Iran, and Australia reported no effect of maternal iron supplementation on length of gestation, with all studies reporting normal gestational ages of between 38 and 40 weeks for both supplementation and placebo groups.42,44,45,47-49,53 The two studies conducted in the United States included women at higher risk for iron deficiency.

Small for gestational age. Four trials (three fair-quality, one good-quality) conducted in Hong Kong, the United States, and Iran reported inconsistent findings for infants exposed to prenatal iron supplementation who were small for gestational age (defined as <10th percentile of birthweight for gestational age), ranging from 3.6 to 15 percent in the supplementation group and 7.5 to 17.7 percent in the placebo group.44,46-48 A trial conducted in Hong Kong of women at average risk for anemia and a trial conducted in the United States of women at higher risk for iron deficiency reported fewer small for gestational age infants in the supplementation group versus placebo (3.6% vs. 7.5%; p=0.013;^44^ and 6.8% vs. 17.7%; p=0.014^47^). Another trial conducted in the United States of women at higher risk for iron deficiency reported no difference between supplementation and placebo groups for small for gestational age infants (10.8% vs. 15.5%; p=0.22^48^). One good-quality Iranian trial of women at average risk for anemia found that women not receiving supplementation had significantly fewer small for gestational age infants (15% vs. 10%; p=0.035).46

The reason for the inconsistencies in these findings is unclear. Attempting to pool the results of these studies leads to a high degree of statistical heterogeneity (I^2^=58%). This heterogeneity can be attributed to two studies that found an increased risk with supplementation and had different dosing (50 and 60 mg elemental iron) than the studies that found a reduced incidence of small for gestational age infants with supplementation (30 mg elemental iron).47,48 Removing these two studies from the analysis eliminates the heterogeneity (I^2^=0%). It is unclear what additional factors may have led to this discrepancy.

Low birthweight. Six trials (five fair-quality, one good-quality) conducted in the United States, Iran, Ireland, and Australia reported the incidence of infants born with low birthweight (mostly defined as <2,500 g) and found inconsistent results, ranging from 0 to 9.4 percent in the supplementation group and 0 to 16.7 percent in the placebo group.42,43,45,47-49 One trial of women at higher risk for iron deficiency conducted in the United States (n=275) found significantly lower rates of low-birthweight infants in the supplementation versus placebo group (4.3% vs. 16.7%; p=0.003).47 However, five trials, including a different U.S. trial of women at higher risk for iron deficiency, found no effect of prenatal iron supplementation on the rate of low-birthweight infants.42,43,45,48,49

Pooled analysis of three comparable studies42,45,49 (supplementing with 20 to 60 mg elemental iron) resulted in a nonstatistically significant RR of 1.10 (95% CI, 0.54 to 2.25; I^2^=0%) favoring placebo (Appendix C2).

Birthweight. Eight trials (seven fair-quality, one good-quality) conducted in Iran, Australia, Norway, Denmark, Hong Kong, and the United States reported mean infant birthweight, with weights all within the normal range; however, some differences were found between groups.42,44, 47-50,52,53 Evidence on infants born with low birthweight is described separately above. Five trials found no difference in mean infant birthweight between women in the supplementation and placebo groups.42,49,50,52,53 Three other trials, including two U.S. trials conducted in higher-risk women, found that women in the placebo group had lower mean birthweight infants than women in the supplementation group, although all were still within the normal range (3,247 vs. 3,151 g; p=0.001;^44^ 3,277 vs. 3,072 g; p=0.010;^47^ and 3,325 vs. 3,217 g; p=0.03^48^).

Apgar scores. Five trials (four fair-quality, one good-quality) conducted in Hong Kong, Australia, Norway, the United States, and Iran reported Apgar scores at 1 minute, 5 minutes, or 10 minutes and found no significant difference between infants exposed to routine maternal iron supplementation versus placebo.42,44-46,53

#### Intermediate Outcomes—Maternal

Twelve good- or fair-quality trials reported maternal intermediate outcomes, including hematological parameters and incidence of iron deficiency anemia, iron deficiency, and anemia (Table 3).42-53 Supplement doses varied across studies, ranging from 20 to 120 mg, and indexes were measured at different timepoints, including second trimester, third trimester, term, and postpartum. Findings on intermediate outcomes are largely consistent with the prior USPSTF reports.37,38 Details are described below.

Iron deficiency anemia. Six trials reported incidence of iron deficiency anemia (defined as hemoglobin <110 g/L and serum ferritin <12 or 20 μg/L), ranging from 0 to 12.7 percent in the supplementation group and 0 to 29 percent in the placebo group during the third trimester, at delivery, or postpartum.42,45,47-50

Three trials found lower incidence of iron deficiency anemia during the third trimester in women receiving iron supplementation (30 to 60 mg elemental iron daily) compared with those taking placebo. Only one of these trials, conducted in Iran (n=148), found the difference to be statistically significant (1.4% vs. 3.8%; p<0.05).49 Two trials conducted in the United States in women at potentially higher risk for iron deficiency anemia (due to enrollment of higher proportions of minority women with higher rates of parity [≥2], lower incomes, and lower educational levels) ended the controlled portion of the study at approximately 28 weeks' gestation and found no significant difference between groups (12.7% vs. 20.9%; p=0.123;^47^ and 10% vs. 15%; p=0.23^48^). Incident rates for women in both the control and supplementation groups were some of the highest of all the studies reporting this outcome, reflecting the higher risk level of the women enrolled.

One good-quality Australian trial (n=430) and a fair-quality trial from Denmark (n=120) reported a significantly lower incidence of iron deficiency anemia at delivery in pregnant women receiving routine iron supplementation (20 and 66 mg elemental iron daily) versus placebo (3% vs. 11%; RR, 0.28 [95% CI, 0.12 to 0.68];42 and 0% vs. 17.5%; p=0.02^50^), yet two smaller fair-quality trials (both <150 participants) conducted in Iran and the United States found no difference between groups (0% in both groups;49 5% vs. 29%; p=0.137 for adolescents and 10.5% vs. 22.2%; p=0.259 for adults45). Incidence in the control group in the U.S. study was quite high, although the study did not indicate that the women and adolescents enrolled were at higher risk. Pooling the findings of these trials (in five populations) resulted in a statistically significant difference between groups favoring supplementation (20 to 66 mg iron daily) (four trials; RR, 0.29 [95% CI, 0.17 to 0.49]; I^2^=0%) (Appendix C3).42,45,49,50

The good-quality Australian trial found no significant difference between groups at 6 months postpartum (2.6% vs. 1.7%; RR, 1.55 [95% CI, 0.38 to 6.40]).42

Iron deficiency. Six trials reported incidence of iron deficiency (defined as serum ferritin <12, 15, or 20 μg/L), ranging from 0 to 56 percent in the supplementation group and 28 to 85 percent in the placebo group, with consistent results across measurement timepoints; however, not all results reached statistical significance.42,47-49,52,53

Two fair-quality trials in the United States of women at higher risk for iron deficiency that replaced the placebo portion with supplementation at approximately 28 weeks' gestation found lower rates of iron deficiency in the supplementation groups (53% vs. 65%; p=0.08;^48^ and 56.4% vs. 65.1%; p=0.214^47^). Incidence was 8.7 to 12 percent lower (absolute differences) in the supplementation groups but did not reach statistical significance in either study. One fair-quality Norwegian trial compared heme iron versus nonheme iron supplements versus placebo (three arms) and found lower rates for both supplementation groups at 38 weeks (29% vs. 52% vs. 85%; p<0.001 and p<0.05) compared with placebo.52 However, the rate of iron deficiency in the control group (85%) was extremely high in a population that was not noted to be at high risk. It is not clear how applicable these data are to average or high-risk populations in the United States.

Three trials (two fair-quality, one good-quality) found lower rates of iron deficiency at delivery in the supplementation group (9.5% vs. 28.2%; p<0.05;^49^ 35% vs. 58%; RR, 0.60 [95% CI, 0.48 to 0.76];42 and 0% vs. 65.2%; p=0.02^53^). Pooled results of the two trials with comparable dosing regimens (20 to 60 mg elemental iron daily) indicated a statistically significant difference in iron deficiency at term in favor of supplementation (two trials; RR, 0.53 [95% CI, 0.33 to 0.84]; p=0.006; I^2^=40%) (Appendix C4).42,49

A good-quality trial reported lower rates of iron deficiency at 6 months postpartum among supplemented pregnant women compared with placebo (16% vs. 29%; RR, 0.57 [95% CI, 0.38 to 0.84]).42 The trial comparing heme iron versus nonheme iron versus placebo (three arms) found that the heme-iron supplemented group had significantly lower rates of iron deficiency than the placebo group at both 6 to 10 weeks postpartum (8% vs. 52%; p<0.01) and 24 weeks postpartum (4% vs. 51%; p<0.001).52 However, the nonheme-iron supplemented group (the typical iron supplement in the United States) was not significantly different from placebo at 6 to 10 weeks postpartum (27% vs. 52%; p=NS), although the absolute difference between groups was quite large. The difference in incidence of iron deficiency was significant at 24 weeks postpartum (17% vs. 51%; p<0.05). As noted above, this study had high control group rates of iron deficiency relative to prevalence in pregnant women in the United States.

Anemia. Four trials reported incidence of anemia (defined as hemoglobin <100 or 110 g/L), ranging from 3.7 to 21 percent in the supplementation group and 4.5 to 27 percent in the placebo group.42,47,48,52

Two fair-quality trials conducted in the United States of women at higher risk for iron deficiency found no difference between groups during the third trimester (19.8% vs. 26.7%; p=0.25;^47^ and 21% vs. 19%; p=0.65^48^).

One good-quality Australian trial reported a significantly lower incidence of anemia at delivery in pregnant women receiving routine iron supplementation versus placebo (7% vs. 16%; RR, 0.45 [95% CI, 0.25 to 0.82]).42

This same Australian trial did not find a difference in rates of anemia at 6 months postpartum (3.7% vs. 4.5%; RR, 0.82 [95% CI, 0.30 to 2.21]).42

Hemoglobin. Eleven good- or fair-quality trials of women receiving iron supplementation versus placebo reported hemoglobin levels during the third trimester, at delivery, or up to 6 months postpartum, ranging from 114 to 139 g/L in the supplementation group and 113 to 134 g/L in the placebo group.42-51,53

One good-quality trial conducted in Iran (n=727) and one fair-quality trial in Ireland reported higher third-trimester hemoglobin levels with supplementation (50 and 120 mg elemental iron daily, respectively) compared with placebo (138 vs. 125 g/L; p<0.001;^46^ and 135 vs. 126 g/L; p=0.04^43^). Two fair-quality trials of higher-risk women, both conducted in the United States (n=275 and 429), found no difference between groups (117 vs. 116 g/L; p=0.499;^47^ and 114 vs. 114 g/L; p=0.81^48^). Overall hemoglobin levels in the U.S. trials were lower, perhaps due to their higher risk status.

Eight trials, with sample sizes ranging from 45 to 1,164 participants, conducted in Australia, Hong Kong, Iran, Norway, Ireland, Denmark, and the United States, found that women in the supplementation group had higher hemoglobin levels at delivery than those receiving placebo, although not all differences were significant. Statistically significant differences were found in five trials of adult women at average risk for anemia receiving 20 to 120 mg elemental iron daily (127 vs. 120 g/L; RR, 6.9 [95% CI, 4.4 to 9.3];42 122 vs. 118 g/L; p<0.001;^44^ 139 vs. 128 g/L; p<0.0001;^51^ 137 vs. 120 g/L; p<0.001;^43^ and 127 vs. 116 g/L; p<0.0001^50^) and a subgroup of adolescents from another trial receiving 60 mg elemental iron daily (122 vs. 115 g/dL; p=0.024).45 Two fair-quality trials conducted in the United States and Iran found no statistical difference between groups of adult women receiving 60 mg elemental iron daily (123 vs. 121 g/L; p=NS;49 and 121 vs. 117 g/L; p=0.135^45^). Although the absolute differences in these two studies (both had <150 participants) were small, they were in the same direction, and the studies may have lacked adequate sample sizes to demonstrate statistical differences. One small (n=45) trial conducted in Norway did not report a p-value but also found higher hemoglobin values in the supplementation group (126 vs. 113 g/L).53

A good-quality Iranian trial found higher hemoglobin levels at 6 weeks postpartum in women receiving iron supplementation (50 mg elemental iron) versus placebo (133 vs. 126 g/L; p<0.0001),51 but the good-quality Australian trial did not find a difference at 6 months postpartum in women receiving 20 mg elemental iron compared with placebo (135 vs. 134 g/L; RR, 1.6 [95% CI, −0.1 to 3.3]).42

Serum ferritin. Ten trials reported serum ferritin levels during the third trimester, at delivery, or up to 6 months postpartum, ranging from 7.4 to 34 μg/L in the supplementation group and 6.0 to 26 μg/L in the placebo group.42-45,47-51,53

Two fair-quality trials of women at higher risk for iron deficiency conducted in the United States found no difference between third-trimester serum ferritin levels with supplementation (30 mg elemental iron daily) versus placebo (7.4 vs. 7.4 μg/L; p=0.985;^47^ and 22.0 vs. 20.3 μg/L; p=0.48^48^). However, one trial of 120 mg elemental iron daily conducted in Ireland found lower serum ferritin levels in the placebo group (32.6 vs. 12.8 μg/L; p=0.04).43

Five trials of women at average risk for anemia (two good-quality, three fair-quality) conducted in Hong Kong, Australia, Denmark, the United States, and Iran found that women receiving supplementation (20 to 66 mg elemental iron) had significantly higher serum ferritin levels at delivery than those receiving placebo (30.3 vs. 24.9 μg/L; p<0.003;^44^ 21 vs. 14 μg/L; RR, 7.1 [95% CI, 4 to 10.2];42 12.0 vs. 6.2 μg/L; p=0.010 for adolescents and 12.9 vs. 7.6 μg/L; p=0.027 for adults;45 26.2 vs. 19.1 μg/L; p<0.0001;^51^ and 22 vs. 14 μg/L; p<0.0001^50^). An additional small (n=45) trial conducted in Norway had results in the same direction (24.0 vs. 6.0 μg/L), but p-values were not reported.53 However, one small fair-quality Iranian trial found no difference in serum ferritin levels between groups at delivery (28.1 vs. 22.1 μg/L; p=NS49).

Two good-quality trials of women at average risk for anemia, one in Iran and one in Australia, also reported ferritin levels at 6 weeks and 6 months postpartum, and both found significantly higher serum ferritin levels in women receiving supplementation (20 to 50 mg elemental iron daily) versus placebo (21.7 vs. 18.5 μg/L; p<0.0001;^51^ and 34 vs. 26 μg/L; RR, 7.9 [95% CI, 3.5 to 12.3,^42^ respectively).

#### Intermediate Outcomes—Infant

A 6-month followup study of the good-quality Australian trial42 of 336 infants whose mothers were randomly allocated to receive 20 mg of elemental iron supplementation daily starting at 20 weeks' gestation and continuing until delivery was the only study to report followup infant hematological outcomes; it found no differences in iron status in children at 6 months (iron deficiency anemia, 0% vs. 0%; p=NS; iron deficiency, 6% vs. 4%; p=0.27; hemoglobin, 121 vs. 119 g/L; p=0.10; and serum ferritin, 32.5 vs. 30.8 μg/L; p=0.48) (Appendix B1).54

### Key Question 2 What Are the Harms of Routine Iron Supplementation in Pregnant Women?

#### Summary

Ten good- and fair-quality trials included for Key Question 2 assessed harms of routine iron supplementation in pregnant women, although none of the harms were serious or associated with long-term significance, and there were mostly no significant differences between groups.42-49,52,53 Most reported harms included transient treatment effects such as nausea, constipation, and diarrhea. Findings on rates of maternal hypertension were inconsistent.

The prior USPSTF report38 included one unblinded fair-quality trial comparing reported adverse effects of routine supplementation with selective supplementation (not placebo).

#### Evidence

Harms were sparsely and variably reported, often as an ad hoc event, in 10 trials that compared iron supplementation with placebo in Australia, Iran, Hong Kong, Ireland, the United States, and Norway (these studies were also included in Key Question 1) (Table 4; Appendixes B1 and B2). Two were rated good-quality42,46 and eight were fair-quality.43-45,47-49,52,53 Details are reported below.

Table 4 Maternal Adverse Events

Study, Year Country N Quality | Iron Supplement Dose and Formulation, Initiation | Risk Factors Reported | Supplementation vs. Control
Study, Year Country N Quality | Iron Supplement Dose and Formulation, Initiation | Risk Factors Reported | Gestational Diabetes | Pregnancy-Induced Hypertension | Gastrointestinal Events | Other
Barton 1994^43^ Ireland N=97 Fair | 120 mg elemental iron daily starting at 14 weeks' gestation | Race: NR (Ireland) Nulliparous: 45%–47% | | Hypertensive disorder: 7.5% vs. 9.0%; p=0.78 | | Antepartum hemorrhage: 5.7% vs. 4.5%; p=0.81
Chan 2009^44^ Hong Kong N=1,164 Fair | 60 mg elemental iron daily starting at <16 weeks' gestation | Race: NR (Hong Kong) Parity ≥2: 0.50 vs. 0.18% BMI: 20.8 vs. 21.0 kg/m^2^ | At 28 weeks' gestation: 10% vs. 10%; OR, 1.04 (95% CI, 0.7 to 1.53) | | | Nonadherence: 46% overall; p=NS
Cogswell 2003^47^ U.S. N=275 Fair | 30 mg elemental iron daily starting at <20 weeks' gestation | Race: 56%–57% white, 24%–26% black, 16%–17% Hispanic Parity ≥2: 31% vs. 24% ≤ High school education: 73%–76% SES: 100% eligible for WIC | | | | Nonadherence at week 28: 36.6% vs. 34.8%; p=NS Side effects reported at >1 visit from enrollment to week 28: 24.6% vs. 18.5%; p=NS
Eskeland 1997^52^ Norway N=90 Fair | 27 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Norway) BMI: 22–23 kg/m^2^ Parity ≥2: 0%–10% Single: 3%–17% Low education: 3%–10% | | | | No difference in fatigue or other side effects; p=NS Nonadherence: 19% (combined 2 iron groups) vs. 18%; p=NS
Falahi 2011^49^ Iran N=148 Fair | 60 mg elemental iron daily starting at <20 weeks' gestation | Race: NR (Iran) BMI: 24–25 kg/m^2^ | | 1.4% (1 case) vs. 0%; p=NS
Makrides 2003^42^ Australia N=430 Good | 20 mg elemental iron daily starting at 20 weeks' gestation | Race: 95% white, 0.9%–3.3% Aboriginal, 1.4%–2.3% Asian Multiparous: 52%–53% BMI: 26 kg/m^2^ Highest level of education: 12%–15% year <10, 27%–28% year 11, 28%–33% year 12, 5%–8% trade certificate or diploma, 21% tertiary degree | | | [underlined: At 36 weeks' gestation:] Nausea: 29% vs. 28%; RR, 1.04 (95% CI, 0.76 to 1.42) Stomach pain: 35% vs. 30%; RR, 1.19 (95% CI, 0.89 to 1.58) Heartburn: 68% vs. 69%; RR, 0.99 (95% CI, 0.86 to 1.13) Vomiting: 12% vs. 13%; RR, 0.89 (95% CI, 0.53 to 1.50) Rash: 7.5% vs. 6.2%; RR, 1.21 (95% CI, 0.58 to 2.51) Bowel movement ≤3 times/week: 4% vs. 1.6%; RR, 2.56 (95% CI, 0.69 to 9.51) | Nonadherence: 14% vs. 15%; p=NS
Meier 2003^45^ U.S. N=111 Fair | 60 mg elemental iron daily starting at 1st prenatal visit | Race: NR (Wisconsin) Private group practice | | | [underlined: Adolescents:] Nausea: 53% vs. 65%; p=NS Vomiting: 41% vs. 41%; p=NS Constipation: 29% vs. 12%; p=NS Diarrhea: 13% vs. 17%; p=NS [underlined: Adults:] Nausea: 63% vs. 53%; p=NS Vomiting: 35% vs. 21%; p=NS Constipation: 24% vs. 28%; p=NS Diarrhea: 14% vs. 24%; p=NS | [underlined: Adolescents:] Nonadherence: 4.5% vs. 12.6%; p=0.320 [underlined: Adults:] Nonadherence: 2.2% vs. 16.1%; p=0.036
Romslo 1983^53^ Norway N=45 Fair | 200 mg elemental iron daily starting within 10 weeks' gestation | Race: NR (Norway) | | | “None of the women complained of discomfort that could be attributed to the medication” | Nonadherence: 45% overall; p=NS
Siega-Riz 2006^48^ U.S. N=429 Fair | 30 mg elemental iron daily starting at <20 weeks' gestation | Race: 58%–65% black, 31%–37% white Single: 75% Parity ≥2: 44% vs. 41% SES: 100% eligible for WIC | | | | Nonadherence: 34% vs. 37%; p=0.27
Ziaei 2007^46^ Iran N=727 Good | 50 mg elemental iron daily starting at 20 weeks' gestation | Race: NR (Iran) BMI: 24 kg/m^2^ Parity: 1.7 | | 10 (2.7%) vs. 3 (0.8%); p=0.05

Note: Bolded p-value shows a significant difference.

Abbreviations: BMI=body mass index; CI=confidence interval; NR=not reported; NS=not significant; OR=odds ratio; RR=relative risk; SES=socioeconomic status; WIC= Special Supplemental Nutrition Program for Women, Infants, and Children.

Gastrointestinal adverse effects. Two trials conducted in Australia and the United States reported no difference in various minor gastrointestinal adverse effects between supplementation (60 and 20 mg elemental iron daily, respectively) and placebo groups.42,45

Any adverse events. Of four studies reporting rates of any adverse event, none reported significant differences between groups, including a good-quality Australian study (n=430) that measured harms at 36 weeks' gestation,42 a U.S. study of pregnant adolescents and adults that measured adverse events at 24 to 28 weeks' gestation,45 another U.S. study of women at higher risk for iron deficiency that reported any adverse event at more than one visit from enrollment to week 28,^47^ and a Norwegian study that measured fatigue and other adverse events at 28 and 36 weeks' gestation.52 One additional Norwegian trial (n=54) reported that none of the women reported discomfort that could be attributed to the medication.53

Hypertension. The sparse findings on maternal hypertension were inconsistent. One good-quality Iranian trial (n=205) found a lower rate of hypertension diagnoses during pregnancy in women not in the supplementation group (2.7% vs. 0.8%; p=0.05).46 A fair-quality Iranian trial (n=148) reported a single case of hypertension during pregnancy in the supplementation group and none in the control group (1.4% vs. 0%; p=NS).49 An Irish trial (N=97) reported no differences between groups in hypertensive disorder (7.5% for supplementation vs. 9.0% for placebo; p=0.78).43

Diabetes. One Hong Kong study found that iron supplementation beginning at less than 16 weeks' gestation did not increase risk for gestational diabetes.44

Nonadherence. While evidence is lacking on discontinuation due to adverse effects, adherence/nonadherence was used as a proxy measure. Nonadherence in adult women was lower with iron supplementation compared with placebo, but nonadherence in adolescents did not reach statistical significance compared with placebo in one small (n=111) trial conducted in the United States (2.2% vs. 16.1%; p=0.036; and 4.5% vs. 12.6%; p=0.320^45^). Six other trials found no difference in nonadherence to supplementation versus placebo,42,44,47,48,52,53 ranging from 2 to 46 percent; however, most studies reported that these data were not available for all included participants.

Accidental overdose. No studies reported on accidental overdose.

## Screening for Iron Deficiency Anemia in Pregnant Women

### Key Question 1 What Are the Benefits of Screening for Iron Deficiency Anemia in Asymptomatic, Pregnant Women on Maternal and Infant Health Outcomes?

No randomized trial or observational study compared clinical outcomes between pregnant women who were screened or not screened for iron deficiency anemia.

### Key Question 2 What Are the Harms of Screening for Iron Deficiency Anemia in Pregnant Women?

No randomized trial or observational study compared harms between pregnant women who were screened or not screened for iron deficiency anemia.

### Key Question 3 What Are the Benefits of Treatment of Iron Deficiency Anemia in Pregnant Women on Maternal and Infant Health Outcomes?

No good- or fair-quality randomized trial or observational study meeting inclusion criteria compared clinical outcomes between pregnant women who were treated or not treated for iron deficiency anemia.

An older poor-quality observational study (n=103) from 1969 examined the effects of iron treatment (two oral formulations and intravenous iron compared with placebo) of anemia in pregnant women72 (iron deficiency was not a criterion for enrollment). Laboratory values were reported by treatment group, but these groups were not analyzed using statistical methods. Women with low hemoglobin values at the first prenatal visit were treated and followed through 36 weeks' gestation. Although there was a significant increase in hemoglobin levels during the first month of therapy for all groups receiving iron therapy compared with the placebo group, there was no significant difference between treatment groups in hemoglobin or serum iron values at 36 weeks.

### Key Question 4 What Are the Harms of Iron Treatment in Pregnant Women?

No randomized good- or fair-quality trial or observational study meeting inclusion criteria compared harms between pregnant women who were treated or not treated for iron deficiency anemia.

The same poor-quality study (n=103) from 1969 discussed in Key Question 3 reported adverse effects of iron treatment (two oral formulations and intravenous iron) of anemia in pregnant women compared with placebo.72 Adverse events were reported at the end of 1 month of therapy, and results were not analyzed with statistical methods. Nausea, vomiting, and abdominal cramping were reported by slightly more patients in the oral iron groups. Constipation was similar between groups receiving placebo and iron gluconate, but slightly lower with ferrous sulfate. No patient experienced adverse effects severe enough to withdraw from therapy.

### Key Question 5 In Pregnant Women With Iron Deficiency, With or Without Anemia, What Is the Association Between Change in Maternal Iron Status (Including Changes in Ferritin or Hemoglobin Level) and Improvement in Newborn and Peripartum Outcomes in U.S.-Relevant Populations?

No good- or fair-quality study meeting inclusion criteria compared the association between change in maternal iron status and clinical outcomes in pregnant women with iron deficiency, with or without anemia. We also found no studies that met inclusion criteria and were conducted in developing countries.

One older poor-quality observational study with a randomized component73 (n=203) evaluated the effect of iron supplementation and treatment in women in France. Twenty women (9.8%) were immigrants from Mediterranean countries, Africa, and the Far East with notably different dietary habits. Iron status was evaluated at 6 months' gestation, and 48 women with hemoglobin levels less than 11g/dL were given iron treatment (105 mg elemental iron), while the remaining nonanemic women were randomized to either supplementation (105 mg elemental iron) or placebo. At delivery, data were available for only 59 percent (120/203) of women, with slightly lower percentages of women in the randomized groups providing data at delivery. Iron as treatment or supplementation resulted in increases in maternal hematological indexes (hemoglobin and ferritin). Baseline serum ferritin levels were 19, 20, and 21 μg/L in women in the anemic, nonanemic supplementation, and nonanemic placebo groups, respectively, and corresponding baseline hemoglobin levels were 10.4, 11.7, and 11.9 g/dL. At delivery, serum ferritin levels were improved similarly in women receiving iron (33 and 34 μg/L) but not in the placebo group (20 μg/L). Hemoglobin values improved in all groups, but more in the iron-treated groups. Mean change in hemoglobin levels was 2.4 g/dL in the anemic group, 1.8 g/dL in the nonanemic group, and 0.9 g/dL in the placebo group. In addition, while iron supplementation resulted in an increase in these maternal hematological indexes, no significant differences in ferritin levels were observed in the newborns across the groups.

With respect to clinical outcomes, the study reported no differences between the three groups for perinatal outcomes, including complications at delivery, length of gestation, birthweight, or Apgar scores (details not reported). No other clinical outcomes were reported.