# Methods

## Key Questions and Analytic Frameworks

Using methods developed by the USPSTF,36 and in consultation with the USPSTF, we determined the scope and Key Questions for this review37,38 and created analytic frameworks with the Key Questions and the patient population, interventions, and outcomes reviewed. The target population was asymptomatic, pregnant women. The Key Questions are presented as two separate analytic frameworks: one for routine supplementation (Figure 1) and one for screening (Figure 2).

Figure 1 Analytic Framework for Routine Iron Supplementation in Pregnant Women

Abbreviation: KQ=key question.

Key Questions
1. What are the benefits of routine iron supplementation in pregnant women on maternal and infant health outcomes?
2. What are the harms of routine iron supplementation in pregnant women?

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the populations, interventions and related harms, and outcomes. The population includes pregnant women who are asymptomatic for iron deficiency anemia. After routine iron supplementation, and the assessment of any harms of routine supplementation, an arrow leads to the outcomes included in the review. Intermediate outcomes include various measure of iron status. A dotted line leads from the intermediate outcomes to the clinical outcomes examined, which include maternal and infant morbidity and mortality, including birth outcomes and quality of life. In addition, an overarching arrow from routine supplementation to the health outcomes of interest represents the direct effect of supplementation on these health outcomes.

Figure 2 Analytic Framework for Screening for Iron Deficiency Anemia in Pregnant Women

Abbreviation: KQ=key question.

Key Questions
1. What are the benefits of screening for iron deficiency anemia in asymptomatic pregnant women on maternal and infant health outcomes?
2. What are the harms of screening for iron deficiency anemia in pregnant women?
3. What are the benefits of treatment of iron deficiency anemia in pregnant women on maternal and infant health outcomes?
4. What are the harms of iron treatment in pregnant women?
5. In pregnant women with iron deficiency anemia, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?

Contextual Questions (not systematically reviewed)
1. How well does risk assessment identify pregnant women who are at increased risk for iron deficiency anemia?
2. What is the yield (number of new diagnoses) of repeat (periodic) screening in asymptomatic pregnant women, and at what timing intervals?

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the populations, intervention and related harms, and outcomes. The population includes pregnant women who are asymptomatic for iron deficiency anemia. After screening, and the assessment of any harms of screening, a box represents the diagnosis of iron deficiency anemia. An arrow leading from this box represents treatment, after which the outcomes included in the review are indicated. Intermediate outcomes include various measure of iron status. A dotted line leads from the intermediate outcomes to the health outcomes examined, representing the association between intermediate and health outcomes. Health outcomes include maternal and infant morbidity and mortality, including birth outcomes and quality of life. A subsequent arrow from treatment examines the resulting harms of treatment. In addition, an overarching arrow from screening to the health outcomes of interest represents the direct effect of screening on these health outcomes.

### Routine Iron Supplementation in Pregnant Women

1. What are the benefits of routine iron supplementation in pregnant women on maternal and infant health outcomes?
2. What are the harms of routine iron supplementation in pregnant women?

### Screening for Iron Deficiency Anemia in Pregnant Women

1. What are the benefits of screening for iron deficiency anemia in asymptomatic, pregnant women on maternal and infant health outcomes?
2. What are the harms of screening for iron deficiency anemia in pregnant women?
3. What are the benefits of treatment of iron deficiency anemia in pregnant women on maternal and infant health outcomes?
4. What are the harms of iron treatment in pregnant women?
5. In pregnant women with iron deficiency, with or without anemia, what is the association between change in maternal iron status (including changes in ferritin or hemoglobin level) and improvement in newborn and peripartum outcomes in U.S.-relevant populations?

We also addressed two Contextual Questions requested by the USPSTF to help inform the report. Contextual Questions address background areas deemed important by the USPSTF for informing its recommendations. Contextual Questions are not reviewed using systematic review methodology but rather by summarizing the evidence from key informative studies.

### Contextual Questions

1. How well do risk-assessment tools identify pregnant women at increased risk for iron deficiency anemia?
2. What is the yield (number of new diagnoses) of repeat (periodic) screening in asymptomatic, pregnant women, and at what timing intervals?

For the screening framework, Key Question 1 focuses on direct evidence on the effectiveness of screening for iron deficiency anemia in asymptomatic, pregnant women compared with no screening. Such direct evidence on the effectiveness of screening interventions may be limited. Therefore, the remainder of the analytic framework (Key Questions 2 through 5) evaluates the chain of indirect evidence needed to link screening with improvement in important health outcomes. Links in the chain of indirect evidence include the accuracy of screening in identifying pregnant women with iron deficiency anemia, the effectiveness of interventions in treating identified iron deficiency anemia and reducing the incidence of complications, the association between improvements in intermediate outcomes and clinical health outcomes, and harms (including infant harms) associated with screening and treatments. Implicit in the indirect chain of evidence is that, to understand the benefits and harms of screening, it is necessary but not sufficient to show that pregnant women with iron deficiency anemia can be identified; it is also necessary to show that there are effective treatments for those identified. Not all of the indirect links are included in this update, as some of the links (e.g., test accuracy) are considered to already be established.

A separate report covers outcomes for children ages 6 to 24 months directly receiving iron supplementation.39

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Ovid MEDLINE® (1996 to August 2014) for relevant studies and systematic reviews. Because of the variation in scope between this report and the prior USPSTF reports, we also searched the reference lists of relevant systematic reviews to identify studies published prior to 1996. Search strategies are available in Appendix A1.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2).

Articles were selected for full review if they were about iron deficiency anemia in pregnant women, were relevant to a Key Question, and met the predefined inclusion criteria. We restricted inclusion to English-language articles and excluded studies published only as abstracts. Studies of nonhuman subjects were also excluded, and studies had to report original data. For supplementation Key Questions 1 and 2 and screening Key Questions 1 through 4, we focused on studies that used iron supplementation and treatment regimens commonly used in clinical practice in the United States and excluded studies conducted in resource-poor populations, including nutritionally-deficient populations in developing countries. We included studies conducted in countries listed as having “high” or “very high” human development, using the United Nations International Human Development Index as a guide.40 For Key Question 5, we also searched for studies conducted in any country and using any intervention that was feasible and/or approved by the Food and Drug Administration that otherwise met our inclusion criteria. Women needed to have iron deficiency (with or without anemia) for inclusion in Key Question 5. Maternal clinical outcomes included Cesarean delivery, postpartum depression, or other clinical outcomes; harms included discontinuation of iron and other harms related to screening, supplementation, or treatment. Maternal intermediate outcomes included incidence of iron deficiency anemia, iron deficiency, and anemia, as well as hematological indexes and ferritin levels. Infant clinical outcomes included birth outcomes (birthweight and size, preterm delivery, gestational age, perinatal mortality) and infant intermediate outcomes included hematological indexes and ferritin levels. We included randomized, controlled trials; nonrandomized controlled clinical trials; and cohort studies for all Key Questions. Association studies were included for Key Question 5. If good- or fair-quality studies were available, evidence from poor-quality studies was excluded.41 However, if evidence was lacking and only poor-quality studies met inclusion criteria, they were included. Appendix A3 shows the results of our literature search and selection process, and Appendix A4 lists excluded studies pulled at the full-text level, with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about each article's study design, patient population, setting, screening method, treatment regimen, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Two investigators independently applied criteria developed by the USPSTF36 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through consensus. When otherwise not reported and where possible, we calculated relative risks (RRs) and 95 percent CIs or p-values.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, or poor) using methods developed by the USPSTF, based on the number, quality, and size of studies; consistency of results among studies; and directness of evidence.36

We conducted meta-analyses to calculate risk ratios of the effects of routine iron supplementation on incidence of preterm delivery, low birthweight, iron deficiency anemia at term, and iron deficiency at term using the Mantel-Haenszel random- or fixed-effects models with RevMan software (The Cochrane Collaboration, Copenhagen, Denmark). Statistical heterogeneity was assessed using the I^2^ statistic. Because of methodological shortcomings in the studies and differences across studies in design, interventions (timing and dosing), patient populations, and other factors, meta-analysis was not attempted for all outcome measures.

## External Review

The draft report was reviewed by content experts (Appendix A6), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners, and was revised prior to finalization.