# Figures

Appendix C1 Meta-Analysis: Preterm Delivery

Abbreviations: CI=confidence interval; M-H=Mantzel-Haenzel.

This figure is a meta-analysis forest plot. Risk ratios of the effects of routine iron supplementation on incidence of preterm delivery were calculated for two studies (Chan 2009 and Falahi 2011), with a pooled risk ratio of 0.88 (95% CI, 0.55 to 1.42) and overall heterogeneity of 0%.

Appendix C2 Meta-Analysis: Low Birthweight

Abbreviations: CI=confidence interval; M-H=Mantzel-Haenzel.

This figure is a meta-analysis forest plot. Risk ratios of the effects of routine iron supplementation on incidence of low birthweight were calculated for three studies (Falahi 2011, Makrides 2003, and Meier 2003 [separate adult and adolescent populations]), with a pooled risk ratio of 1.10 (95% CI, 0.54 to 2.25) and overall heterogeneity of 0%.

Appendix C3 Meta-Analysis: Iron Deficiency Anemia at Term

Abbreviations: CI=confidence interval; M-H=Mantzel-Haenzel.

This figure is a meta-analysis forest plot. Risk ratios of the effects of routine iron supplementation on incidence of maternal iron deficiency anemia at term were calculated for four studies (Falahi 2011, Makrides 2003, Meier 2003 [separate adult and adolescent populations], and Milman 1994), with a pooled risk ratio of 0.29 (95% CI, 0.17 to 0.49) and overall heterogeneity of 0%.

Appendix C4 Meta-Analysis: Iron Deficiency at Term

Note: Meta-analysis includes 2 studies with dosages of 20 and 60 mg (Romslo study with dosage of 200 mg excluded).

Abbreviations: CI=confidence interval; M-H=Mantzel-Haenzel.

This figure is a meta-analysis forest plot. Risk ratios of the effects of routine iron supplementation on incidence of maternal iron deficiency at term were calculated for three studies (Falahi 2011, Makrides 2003, Romslo 1983), with a pooled risk ratio of 0.53 (95% CI, 0.33 to 0.84) and overall heterogeneity of 40%.