# Evidence and Quality Tables

Appendix B1 Evidence Table of Trials of Routine Iron Supplementation in Pregnant Women

Appendix B2 Quality Assessment of Trials of Routine Iron Supplementation in Pregnant Women