# Detailed Methods

## Appendix A1 Search Strategies

### Supplementation: Key Questions 1 and 2

Database: Ovid MEDLINE(R) without Revisions

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. pc.fs.
6. Dietary Supplements/
7. Iron/
8. 6 and 7
9. (iron adj2 supplemen$).mp.
10. Iron, Dietary/ad
11. or/8-10
12. 4 and 5
13. 4 and 11
14. 12 or 13
15. limit 14 to humans
16. limit 15 to english language
17. limit 15 to abstracts
18. exp Pregnancy/
19. pregnan$.mp.
20. 18 or 19
21. 17 and 20

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. pc.fs.
6. Dietary Supplements/
7. Iron/
8. 6 and 7
9. (iron adj2 supplemen$).mp.
10. Iron, Dietary
11. or/8-10
12. 4 and 5
13. 4 and 11
14. 12 or 13
15. exp Pregnancy/
16. pregnan$.mp.
17. 15 or 16
18. 14 and 17

### Screening: Key Questions 1 and 2

Database: Ovid MEDLINE(R) without Revisions

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. exp Mass Screening/
6. screen$.mp.
7. 5 or 6
8. 4 and 7
9. Pregnancy/
10. pregnan$.mp.
11. 9 or 10
12. 8 and 11
13. limit 8 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
14. 12 or 13
15. limit 14 to humans
16. limit 15 to english language
17. limit 15 to abstracts
18. 16 or 17

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. exp Mass Screening/
6. screen$.mp.
7. 5 or 6
8. 4 and 7
9. Pregnancy/
10. pregnan$.mp.
11. 9 or 10
12. 8 and 11

### Treatment: Key Questions 3 and 4

Database: Ovid MEDLINE(R) without Revisions

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. (de or dt or th).fs.
6. Iron/or Iron, Dietary/
7. 4 and (5 or 6)
8. exp Pregnancy/
9. pregnan$.mp.
10. 7 and (8 or 9)
11. limit 10 to (english language and humans)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. (de or dt or th).fs.
6. Iron/or Iron, Dietary
7. 4 and (5 or 6)
8. exp Pregnancy/
9. pregnan$.mp.
10. 7 and (8 or 9)

### Association: Key Question 5

Database: Ovid MEDLINE(R) without Revisions

1. Iron/
2. Iron, Dietary/
3. Anemia, Iron-Deficiency/
4. 1 or 2
5. 4 and (anemia or anemic or deficiency or deficient).mp.
6. 3 or 5
7. Treatment Outcome/
8. 6 and 7
9. 6 and association.mp.
10. 8 or 9
11. limit 10 to humans
12. limit 11 to english language

### Systematic Reviews: All Key Questions

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. iron deficiency anemia.mp.
2. (“iron deficiency” adj2 anemia).mp.
3. 1 or 2

### Iron Deficiency Without Anemia

Database: Ovid MEDLINE(R) without Revisions

1. Iron/df [Deficiency]
2. Pregnancy Complications, Hematologic/or Pregnancy
3. 1 and 2
4. limit 3 to humans

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Iron/df [Deficiency]
2. Pregnancy Complications, Hematologic/or Pregnancy/
3. 1 and 2

## Appendix A2 Inclusion and Exclusion Criteria

Routine Iron Supplementation in Pregnant Women

| Include | Exclude
Populations | Pregnant adolescents and women and their infants | Severely malnourished populations not representative of those in the United States
Interventions | Oral iron supplementation, iron-fortified foods | Injectable forms of iron
Comparators | No supplementation
Outcomes | KQ 1: Maternal outcomes (Cesarean delivery rates, postpartum depression, incidence of iron deficiency anemia and iron deficiency, hematological indexes and ferritin levels) and infant outcomes (low birthweight, preterm delivery, perinatal mortality, hematological indexes and ferritin levels) KQ 2: More serious harms; discontinuations; accidental overdose
Settings | Primary care relevant
Timing | KQ 1: Long term KQ 2: Short or long term
Study Designs | KQ 1: Randomized, controlled trials; controlled cohort studies and other controlled observational studies KQ 2: Studies from KQ 1 and large uncontrolled observational studies | KQ 1: Uncontrolled studies

Screening for Iron Deficiency Anemia in Pregnant Women

| Include | Exclude
Populations | KQs 1, 2: Pregnant adolescents and women and their infants asymptomatic for iron deficiency anemia KQs 3, 4: Pregnant adolescents and women with iron deficiency anemia and their infants KQ 5: Pregnant women with iron deficiency, with or without anemia and their infants | - Severely malnourished populations not representative of those in the United States; - Those symptomatic for iron deficiency anemia
Interventions | KQs 1, 2: Screening for iron deficiency anemia KQs 3, 4: Oral iron supplementation, iron-fortified foods | Injectable forms of iron
Comparators | KQs 1, 2: No screening for iron deficiency anemia KQs 3, 4: No treatment KQ 5: Change in maternal iron deficiency and/or iron deficiency anemia status
Outcomes | KQs 1, 3, 5: Maternal outcomes (Cesarean delivery rates, postpartum depression) and infant outcomes (low birthweight, preterm delivery, perinatal mortality, hematological indexes and ferritin levels) KQ 2: Overdiagnosis, anxiety, labeling KQ 3: Incidence of iron deficiency anemia and iron deficiency; hematological indexes and ferritin levels KQ 4: More serious harms; discontinuations and overtreatment
Settings | Primary care relevant
Timing | KQs 1, 3: Long term KQs 2, 4, 5: Short or long term
Study Designs | KQs 1, 3: Randomized, controlled trials; controlled cohort studies and other controlled observational studies KQs 2, 4: Studies included from other KQs and large uncontrolled observational studies KQ 5: Association studies | KQs 1, 3: Uncontrolled studies

Abbreviation: KQ=key question.

## Appendix A3 Literature Flow Diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^b^ Other sources include prior reports, reference lists of relevant articles, and systematic reviews.

^c^ Some studies are included for more than one Key Question.

^d^ Excluded poor-quality studies for this Key Question because of availability of good- and fair-quality evidence.

This figure is a literature flow diagram depicting the search and selection of studies for the present review. The diagram shows that 1,431 abstracts of potentially relevant articles were identified through the MEDLINE and Cochrane databases, 1,148 articles and background papers were excluded, 283 articles were reviewed at the full-text level, and 269 articles were excluded for the following reasons: 61 due to wrong population, 21 due to wrong intervention, 12 due to wrong outcome, 44 due to wrong study design, 41 due to wrong publication type, 6 due to non-English language, 57 due to wrong comparison, 11 were systematic reviews that were not directly used, and 16 due to poor-quality for supplementation Key Question 1. 12 unique trials (in 14 publications) were ultimately included in the review. For the Routine Iron Supplementation section of the report, for Key Question 1, 5 trials were included for maternal clinical outcomes, 11 trials were included for infant birth outcomes, and 12 trials were included for hematological outcomes. For Key Question 2, 10 trials were included on harms of supplementation. For the Screening for Iron Deficiency Anemia section of the report, no studies were included for any of the Key Questions.

## Appendix A4 Excluded Studies

### Wrong Population

Adetifa I, Okomo U. Iron supplementation for reducing morbidity and mortality in children with HIV. Cochrane Database Syst Rev. 2009;(1):19160298. [pmid: 19160298].
Agarwal DK, Agarwal KN, Satya K, et al. Weight gain during pregnancy--a key factor in perinatal and infant mortality. Indian Pediatr. 1998;35(8):733-43. [pmid: 10216567].
Agarwal KN, Agarwal DK, Mishra KP. Impact of anaemia prophylaxis in pregnancy on maternal haemoglobin, serum ferritin & birth weight. Indian J Med Res. 1991;94:277-80. [pmid: 1959958].
Aikawa R, Jimba M, Nguen KC, et al. Prenatal iron supplementation in rural Vietnam. Eur J Clin Nutr. 2008;62(8):946-52. [pmid: 17522600].
Arbuckle TE, Sherman GJ. Comparison of the risk factors for pre-term delivery and intrauterine growth retardation. Paediatr Perinat Epidemiol. 1989;3(2):115-29. [pmid: 2786628].
Aukett MA, Parks YA, Scott PH, et al. Treatment with iron increases weight gain and psychomotor development. Arch Dis Child. 1986;61(9):849-57. [pmid: 2429622].
Bokhari F, Derbyshire E, Li W, et al. A study to establish whether food-based approaches can improve serum iron levels in child-bearing aged women. J Hum Nutr Diet. 2012;25(1):95-100. [pmid: 21749488].
Bondevik GT, Lie RT, Ulstein M, et al. Maternal hematological status and risk of low birth weight and preterm delivery in Nepal. Acta Obstet Gynecol Scand. 2001;80(5):402-8. [pmid: 11328215].
Borch-Iohnsen B, Sandstad B, Asberg A. Iron status among 3005 women aged 20-55 years in central Norway: the Nord-Trøndelag Health Study (the HUNT study). Scand J Clin Lab Invest. 2005;65(1):45-54. [pmid: 15859026].
Britto MT. Using evidence-based techniques to modify anemia screening practice. Am J Manag Care. 1997;3(10):1507-9. [pmid: 10178457].
Cavalli-Sforza T, Berger J, Smitasiri S, et al. Weekly iron-folic acid supplementation of women of reproductive age: impact overview, lessons learned, expansion plans, and contributions toward achievement of the millennium development goals. Nutr Rev. 2005;63(12 Pt 2):S152-8. [pmid: 16466092].
Chang SC, O'Brien KO, Nathanson MS, et al. Hemoglobin concentrations influence birth outcomes in pregnant African-American adolescents. J Nutr. 2003;133(7):2348-55. [pmid: 12840205].
Charoenlarp P, Dhanamitta S, Kaewvichit R, et al. A WHO collaborative study on iron supplementation in Burma and in Thailand. Am J Clin Nutr. 1988;47(2):280-97. [pmid: 2963533].
Choudhury N, Aimone A, Hyder SM, et al. Relative efficacy of micronutrient powders versus iron-folic acid tablets in controlling anemia in women in the second trimester of pregnancy. Food Nutr Bull. 2012;33(2):142-9. [pmid: 22908696].
Christian P, Murray-Kolb LE, Khatry SK, et al. Prenatal micronutrient supplementation and intellectual and motor function in early school-aged children in Nepal. JAMA. 2010;304(24):2716-23. [pmid: 21177506].
Christian P, Stewart CP, LeClerq SC, et al. Antenatal and postnatal iron supplementation and childhood mortality in rural Nepal: a prospective follow-up in a randomized, controlled community trial. Am J Epidemiol. 2009;170(9):1127-36. [pmid: 19778983].
Conde-Agudelo A, Belizan JM, Diaz-Rossello JL. Epidemiology of fetal death in Latin America. Acta Obstet Gynecol Scand. 2000;79(5):371-8. [pmid: 10830764].
Crape BL, Kenefick E, Cavalli-Sforza T, et al. Positive impact of a weekly iron-folic acid supplement delivered with social marketing to Cambodian women: compliance, participation, and hemoglobin levels increase with higher socioeconomic status. Nutr Rev. 2005;63(12 Pt 2):S134-8. [pmid: 16466089].
Fadnavis R, Faruqui AA, Joshi C. Evaluation of efficacy and tolerability of RB Tone forte tablet in the treatment of pregnancy anaemia. J Indian Med Assoc. 2011;109(2):121-123. [pmid: 21888180].
Fleming AF, Ghatoura GB, Harrison KA, et al. The prevention of anaemia in pregnancy in primigravidae in the Guinea savanna of Nigeria. Ann Trop Med Parasitol. 1986;80(2):211-33. [pmid: 3530158].
Hamalainen H, Hakkarainen K, Heinonen S. Anaemia in the first but not in the second or third trimester is a risk factor for low birth weight. Clin Nutr. 2003;22(3):271-5. [pmid: 12765667].
Han XX, Sun YY, Ma AG, et al. Moderate NaFeEDTA and ferrous sulfate supplementation can improve both hematologic status and oxidative stress in anemic pregnant women. Asia Pac J Clin Nutr. 2011;20(4):514-20. [pmid: 22094835].
Hwang HS, Kim YH, Kwon JY, et al. Uterine and umbilical artery Doppler velocimetry as a predictor for adverse pregnancy outcomes in pregnant women with anemia. J Perinat Med. 2010;38(5):467-71. [pmid: 20443671].
Idjradinata P, Pollitt E. Reversal of developmental delays in iron-deficient anaemic infants treated with iron. Lancet. 1993;341(8836):1-4. [pmid: 7678046].
Irigoyen M, Davidson LL, Carriero D, et al. Randomized, placebo-controlled trial of iron supplementation in infants with low hemoglobin levels fed iron-fortified formula. Pediatrics. 1991;88(2):320-6. [pmid: 1861932].
Jehan I, McClure EM, Salat S, et al. Stillbirths in an urban community in Pakistan. Am J Obstet Gynecol. 2007;197(3):257.e251-8. [pmid: 17826410].
Klebanoff MA, Shiono PH, Berendes HW, et al. Facts and artifacts about anemia and preterm delivery. JAMA. 1989;262(4):511-5. [pmid: 2661878].
Knottnerus JA, Delgado LR, Knipschild PG, et al. Haematologic parameters and pregnancy outcome. A prospective cohort study in the third trimester. J Clin Epidemiol. 1990;43(5):461-6. [pmid: 2324786].
Levy A, Fraser D, Katz M, et al. Maternal anemia during pregnancy is an independent risk factor for low birthweight and preterm delivery. Eur J Obstet Gynecol Reprod Biol. 2005;122(2):182-6. [pmid: 16219519].
Little MP, Brocard P, Elliott P, et al. Hemoglobin concentration in pregnancy and perinatal mortality: a London-based cohort study. Am J Obstet Gynecol. 2005;193(1):220-6. [pmid: 16021083].
Liu XN, Liu PY. The effectiveness of weekly iron supplementation regimen in improving the iron status of Chinese children and pregnant women. Biomed Environ Sci. 1996;9(2-3):341-7. [pmid: 8886348].
Lone FW, Qureshi RN, Emanuel F. Maternal anaemia and its impact on perinatal outcome. Trop Med Int Health. 2004;9(4):486-90. [pmid: 15078267].
Lozoff B, De Andraca I, Castillo M, et al. Behavioral and developmental effects of preventing iron-deficiency anemia in healthy full-term infants. Pediatrics. 2003;112(4):846-54. [pmid: 14523176].
Lozoff B, Jimenez E, Hagen J, et al. Poorer behavioral and developmental outcome more than 10 years after treatment for iron deficiency in infancy. Pediatrics. 2000;105(4):E51. [pmid: 10742372].
Malhotra M, Sharma JB, Batra S, et al. Maternal and perinatal outcome in varying degrees of anemia. Int J Gynaecol Obstet. 2002;79(2):93-100. [pmid: 12427391].
Mamun AA, Padmadas SS, Khatun M. Maternal health during pregnancy and perinatal mortality in Bangladesh: evidence from a large-scale community-based clinical trial. Paediatr Perinat Epidemiol. 2006;20(6):482-90. [pmid: 17052283].
Marahatta R. Study of anaemia in pregnancy and its outcome in Nepal Medical College Teaching Hospital, Kathmandu, Nepal. Nepal Med Coll J. 2007;9(4):270-4. [pmid: 18298019].
Mau G. Hemoglobin changes during pregnancy and growth disturbances in the neonate. J Perinat Med. 1977;5(4):172-7. [pmid: 592079].
Menendez C, Todd J, Alonso PL, et al. The effects of iron supplementation during pregnancy, given by traditional birth attendants, on the prevalence of anaemia and malaria. Trans R Soc Trop Med Hyg. 1994;88(5):590-3. [pmid: 7992349].
Mitra AK, Khoury AJ. Universal iron supplementation: a simple and effective strategy to reduce anaemia among low-income, postpartum women. Public Health Nutr. 2012;15(3):546-53. [pmid: 21729466].
Moffatt ME, Longstaffe S, Besant J, et al. Prevention of iron deficiency and psychomotor decline in high-risk infants through use of iron-fortified infant formula: a randomized clinical trial. J Pediatr. 1994;125(4):527-34. [pmid: 7523647].
Murphy JF, O'Riordan J, Newcombe RG, et al. Relation of haemoglobin levels in first and second trimesters to outcome of pregnancy. Lancet. 1986;1(8488):992-5. [pmid: 2871331].
Nordenvall M, Sandstedt B. Placental lesions and maternal hemoglobin levels. A comparative investigation. Acta Obstet Gynecol Scand. 1990;69(2):127-33. [pmid: 2386016].
Paesano R, Torcia F, Berlutti F, et al. Oral administration of lactoferrin increases hemoglobin and total serum iron in pregnant women. Biochem Cell Biol. 2006;84(3):377-80. [pmid: 16936810].
Preziosi P, Prual A, Galan P, et al. Effect of iron supplementation on the iron status of pregnant women: consequences for newborns. Am J Clin Nutr. 1997;66(5):1178-82. [pmid: 9356536].
Scanlon KS, Yip R, Schieve LA, et al. High and low hemoglobin levels during pregnancy: differential risks for preterm birth and small for gestational age. Obstet Gynecol. 2000;96(5 Pt 1):741-8. [pmid: 11042311].
Seshadri S, Gopaldas T. Impact of iron supplementation on cognitive functions in preschool and school-aged children: the Indian experience. Am J Clin Nutr. 1989;50(3 Suppl):675-84. discussion 685-6. [pmid: 2773845].
Shobeiri F, Begum K, Nazari M. A prospective study of maternal hemoglobin status of Indian women during pregnancy and pregnancy outcome. Nutr Res. 2006;26:209-13.
Siega-Riz AM, Adair LS, Hobel CJ. Maternal hematologic changes during pregnancy and the effect of iron status on preterm delivery in a West Los Angeles population. Am J Perinatol. 1998;15(9):515-22. [pmid: 9890247].
Soemantri AG. Preliminary findings on iron supplementation and learning achievement of rural Indonesian children. Am J Clin Nutr. 1989;50(3 Suppl):698-701. discussion 701-2. [pmid: 2773847].
Soewondo S, Husaini M, Pollitt E. Effects of iron deficiency on attention and learning processes in preschool children: Bandung, Indonesia. Am J Clin Nutr. 1989;50(3 Suppl):667-73. discussion 673-4. [pmid: 2773844].
Sood SK, Ramachandran K, Mathur M, et al. WHO sponsored collaborative studies on nutritional anaemia in India, 1: the effects of supplemental oral iron administration to pregnant women. Q J Med. 1975;44(174):241-58. [pmid: 1103213].
Suharno D, West CE, Muhilal, Karyadi D, et al. Supplementation with vitamin A and iron for nutritional anaemia in pregnant women in West Java, Indonesia. Lancet. 1993;342(8883):1325-8. [pmid: 7901636].
Sun YY, Ma AG, Yang F, et al. A combination of iron and retinol supplementation benefits iron status, IL-2 level and lymphocyte proliferation in anemic pregnant women. Asia Pac J Clin Nutr. 2010;19(4):513-9. [pmid: 21147712].
Vijayalaxmi KG, Urooj A. Biochemical profile and outcome in normal and high risk subjects. Indian J Clin Biochem. 2009;24:269-74. [pmid: 23105848].
von Tempelhoff GF, Heilmann L, Rudig L, et al. Mean maternal second-trimester hemoglobin concentration and outcome of pregnancy: a population-based study. Clin Appl Thromb Hemost. 2008;14(1):19-28. [pmid: 18182680].
Wallenburg HC, van Eijk HG. Effect of oral iron supplementation during pregnancy on maternal and fetal iron status. J Perinat Med. 1984;12(1):7-12. [pmid: 6726596].
Williams LA, Evans SF, Newnham JP. Prospective cohort study of factors influencing the relative weights of the placenta and the newborn infant. BMJ. 1997;314(7098):1864-8. [pmid: 9224128].
Wu Y, Weng L, Wu L. Clinical experience with iron supplementation in pregnancy. [Chinese]. Zhonghua Fu Chan Ke Za Zhi. 1998;33(4):206-8. [pmid: 10682464].
Xiong X, Buekens P, Fraser WD, et al. Anemia during pregnancy in a Chinese population. Int J Gynaecol Obstet. 2003;83(2):159-64. [pmid: 14550590].
Zhang Q, Ananth CV, Rhoads GG, et al. The impact of maternal anemia on perinatal mortality: a population-based, prospective cohort study. Ann Epidemiol. 2009;19:793-9. [pmid: 19648029].

### Wrong Intervention

Baykan A, Yalcin SS, Yurdakok K. Does maternal iron supplementation during the lactation period affect iron status of exclusively breast-fed infants?. Turk J Pediatr. 2006;48(4):301-7. [pmid: 17290563].
Beucher G, Grossetti E, Simonet T, et al. Iron deficiency anemia and pregnancy. Prevention and treatment. [French]. J Gynecol Obstet Biol Reprod. (Paris). 2011;40(3):185-200. [pmid: 21333465].
Binder T, Záhumenský J, Feldmár P, et al. Intravenous treatment of postpartum anemia with trivalent ferrum preparation. [Czech]. Ceska Gynekol. 2007;72(3):169-174. [pmid: 17616069].
Bokhari F, Derbyshire EJ, Hickling D, et al. A randomized trial investigating an iron-rich bread as a prophylaxis against iron deficiency in pregnancy. Int J Food Sci Nutr. 2012;63(4):461-7. [pmid: 22081981].
Breymann C, Visca E, Huch R, et al. Efficacy and safety of intravenously administered iron sucrose with and without adjuvant recombinant human erythropoietin for the treatment of resistant iron-deficiency anemia during pregnancy. Am J Obstet Gynecol. 2001;184(4):662-7. [pmid: 11262469].
Christian P, Khatry SK, Katz J, et al. Effects of alternative maternal micronutrient supplements on low birth weight in rural Nepal: double blind randomised community trial. BMJ. 2003;326(7389):571. [pmid: 12637400].
Dawson DW, Goldthorp WO, Spencer D. Parenteral iron therapy in pregnancy. BJOG. 1965;72(1):89-93.
Dibley MJ, Titaley CR, d'Este C, et al. Iron and folic acid supplements in pregnancy improve child survival in Indonesia. Am J Clin Nutr. 2012;95(1):220-30. [pmid: 22170356].
Gupta R, Ramji S. Effect of delayed cord clamping on iron stores in infants born to anemic mothers: a randomized controlled trial. Indian Pediatr. 2002;39(2):130-135. [pmid: 11867842].
Kurbanova FA. Profilactics and treatment of pregnant women with anemia in risk of miscarriage. [Russian]. Georgian Med News. 2006;138:37-40. [pmid: 17057294].
Laskowska-Klita T, Chelchowska M, Leibschang J. The effect of vitamin, macro and microelement supplementation on markers of iron status in blood of pregnant women. [Polish]. Przegl Lek. 2004;61(7):751-4. [pmid: 15792014].
Lebrecht A, Häberlin F, Eberhard J. Anemia in puerperium; parenteral iron substitution renders erythropoietin therapy dispensable. [German]. Geburtshilfe Frauenheilkd. 1995;55(3):167-70. [pmid: 7665066].
Mara M, Eretova V, Zivny J, et al. Anemia and its treatment with peroral anti-anemia agents in women during the postpartum period. [Czech]. Ceska Gynekol. 1999;64(3):153-8. [pmid: 10568044].
Mara M, Zivny J, Eretova V, et al. Changes in markers of anemia and iron metabolism and how they are influenced by antianemics in postpartum period. Acta Obstet Gynecol Scand. 2001;80(2):142-8. [pmid: 11167209].
McKenna D, Spence D, Haggan SE, et al. A randomized trial investigating an iron-rich natural mineral water as a prophylaxis against iron deficiency in pregnancy. Clin Lab Haematol. 2003;25(2):99-103. [pmid: 12641613].
Paesano R, Berlutti F, Pietropaoli M, et al. Lactoferrin efficacy versus ferrous sulfate in curing iron disorders in pregnant and non-pregnant women. Int J Immunopathol Pharmacol. 2010;23(2):577-87. [pmid: 20646353].
Saaka M. Combined iron and zinc supplementation improves haematologic status of pregnant women in upper west region of Ghana. Ghana Med J. 2012;46(4):225-33. [pmid: 23661841].
Scott JM, Govan AD. Anemia of pregnancy treated with intravenous iron. 1951. Eur J Obstet Gynecol Reprod Biol. 2005;123(Suppl 2):S29-32. [pmid: 16360538].
Singh K, Fong YF, Kuperan P. A comparison between intravenous iron polymaltose complex (ferrum Hausmann) and oral ferrous fumarate in the treatment of iron deficiency anaemia in pregnancy. Eur J Haematol. 1998;60(2):119-24. [pmid: 9508353].
Thirunavukkarasu S, Bhandary A. A novel short-course regimen of intramuscular iron therapy for anaemic pregnant women. Trop Doct. 2009;39(4):227-8. [pmid: 19671779].
Ursell B. Management of iron deficiency in pregnancy. RCM Midwives. 2005;8(2):78-9. [pmid: 15732619].

### Wrong Outcome

Beard JL, Hendricks MK, Perez EM, et al. Maternal iron deficiency anemia affects postpartum emotions and cognition. J Nutr. 2005;135(2):267-72. [pmid: 15671224].
Belfort MB, Rifas-Shiman SL, Rich-Edwards JW, et al. Maternal iron intake and iron status during pregnancy and child blood pressure at age 3 years. Int J Epidemiol. 2008;37(2):301-8. [pmid: 18263646].
Bokhari F, Derbyshire EJ, Li W, et al. Can an iron-rich staple food help women to achieve dietary targets in pregnancy?. Int J Food Sci Nutr. 2012;63(2):199-207. [pmid: 21942813].
Brion MJ, Leary SD, Smith GD, et al. Maternal anemia, iron intake in pregnancy, and offspring blood pressure in the Avon Longitudinal Study of Parents and Children. Am J Clin Nutr. 2008;88(4):1126-33. [pmid: 18842803].
Carroll AE, Biondich PG, Anand V, et al. Targeted screening for pediatric conditions with the CHICA system. J Am Med Inform Assoc. 2011;18(4):485-90. [pmid: 21672910].
Feldman RE, Scholl TJ, Alford JK, et al. Results for diffusion-weighted imaging with a fourth-channel gradient insert. Magn Reson Med. 2011;66(6):1798-808. [pmid: 21604300].
Hemminki E, Uski A, Koponen P, et al. Iron supplementation during pregnancy--experiences of a randomized trial relying on health service personnel. Control Clin Trials. 1989;10(3):290-8. [pmid: 2791561].
Paintin DB, Thomson AM, Hytten FE. Iron and the haemoglobin level in pregnancy. BJOG. 1966;73(2):181-90.
Parsons AG, Zhou SJ, Spurrier NJ, et al. Effect of iron supplementation during pregnancy on the behaviour of children at early school age: long-term follow-up of a randomised controlled trial. Br J Nutr. 2008;99(5):1133-9. [pmid: 17967217].
Ren A, Wang J, Ye RW, et al. Low first-trimester hemoglobin and low birth weight, preterm birth and small for gestational age newborns. Int J Gynaecol Obstet. 2007;98(2):124-8. [pmid: 17585914].
Rohlfs EM, Zhou Z, Heim RA, et al. Cystic fibrosis carrier testing in an ethnically diverse US population. Clin Chem. 2011;57(6):841-8. [pmid: 21474639].
Zhou SJ, Gibson RA, Crowther CA, et al. Effect of iron supplementation during pregnancy on the intelligence quotient and behavior of children at 4 y of age: long-term follow-up of a randomized controlled trial. Am J Clin Nutr. 2006;83(5):1112-7. [pmid: 16685054].

### Wrong Study Design for Key Question

Akhter S, Momen MA, Rahman MM, et al. Effect of maternal anemia on fetal outcome. Mymensingh Med J. 2010;19(3):391-8. [pmid: 20639833].
Al RA, Unlubilgin E, Kandemir O, et al. Intravenous versus oral iron for treatment of anemia in pregnancy: a randomized trial. Obstet Gynecol. 2005;106(6):1335-40. [pmid: 16319260].
Allen LH. Anemia and iron deficiency: effects on pregnancy outcome. Am J Clin Nutr. 2000;71(5 Suppl):1280S-4. [pmid: 10799402].
Allen LH. Biological mechanisms that might underlie iron's effects on fetal growth and preterm birth. J Nutr. 2001;131(2 Suppl):581S-9. [pmid: 11160591].
Alwan NA, Greenwood DC, Simpson NA, et al. Dietary iron intake during early pregnancy and birth outcomes in a cohort of British women. Hum Reprod. 2011;26(4):911-9. [pmid: 21303776].
Armony-Sivan R, Kaplan-Estrin M, Jacobson SW, et al. Iron-deficiency anemia in infancy and mother-infant interaction during feeding. J Dev Behav Pediatr. 2010;31(4):326-32. [pmid: 20431398].
Baker PN, Wheeler SJ, Sanders TA, et al. A prospective study of micronutrient status in adolescent pregnancy. Am J Clin Nutr. 2009;89(4):1114-24. [pmid: 19244368].
Balarajan Y, Subramanian SV, Fawzi WW. Maternal iron and folic acid supplementation is associated with lower risk of low birth weight in India. J Nutr. 2013;143(8):1309-15. [pmid: 23761647].
Bánhidy F, Acs N, Puhó EH, et al. Iron deficiency anemia: pregnancy outcomes with or without iron supplementation. Nutrition. 2011;27(1):65-72. [pmid: 20381313].
Barroso F, Allard S, Kahan BC, et al. Prevalence of maternal anaemia and its predictors: a multi-centre study. Eur J Obstet Gynecol Reprod Biol. 2011;159(1):99-105. [pmid: 21890259].
Bodnar LM, Siega-Riz AM, Arab L, et al. Predictors of pregnancy and postpartum haemoglobin concentrations in low-income women. Public Health Nutr. 2004;7(6):701-11. [pmid: 15369607].
Bodnar LM, Siega-Riz AM, Cogswell ME. High prepregnancy BMI increases the risk of postpartum anemia. Obes Res. 2004;12(6):941-8. [pmid: 15229333].
Callen BL. Program of care for young women with iron deficiency anemia: a pilot. J Community Health Nurs. 2000;17(4):247-62. [pmid: 11126896].
Carretti N, Paticchio MR, Eremita GA. Intravenous iron therapy for severe pregnancy anemia with high erythropoietin levels. Obstet Gynecol. 1997;90(4 Pt 2):650-3. [pmid: 11770580].
Casanueva E, Pfeffer F, Drijanski A, et al. Iron and folate status before pregnancy and anemia during pregnancy. Ann Nutr Metab. 2003;47(2):60-3. [pmid: 12652056].
Charles AM, Campbell-Stennett D, Yatich N, et al. Predictors of anemia among pregnant women in Westmoreland, Jamaica. Health Care Women Int. 2010;31(7):585-98. [pmid: 20526925].
Chelchowska M, Laskowska-Klita T. Effect of maternal smoking on some markers of iron status in umbilical cord blood. Rocz Akad Med Bialymst. 2002;47:235-40. [pmid: 12533965].
Chelchowska M, Laskowska-Klita T, Leibschang J. Concentration of ferritin, transferrin and iron as a markers of iron deficiency in healthy women in reproductive age. [Polish]. Pol Merkuriusz Lek. 2007;22(127):25-7. [pmid: 17477085].
Chesnokov PE, Klimenko GI, Kosolapov VP, et al. The medical social risk factors of developing the iron-deficiency anemia in pregnant women. [Russian]. Probl Sotsialnoi Gig Zdravookhranenniiai Istor Med. 2010;(2):16-9. [pmid: 20731145].
Chotnopparatpattara P, Limpongsanurak S, Charnngam P. The prevalence and risk factors of anemia in pregnant women. J Med Assoc Thai. 2003;86(11):1001-7. [pmid: 14696781].
da Silva CL, Saunders C, Szarfarc SC, et al. Anaemia in pregnant women before and after the mandatory fortification of wheat and corn flours with iron. Public Health Nutr. 2012;15(10):1802-9. [pmid: 22578817].
Dairo MD, Lawoyin TO. Demographic factors determining compliance to iron supplementation in pregnancy in Oyo State, Nigeria. Niger J Med. 2006;15(3):241-4. [pmid: 17111751].
Dal Pizzol Tda S, Giugliani ER, Mengue SS. Association between iron supplementation during pregnancy and prematurity, low birth weight, and very low birth weight. [Portuguese]. Cad Saude Publica. 2009;25(1):160-8. [pmid: 19180298].
Emamghorashi F, Heidari T. Iron status of babies born to iron-deficient anaemic mothers in an Iranian hospital. East Mediterr Health J. 2004;10(6):808-14. [pmid: 16335768].
Fujimori E, Sato AP, Szarfarc SC, et al. Anemia in Brazilian pregnant women before and after flour fortification with iron. Rev Saude Publica. 2011;45(6):1027-35. [pmid: 22127652].
Georgieff MK, Wewerka SW, Nelson CA, et al. Iron status at 9 months of infants with low iron stores at birth. J Pediatr. 2002;141(3):405-9. [pmid: 12219063].
Hess SY, Zimmermann MB, Brogli S, et al. A national survey of iron and folate status in pregnant women in Switzerland. Int J Vitam Nutr Res. 2001;71(5):268-73. [pmid: 11725691].
Hopkins D, Emmett P, Steer C, et al. Infant feeding in the second 6 months of life related to iron status: an observational study. Arch Dis Child. 2007;92(10):850-4. [pmid: 17537759].
Leblanc CP, Rioux FM. Iron deficiency anemia following prenatal nutrition interventions. Can J Diet Pract Res. 2007;68(4):222-5. [pmid: 18073006].
Lee HS, Kim MS, Kim MH, et al. Iron status and its association with pregnancy outcome in Korean pregnant women. Eur J Clin Nutr. 2006;60(9):1130-5. [pmid: 16639418].
Lozoff B, Jimenez E, Smith JB. Double burden of iron deficiency in infancy and low socioeconomic status: a longitudinal analysis of cognitive test scores to age 19 years. Arch Pediatr Adolesc Med. 2006;160(11):1108-13. [pmid: 17088512].
Mabry-Hernandez IR. Screening for iron deficiency anemia--including iron supplementation for children and pregnant women. Am Fam Physician. 2009;79(10):897-8. [pmid: 19496390].
Macgregor MW. Maternal anaemia as a factor in prematurity and perinatal mortality. Scott Med J. 1963;8:134.
Means RT. Iron deficiency anemia. Hematol. 2013;18(5):305-6. [pmid: 24020489].
Nishiyama S, Kiwaki K, Miyazaki Y, et al. Zinc and IGF-I concentrations in pregnant women with anemia before and after supplementation with iron and/or zinc. J Am Coll Nutr. 1999;18(3):261-7. [pmid: 10376783].
Ortiz R, Toblli JE, Romero JD, et al. Efficacy and safety of oral iron (III) polymaltose complex versus ferrous sulfate in pregnant women with iron-deficiency anemia: a multicenter, randomized, controlled study. J Matern Fetal Neonatal Med. 2011;24(11):1-6. [pmid: 21859366].
Paiva Ade A, Rondó PH, Pagliusi RA, et al. Relationship between the iron status of pregnant women and their newborns. Rev Saude Publica. 2007;41(3):321-7. [pmid: 17515983].
Pasricha SR. Should we screen for iron deficiency anaemia? A review of the evidence and recent recommendations. Pathology. 2012;44(2):139-47. [pmid: 22198251].
Provan D. Mechanisms and management of iron deficiency anaemia. Br J Haematol. 1999;105(Suppl 1):19-26. [pmid: 10330929].
Ribot B, Aranda N, Giralt M, et al. Effect of different doses of iron supplementation during pregnancy on maternal and infant health. Ann Hematol. 2013;92(2):221-9. [pmid: 23053178].
Ribot B, Aranda N, Viteri F, et al. Depleted iron stores without anaemia early in pregnancy carries increased risk of lower birthweight even when supplemented daily with moderate iron. Hum Reprod. 2012;27(5):1260-6. [pmid: 22357769].
Sichieri R, Fonseca VM, Hoffman D, et al. Lack of association between iron status at birth and growth of preterm infants. Rev Saude Publica. 2006;40(4):641-7. [pmid: 17063240].
Singh K, Fong YF, Arulkumaran S. The role of prophylactic iron supplementation in pregnancy. Int J Food Sci Nutr. 1998;49(5):383-9. [pmid: 10367008].
Turner S, Seybold D, Celestine C, et al. Incidence of anemia among obstetric patients in an Appalachian teaching clinic. Mil Med. 2012;177(10):1212-6. [pmid: 23113450].

### Wrong Publication Type (Not a Study)

Non-anaemic pregnant women should not take iron supplements. Prescrire Int. 2009;18(104):261-2. [pmid: 20025097].
Adil SN, Shaikh MU. Iron deficiency anemia: preventive strategies and controversies. J Pak Med Assoc. 2003;53(4):130. [pmid: 12776893].
Agarwal R. Nonhematological benefits of iron. Am J Nephrol. 2007;27(6):565-71. [pmid: 17804903].
Akkad A, Howarth E, Smith G, et al. To transfuse or not to transfuse: iatrogenic compromise of women's reproductive careers. Hosp Med. 2001;62(5):310-1. [pmid: 11385897].
Allen JD. Intravenous versus oral iron for treatment of anemia in pregnancy: a randomized trial. Obstet Gynecol. 2006;107(3):742. author reply 742. [pmid: 16507953].
Allen LH. Pregnancy and iron deficiency: unresolved issues. Nutr Rev. 1997;55(4):91-101. [pmid: 9197129].
Allen LH, Peerson JM, Maternal Micronutrient Supplementation Study Group. Impact of multiple micronutrient versus iron-folic acid supplements on maternal anemia and micronutrient status in pregnancy. Food Nutr Bull. 2009;30(4 Suppl):S527-32. [pmid: 20120794].
Andrews NC. Iron homeostasis: insights from genetics and animal models. Nat Rev Genet. 2000;1(3):208-17. [pmid: 11252750].
Baker RD, Greer FR, et al. Diagnosis and prevention of iron deficiency and iron-deficiency anemia in infants and young children (0-3 years of age). Pediatrics. 2010;126(5):1040-50. [pmid: 20923825].
Bamberg R. Occurrence and detection of iron-deficiency anemia in infants and toddlers. Clin Lab Sci. 2008;21(4):225-31. [pmid: 19174983].
Beard JL. Iron deficiency and neural development: an update. Arch Latinoam Nutr. 1999;49(3 Suppl 2):34S-9. [pmid: 10971834].
Beard JL. Effectiveness and strategies of iron supplementation during pregnancy. Am J Clin Nutr. 2000;71(5 Suppl):1288S-94. [pmid: 10799404].
Black MM. Integrated strategies needed to prevent iron deficiency and to promote early child development. J Trace Elem Med Biol. 2012;26(2-3):120-3. [pmid: 22664336].
Black MM, Quigg AM, Hurley KM, et al. Iron deficiency and iron-deficiency anemia in the first two years of life: strategies to prevent loss of developmental potential. Nutr Rev. 2011;69(Suppl 1):S64-70. [pmid: 22043885].
Blot I, Diallo D, Tchernia G. Iron deficiency in pregnancy: effects on the newborn. Curr Opin Hematol. 1999;6(2):65-70. [pmid: 10088634].
Breymann C. Anemia during pregnancy and in the postpartum: intravenous iron therapy revisited. Eur J Obstet Gynecol Reprod Biol. 2005;123(Suppl 2):S1-35. [pmid: 16360535].
Breymann C. Treatment of iron deficiency anaemia in pregnancy and postpartum with special focus on intravenous iron sucrose complex. J Med Assoc Thai. 2005;88(Suppl 2):S108-9. [pmid: 17718296].
Breymann C, Honegger C, Holzgreve W, et al. Diagnosis and treatment of iron-deficiency anaemia during pregnancy and postpartum. Arch Gynecol Obstet. 2010;282(5):577-80. [pmid: 20577752].
Chaparro CM. Setting the stage for child health and development: prevention of iron deficiency in early infancy. J Nutr. 2008;138(12):2529-33. [pmid: 19022984].
Christian P. Antenatal iron supplementation as a child survival strategy. Am J Clin Nutr. 1998;68(2):404-5. [pmid: 9701202].
Coad J, Conlon C. Iron deficiency in women: assessment, causes and consequences. Curr Opin Clin Nutr Metab Care. 2011;14(6):625-34. [pmid: 21934611].
Crowther S. Blood tests for investigating maternal wellbeing, 2: testing for anaemia in pregnancy. Pract Midwife. 2010;13(10):48-52. [pmid: 21155475].
Cuciti C, Mayer DC, Arnette R, et al. Anaphylactoid reaction to intravenous sodium ferric gluconate complex during pregnancy. Int J Obstet Anesth. 2005;14(4):362-4. [pmid: 16140521].
Dary O. Staple food fortification with iron: a multifactorial decision. Nutr Rev. 2002;60(7 Pt 2):S34-41. discussion S46-9. [pmid: 12141599].
Frewin R, Henson A, Provan D. ABC of clinical haematology. Iron deficiency anaemia. BMJ. 1997;314(7077):360-3. [pmid: 9040336].
Ghinea MM. Treatment of iron deficiency anemia with Ferro-Folgamma. Rom J Intern Med. 2004;42(1):225-30. [pmid: 15529613].
Govan AD, Scott JM. Intravenous iron in the treatment of anemia of pregnancy. 1949. Eur J Obstet Gynecol Reprod Biol. 2005;123(Suppl 2):S33-5. [pmid: 16360540].
Hollan S. Iron supplementation and cognitive function. Lancet. 1996;348(9042):1669-70. [pmid: 8962025].
Institute of Medicine. Dietary Reference Intakes for Vitamin A, Vitamin K, Arsenic, Boron, Chromium, Copper, Iodine, Iron, Manganese, Molybdenum, Nickel, Silicon, Vanadium, and Zinc. Washington DC. 2001.
Mahomed K. Iron supplementation in pregnancy. Cochrane Database Syst Rev. 2000;(2). CD000117. [pmid: 10796140].
Mahoney MC. Screening for iron deficiency anemia among children and adolescents. Am Fam Physician. 2000;62(3):671-3. [pmid: 10950220].
Rioux FM, LeBlanc CP. Iron supplementation during pregnancy: what are the risks and benefits of current practices?. Appl Physiol Nutr Metab. 2007;32(2):282-8. [pmid: 17486170].
Rosser J. Iron supplementation in pregnancy. Pract Midwife. 2001;4(1):10-1. [pmid: 12026593].
Russell L. The patient's page. South Med J. 2004;97(9):918. [pmid: 15455993].
Sanghvi TG, Harvey PW, Wainwright E. Maternal iron-folic acid supplementation programs: evidence of impact and implementation. Food Nutr Bull. 2010;31(2 Suppl):S100-7. [pmid: 20715594].
Scholl TO, Hediger ML. Anemia and iron-deficiency anemia: compilation of data on pregnancy outcome. Am J Clin Nutr. 1994;59(2 Suppl):492S-500. discussion 500-1. [pmid: 8304287].
Scholl TO, Reilly T. Anemia, iron and pregnancy outcome. J Nutr. 2000;130(2 Suppl):443S-7. [pmid: 10721924].
Wu AC, Lesperance L, Bernstein H. Screening for iron deficiency. Pediatr Rev. 2002;23(5):171-8. [pmid: 11986493].
Yadav D, Chandra J. Iron deficiency: beyond anemia. Indian J Pediatr. 2011;78(1):65-72. [pmid: 20814842].

### Not English-Language, but Possibly Relevant

De Benaze C, Galan P, Wainer R, et al. Prevention of iron-deficiency anemia in pregnancy using early iron supplementation: a controlled trial. [French]. Rev Epidemiol Sante Publique. 1989;37(2):109-18. [pmid: 2672177].
El Guindi W, Pronost J, Carles G, et al. Anémies maternelles sévères et issues de grossesse. [French]. J Gynecol Obstet Biol Reprod (Paris). 2004;33(6):506-9. [pmid: 15567966].
Macedo A, Cardoso S. Routine iron supplementation in pregnancy. [Portuguese]. Acta Med Port. 2010;23(5):785-92. [pmid: 21144317].
Peiker G, Muller B, Schwarz A, et al. Diagnosis and therapy of iron deficiency anemia in pregnancy. [German]. Zentralbl Gynakol. 1986;108(24):1487-92. [pmid: 3577453].
Tchernia G, Blot I, Rey A, et al. Carences maternelles en feret folates: repercussions sur le nouveau-né. [French]. Sem Hop Paris. 1983;59:416-20. [pmid: 6302880].
Tura S, Carenza L, Baccarani M, et al. Therapy and iron supplements with ferritin iron during pregnancy. Randomized prospective study of 458 cases. [Italian]. Recenti Prog Med. 1989;80(11):607-14. [pmid: 2696020].

### Wrong Comparison

al-Momen AK, al-Meshari A, al-Nuaim L, et al. Intravenous iron sucrose complex in the treatment of iron deficiency anemia during pregnancy. Eur J Obstet Gynecol Reprod Biol. 1996;69(2):121-4. [pmid: 8902444].
Aranda N, Ribot B, Garcia E, et al. Pre-pregnancy iron reserves, iron supplementation during pregnancy, and birth weight. Early Hum Dev. 2011;87(12):791-7. [pmid: 21723050].
Ayub R, Tariq N, Adil MM, et al. Efficacy and safety of total dose infusion of low molecular weight iron dextran in the treatment of iron deficiency anemia during pregnancy. J Coll Physicians Surg Pak. 2008;18(7):424-7. [pmid: 18760066].
Baumslag N, Edelstein T, Metz J. Reduction of incidence of prematurity by folic acid supplementation in pregnancy. Br Med J. 1970;1(5687):16-7. [pmid: 5460838].
Bayoumeu F, Subiran-Buisset C, Baka NE, et al. Iron therapy in iron deficiency anemia in pregnancy: intravenous route versus oral route. Am J Obstet Gynecol. 2002;186(3):518-22. [pmid: 11904617].
Bencaiova G, von Mandach U, Zimmermann R. Iron prophylaxis in pregnancy: intravenous route versus oral route. Eur J Obstet Gynecol Reprod Biol. 2009;144(2):135-9. [pmid: 19406557].
Bhutta ZA, Rizvi A, Raza F, et al. A comparative evaluation of multiple micronutrient and iron-folic acid supplementation during pregnancy in Pakistan: impact on pregnancy outcomes. Food Nutr Bull. 2009;30(4 Suppl):S496-505. [pmid: 20120791].
Bodnar LM, Cogswell ME, Scanlon KS. Low income postpartum women are at risk of iron deficiency. J Nutr. 2002;132(8):2298-302. [pmid: 12163678].
Bouzari Z, Basirat Z, Zeinal Zadeh M, et al. Daily versus intermittent iron supplementation in pregnant women. BMC Res Notes. 4:444. [pmid: 22026956].
Buglanov AA, Saiapina EV, Turaev AT. A comparative study of the effectiveness of iron preparations in the treatment of iron deficiency anemias in pregnant women. [Russian]. Akush Ginekol (Mosk). 1994;6:16-8. [pmid: 7892940].
Casanueva E, Viteri FE, Mares-Galindo M, et al. Weekly iron as a safe alternative to daily supplementation for nonanemic pregnant women. Arch Med Res. 2006;37(5):674-82. [pmid: 16740440].
Casparis D, Del Carlo P, Branconi F, et al. Effectiveness and tolerance of oral doses of liquid ferrous gluconate in iron-deficiency anaemia during pregnancy and in the immediate post-natal period: comparison with other liquid or solid formulations containing bivalent or trivalent iron. [Italian]. Minerva Ginecol. 1996;48(11):511-8. [pmid: 9005381].
Chew F, Torun B, Viteri FE. Comparision of weekly and daily iron supplementation to pregnant women in Guatemala. FASEB J. 1996;10:A4221.
de Souza AI, Batista Filho M, Ferreira LO, et al. The effectiveness of three regimens using ferrous sulfate to treat anemia in pregnant women. [Spanish]. Rev Panam Salud Publica. 2004;15(5):313-9. [pmid: 15231078].
Dede A, Uygur D, Yilmaz B, et al. Intravenous iron sucrose complex vs. oral ferrous sulfate for postpartum iron deficiency anemia. Int J Gynaecol Obstet. 2005;90(3):238-9. [pmid: 16043181].
Digumarthi L, Cheruku V. Comparison of intravenous versus oral iron in iron deficiency anaemia of pregnancy. BJOG. 2008;115(Suppl 1):53.
Fareh OI, Rizk DE, Thomas L, et al. Obstetric impact of anaemia in pregnant women in United Arab Emirates. J Obstet Gynaecol. 2005;25(5):440-4. [pmid: 16183576].
Feresu SA, Harlow SD, Woelk GB. Risk factors for prematurity at Harare Maternity Hospital, Zimbabwe. Int J Epidemiol. 2004;33(6):1194-201. [pmid: 15522924].
Fletcher J, Gurr A, Fellingham FR, et al. The value of folic acid supplements in pregnancy. BJOG. 1971;78(9):781-5.
Geltman PL, Meyers AF, Mehta SD, et al. Daily multivitamins with iron to prevent anemia in high-risk infants: a randomized clinical trial. Pediatrics. 2004;114(1):86-93. [pmid: 15231912].
Gonzales GF, Steenland K, Tapia V. Maternal hemoglobin level and fetal outcome at low and high altitudes. Am J Physiol Regul Integr Comp Physiol. 2009;297(5):R1477-85. [pmid: 19741055].
Goonewardene M, Liyanage C, Fernando R. Intermittent oral iron supplementation during pregnancy. Ceylon Med J. 2001;46(4):132-5. [pmid: 12164031].
Hallak M, Sharon AS, Diukman R, et al. Supplementing iron intravenously in pregnancy. A way to avoid blood transfusions. J Reprod Med. 1997;42(2):99-103. [pmid: 9058345].
Harrison KA, Lister UG, Rossiter CE, et al. Perinatal mortality. BJOG. 1985;5:86-99.
Hartman-Craven B, Christofides A, O'Connor DL, et al. Relative bioavailability of iron and folic acid from a new powdered supplement compared to a traditional tablet in pregnant women. BMC Pregnancy Childbirth. 2009;9:33. [pmid: 19635145].
Iyengar L. Folic acid requirements of Indian pregnant women. Am J Obstet Gynecol. 1971;111(1):13-6. [pmid: 5096349].
Iyengar L, Rajalakshmi K. Effect of folic acid supplement on birth weights of infants. Am J Obstet Gynecol. 1975;122(3):332-6. [pmid: 1130456].
Juarez-Vazquez J, Bonizzoni E, Scotti A. Iron plus folate is more effective than iron alone in the treatment of iron deficiency anaemia in pregnancy: a randomised, double blind clinical trial. BJOG. 2002;109(9):1009-14. [pmid: 12269674].
Kaisi M, Ngwalle EW, Runyoro DE, et al. Evaluation of tolerance of and response to iron dextran (Imferon) administered by total dose infusion to pregnant women with iron deficiency anemia. Int J Gynaecol Obstet. 1988;26(2):235-43. [pmid: 2898400].
Khalafallah A, Dennis A, Bates J, et al. A prospective randomized, controlled trial of intravenous versus oral iron for moderate iron deficiency anaemia of pregnancy. J Intern Med. 2010;268(3):286-95. [pmid: 20546462].
Khalid S, Ahmad SI. Correction of iron deficiency anemia in pregnancy and its effects on superoxide dismutase. Pak J Pharm Sci. 2012;25(2):423-7. [pmid: 22459472].
Komolafe JO, Kuti O, Ijadunola KT, et al. A comparative study between intramuscular iron dextran and oral ferrous sulphate in the treatment of iron deficiency anaemia in pregnancy. J Obstet Gynaecol. 2003;23(6):628-31. [pmid: 14617464].
Krafft A, Bencaiova G, Breymann C. Selective use of recombinant human erythropoietin in pregnant patients with severe anemia or nonresponsive to iron sucrose alone. Fetal Diagn Ther. 2009;25(2):239-45. [pmid: 19506383].
Krafft A, Breymann C. Iron sucrose with and without recombinant erythropoietin for the treatment of severe postpartum anemia: a prospective, randomized, open-label study. J Obstet Gynaecol Res. 2011;37(2):119-24. [pmid: 21159035].
Kumar A, Jain S, Singh NP, et al. Oral versus high dose parenteral iron supplementation in pregnancy. Int J Gynaecol Obstet. 2005;89(1):7-13. [pmid: 15777891].
Lao TT, Chan LY, Tam KF, et al. Maternal hemoglobin and risk of gestational diabetes mellitus in Chinese women. Obstet Gynecol. 2002;99(5 Pt 1):807-12. [pmid: 11978291].
Madhavan Nair K, Bhaskaram P, Balakrishna N, et al. Response of hemoglobin, serum ferritin, and serum transferrin receptor during iron supplementation in pregnancy: a prospective study. Nutrition. 2004;20(10):896-9. [pmid: 15474878].
Melamed N, Ben-Haroush A, Kaplan B, et al. Iron supplementation in pregnancy--does the preparation matter?. Arch Gynecol Obstet. 2007;276(6):601-4. [pmid: 17541618].
Milman N, Bergholt T, Eriksen L, et al. Iron prophylaxis during pregnancy-- how much iron is needed? A randomized dose-response study of 20-80 mg ferrous iron daily in pregnant women. Acta Obstet Gynecol Scand. 2005;84(3):238-47. [pmid: 15715531].
Milman N, Byg KE, Bergholt T, et al. Side effects of oral iron prophylaxis in pregnancy--myth or reality?. Acta Haematol. 2006;115(1-2):53-7. [pmid: 16424650].
Milman N, Byg KE, Bergholt T, et al. Body iron and individual iron prophylaxis in pregnancy--should the iron dose be adjusted according to serum ferritin?. Ann Hematol. 2006;85(9):567-73. [pmid: 16733739].
Mola G, Permezel M, Amoa AB, et al. Anaemia and perinatal outcome in Port Moresby. Aust N Z J Obstet Gynaecol. 1999;39(1):31-4. [pmid: 10099745].
Mumtaz Z, Shahab S, Butt N, et al. Daily iron supplementation is more effective than twice weekly iron supplementation in pregnant women in Pakistan in a randomized double-blind clinical trial. J Nutr. 2000;130(11):2697-702. [pmid: 11053509].
Nappi C, Tommaselli GA, Morra I, et al. Efficacy and tolerability of oral bovine lactoferrin compared to ferrous sulfate in pregnant women with iron deficiency anemia: a prospective controlled randomized study. Acta Obstet Gynecol Scand. 2009;88(9):1031-5. [pmid: 19639462].
Naz N, Mashoori GR, Zehra T, et al. Intra venous iron sucrose versus oral ferrous sulphate for treatment of iron deficiency anemia in pregnancy. Medical Channel. 2008;14(1):55-8.
Rae PG, Robb PM. Megaloblastic anaemia of pregnancy: a clinical and laboratory study with particular reference to the total and labile serum folate levels. J Clin Pathol. 1970;23(5):379-91. [pmid: 5476865].
Rayado B, Carrillo JA, Fernandez-Esteban JA, et al. A comparative study of 2 ferrous proteins in the prevention of iron deficiency anaemia during pregnancy. Clin Invest Ginecol Obstet. 1997;24(2):46-50.
Saha L, Pandhi P, Gopalan S, et al. Comparison of efficacy, tolerability, and cost of iron polymaltose complex with ferrous sulphate in the treatment of iron deficiency anemia in pregnant women. Med Gen Med. 2007;9(1):1. [pmid: 17435611].
Scholl TO, Hediger ML, Fischer RL, et al. Anemia vs iron deficiency: increased risk of preterm delivery in a prospective study. Am J Clin Nutr. 1992;55(5):985-8. [pmid: 1570808].
Sifakis S, Angelakis E, Papadopoulou E, et al. The efficacy and tolerability of iron protein succinylate in the treatment of iron-deficiency anemia in pregnancy. Clin Exp Obstet Gynecol. 2005;32(2):117-22. [pmid: 16108396].
Singh U, Sinha nee Mehrotra S, Gupta HP, et al. Once a week (200 mg) elemental iron: an effective option for prophylaxis in non-anaemic pregnant women. J Indian Med Assoc. 2011;109(9):654-6. [pmid: 22480099].
Srinivasan V, Radhakrishna S, Sudha R, et al. Randomised controlled field trial of two antenatal care packages in rural south India. Indian J Med Res. 1995;102:86-94. [pmid: 8834820].
Thomsen JK, Prien-Larsen JC, Devantier A, et al. Low dose iron supplementation does not cover the need for iron during pregnancy. Acta Obstet Gynecol Scand. 1993;72(2):93-8. [pmid: 8383415].
Trigg KH, Rendall EJ, Johnson A, et al. Folate supplements during pregnancy. J R Coll Gen Pract. 1976;26(164):228-30. [pmid: 1263177].
Yekta Z, Pourali R, Mladkova N, et al. Role of iron supplementation in promoting maternal and fetal outcome. Ther Clin Risk Manag. 7:421-8. [pmid: 22162919].
Zamani A, Farajzadegan Z, Ghahiri A, et al. Effectiveness of twice weekly iron supplementation compared with daily regimen in reducing anemia and iron deficiency during pregnancy: a randomized trial in Iran. J Res Med Sci. 2008;13(5):230-9.
Zhou LM, Yang WW, Hua JZ, et al. Relation of hemoglobin measured at different times in pregnancy to preterm birth and low birth weight in Shanghai, China. Am J Epidemiol. 1998;148(10):998-1006. [pmid: 9829872].

### Systematic Review, Not Directly Used

Cuervo LG, Mahomed K. Treatments for iron deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2001;(2). CD003094. [pmid: 11406073].
Haider BA, Olofin I, Wang M, et al. Anaemia, prenatal iron use, and risk of adverse pregnancy outcomes: systematic review and meta-analysis. BMJ. 2013;346. [pmid: 23794316].
Mahomed K. Iron and folate supplementation in pregnancy. Cochrane Database Syst Rev. 2000;(2). CD001135. [pmid: 10796246].
Pena-Rosas JP, De-Regil LM, Dowswell T, et al. Intermittent oral iron supplementation during pregnancy. Cochrane Database Syst Rev. 2012;(7). CD009997. [pmid: 22786531].
Pena-Rosas JP, Viteri FE. Effects of routine oral iron supplementation with or without folic acid for women during pregnancy. Cochrane Database Syst Rev. 2006;(3). CD004736. [pmid: 16856058].
Pena-Rosas JP, Viteri FE. Effects and safety of preventive oral iron or iron+folic acid supplementation for women during pregnancy. Cochrane Database Syst Rev. 2009;(4). CD004736. [pmid: 19821332].
Rasmussen K. Is there a causal relationship between iron deficiency or iron-deficiency anemia and weight at birth, length of gestation and perinatal mortality?. J Nutr. 2001;131(2 Suppl):590S-601. discussion 601-3. [pmid: 11160592].
Reveiz L, Gyte ML, Cuervo GL, et al. Treatments for iron-deficiency anaemia in pregnancy. Cochrane Database Syst Rev. 2007;(2). CD003094. [pmid: 17443522].
Vucic V, Berti C, Vollhardt C, et al. Effect of iron intervention on growth during gestation, infancy, childhood, and adolescence: a systematic review with meta-analysis. Nutr Rev. 2013;71(6):386-401. [pmid: 23731448].

### Poor Quality for Supplementation (Key Question 1)

Bloxam DL, Williams NR, Waskett RJ, et al. Maternal zinc during oral iron supplementation in pregnancy: a preliminary study. Clin Sci (Lond). 1989;76(1):59-65. [pmid: 2920535].
Butler EB. Effect of iron and folic acid on red cell and plasma volume in pregnancy. J Obstet Gynaecol Br Commonw. 1968;75(5):497-510. [pmid: 5742694].
Buytaert G, Wallenburg HC, van Eijck HG, et al. Iron supplementation during pregnancy. Eur J Obstet Gynecol Reprod Biol. 1983;15(1):11-6. [pmid: 6884561].
Cantlie GS, De Leeuw NK, Lowenstein L. Iron and folate nutrition in a group of private obstetrical patients. Am J Clin Nutr. 1971;24(6):637-41. [pmid: 5581003].
Chisholm M. A controlled clinical trial of phrophylactic folic acid and iron in pregnancy. BJOG. 1966;73(2):191-6.
Dawson EB, Albers J, McGanity WJ. Serum zinc changes due to iron supplementation in teen-age pregnancy. Am J Clin Nutr. 1989;50(4):848-52. [pmid: 2801591].
Dawson EB, McGanity WJ. Protection of maternal iron stores in pregnancy. J Reprod Med. 1987;32(6 Suppl):478-87. [pmid: 3612641].
Fleming AF, Martin JD, Hahnel R, et al. Effects of iron and folic acid antenatal supplements on maternal haematology and fetal wellbeing. Med J Aust. 1974;2(12):429-36. [pmid: 4431344].
Harvey LJ, Dainty JR, Hollands WJ, et al. Effect of high-dose iron supplements on fractional zinc absorption and status in pregnant women. Am J Clin Nutr. 2007;85(1):131-6. [pmid: 17209188].
Holly RG. Anemia in pregnancy. Obstet Gynecol. 1955;5(4):562-8. [pmid: 14370701].
Lee JI, Lee JA, Lim HS. Effect of time of initiation and dose of prenatal iron and folic acid supplementation on iron and folate nutriture of Korean women during pregnancy. Am J Clin Nutr. 2005;82(4):843-9. [pmid: 16210715].
Pritchard JA, Hunt CF. A comparison of the hematologic responses following the routine prenatal administration of intramuscular and oral iron. Surg Gynecol Obstet. 1958;106(5):516-8. [pmid: 13556464].
Puolakka J, Janne O, Pakarinen A, et al. Serum ferritin as a measure of iron stores during and after normal pregnancy with and without iron supplements. Acta Obstet Gynecol Scand Suppl. 1980;95:43-51. [pmid: 6935911].
Svanberg B, Arvidsson B, Norrby A, et al. Absorption of supplemental iron during pregnancy--a longitudinal study with repeated bone-marrow studies and absorption measurements. Acta Obstet Gynecol Scand Suppl. 1975;48:87-108. [pmid: 1062910].
Taylor DJ, Mallen C, McDougall N, et al. Effect of iron supplementation on serum ferritin levels during and after pregnancy. Br J Obstet Gynaecol. 1982;89(12):1011-7. [pmid: 7171510].
Van Eijk HG, Kroos MJ, Hoogendoorn GA, et al. Serum ferritin and iron stores during pregnancy. Clin Chim Acta. 1978;83(1-2):81-91. [pmid: 620471].

## Appendix A5 USPSTF Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The USPSTF Methods Workgroup developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria that relate to internal validity, and the associated definitions of quality categories, at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### RCTs and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs

#### Definition of ratings based on above criteria

Good: Meets all criteria; comparable groups are assembled initially and maintained throughout the study (follow-up ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate ≥80%; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables

Fair: Recent, relevant, without major apparent selection or diagnostic workup bias but with response rate <80 %or attention to some but not all important confounding variables

Poor: Major selection or diagnostic workup biases, response rates <50%, or inattention to confounding variables

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance are especially important

#### Definition of ratings from above criteria

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Source: U.S. Preventive Services Task Force Procedure Manual. Available at: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual

## Appendix A6 Reviewers of the Draft Report

- Jane Brotanek, MD, MPH
  Pediatrician, Ridgefield Pediatrics
  Ridgefield, CT
- Michael Georgieff, MD
  Professor of Pediatrics and Child Psychology, University of Minnesota School of Medicine
  Minneapolis, MN
- Robert Justice, MD, MS
  Supervisory Medical Officer, Office of Hematology and Oncology Products, Food and Drug Administration
  Silver Spring, MD
- Kimberly O'Brien, PhD
  Professor, Division of Nutritional Sciences, Cornell University
  Ithaca, NY
- Ekwutosi Okoroh, MD, MPH
  Medical Epidemiologist, Division of Blood Disorders, Centers for Disease Control and Prevention
  Atlanta, GA
- Matthew Short, MD, FAAFP
  Family Medicine, Madigan Army Medical Center
  Tacoma, WA