# References

1 U.S. Preventive Services Task Force. Recommendation Statement: Screening for Iron Deficiency Anemia, Including Iron Supplementation for Children and Pregnant Women. Rockville, MD. U.S. Preventive Services Task Force. 2006.
2 Griffin IJ, Abrams SA. Iron and breastfeeding. Pediatr Clin North Am. 2001;48(2):401-13. [pmid: 11339160].
3 World Health Organization. Iron Deficiency Anaemia: Assessment, Prevention, and Control: A Guide for Programme Managers. Geneva. World Health Organization. 2001. Accessed at http://www.who.int/nutrition/publications/en/ida_assessment_prevention_control.pdf.
4 Centers for Disease Control and Prevention. Recommendations to prevent and control iron deficiency in the United States. MMWR. 1998;47(RR-3):1-36.
5 Zimmermann MB, Hurrell RF. Nutritional iron deficiency. Lancet. 2007;370(9586):511-20. [pmid: 17693180].
6 Baker RD, Greer FR, Committee on Nutrition, American Academy of Pediatrics. Diagnosis and prevention of iron deficiency and iron-deficiency anemia in infants and young children (0-3 years of age). Pediatrics. 2010;126(5):1040-50. [pmid: 20923825].
7 World Health Organization, Centers for Disease Control and Prevention. Assessing the Iron Status of Populations: Including Literature Reviews. 2nd ed. Report of a Joint World Health Organization/Centers for Disease Control and Prevention Technical Consultation on the Assessment of Iron Status at the Population Level. 2004 Apr 6–8. Geneva, Switzerland. 2007.
8 Cogswell ME, Looker AC, Pfeiffer CM, et al. Assessment of iron deficiency in US preschool children and nonpregnant females of childbearing age: National Health and Nutrition Examination Survey 2003-2006. Am J Clin Nutr. 2009;89(5):1334-42. [pmid: 19357218].
9 Bamberg R. Occurrence and detection of iron-deficiency anemia in infants and toddlers. Clin Lab Sci. 2008;21(4):225-31. [pmid: 19174983].
10 Brotanek JM, Gosz J, Weitzman M, Flores G. Secular trends in the prevalence of iron deficiency among US toddlers, 1976-2002. Arch Pediatr Adolesc Med. 2008;162(4):374-81. [pmid: 18391147].
11 Schneider JM, Fujii ML, Lamp CL, et al. Anemia, iron deficiency, and iron deficiency anemia in 12-36-mo-old children from low-income families. Am J Clin Nutr. 2005;82(6):1269-75. [pmid: 16332660].
12 Centers for Disease Control and Prevention. Iron deficiency--United States, 1999-2000. MMWR. 2002;51(40):897-9. [pmid: 12418542].
13 Cusick SE, Mei Z, Freedman DS, et al. Unexplained decline in the prevalence of anemia among US children and women between 1988-1994 and 1999-2002. Am J Clin Nutr. 2008;88(6):1611-7. [pmid: 19064522].
14 Hay G, Sandstad B, Whitelaw A, Borch-Iohnsen B. Iron status in a group of Norwegian children aged 6-24 months. Acta Paediatr. 2004;93(5):592-8. [pmid: 15174778].
15 Oti-Boateng P, Seshadri R, Petrick S, et al. Iron status and dietary iron intake of 6-24-month-old children in Adelaide. J Paediatr Child Health. 1998;34(3):250-3. [pmid: 9633972].
16 Brotanek JM, Halterman JS, Auinger P, et al. Iron deficiency, prolonged bottle-feeding, and racial/ethnic disparities in young children. Arch Pediatr Adolesc Med. 2005;159(11):1038-42. [pmid: 16275794].
17 Oregon Evidence-based Practice Center. Screening for Iron Deficiency Anemia in Childhood and Pregnancy: Update of the 1996 U.S. Preventive Services Task Force Review. Evidence Synthesis No. 40. AHRQ Publication No. 06-0590-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2006.
18 Lozoff B. Iron deficiency and child development. Food Nutr Bull. 2007;28(4 Suppl):S560-71. [pmid: 18297894].
19 McCann JC, Ames BN. An overview of evidence for a causal relation between iron deficiency during development and deficits in cognitive or behavioral function. Am J Clin Nutr. 2007;85(4):931-45. [pmid: 17413089].
20 Lozoff B, Jimenez E, Hagen J, et al. Poorer behavioral and developmental outcome more than 10 years after treatment for iron deficiency in infancy. Pediatrics. 2000;105(4):E51. [pmid: 10742372].
21 Lozoff B, Brittenham GM, Wolf AW, et al. Iron deficiency anemia and iron therapy effects on infant developmental test performance. Pediatrics. 1987;79(6):981-95. [pmid: 2438638].
22 Walter T, De Andraca I, Chadud P, Perales CG. Iron deficiency anemia: adverse effects on infant psychomotor development. Pediatrics. 1989;84(1):7-17. [pmid: 2472596].
23 Lozoff B, Jimenez E, Smith JB. Double burden of iron deficiency in infancy and low socioeconomic status: a longitudinal analysis of cognitive test scores to age 19 years. Arch Pediatr Adolesc Med. 2006;160(11):1108-13. [pmid: 17088512].
24 Lukowski AF, Koss M, Burden MJ, et al. Iron deficiency in infancy and neurocognitive functioning at 19 years: evidence of long-term deficits in executive function and recognition memory. Nutr Neurosci. 2010;13(2):54-70. [pmid: 20406573].
25 Munot P, De Vile C, Hemingway C, et al. Severe iron deficiency anaemia and ischaemic stroke in children. Arch Dis Child. 2011;96(3):276-9. [pmid: 21030379].
26 Maguire JL, deVeber G, Parkin PC. Association between iron-deficiency anemia and stroke in young children. Pediatrics. 2007;120(5):1053-7. [pmid: 17974743].
27 Mahoney DH Jr. Iron Deficiency in Infants and Young Children: Screening, Prevention, Clinical Manifestations, and Diagnosis. UpToDate®. 2013.
28 Iron Deficiency Anemia. DISEASEDEX™ General Medicine Clinical Review. 2013.
29 American Pharmaceutical Association. Pediatric Dosage Handbook. 12th ed. Hudson, OH. Lexi-Comp. 2005.
30 Zlotkin S, Arthur P, Antwi KY, Yeung G. Randomized, controlled trial of single versus 3-times-daily ferrous sulfate drops for treatment of anemia. Pediatrics. 2001;108(3):613-6. [pmid: 11533326].
31 Tenenbein M. Unit-dose packaging of iron supplements and reduction of iron poisoning in young children. Arch Pediatr Adolesc Med. 2005;159(6):557-60. [pmid: 15939855].
32 U.S. Department of Health and Human Services, U.S. Food and Drug Administration. Iron-containing supplements and drugs; label warning statements and unit-dose packaging requirements; removal of regulations for unit-dose packaging requirements for dietary supplements and drugs. Federal Register. 2003;68:201.
33 Chang TP, Rangan C. Iron poisoning: a literature-based review of epidemiology, diagnosis and management. Pediatr Emerg Care. 2011;27(10):978-85. [pmid: 21975503].
34 Bronstein AC, Spyker DA, Cantilena LR Jr, et al. 2010 Annual Report of the American Association of Poison Control Centers' National Poison Data System (NPDS): 28th Annual Report. Clin Toxicol (Phila). 2011;49(10):910-41. [pmid: 22165864].
35 Bronstein AC, Spyker DA, Cantilena LR Jr, et al. 2009 Annual Report of the American Association of Poison Control Centers' National Poison Data System (NPDS): 27th Annual Report. Clin Toxicol (Phila). 2010;48(10):979-1178. [pmid: 21192756].
36 Bronstein AC, Spyker DA, Cantilena LR Jr, et al. 2011 Annual Report of the American Association of Poison Control Centers' National Poison Data System (NPDS): 29th Annual Report. Clin Toxicol (Phila). 2012;50(10):911-1164. [pmid: 23272763].
37 Institute of Medicine, Committee on the Prevention, Detection, and Management of Iron Deficiency Anemia Among U.S. Children and Women of Childbearing Age. Iron Deficiency Anemia: Recommended Guidelines for the Prevention, Detection, and Management Among U.S. Children and Women of Childbearing Age. Washington, DC. National Academies Press. 1993.
38 Bright Futures. Nutrition Supervision. 3rd ed. Elk Grove Village, IL. American Academy of Pediatrics. 2011.
39 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Iron Deficiency Anemia. Leawood, KS. American Academy of Family Physicians. 2006. Accessed at http://www.aafp.org/patient-care/clinical-recommendations/all/iron-deficiency-anemia.html.
40 Skalicky A, Meyers AF, Adams WG, et al. Child food insecurity and iron deficiency anemia in low-income infants and toddlers in the United States. Matern Child Health J. 2006;10(2):177-85. [pmid: 16328705].
41 Brotanek JM, Gosz J, Weitzman M, Flores G. Iron deficiency in early childhood in the United States: risk factors and racial/ethnic disparities. Pediatrics. 2007;120(3):568-75. [pmid: 17766530].
42 Schneider JM, Fujii ML, Lamp CL, et al. The use of multiple logistic regression to identify risk factors associated with anemia and iron deficiency in a convenience sample of 12-36-mo-old children from low-income families. Am J Clin Nutr. 2008;87(3):614-20. [pmid: 18326599].
43 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2008. Accessed at http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
44 U.S. Preventive Services Task Force. Screening for iron deficiency anemia, including iron prophylaxis. Guide to Clinical Preventive Services. 2nd ed. Baltimore, MD. Williams & Wilkins. 1996.
45 United Nations Development Programme. Human Development Index (HDI). New York, NY. United Nations Development Programme. 2014. Accessed at http://hdr.undp.org/en/statistics/.
46 Daly A, MacDonald A, Aukett A, et al. Prevention of anaemia in inner city toddlers by an iron supplemented cows' milk formula. Arch Dis Child. 1996;75(1):9-16. [pmid: 8813864].
47 Williams J, Wolff A, Daly A, et al. Iron supplemented formula milk related to reduction in psychomotor decline in infants from inner city areas: randomised study. BMJ. 1999;318(7185):693-7. [pmid: 10074011].
48 Geltman PL, Meyers AF, Mehta SD, et al. Daily multivitamins with iron to prevent anemia in high-risk infants: a randomized clinical trial. Pediatrics. 2004;114(1):86-93. [pmid: 15231912].
49 Gill DG, Vincent S, Segal DS. Follow-on formula in the prevention of iron deficiency: a multicentre study. Acta Paediatr. 1997;86(7):683-9. [pmid: 9240873].
50 Lozoff B, De Andraca I, Castillo M, et al. Behavioral and developmental effects of preventing iron-deficiency anemia in healthy full-term infants. Pediatrics. 2003;112(4):846-54. [pmid: 14523176].
51 Makrides M, Leeson R, Gibson R, Simmer K. A randomized controlled clinical trial of increased dietary iron in breast-fed infants. J Pediatr. 1998;133(4):559-62. [pmid: 9787699].
52 Morley R, Abbott R, Fairweather-Tait S, et al. Iron fortified follow on formula from 9 to 18 months improves iron status but not development or growth: a randomised trial. Arch Dis Child. 1999;81(3):247-52. [pmid: 10451399].
53 Szymlek-Gay EA, Ferguson EL, Heath AL, et al. Food-based strategies improve iron status in toddlers: a randomized controlled trial. Am J Clin Nutr. 2009;90(6):1541-51. [pmid: 19828711].
54 Yalçin SS, Yurdakök K, Açikgöz D, Özmert E. Short-term developmental outcome of iron prophylaxis in infants. Pediatr Int. 2000;42(6):625-30. [pmid: 11192518].
55 Yeung GS, Zlotkin SH. Efficacy of meat and iron-fortified commercial cereal to prevent iron depletion in cow milk-fed infants 6 to 12 months of age: a randomized controlled trial. Can J Public Health. 2000;91(4):263-7. [pmid: 10986782].
56 Domellof M, Cohen RJ, Dewey KG, et al. Iron supplementation of breast-fed Honduran and Swedish infants from 4 to 9 months of age. J Pediatr. 2001;138(5):679-87. [pmid: 11343043].
57 Jary S, Whitelaw A, Walløe L, Thoresen M. Comparison of Bayley-2 and Bayley-3 scores at 18 months in term infants following neonatal encephalopathy and therapeutic hypothermia. Dev Med Child Neurol. 2013;55(11):1053-9. [pmid: 23927586].
58 Moore T, Johnson S, Haider S, et al. The Bayley-III cognitive and language scales: how do scores relate to the Bayley II?. Arch Dis Child. 2011;96(Suppl 1):A39-40.
59 American Academy of Pediatrics. Why Formula Instead of Cow's Milk?. Elk Grove Village, IL. American Academy of Pediatrics. 2013.
60 Wang B, Zhan S, Gong T, Lee L. Iron therapy for improving psychomotor development and cognitive function in children under the age of three with iron deficiency anaemia. Cochrane Database Syst Rev. 2013;(6). CD001444.
61 Sachdev H, Gera T, Nestel P. Effect of iron supplementation on mental and motor development in children: systematic review of randomised controlled trials. Public Health Nutr. 2005;8(2):117-32. [pmid: 15877905].
62 Gera T, Sachdev HP. Effect of iron supplementation on incidence of infectious illness in children: systematic review. BMJ. 2002;325(7373):1142. [pmid: 12433763].
63 Lozoff B, Castillo M, Clark KM, Smith JB. Iron-fortified vs low-iron infant formula: developmental outcome at 10 years. Arch Pediatr Adolesc Med. 2012;166(3):208-15. [pmid: 22064877].
64 Aukett MA, Parks YA, Scott PH, Wharton BA. Treatment with iron increases weight gain and psychomotor development. Arch Dis Child. 1986;61(9):849-57. [pmid: 2429622].
65 Idjradinata P, Pollitt E. Reversal of developmental delays in iron-deficient anaemic infants treated with iron. Lancet. 1993;341(8836):1-4. [pmid: 7678046].
66 Lozoff B, Brittenham GM, Viteri FE, et al. The effects of short-term oral iron therapy on developmental deficits in iron-deficient anemic infants. J Pediatr. 1982;100(3):351-7. [pmid: 6174719].
67 Vucic V, Berti C, Vollhardt C, et al. Effect of iron intervention on growth during gestation, infancy, childhood, and adolescence: a systematic review with meta-analysis. Nutr Rev. 2013;71(6):386-401. [pmid: 23731448].
68 Logan S, Martins S, Gilbert R. Iron therapy for improving psychomotor development and cognitive function in children under the age of three with iron deficiency anaemia. Cochrane Database Syst Rev. 2001;(2). CD001444.
69 Driva A, Kafatos A, Solman M. Iron deficiency and the cognitive and psychomotor development of children: a pilot study with institutionalised children. Early Child Dev Care. 1985;22(1):73-82.
70 Honig AS, Oski FA. Developmental scores of iron deficient infants and the effects of therapy. Infant Behav Dev. 1978;1:168-76.
71 Kimmons G, Moffatt M, Lonstaffe S, Whalen-Besant J. Short term effects of intramuscular iron on the behaviour of iron-deficient children: a clinical trial [personal communication]. Letter to Susana Martins, Federal University of São Paulo, São Paulo, Brazil. November. 30. 2000.
72 Rosado JL, López P, Muñoz E, et al. Zinc supplementation reduced morbidity, but neither zinc nor iron supplementation affected growth or body composition of Mexican preschoolers. Am J Clin Nutr. 1997;65(1):13-9. [pmid: 8988907].
73 Idjradinata P, Watkins WE, Pollitt E. Adverse effect of iron supplementation on weight gain of iron-replete young children. Lancet. 1994;343(8908):1252-4. [pmid: 7910275].
74 Irigoyen M, Davidson LL, Carriero D, Seaman C. Randomized, placebo-controlled trial of iron supplementation in infants with low hemoglobin levels fed iron-fortified formula. Pediatrics. 1991;88(2):320-6. [pmid: 1861932].
75 Lind T, Lönnerdal B, Stenlund H, et al. A community-based randomized controlled trial of iron and zinc supplementation in Indonesian infants: effects on growth and development. Am J Clin Nutr. 2004;80(3):729-36. [pmid: 15321815].
76 Majumdar I, Paul P, Talib VH, Ranga S. The effect of iron therapy on the growth of iron-replete and iron-deplete children. J Trop Pediatr. 2003;49(2):84-8. [pmid: 12729289].
77 Pollitt E, Saco-Pollitt C, Jahari A, et al. Effects of an energy and micronutrient supplement on mental development and behavior under natural conditions in undernourished children in Indonesia. Eur J Clin Nutr. 2000;54(Suppl 2):S80-90. [pmid: 10902991].
78 Olney DK, Pollitt E, Kariger PK, et al. Combined iron and folic acid supplementation with or without zinc reduces time to walking unassisted among Zanzibari infants 5- to 11-mo old. J Nutr. 2006;136(9):2427-34. [pmid: 16920865].
79 Villalpando S, Shamah T, Rivera JA, et al. Fortifying milk with ferrous gluconate and zinc oxide in a public nutrition program reduced the prevalence of anemia in toddlers. J Nutr. 2006;136(10):2633-7. [pmid: 16988138].
80 Akman M, Cebeci D, Okur V, et al. The effects of iron deficiency on infants' developmental test performance. Acta Paediatr. 2004;93(10):1391-6. [pmid: 15499963].
81 Engstrom EM, Castro IR, Portela M, et al. Effectiveness of daily and weekly iron supplementation in the prevention of anemia in infants. Revista de Saude Publica. 2008;42(5):786-95. [pmid: 18709235].
82 Abdelrazik N, Al-Haggar M, Al-Marsafawy H, et al. Impact of long-term oral iron supplementation in breast-fed infants. Indian J Pediatr. 2007;74(8):739-45. [pmid: 17785896].
83 Berglund S, Westrup B, Domellof M. Iron supplements reduce the risk of iron deficiency anemia in marginally low birth weight infants. Pediatrics. 2010;126(4):e874-83. [pmid: 20819898].
84 Sankar MJ, Saxena R, Mani K, et al. Early iron supplementation in very low birth weight infants--a randomized controlled trial. Acta Paediatr. 2009;98(6):953-8. [pmid: 19484832].
85 Ziegler EE, Nelson SE, Jeter JM. Iron supplementation of breastfed infants from an early age. Am J Clin Nutr. 2009;89(2):525-32. [pmid: 19073791].