# Discussion

## Summary of Review Findings

Table 5 summarizes the evidence reviewed for this update.

Table 5 Summary of Evidence

Routine Iron Supplementation in Children

Main Findings From Prior USPSTF Reviews | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality^a^
Key Question 1. What are the benefits of routine iron supplementation in children ages 6 to 24 months on child health outcomes?
Clinical outcomes
No evidence on clinical outcomes. Mixed results were found on the effect of iron supplementation on child developmental test scores in developing and developed countries | Growth: 6 trials Developmental test scores: 4 trials | No trials reported developmental diagnoses or other clinical outcomes; the clinical implications of test scores are unclear | Growth: consistent Developmental test scores: inconsistent | 1 trial was conducted in Turkey and 1 in Chile | Evidence from 5 of 6 trials found no difference in short-term growth parameters between supplemented and nonsupplemented groups. The sixth trial was methodologically flawed, with important differences at baseline. None of the 3 studies that used the Bayley Scale of Infant Development reported significant differences in developmental test scores between groups. Another trial found that scores on the Griffiths scale, a measure of psychomotor development, declined in both groups over the course of the study but declined somewhat less in the iron-supplemented group after 24 months (p=0.04). No trials assessed the effect of routine iron supplementation on other clinical outcomes. | Growth: Fair Developmental test scores: Poor
Intermediate outcomes
Older studies of supplementation found reduced incidence of iron deficiency and iron deficiency anemia based on evidence in developing and developed countries. These studies were not reassessed in the 2006 update | 10 trials | Interventions were widely variable, some studies were conducted in developing countries, and many studies had high attrition or exclusion from analysis | Inconsistent | 1 trial was conducted in Turkey and 1 in Chile. Others in U.S. or countries with similar economic profile | A significant benefit of supplementation was reported in 1 of 5 trials reporting iron deficiency anemia (RR, 0.14 [95% CI, 0.09 to 0.20]); 2 of 5 trials reporting iron deficiency (RR, 0.52 [95% CI, 0.45 to 0.59]) and 6% of supplemented children vs. 22% of unsupplemented children (RR not calculable); and 2 of 6 trials reporting anemia (RR, 0.14 [95% CI, 0.09 to 0.20] and RR, 0.07 [95% CI, 0.01 to 0.48]). 1 trial, which had methodological flaws, found beneficial effects for all 3 outcomes. | Fair
Key Question 2. What are the harms of routine iron supplementation in children ages 6 to 24 months?
Harms included were gastrointestinal symptoms and fatal overdose, though evidence from controlled trials was lacking. 1 meta-analysis reported an 11% increase in risk for diarrhea. | 2 trials | Harms were rarely reported | Consistent | 1 study conducted in New Zealand used a nonstandard intervention (red meat) | 1 trial reported no difference in rates of gastrointestinal adverse events between toddlers receiving iron-fortified milk and those consuming unfortified milk (RR, 1.0 [95% CI, 0.9 to 11]), while another trial stated that no clinically significant adverse events were judged by investigators to be attributable to study interventions. Some between-group differences were observed in nonadherence; however, the differences appear to be based on the type of supplement/control rather than the iron content. Other harms were not reported. | Poor

Abbreviations: CI=confidence interval; N/A= not applicable; RR=relative risk.

a “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

Screening for Iron Deficiency Anemia in Children

Main findings From Prior USPSTF Reviews | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality^a^
Key Question 1. What are the benefits of screening for iron deficiency anemia in asymptomatic children ages 6 to 24 months on child health outcomes?
No controlled trials evaluated screening for iron deficiency anemia | No studies | No studies | N/A | N/A | No evidence | N/A
Key Question 2. What are the harms of screening for iron deficiency anemia in children ages 6 to 24 months?
No studies evaluated harms of screening for iron deficiency anemia | No studies | No studies | N/A | N/A | No evidence | N/A
Key Question 3. What are the benefits of treatment of iron deficiency anemia in children ages 6 to 24 months on child health outcomes?
7 trials of treatment for iron deficiency anemia reported few benefits of treatment on psychomotor development outcomes in mostly developing countries | No studies | No studies | N/A | N/A | No evidence | N/A
Key Question 4. What are the harms of iron treatment in children ages 6 to 24 months?
Harms of iron treatment were considered to be similar to harms of iron supplementation and were not directly assessed | No studies | No studies | N/A | N/A | No evidence | N/A
Key Question 5. What is the association between a change in iron status and improvement in child-health outcomes in U.S.-relevant populations?
Not assessed | No studies | No studies | N/A | N/A | No evidence | N/A

Abbreviations: CI=confidence interval; N/A= not applicable; RR=relative risk.

a “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

As in the prior reviews, no trials assessed the effects of routine iron supplementation compared with placebo in children ages 6 to 24 months on diagnosis of psychomotor or neurodevelopmental delay or quality of life, and five of six trials reporting growth outcomes found no benefit of supplementation. Although not clearly clinical outcomes, developmental test scores after 3- to 12-month followup periods were reported in four trials, with mostly nonsignificant findings (Table 2; Appendix B1).47,50,52,54 The clinical significance of these findings is unclear. These findings are similar to those in the prior reviews,17,44 which also included evidence from developing countries. Several studies46,49,50,52,53,56 (including two poor-quality studies54,55) reported growth outcomes, such as weight, length, and head circumference. All but the study by Lozoff et al50 (in which the groups differed by weight and length at baseline) found no significant differences between groups. Similarly, a recent systematic review and meta-analysis of 21 RCTs showed no effects of iron intervention on growth parameters.67

Ten trials (in 11 publications) that assessed routine iron supplementation versus placebo or other control interventions in children reported inconsistent findings for incidence of iron deficiency anemia, iron deficiency, and anemia, as well as venous hemoglobin and serum ferritin concentrations.46-56 Iron deficiency anemia was reported in five studies; of these, one good-quality study and two fair-quality studies in the United States found no differences between groups. One large study with a very high rate of iron deficiency anemia in the control group reported a significant benefit (RR, 0.14 [95% CI, 0.09 to 0.20]).50 This same study and another fair-quality study49 reported a significant benefit of supplementation on iron deficiency (RR, 0.52 [95% CI, 0.45 to 0.59]), with deficiency found in 6 percent of supplemented children versus 22 percent of unsupplemented children (RR not calculable from data reported). Two other studies, including one in the United States, found no difference between groups (RR, 0.94 [95% CI, 0.74 to 1.20] and 1.81 [95% CI, 0.38 to 8.60], respectively). Two of six studies reporting iron deficiency anemia found a significant benefit of iron supplementation (RR, 0.14 [95% CI, 0.09 to 0.20] and 0.07 [95% CI, 0.01 to 0.48]), although both trials had methodological shortcomings.46, 47,50 Hemoglobin concentration was reported in eight studies and ferritin concentration was reported in nine studies, with conflicting results.47-54,56

Partly because of the variation in methods used to identify and define iron deficiency anemia, iron deficiency, and anemia, incidence rates in control groups varied widely across these studies. Additional factors may have contributed to this variability, such as the unknown mixture of baseline risk in enrolled children (e.g., proportion of control group using nonfortified cow's milk as the primary nutrition source), which were rarely reported and not analyzed, so further analysis with risk stratification could not be undertaken. As mentioned, children receiving cow's milk may be a flawed comparison group, as cow's milk is considered a risk factor for iron deficiency anemia, and its consumption is advised against before age 12 months by IOM, AAP, and CDC. For these reasons, the inconsistencies in this evidence cannot be resolved and the interpretability of these findings for populations in the United States is somewhat limited. Sample sizes were not calculated a priori in some cases, and some studies were not powered to detect differences for specific outcomes.

Harms of routine iron supplementation in children were rarely reported. No studies reported accidental overdose. One good-quality trial reported no difference in rates of gastrointestinal adverse events in toddlers consuming iron-fortified milk and those consuming nonfortified milk (2% vs. 2%; RR, 1.0 [95% CI, 0.9 to 11]),53 and one other trial reported no clinically significant adverse events that investigators judged to be due to study interventions. Other harms were not reported. This result was similar to findings in the prior USPSTF reports,17,44 which included evidence from a meta-analysis of 28 studies (published and unpublished RCTs and cohort studies) and found a slightly increased risk for diarrhea with iron supplementation (RR, 1.1 [95% CI, 1.0 to 1.2]).62 The majority of studies included in this meta-analysis were conducted in developing countries, and the age of the populations ranged from 2 days to 14 years.

As in the prior USPSTF reports, no trials were identified to address the Key Questions on the benefits or harms of screening for iron deficiency anemia in children ages 6 to 24 months. No new trials addressed treatment of iron deficiency anemia in children ages 6 to 24 months. The prior USPSTF reviews included trials of treatment conducted in mostly developing countries; the only study conducted in a country directly generalizable to the United States (England) was rated poor-quality.64 This study compared treatment for 1 week versus placebo and found no differences in psychomotor development outcomes but improved hemoglobin and ferritin levels and growth velocity in the treatment group. Finally, no new studies reported harms of treatment of iron deficiency anemia, although we identified an older trial74 that reported no differences between iron- and placebo-treated children in incidence of overall or specific adverse events, including gastrointestinal events. Based on small short-term trials conducted in countries other than the United States, prior USPSTF reports concluded that there was no evidence on the relative harms of treatment.

No studies that assessed an association between change in iron-deficient status and differences in growth or development were found. Indirect evidence from three studies of infants who were iron replete at baseline but showed increased iron status with supplementation did not find an association between this change and growth or developmental outcomes.

## Limitations

Limitations of our report include restricting inclusion to studies published in English, RCTs and controlled observational studies, and studies conducted in developed countries or developing countries where the enrolled population was similar to the U.S. population, particularly in terms of rates of malnutrition, hemoparasite burden, and general socioeconomic status. Numerous studies of iron supplementation and treatment that were conducted in developing countries were excluded.75-81 Malnourishment, very low socioeconomic status, and/or presence of parasitic endemic diseases were common in included populations in these studies. We also excluded studies of iron supplementation that enrolled children younger than age 6 months, as this population was determined to be outside the scope of this review.82-85

Limitations of the evidence are described throughout the report and can be summarized as lack of adequate sample sizes, inconsistency in method and timing of outcome measurement, and lack of reporting of clinical outcomes.

## Emerging Issues

We did not identify ongoing studies or emerging issues relevant to a U.S.-applicable population.

## Relevance for Priority Populations

Race or ethnicity was not reported in most studies. It was predominately white in two studies46,47, 53 and approximately half black in one study conducted in the United States.48 This provides limited ability to extrapolate on any racial or ethnic issues.

## Future Research

Good-quality RCTs of routine supplementation and screening programs for iron deficiency anemia in children ages 6 to 24 months that have adequate sample sizes are needed. Such trials should more clearly report baseline characteristics of enrolled children and details of interventions and harms, in addition to examining longer-term benefits, especially clinical and developmental outcomes using appropriate neurodevelopmental tests. The clinical significance of developmental test scores is unclear.

## Conclusions

More research is needed to assess the benefits and harms of routine iron supplementation to prevent iron deficiency anemia, and screening for and treatment of iron deficiency anemia, in children ages 6 to 24 months. While some evidence is available showing improvements in hematological values, trials reporting clinical outcomes, including developmental outcomes, are lacking.