# Results

## Routine Iron Supplementation in Children

### Key Question 1 What Are the Benefits of Routine Iron Supplementation in Children Ages 6 to 24 Months on Child Health Outcomes?

#### Summary

In the current review, six placebo-controlled trials of routine iron supplementation in children ages 6 to 24 months reported growth outcomes, with most studies finding no effect of supplementation on weight, length, or head circumference. Other clinical outcomes, such as diagnosis of psychomotor or neurodevelopmental delay or quality of life, were not reported in any trial. Although not clearly clinical outcomes, developmental test scores were reported in four trials after 3- to 12-month followup periods, with mostly nonsignificant findings. The clinical significance of these findings is unclear.

Ten trials that assessed iron supplementation in children reported inconsistent findings for incidence of iron deficiency anemia, iron deficiency, and anemia, as well as hemoglobin and serum ferritin concentrations. Iron deficiency anemia was reported in five studies, one of which reported a significant benefit (RR, 0.14 [95% CI, 0.09 to 0.20]). This same study reported a significant benefit of supplementation on iron deficiency (RR, 0.52 [95% CI, 0.45 to 0.59]). Another study, in which 6 percent of children received iron-fortified formula, 22 percent received nonfortified formula, and 43 percent received cow's milk, also reported a significant benefit of supplementation on iron deficiency, but the RR was not calculable because the authors reported percentages that do not correspond to whole numbers of participants according to group sizes. Two studies reported results suggesting a benefit but failed to reach significance, and two other studies found no difference between groups. Two of six studies reporting anemia found a significant benefit of iron supplementation (RR, 0.14 [95% CI, 0.09 to 0.20] and 0.07 [95% CI, 0.01 to 0.48]), although both trials had methodological shortcomings. Hemoglobin concentration was reported in eight studies and ferritin concentration was reported in nine studies, with conflicting results.

The USPSTF recommendation from 1996^44^ found adequate evidence that iron supplementation resulted in reduced incidence of iron deficiency and iron deficiency anemia but found little evidence focused on clinical outcomes. The 2006 USPSTF review17 did not assess the effect of supplementation on hematological indexes or incidence of iron deficiency and iron deficiency anemia, and found mixed evidence supporting the benefit of iron supplementation on neurodevelopmental test scores.

#### Evidence

Ten trials (in 11 publications) were included (Tables 2 and 3; Appendix B1) (two poor-quality trials were omitted from tables).46-58 Studies were conducted in primary care and community settings in the United States (one study), United Kingdom (four studies), Canada (one study), New Zealand (one study), Chile (one study), Australia (one study), Sweden (one study), and Turkey (one study). Children were generally enrolled at ages between 6 and 9 months, with one study enrolling children with a mean age of approximately 10 months52 and another study at approximately 17 months.53 Iron supplementation was administered for durations ranging from 3 to 18 months. Supplementation was provided as oral iron drops in three studies;48,54,56 iron-fortified formula in four studies;46,47,49,50,52 and iron-fortified milk, foods, or meat in three studies.51,53,55 Control groups were given a non–iron-containing formula or supplement or a weaning diet in four trials;48,49,51,56 cow's milk in four trials;47,49,52,53 and no treatment, instructions, or supplement in three trials.50,54,55 Race or ethnicity was not reported in seven studies,49-52,54-56 was predominately white in two studies,46,47,53 and approximately half black in one study conducted in the United States.48 Studies enrolled nearly equal proportions of males and females (proportion of females ranged from 43% to 58%). Most studies excluded children born prematurely and those with conditions likely to affect iron absorption, growth, or development. Enrolled sample sizes ranged from 24 to 493 except for one larger study of 1,798 children, and many studies analyzed fewer numbers because of loss to followup or refusal to undergo venipuncture. Only one study analyzed children on an intention-to-treat basis;53 the proportion of the sample available for analysis at the end of the other studies ranged from 53 to 92 percent.

Table 2 Child Bayley Scale Outcomes in Iron Supplementation Studies

| | | | Supplementation vs. Control
Study, Year Country n Quality | Duration | Risk Factors Reported | Interventions and Comparator | Mental Development Index | Psychomotor Development Index
Lozoff, 2003^50^ Chile n=1,657 Fair | 6 months | Race: NR Preterm and low birth weight infants excluded | A. Multiple interventions with varying iron concentrations; B. No iron supplementation | 103.9 vs. 104.6; p=NS | 96.7 vs. 97.5; p=NS
Morley, 1999^52^ United Kingdom n=428 Fair | 9 months | Race: NR Preterm and low birth weight infants excluded | A. Iron-fortified formula, 1.2 mg iron/L; B. Unfortified formula, 0.9 mg iron/L; C. Cow's milk | 93.9 vs. 94.5 vs. 96.2; p=NS | 94.8 vs. 94.6 vs. 93.6; p=NS

Abbreviations: NR=not reported; NS=not significant.

Note 1: Cutoffs used for Bayley Scale Mental and Psychomotor Development Index scores vary, but several authors suggest that scores <85 represent moderate developmental delay, while scores <70 represent severe delay.57,58

Note 2: One additional fair-quality study conducted in the United Kingdom (n=92) reported developmental test scores using the Griffiths scale.47 Scores declined in both groups over the course of the study but declined somewhat less in the iron-supplemented group (general quotient score at 24 months, −9.3 vs. −14.7; p=0.04). The clinical meaning of this difference (5.4) is unclear, particularly because both group's scores at 24 months were within normal limits.

Note 3: One trial omitted from table due to poor-quality rating (Yalcin, 2000^54^).

Table 3 Good- and Fair-Quality Trials of Iron Supplementation in Children Ages 6 to 24 Months on Hematological Outcomes

| | | Supplementation vs. Control
Study, Year Country n Duration Quality | Risk Factors Reported | Interventions and Comparator | Hemoglobin | Serum Ferritin | Iron Deficiency^a^ | Anemia (Hb <110 g/L) | Iron Deficiency Anemia (Hb <110 g/L and Iron Deficiency^a^)
Domellof, 2001^56^ Sweden n=70 3 months Fair | Race: NR Preterm and low birth weight infants excluded | A. Placebo from 4 to 6 months and iron supplement from 6 to 9 months (n=34); B. Placebo from 4 to 9 months (n=36) | 117.1 vs. 114.4 g/L; p=NS | 47.3 vs. 22.9 μg/L; p<0.001 | | | No effect (numbers NR)
Geltman, 2004^48^ United States n=284 3 months Fair | Race: 55% vs. 48% black Preterm and low birth weight infants excluded | A. Oral multivitamin drops, 10 mg iron/day; B. Multivitamin drops without iron | 117 vs. 117 g/L; p=NS | 32.0 vs. 29.2 μg/L; p=NS | 78% (108/138) vs. 84% (121/144) had 1 abnormal hematological value indicative of iron deficiency; RR, 0.93, (95% CI, 0.83 to 1.04) | 22% (31/138) vs. 19% (27/144); RR, 1.20 (95% CI, 0.76 to 1.90) | 8% (11/138) vs. 8% (11/144) anemic and had 2 other abnormal hematological values; RR, 1.04 (95% CI, 0.47 to 2.33)
Gill, 1997^49^ United Kingdom and Ireland n=302 11 months Fair | Race: NR Preterm and low birth weight infants excluded | A. Iron-fortified formula; B. Unfortified formula; C. Cow's milk | 121.5 vs. 117.7 vs. 111.4 g/L^b^; p=0.006 | 25.1 vs. 15.3 vs. 11.0 μg/L; p<0.001 | 6% vs. 22% vs. 43%^c^ | 11% vs. 13% vs. 33%^c^
Lozoff, 2003^50^ Chile n=1,657 6 months Fair | Race: NR Preterm and low birth weight infants excluded | A. Multiple interventions with varying iron concentrations; B. No iron supplementation | 123.6 vs. 115.6 g/L; p<0.001 | 14.0 vs. 8.7 μg/L; p<0.001 | 26.5% (286/1081) vs. 51.3% (273/532); RR, 0.52 (95% CI, 0.45 to 0.59) | 4.3% (48/1123) vs. 25.8% (138/534); RR, 0.17 (95% CI, 0.12 to 0.23) | 3.1% (34/1114) vs. 22.6% (116/514); RR, 0.14 (95% CI, 0.09 to 0.20)
Makrides, 1998^51^ Australia n=62 6 months Fair | Race: NR Preterm and low birth weight infants excluded | A. High-iron weaning diet; B. Control weaning diet | 120 vs. 115 g/L; p=NS | 26 vs. 35 μg/L; p=NS | 3.9% (5/36) vs. 7.7% (2/26); RR, 1.81 (95% CI, 0.38 to 8.60) | 0 vs. 19.2% (5/26); RR, 0.07 (95% CI, 0.00 to 1.15) | 0 vs. 0
Morley, 1999^52^ United Kingdom n=428 9 months Fair | Race: NR Preterm and low birth weight infants excluded | A. Iron-fortified formula, 1.2 mg iron/L; B. Unfortified formula, 0.9 mg iron/L; C. Cow's milk | 126 vs. 120 vs. 119 g/L; p<0.01 for A vs. C, p<0.05 for A vs. B | 21.7 vs. 13.1 vs. 14.3 μg/L; p<0.0001 for A vs. B and A vs. C
Szymlek-Gay, 2009^53^ New Zealand n=225 5 months Good | Race: 76% vs. 84% vs. 78% white | A. ≥2 portions of red meat, 1.3 mg iron per portion; B. Iron-fortified milk, 1.5 mg iron/100 g; C. Cow's milk | 121.5 vs. 118.6 vs. 120.2 g/L; p=NS | 43.5 vs. 32.8 vs. 29.9 μg/L; effect size in fortified milk group, 1.68 (95% CI, 1.27 to 2.24) | | | No difference between groups (data only reported in a figure)
Williams, 1999^47^ Other publication: Daly, 1996^46^ United Kingdom n=92 10 to 12 months Fair | Race: 74% white, 24% black, 2% Asian Receiving income support: 59% Preterm and low birth weight infants excluded | A. Iron-supplemented formula, 1.2 mg iron/100 mL; B. Cow's milk | | 30.5 vs. 15.9 μg/L; p=0.001 | | At age 18 months: 2% (1/46) vs. 33% (15/46); RR, 0.07 (95% CI, 0.01 to 0.48)

Abbreviations: CI=confidence interval; Hb=hemoglobin; NR=not reported; NS=not significant; RR=relative risk.

a Iron deficiency was defined variably as serum ferritin <10,^49,51,54^ <15,^48^ or <12 μg/L in addition to 1 of 2 other hematological indicators.50

b Groups differed significantly at baseline.

c RR not calculable based on data reported.

Note: Two trials omitted from table due to poor-quality rating (Yalcon, 2000^54^ and Yeung, 2000^55^).

These studies mostly represent children at average risk for iron deficiency anemia because all enrolled healthy children and most excluded children born preterm (except for one study) or with low birthweight (eight of 10 studies). One of the studies conducted in the United Kingdom47 considered its population to be at higher risk for iron deficiency anemia because it included children from a socioeconomically deprived neighborhood. Information on race or ethnicity was poorly reported; six of nine studies did not report race or ethnicity distributions and none analyzed results by these characteristics. Other risk factors (which are more fully described in Contextual Question 1), such as having a pregnant mother, having a low rate of weight gain, and consuming cow's milk as the main source of nutrition, were not reported in any trial. Cow's milk was used as a comparator in four studies, and while it is unclear whether it was the primary source of nutrition for these children, as noted above, the control groups may have been at higher risk for iron deficiency anemia than the intervention or other control groups (e.g., receiving nonfortified formula). The IOM, AAP, and CDC advise against giving infants cow's milk before age 12 months because of potential issues with digestion, irritation of the stomach and intestine lining, and risk for illness, and because it may even cause iron deficiency anemia.59

One study was rated good-quality,53 seven fair-quality,46-52,56 and two poor-quality54,55 (Appendix B2). Methodological shortcomings included unclear methods of randomization and allocation concealment,49-51,54-56 lack of or unclear methods of blinding,46,47,49,51,54,55 and high or differential loss to followup.48,51,52,54,55

One study, conducted in Chile by Lozoff et al,50 initially randomized children to low- or high-iron supplementation, but the low-iron intervention was replaced with a noniron intervention partway through the study, in part because interim analysis suggested that the low-iron intervention was sufficient to prevent iron deficiency anemia. For analysis, the authors combined all children who received any iron supplementation and compared them with children who did not receive supplementation, essentially breaking randomization and leading to baseline differences between the groups. Because randomization was broken, we considered the results to be comparable with those of a fair-quality comparative observational study.

Seven studies (including one poor-quality trial55) reported power or sample size calculations.48,50-53,55,56 Two studies were powered to detect effects on developmental outcomes, with one sufficient to detect a 5-point difference on the Bayley Scale52 and one sufficient to detect a 2.5-point difference in developmental scores (no specific scale cited).50 One study was powered to detect a 50 percent reduction in the rate of iron deficiency anemia.48 One was powered to detect mean reductions of 6 g/L for hemoglobin and 18 μg/L for ferritin,51 and another was powered to detect a difference in hemoglobin of 5 g/L.56 A good-quality study was powered to detect a reduction in iron deficiency prevalence of 20 percent (decrease from 30% to 10%) for one group only (red meat diet) but powered to detect an increase in ferritin of at least 5 μg/L for the other groups (fortified milk and control).53

Because of the heterogeneity of the studies in supplementation method, dose, duration, timing of initiation, and timing of followup, we did not pool results. In addition, risk factors were largely not reported, and no studies stratified results by risk groups.

#### Clinical Outcomes

Similar to the prior USPSTF reviews,17,44 no trials assessed the long-term effects of routine iron supplementation compared with placebo in children ages 6 to 24 months on clinical outcomes aside from growth. In the current review, six trials reported growth outcomes, with most studies reporting no differences between groups, but no placebo-controlled trials of routine iron supplementation in children ages 6 to 24 months reported on diagnosis of psychomotor or neurodevelopmental delay or quality of life. Four trials reported developmental test scores (not diagnosis of delay) after 3- to 12-month followup periods, with mostly nonsignificant findings. The clinical significance of these findings is unclear.

Growth. Growth parameters were reported in six studies,46,49,50,52,53,56 with only one study reporting significant differences. One reported no difference between groups in weight (8.9 vs. 8.9 kg),56 two reported no differences in weight (11.1 vs. 11.1 vs. 11.3 kg49 and 11.4 vs. 11.3 vs. 11.4 kg52) or length (78.9 vs. 79.1 vs. 80.3 cm49 and 82.3 vs. 82.3 vs. 82.6 cm52), and two studies reported no differences in growth parameters, without showing data.46,53 The study by Lozoff et al50 reported small but significant differences in length (74.7 vs. 75.1 cm; p<0.001; length-for-age z-score, p<0.01) and head circumference (46.7 vs. 47.0 cm; p<0.001). While the study reported a significant difference in absolute weight at the endpoint (9,958 vs. 10,082 g; p<0.05), no difference was found in weight-for-age z-scores. These results should be interpreted with caution, as the groups differed by weight and length at baseline (7,984 vs. 8,092 g and 66.6 vs. 66.9 cm, respectively; both p<0.01).

Developmental scale scores. Four trials reported scores on developmental tests, with mixed results depending on the scale or method used for assessment. Three of the studies were rated fair-quality,47,50,52 one was rated poor-quality,54 and none of the trials were conducted in the United States.

The best evidence on developmental outcomes comes from two fair-quality trials of children at average risk for iron deficiency anemia, which found no difference between groups on the Bayley Scale of Infant Development (between-group differences ranged from 0.6 to 0.7 for mental development and 0.2 to 0.7 for psychomotor development scores) (Table 2).50,52 A Cochrane meta-analysis of older studies from any country was included in the 2006 report and was recently updated. This review reported no statistically significant differences on the Bayley Scale indexes.60

One fair-quality trial of children potentially at higher risk for iron deficiency anemia used the Griffiths scale to measure psychomotor development and reported that scores declined in both groups over the course of the study but declined somewhat less in the iron-supplemented group after 24 months (general quotient score at 24 months, −9.3 vs. −14.7; p=0.04).47 The clinical meaning of this difference (5.4) is unclear, particularly because both groups' scores at 24 months were within normal limits.

Other developmental measures. In addition to measuring the Bayley Scale, the Lozoff study reported that children in the intervention group began crawling earlier than children in the control group (298 vs. 303 days; p<0.01).50 Using a method that involved measuring the amount of time children spent looking at pairs of novel and familiar pictures, children in the intervention group spent a significantly shorter time than children in the control group (1.39 vs. 1.46 seconds; p<0.01). Although these differences are statistically significant, it is not clear that crawling 5 days earlier or a difference of 0.07 seconds viewing time are clinically important differences. This study also reported that unsupplemented children were more likely than supplemented children to be rated as showing no positive affect, making no attempt to interact socially, and making no bids for help. They were also more likely to be rated as “adaptable,” and a greater proportion could not be soothed by words or objects when distressed. However, the trial had methodological flaws, which are detailed above, and the clinical significance of these findings is unclear.

The prior USPSTF report cited a meta-analysis of 17 trials of iron supplementation, which found no significant differences between groups on individual mental and motor development tests.61 While the review found a small but significant benefit in a composite mental development score, derived from a variety of mental development tests, subgroup analysis attributed this difference to trials in children age 7 years and older that were conducted in developing countries.

#### Intermediate Outcomes

Ten trials (in 11 publications) reported the incidence of iron deficiency anemia, iron deficiency, or anemia and hematological parameters in children ages 6 to 24 months receiving iron supplementation compared with no supplementation (Table 3).46-56 All trials except one47 were of children at average risk for iron deficiency anemia.

One study was rated good-quality,53 seven fair-quality,46-52,56 and two poor-quality,54,55 with only one conducted in the United States.48 It should be noted that the trial by Lozoff et al,50 with the methodological issues described above, also reported hematological outcomes.

The 1996 USPSTF review44 found that supplementation reduced the incidence of iron deficiency and iron deficiency anemia based on older studies conducted in developing and developed countries. The 2006 USPSTF review17 did not reassess these outcomes.

Iron deficiency anemia. Five trials (one good-quality53 and four fair-quality48,50,51,56) reported incidence of iron deficiency anemia, with ranges of 0 to 8 percent for those in the supplementation group and 0 to 22.6 percent in the placebo group. Iron deficiency anemia was variably defined as hemoglobin level less than 110 g/L and two of three abnormal iron measures (specifically ferritin, mean cell volume, and zinc protoporphyrin),48,53,56 hemoglobin level less than 100 g/L and two or more abnormal iron measures,50 or hemoglobin level less than 105 g/L and ferritin level less than 10 μg/L.51 Four studies found no difference between groups in incidence of iron deficiency anemia, including one good-quality trial conducted in New Zealand (data represented in a figure in the article),53 one study conducted in the United States (n=282) that reported that 8 percent of children in both groups (iron supplement and placebo) were anemic and had two other abnormal hematological values (RR, 1.04 [95% CI, 0.47 to 2.33]),48 one study in Sweden that reported no effect of iron supplementation on rates of iron deficiency anemia (numbers not reported),56 and one small study in Australia that reported no instances of iron deficiency anemia in either group.51 The study by Lozoff et al, conducted in Chile, found that children receiving iron supplementation were significantly less likely to have iron deficiency anemia than untreated children (3.1% [34/1,114] vs. 22.6% [116/514]; RR, 0.14 [95% CI, 0.09 to 0.20]).50 Incidence in the control group in this study (22.6%) was very high compared with the other studies (control group rates, 0% to 8%) and higher than estimated prevalence rates in the United States, suggesting that an effect may be evident in populations with higher baseline risk. However, known risk factors for iron deficiency anemia (e.g., proportion of control group using nonfortified cow's milk as the primary nutrition source) in included populations were not reported in these studies, so further analysis of this stratification could not be undertaken.

Iron deficiency. Five studies (four fair-quality and one poor-quality54) reported measures of iron deficiency, with incidence ranging from 3.9 to 78 percent for children in the supplementation group and 7.7 to 84 percent in the placebo group; only one study was conducted in the United States.48-51,54 The fair-quality study conducted in the United States found no difference in the incidence of iron deficiency, defined as the presence of two abnormal iron measures, with supplementation.48 Forty-eight percent (66/138) of those receiving oral iron drops and 51 percent (73/144) of those receiving placebo drops had two abnormal hematological values indicative of iron deficiency (i.e., zinc protoporphyrin, mean corpuscular volume, red cell distribution width, ferritin, transferritin saturation, and reticulocyte hemoglobin content) (RR, 0.94 [95% CI, 0.74 to 1.20]). This study provided iron supplementation for 3 months. A small fair-quality study also did not find statistically significant differences between groups, with serum ferritin concentration less than 10 μg/L in 3.9 percent (5/36) of children in the iron group and 7.7 percent (2/26) in the control group (RR, 1.81 [95% CI, 0.38 to 8.60]).51 Two studies, however, reported a significant benefit of iron supplementation on incidence of iron deficiency.49,50 A fair-quality study that compared iron-fortified formula with nonfortified formula and cow's milk reported a benefit of iron supplementation on incidence of iron deficiency (6% vs. 22% vs. 43%; RR not calculable based on data reported), defined as serum ferritin concentration less than 10 μg/L.49 The study by Lozoff et al found a beneficial effect of iron supplementation on incidence of iron deficiency (26.5% [286/1,081] vs. 51.3% [273/532]; RR, 0.52 [95% CI, 0.45 to 0.59]), defined as two of three abnormal iron measures (serum ferritin concentration <12 μg/L, mean cell volume <70 fL, and erythrocyte protoporphyrin >100 μg/dL red blood cells).50 Finally, a poor-quality study54 found no difference in incidence of iron deficiency (defined as serum ferritin concentration <10 μg/L), likely due to lack of statistical power.

Partly because of the variation in methods used to identify and define iron deficiency, incidence rates in control groups varied widely across these studies, ranging from 7.7 to 84 percent. Additional factors may have contributed to this variability, such as known risk factors in the included population that were not reported or analyzed. For these reasons, the inconsistencies in this evidence cannot be resolved.

Anemia. Six trials, including one study of children at higher risk for iron deficiency anemia47 and one poor-quality trial,54 reported incidence of anemia, ranging from 0 to 22 percent in the supplementation group and 13 to 33 percent in the placebo group. Iron deficiency anemia was variably defined as venous hemoglobin concentration less than 110 g/L,46-49,54 less than 105 g/L,51 or less than 100 g/L.50

Two fair-quality studies found very similar rates of anemia across supplemented and nonsupplemented groups. A fair-quality study conducted in the United States reported that 22 percent (31/138) of treated patients and 19 percent (27/144) of patients receiving placebo were anemic after 3 months (RR, 1.20 [95% CI, 0.76 to 1.90]).48 Similarly, a study from the United Kingdom found no difference in incidence of anemia in children given iron-fortified formula and nonfortified formula (11% vs. 13%; RR not calculable based on data reported).49

Three other studies found a benefit of supplementation on the incidence of anemia. One small study from Australia found no cases of anemia in the supplemented group compared with 19.2 percent (5/26) of children in the unsupplemented group (RR, 0.07 [95% CI, 0.00 to 1.15]).51 The study by Lozoff et al found that after 6 months of treatment, anemia was present in 3 percent (34/1,114) of children in the intervention group compared with 23 percent (116/514) in the control group (RR, 0.14 [95% CI, 0.09 to 0.20]).50 One U.K. trial of iron-fortified formula compared with unmodified cow's milk in children at higher risk for iron deficiency anemia, also found a benefit after 12 months' followup, reporting rates of anemia of 2 percent (1/46) in the intervention group versus 33 percent (15/46) in the control group (RR, 0.07 [95% CI, 0.01 to 0.48]).46,47

Lastly, a very small poor-quality trial of oral iron drops reported that no treated patients (0/9) and 22 percent of untreated patients (2/9) were anemic.54

Variability in the definitions of anemia, the unknown mixture of baseline risk in enrolled children, and the variation in control group rates across these studies limit the interpretability of the findings for U.S. populations. For example, while prevalence rates of iron deficiency among infants and toddlers in the United States are currently estimated at 8 percent, control group rates in these studies ranged from 13 to 33 percent. Studies finding a benefit generally had higher rates of iron deficiency in the control group than studies that did not find a benefit, suggesting that baseline risk is important in determining who will benefit from supplementation in terms of preventing iron deficiency.

Hemoglobin levels. Mean hemoglobin concentration was reported in eight studies, including one poor-quality study,54 ranging from 116 to 126 g/L for children in the supplementation group and 111 to 120 g/L in the placebo group.48-54,56 Five studies (one good-quality,53 one poor-quality,54 and three fair-quality48,51,56) reported no significant difference in hemoglobin values between groups. In contrast, three fair-quality studies reported significantly higher values in the iron-treated group.49,50,52 Control group rates again varied widely, from 111 to 120.2 g/L across all studies. The most relevant evidence in this group of studies comes from the only study conducted in the United States (117 g/L in both groups)48 and from the only good-quality study (118.6 vs. 120.2 g/L),53 both of which found no significant difference between groups.

Serum ferritin levels. Serum ferritin concentrations were reported in nine trials, including one study of children at higher risk for iron deficiency anemia47 and one poor-quality study,54 ranging from 14 to 47.3 μg/L for children in the supplementation group and 8.7 to 35 μg/L in the placebo group at followup of 3 to 12 months.46-54,56 Six of these studies, including a good-quality study, found significantly higher values in the treated group.46,49,50,52,53,56 Studies finding a difference compared iron-fortified cow's milk, fortified formula, or iron drops with nonfortified milk or formula, placebo, or no specific intervention.

A good-quality study compared children eating two or more portions of red meat daily with children receiving iron-fortified milk and a control group of children receiving cow's milk, reporting median ferritin values after 20 weeks of 43.5 versus 32.8 versus 29.9 μg/L (effect size in fortified milk group, 1.68 [95% CI, 1.27 to 2.24]).53 A trial of higher-risk children compared iron-supplemented formula with cow's milk and reported median ferritin concentrations of 30.5 μg/L in the treated group versus 15.9 μg/L in the control group (p=0.001). A second study of iron-fortified formula versus cow's milk in an average-risk population reported values of 21.7 versus 13.1 μg/L for iron-fortified formula versus cow's milk (p<0.001) and 21.7 versus 14.3 μg/L for iron-fortified versus nonfortified formula (p<0.001).52 A study of children receiving iron-fortified versus nonfortified formula reported values of 25.1 versus 15.3 μg/L (p<0.001).49 A study of iron drops reported mean ferritin values of 47.3 μg/L in the supplementation group and 22.9 μg/L in the placebo group (p<0.001).56 Finally, Lozoff et al reported values of 14.0 μg/L in children supplemented with iron-fortified formula versus a low mean value of 8.7 μg/L in unsupplemented children (p<0.001).50

In contrast, two studies, including one conducted in the United States, found no difference between groups.48,51 These studies reported ferritin values of 32.0 μg/L in children receiving oral multivitamin drops with 10 mg iron compared with 29.2 μg/L in children receiving multivitamin drops without iron, and 26 μg/L in children receiving a high-iron weaning diet compared with 35 μg/L in children receiving a control weaning diet.48,51 The poor-quality study was very small and also found no difference between groups.54

In studies finding a significant difference, ferritin levels in the control groups ranged from 8.7 μg/L (study in Chile) to 29.9 μg/L (study in New Zealand), and in studies not finding a difference, they ranged from 29.2 to 35 μg/L. Additionally, three of the six studies finding a difference used nonfortified cow's milk (a known risk factor for iron deficiency) as the control.

### Key Question 2 What Are the Harms of Routine Iron Supplementation in Children Ages 6 to 24 Months?

#### Summary

Harms associated with routine iron supplementation were not well reported; the limited evidence indicates few adverse events, with no differences between treatment and placebo groups. No serious adverse events, including accidental overdose, were reported.

#### Evidence

Incidence of serious harms, including accidental overdose, was not reported in studies of iron supplementation (Appendix B1). One fair-quality trial stated that no clinically significant adverse events thought to be related to study interventions were reported.49

No study reported comparative evidence on withdrawals due to adverse events, although one study noted that a child consuming two or more meals of red meat per day discontinued because of dislike of the study-provided meals.53 One good-quality study53 and two fair-quality48,52 studies reported rates of intervention adherence, which we considered a surrogate marker of discontinuation rates in the absence of data on withdrawals due to adverse events. A wide range of nonadherence was reported across the studies (9% to 59% in supplementation groups and 4% to 59% in control groups). Some between-group differences were observed, but the differences appear to be based on the type of supplement/control rather than the iron content. One study found that infants and toddlers given iron-fortified or nonfortified formula had significantly higher rates of nonadherence compared with those consuming regular cow's milk (22% [36/162] vs. 4% [7/166]; RR, 5.3 [95% CI, 2.42 to 11.5] and 23% [38/165] vs. 4% [7/166]; RR, 5.46 [95% CI, 2.52 to 11.88]).52 In a second study, toddlers eating two or more meals of red meat per day were more likely to be nonadherent than children in the control group drinking nonfortified powdered cow's milk (30% [26/87] vs. 11% [9/85]; RR, 2.82 [95% CI, 1.41 to 5.66]). In the same study, there was no significant difference in nonadherence between those using fortified and nonfortified powdered cow's milk (19% [8/43] vs. 11% [9/85]; RR, 1.76 [95% CI, 0.73 to 4.23]).53 There was also no significant difference in nonadherence between groups in a third study comparing multivitamin drops with or without iron supplementation, although nonadherence was higher in both the supplementation and control groups compared with the other two studies (41% vs. 41%; RR, 1.01 [95% CI, 0.83 to 1.22]).48 There was no significant difference between supplementation and control groups in nonadherence in two poor-quality studies.54,55

One good-quality trial reported no difference in rates of gastrointestinal adverse events in toddlers consuming iron-fortified versus nonfortified milk (2% vs. 2%; RR, 1.0 [95% CI, 0.9 to 11]).53 No other studies reported incidence of gastrointestinal adverse events. The prior USPSTF report17,44 included evidence from a meta-analysis of 28 studies (published and unpublished RCTs and cohort studies) that found a slightly increased risk for diarrhea with iron supplementation (RR, 1.1 [95% CI, 1.0 to 1.2]).62 The majority of studies included in this meta-analysis were conducted in developing countries, and the age of the populations ranged from 2 days to 14 years.31

A recently published study provides some contextual evidence on the long-term harms of iron supplementation.63 The study randomized 835 healthy Chilean infants without iron deficiency anemia to supplementation with low-iron formula (mean, 2.3 mg/L) or high-iron formula (mean, 12.7 mg/L, similar to levels in current iron-fortified formulas in the United States). It was not eligible for inclusion for this report because of the lack of a placebo/untreated control group. At 10 years' followup of 473 study participants (57%), those randomized to receive high-iron formula (particularly those with a hemoglobin level >12.8 g/L) scored lower on multiple developmental outcomes, including measures of visual and motor skills and mathematical ability, than those who had received low-iron formula, suggesting that supplementation of iron-replete children may unnecessarily expose children to harm. In most cases, the score differences between the low- and high-iron groups were small and not statistically significant. The generalizability of these study results to current populations in the United States is not clear.

## Screening for Iron Deficiency Anemia in Children

### Key Question 1 What Are the Benefits of Screening for Iron Deficiency Anemia in Asymptomatic Children Ages 6 to 24 Months on Child Health Outcomes?

No studies that evaluated screening programs for iron deficiency anemia in asymptomatic children ages 6 to 24 months were found, as was the case in the prior reviews.17,44

### Key Question 2 What Are the Harms of Screening for Iron Deficiency Anemia in Children Ages 6 to 24 Months?

No studies that evaluated screening programs for iron deficiency anemia or harms of screening in asymptomatic children ages 6 to 24 months were found, as was the case in the prior reviews.17,44

### Key Question 3 What Are the Benefits of Treatment of Iron Deficiency Anemia in Children Ages 6 to 24 Months on Child Health Outcomes?

No new studies of treatment of iron deficiency anemia with oral iron in infants and children ages 6 to 24 months were found.

The 2006 review included seven older trials of iron therapy, five of which used oral formulations.21,22,64-66 These studies were conducted in England (one study), Chile (two studies), Guatemala (one study), and Indonesia (one study). The study most applicable to the U.S. population is the study conducted in England, which was rated poor-quality. It compared treatment for only 1 week with placebo and found no differences in psychomotor development outcomes using the Denver scale but improved hemoglobin and ferritin levels and growth velocity in the treatment group.64 No growth outcomes were reported.

Searches of other systematic reviews of treatment of iron deficiency anemia did not identify additional trials published prior to 1996 that were eligible for the current review.60,67,68 Studies included in these reviews either were included in the prior report,21,22,64-66 used injectable iron formulations,69-71 were conducted in older children,72 or were studies of supplementation of nonanemic children.73

### Key Question 4 What Are the Harms of Iron Treatment in Children Ages 6 to 24 Months?

No newly published studies that reported harms of iron treatment in children ages 6 to 24 months were found.

One older RCT (n=334), published in 1991 and not included in the prior USPSTF review,74 compared oral iron with placebo in children already receiving iron-fortified formula. This study reported no differences between iron- and placebo-treated children in incidence of overall or specific adverse events, including gastrointestinal events. Based on small short-term trials conducted in countries other than the United States, prior USPSTF reports concluded that there was no evidence on the relative harms of treatment.

### Key Question 5 What Is the Association Between Change in Iron Status and Improvement in Child Health Outcomes in U.S.-Relevant Populations?

#### Summary

To answer this question, studies were required to include infants ages 6 to 24 months who were iron deficient (with or without anemia) at baseline and to report growth or neurodevelopmental outcomes for those children whose iron status did and did not improve over time. This design would allow for detection of any association between improvement in iron status and child health outcomes. We did not find any studies meeting these criteria. The only evidence found to indirectly answer this question were studies of iron supplementation in iron-sufficient children. One poor-quality study and two fair-quality studies found no difference between iron-supplemented and nonsupplemented infants in changes in iron status and measures of growth or development scale scores.

#### Evidence

Growth. Searches identified no studies directly meeting eligibility criteria for this Key Question that reported growth outcomes.

The best evidence available is indirect evidence from studies of iron supplementation in children ages 6 to 24 months. Three studies reported iron status and measures of growth at baseline and at followup (Table 4).46,49,54 These studies are also included in Key Question 1.

Table 4 Association Between Change in Iron Status and Health Outcomes

Study, Year Country n Quality | Duration | Intervention Groups | Baseline Iron Status | Follow-Up Iron Status | Mean Change in Iron Status | Health Outcomes
Daly, 1996^46^ United Kingdom n=84 Fair | 18 months | A. Iron-fortified formula (n=41); B. Cow's milk (n=43) | [underlined: A vs. B] Hemoglobin: 119 vs. 120 g/L Serum ferritin: 33.2 vs. 34.6 μg/L | [underlined: A vs. B] Hemoglobin: 124 vs. 118 g/L Serum ferritin: 32.4 vs. 14.9 μg/L | [underlined: A vs. B] Hemoglobin: 5.0 vs. −2.0 g/L (p<0.0001) Serum ferritin: 0.8 vs. −19.7 μg/L (p<0.0001) | [underlined: A vs. B] No difference between groups in weight for age, weight for height, or height for age (data not shown)
Gill, 1997^49^ United Kingdom and Ireland n=406 Fair | 9 months | A. Iron-fortified formula (n=264); B. Unfortified formula (n=85); C. Cow's milk (n=57) | [underlined: A vs. B vs. C] Hemoglobin: 118.9 vs. 116.6 vs. 114.4 μg/L Serum ferritin: 41.6 vs. 42.3 vs. 31.9 μg/L Serum iron: 14.9 vs. 13.9 vs. 12.5 mmol/L Total iron binding capacity: 61.1 vs. 59.0 vs. 64.9 mmol/L | [underlined: A vs. B vs. C] Hemoglobin: 121.5 vs. 117.7 vs. 111.4 μg/L Serum ferritin: 25.1 vs. 15.3 vs. 11.0 μg/L Serum iron: 14.4 vs. 12.9 vs. 10.0 mmol/L Total iron binding capacity: 63.0 vs. 70.3 vs. 73.2 mmol/L | [underlined: A vs. B vs. C] Hemoglobin: 2.6 vs. 1.1 vs. −3.0 μg/L (A vs. B and C; p<0.01) Serum ferritin: −16.5 vs. −27.0 vs. −20.9 μg/L (A vs. B and C, p<0.001) Serum iron: −0.5 vs. −1.0 vs. −2.5 mmol/L (A vs. B and C; p=0.04) Total iron binding capacity: 1.9 vs. 11.3 vs. 8.3 mmol/L (A vs. B and C; p=0.05) | [underlined: A vs. B vs. C] Weight, mean change from baseline: 11.1 (3.2) vs. 11.1 (3.1) vs. 11.3 (3.0) kg (p=NS for all comparisons) Length, mean change from baseline: 79.1 (11.3) vs. 78.9 (11.5) vs. 80.3 (12.2) cm (p=NS for all comparisons)

Abbreviation: NS=not significant.

Note: Poor-quality trial omitted from table (Yalcin, 2000^54^).

Two studies were rated fair-quality and the other poor-quality (Appendix B2). The studies enrolled infants at age 6 months, with duration of followup ranging from 3 to 18 months. The two fair-quality studies compared iron-fortified formula with cow's milk and/or nonfortified formula, while the poor-quality study compared ferrous sulfate with placebo, with only 3 months' followup. While differences in iron status measures were reported in these studies, no differences in growth parameters were found between groups.

The largest study (n=406) randomized 6-month-old infants to iron-fortified formula (n=264), nonfortified formula (n=85), or cow's milk (n=57).49 Baseline serum ferritin levels were 41.6, 42.3, and 31.9 μg/L, respectively, and corresponding hemoglobin levels were 118.9, 116.6, and 114.4 g/L, indicating that the infants enrolled in this study were iron replete at baseline. Although all groups had a significant decrease in ferritin levels in the first 3 months, both hemoglobin and ferritin levels were higher in the supplemented group after 9 months' followup (at age 15 months), particularly compared with the cow's milk group. Comparing the iron-supplemented group and the cow's milk group allows comparison of the largest differences in iron status and the corresponding change in growth. The supplemented group had better iron status measures at followup than the cow's milk group, but weight and length changes were not significantly different between groups (p-value not reported). The supplemented group's hemoglobin level increased by a mean of 2.6 g/L (range, 118.9 to 121.5 g/L) compared with a decrease of 3.0 g/L in the cow's milk group. Mean serum ferritin level decreased by 16.6 μg/L in the supplemented group versus 20.9 μg/L in the cow's milk group. Mean weight change in the supplemented group was 3.2 kg compared with 3.0 kg in the cow's milk group, and mean length change was 11.3 cm in the supplemented group compared with 12.2 cm in the cow's milk group.

The second fair-quality trial was smaller (n=84) and also compared iron-fortified formula with cow's milk.46 At 18 months, mean changes in hemoglobin level were 5 versus −2 g/L and mean changes in serum ferritin level were 0.8 versus −19.7 μg/L in the supplemented and nonsupplemented groups, respectively. The study reported no difference in z-scores for measures of growth (e.g., weight for height, weight for age) but no data or p-values were reported.

The poor-quality study was very small (n=24) and reported differences favoring supplementation between groups in transferrin saturation and serum iron level but not hemoglobin or serum ferritin levels, and no difference between groups in measures of growth.54

Developmental scale scores. Only the small poor-quality study described above reported neurodevelopmental outcomes. As noted above, the study reported differences favoring supplementation between groups in transferrin saturation and serum iron level but not hemoglobin or serum ferritin levels. No difference between groups was found on the Bayley Scale mental or motor scores.54