# Methods

## Key Questions and Analytic Frameworks

Using the methods developed by the USPSTF,43 we collaborated with the USPSTF and the Agency for Healthcare Research and Quality to determine the scope and Key Questions for this review to update the prior reports.17,44 Investigators created analytic frameworks with the Key Questions for the patient populations, interventions, and outcomes reviewed. The target population was asymptomatic children ages 6 to 24 months representative of children in the United States with respect to rates of malnutrition, hemoparasite burden, and general socioeconomic status.

The Key Questions are presented as two separate analytic frameworks: one for routine iron supplementation (Figure 1) and one for screening for iron deficiency anemia (Figure 2).

Figure 1 Analytic Framework for Routine Iron Supplementation in Children

Key Questions
1. What are the benefits of routine iron supplementation in children ages 6 to 24 months on child health outcomes?
2. What are the harms of routine iron supplementation in children ages 6 to 24 months?

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the populations, interventions and related harms, and outcomes. The population includes children ages 6 to 24 months who are asymptomatic for iron deficiency anemia. After routine iron supplementation, and the assessment of any harms of routine supplementation, an arrow leads to the outcomes included in the review. Intermediate outcomes include various measure of iron status. A dotted line leads from the intermediate outcomes to the clinical outcomes examined, which include morbidity (cognitive, psychomotor, and neurodevelopmental outcomes; developmental delay), growth, mortality, and quality of life. In addition, an overarching arrow from routine supplementation to the health outcomes of interest represents the direct effect of supplementation on these health outcomes.

Figure 2 Analytic Framework for Screening for Iron Deficiency Anemia in Children

Key Questions
1. What are the benefits of screening for iron deficiency anemia in asymptomatic children ages 6 to 24 months on child health outcomes?
2. What are the harms of screening for iron deficiency anemia in children ages 6 to 24 months?
3. What are the benefits of treatment of iron deficiency anemia in children ages 6 to 24 months on child health outcomes?
4. What are the harms of iron treatment in children ages 6 to 24 months?
5. What is the association between change in iron deficiency anemia status and improvement in child health outcomes in U.S.-relevant populations?

Contextual Question (not systematically reviewed)
1. How well does risk assessment identify children who are at increased risk for iron deficiency anemia?

This figure depicts the analytic framework ,which outlines the evidence areas covered in the review, including the populations, intervention and related harms, and outcomes. The population includes children ages 6 to 24 months who are asymptomatic for iron deficiency anemia. After screening, and the assessment of any harms of screening, a box represents the diagnosis of iron deficiency anemia. An arrow leading from this box represents treatment, after which the outcomes included in the review are indicated. Intermediate outcomes include various measure of iron status. A dotted line leads from the intermediate outcomes to the health outcomes examined, representing the association between intermediate and health outcomes. Health outcomes include morbidity (cognitive, psychomotor, and neurodevelopmental outcomes; developmental delay), growth, mortality, and quality of life. An arrow from treatment examines the resulting harms of treatment. In addition, an overarching arrow from screening to the health outcomes of interest represents the direct effect of screening on these health outcomes.

### Routine Iron Supplementation in Children

1. What are the benefits of routine iron supplementation in children ages 6 to 24 months on child health outcomes?
2. What are the harms of routine iron supplementation in children ages 6 to 24 months?

### Screening for Iron Deficiency Anemia in Children

1. What are the benefits of screening for iron deficiency anemia in asymptomatic children ages 6 to 24 months on child health outcomes?
2. What are the harms of screening for iron deficiency anemia in children ages 6 to 24 months?
3. What are benefits of treatment of iron deficiency anemia in children ages 6 to 24 months on child health outcomes?
4. What are the harms of iron treatment in children ages 6 to 24 months?
5. What is the association between change in iron status and improvement in child health outcomes in U.S.-relevant populations?

We also addressed a Contextual Question requested by the USPSTF to help inform the report. Contextual Questions address background areas deemed important by the USPSTF for informing its recommendations. Contextual Questions are not reviewed using systematic review methodology but rather summarize the evidence from key informative studies.

### Contextual Question

1. What risk factors are associated with iron deficiency anemia, and how well do risk-assessment tools identify children at increased risk for iron deficiency anemia?

For the screening framework, Key Questions 1 and 2 focus on direct evidence on the effectiveness and harms of screening for iron deficiency anemia in asymptomatic children ages 6 to 24 months compared with not screening. Such direct evidence on the effectiveness of screening interventions may be limited. Therefore, the remainder of the analytic framework (Key Questions 3 through 5) evaluates the chain of indirect evidence needed to link screening with improvement in important health outcomes. Links in the chain of indirect evidence include the accuracy of screening in identifying children with iron deficiency anemia or at risk for iron deficiency anemia, the effectiveness of interventions in reducing the incidence of iron deficiency anemia and associated complications, the association between improvements in intermediate outcomes and clinical health outcomes, and harms associated with preventive treatments. Implicit in the indirect chain of evidence is that, to understand the benefits and harms of screening, it is necessary but not sufficient to show that children at risk for iron deficiency anemia can be identified; it is also necessary to show that there are effective treatments for those identified. Not all of the indirect links are included in this update, as some of the links (e.g., test accuracy) have been considered to be established.

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, and Ovid MEDLINE® (1996 to August 2014) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed the prior USPSTF reports, reference lists of relevant articles, and related systematic reviews. Based on feedback from the USPSTF, and because the 2006 review focused on systematic reviews and key studies of treatment of iron deficiency anemia, we also searched the reference lists of systematic reviews to identify relevant additional studies published prior to 1996.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies published since 1996 to update the prior systematic evidence reviews17,44 on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2). Since the scope of the 1996 and 2006 reviews differed somewhat from the scope of this update, we also included studies published before 1996 that had not been included in either of those reports.

Articles were selected for full review if they were about iron deficiency anemia in children who received intervention between the ages of 6 and 24 months, were relevant to a Key Question, and met the predefined inclusion criteria. We restricted inclusion to English-language articles and excluded studies published only as abstracts. Studies of nonhuman subjects were also excluded, and studies had to report original data. For supplementation Key Questions 1 and 2 and screening Key Questions 1 through 4, we excluded studies conducted in resource-poor populations, including nutritionally-deficient populations in developing countries and populations in areas considered to have high prevalence of hemoparasites. We included studies conducted in countries listed as having “high” or “very high” human development based on the United Nations International Human Development Index as a guide.45 For screening Key Questions 3 and 4, we focused on studies that used iron supplementation and treatment regimens commonly used in clinical practice in the United States. For screening Key Question 5, we included studies conducted in any country but prioritized those conducted in countries with high or very high human development ratings.

Included clinical outcomes were morbidity (including cognitive, psychomotor, and neurodevelopmental outcomes and diagnosis of developmental delay), growth, mortality, and quality of life. Harms outcomes included accidental overdose, study discontinuations, and other harms related to screening, supplementation, or treatment. Included intermediate outcomes were incidence of iron deficiency anemia, iron deficiency, and anemia, as well as hematological indexes (including ferritin levels). We included randomized, controlled trials (RCTs); nonrandomized controlled clinical trials; and controlled cohort studies for supplementation Key Questions 1 and 2 and screening Key Questions 1 through 4, and longitudinal studies for screening Key Question 5. Appendix A3 shows the results of our literature search and selection process and Appendix A4 lists excluded studies pulled at the full-text level with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. When otherwise not reported and where possible, we calculated relative risks (RRs) and 95 percent CIs or p-values. Two investigators independently applied criteria developed by the USPSTF43 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process. Studies deemed poor quality were not synthesized with higher-quality evidence and not reported in evidence tables but are cited in the report for transparency.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, or poor) using methods developed by the USPSTF,43 based on the number, quality, and size of studies; consistency of results between studies; and directness of evidence. Meta-analysis was not attempted because of the limited number of studies for each Key Question and differences among studies in design, population, and outcomes.

## External Review

The draft report was reviewed by content experts (Appendix A6), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners, and revised prior to finalization.