# Evidence and Quality Tables

Appendix B1 Evidence Table of Trials of Routine Iron Supplementation in Children Ages 6 to 24 Months

Appendix B2 Quality Assessment of Trials of Routine Iron Supplementation in Children Ages 6 to 24 Months