# Detailed Methods

## Appendix A1 Search Strategies

### Supplementation: Key Questions 1 and 2

Database: Ovid MEDLINE(R) without Revisions

1 exp Anemia, Iron-Deficiency/
2 “iron deficiency anemia”.mp.
3 (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
5 pc.fs.
6 Dietary Supplements/
7 Iron/
8 6 and 7
9 (iron adj2 supplemen$).mp.
10 Iron, Dietary/ad [Administration & Dosage]
11 or/8-10
12 4 and 5
13 4 and 11
14 12 or 13
15 limit 14 to humans
16 limit 15 to english language
17 limit 15 to abstracts
18 (infan$ or pediatr$ or neonate$ or newborn or child$ or offspring).mp.
19 17 and 18

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 exp Anemia, Iron-Deficiency/
2 “iron deficiency anemia”.mp.
3 (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4 or/1-3
5 pc.fs.
6 Dietary Supplements/
7 Iron/
8 6 and 7
9 (iron adj2 supplemen$).mp.
10 Iron, Dietary
11 or/8-10
12 4 and 5
13 4 and 11
14 12 or 13
15 (infan$ or pediatr$ or neonate$ or newborn or child$ or offspring).mp.
19 14 and 15

### Screening: Key Questions 1 and 2

Database: Ovid MEDLINE(R) without Revisions

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. exp Mass Screening/
6. screen$.mp.
7. 5 or 6
8. 4 and 7
9. limit 8 to “all infant (birth to 23 months)”
10. limit 9 to humans
11. limit 10 to english language
12. limit 10 to abstracts
13. 11 or 12

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. exp Mass Screening/
6. screen$.mp.
7. 5 or 6 (12598)
8. 4 and 7 (25)

### Treatment: Key Questions 3 and 4

Database: Ovid MEDLINE(R) without Revisions

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. Infant Formula/
6. Iron, Dietary/
7. (de or dt or th).fs.
8. 4 and 7
9. 4 and (5 or 6)
10. 8 or 9
11. (infan$ or neonate$ or newborn or child$ or offspring).mp.
12. 10 and 11

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Anemia, Iron-Deficiency/
2. “iron deficiency anemia”.mp.
3. (“ida” or (“iron deficiency” adj2 “anemia”)).mp.
4. or/1-3
5. Infant Formula/
6. Iron, Dietary
7. (de or dt or th).fs.
8. 4 and 7
9. 4 and (5 or 6)
10. 8 or 9
11. (infan$ or neonate$ or newborn or child$ or offspring).mp.
12. 10 and 11

### Association: Key Question 5

Database: Ovid MEDLINE(R) without Revisions

1. Iron/
2. Iron, Dietary/
3. Anemia, Iron-Deficiency/
4. 1 or 2
5. 4 and (anemia or anemic or deficiency or deficient).mp.
6. 3 or 5
7. Treatment Outcome/
8. 6 and 7
9. 6 and association.mp.
10. 8 or 9
11. limit 10 to humans
12. limit 11 to english language

### Systematic Reviews: All Key Questions

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. iron deficiency anemia.mp.
2. (“iron deficiency” adj2 anemia).mp.
3. 1 or 2

### Iron Deficiency Without Anemia: All Key Questions

Database: Ovid MEDLINE(R) without Revisions

1. Iron/df [Deficiency]
2. limit 1 to “all infant (birth to 23 months)”
3. (infan$ or neonate$ or newborn or child$ or offspring).mp
4. 1 and 3
5. 2 or 4
6. limit 5 to humans
7. limit 6 to english language

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Iron/df [Deficiency]
2. limit 1 to “all infant (birth to 23 months)”
3. (infan$ or neonate$ or newborn or child$ or offspring).mp
4. 1 and 3
5. 2 or 4

## Appendix A2 Inclusion and Exclusion Criteria

Routine Iron Supplementation in Children

| Include | Exclude
Populations | Children ages 6 to 24 months | Severely malnourished children who are not representative of those in the United States
Interventions | Oral iron supplementation; iron-fortified formulas and foods | Injectable forms of iron
Comparators | No supplementation
Outcomes | KQ 1: Morbidity (including cognitive, psychomotor, and neurodevelopmental outcomes; developmental delay), growth, mortality, quality of life; incidence of iron deficiency anemia; incidence of iron deficiency; hematological indices and ferritin levels KQ 2: More serious harms; discontinuations; accidental overdose
Settings | Primary care relevant
Timing | KQ 1: Long term KQ 2: Short or long term
Study Designs | KQ 1: Randomized, controlled trials; controlled cohort studies and other controlled observational studies (KQ1) KQ 2: Studies from KQ 1 and large uncontrolled observational studies | KQ 1: Uncontrolled studies

Screening for Iron Deficiency Anemia in Children

| Include | Exclude
Populations | KQs 1, 2: Asymptomatic children ages 6 to 24 months KQs 3, 4: Children ages 6 to 24 months with iron deficiency anemia KQ 5: Children with iron deficiency, with or without anemia | - Severely malnourished children who are not representative of those in the United States; - Children who are symptomatic for iron deficiency anemia; - Children ages <6 or >24 months
Interventions | KQs 1, 2: Screening for iron deficiency anemia KQs 3, 4: Oral iron treatment; iron-fortified formulas and foods | Injectable forms of iron
Comparators | KQs 1, 2: No screening for iron deficiency anemia KQs 3, 4: No treatment KQ 5: Change in iron deficiency and/or iron deficiency anemia status
Outcomes | KQs 1, 3, 5: Morbidity (including growth, cognitive, psychomotor, and neurodevelopmental outcomes; developmental delay), growth, mortality, quality of life KQ 2: Overdiagnosis, anxiety, labeling KQ 3: Incidence of iron deficiency anemia; incidence of iron deficiency; hematological indices and ferritin levels KQ 4: More serious harms; discontinuations and overtreatment
Settings | U.S. primary care relevant
Timing | KQs 1, 3: Long term KQs 2, 4, 5: Short or long term
Study Designs | KQs 1, 3: Randomized, controlled trials; controlled cohort studies and other controlled observational studies KQs 2, 4: Studies included from other KQs and large uncontrolled observational studies KQ 5: Longitudinal studies | KQs 1, 3: Uncontrolled studies KQ 5: Case-control and cross-sectional studies

Abbreviation: KQ=key question.

## Appendix A3 Literature Flow Diagram

a Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

b Other sources include prior reports, reference lists of relevant articles, and systematic reviews

c Some studies are included for more than one key question.

d Including 2 poor-quality studies.

This figure is a literature flow diagram depicting the search and selection of studies for the review. The diagram shows that 2,159 abstracts of potentially relevant articles were identified through the MEDLINE and Cochrane databases, 2,030 articles and background papers were excluded, 129 articles were reviewed at the full-text level, and 118 articles were excluded for the following reasons: 53 due to wrong population, 14 due to wrong intervention, 5 due to wrong outcome, 19 due to wrong study design, 5 due to wrong publication type, 13 due to wrong comparison, 8 were systematic reviews that were not directly used, and 1 due to data being used from another source. 10 unique trials (in 11 publications) were ultimately included in the review. For Key Question 1 on routine iron supplementation, 6 trials were included for growth outcomes, 4 trials were included for developmental test score outcomes, and 10 trials were included for hematological outcomes (including 2 poor-quality studies). For Key Question 2, 2 trials were included on harms of supplementation. For the section of the report on screening for iron deficiency anemia, no studies were includes for any of the Key Questions.

## Appendix A4 Excluded Studies

### Wrong Population

Abdelrazik N, Al-Haggar M, Al-Marsafawy H, et al. Impact of long-term oral iron supplementation in breast-fed infants. Indian J Pediatr. 2007;74(8):739-45. [pmid: 17785896].
Adetifa I, Okomo U. Iron supplementation for reducing morbidity and mortality in children with HIV. Cochrane Database Syst Rev. 2009;(1). CD006736.
Aranda N, Ribot B, Garcia E, et al. Pre-pregnancy iron reserves, iron supplementation during pregnancy, and birth weight. Early Hum Dev. 2011;87(12):791-7. [pmid: 21723050].
Arvas A, Elgormus Y, Gur E, et al. Iron status in breast-fed full-term infants. Turk J Pediatr. 2000;42(1):22-6. [pmid: 10731864].
Berger J, Ninh N, Khan N, et al. Efficacy of combined iron and zinc supplementation on micronutrient status and growth in vietnamese infants. Eur J Clin Nutr. 2006;60(4):443-54. [pmid: 16306925].
Berglund S, Westrup B, Domellof M. Iron supplements reduce the risk of iron deficiency anemia in marginally low birth weight infants. Pediatrics. 2010;126(4):e874-83. [pmid: 20819898].
Black MM, Baqui AH, Zaman K, et al. Iron and zinc supplementation promote motor development and exploratory behavior among Bangladeshi infants. Am J Clin Nutr. 2004;80(4):903-10. [pmid: 15447897].
Capozzi L, Russo R, Bertocco F, et al. Effect on haematological and anthropometric parameters of iron supplementation in the first 2 years of life. Risks and benefits. Hematol. 2011;16(5):261-4.
Casanueva E, Viteri FE, Mares-Galindo M, et al. Weekly iron as a safe alternative to daily supplementation for nonanemic pregnant women. Arch Med Res. 2006;37(5):674-82. [pmid: 16740440].
de Silva A, Atukorala S, Weerasinghe I, et al. Iron supplementation improves iron status and reduces morbidity in children with or without upper respiratory tract infections: a randomized controlled study in Colombo, Sri Lanka. Am J Clin Nutr. 2003;77(1):234-41. [pmid: 12499347].
Dijkhuizen MA, Wieringa FT, West CE, et al. Effects of iron and zinc supplementation in Indonesian infants on micronutrient status and growth. J Nutr. 2001;131(11):2860-5. [pmid: 11694609].
Eickmann SH, Brito CM, Lira PI, et al. Effectiveness of weekly iron supplementation on hemoglobin concentration, nutritional status and development of infants of public daycare centers in Recife, Pernambuco State, Brazil. [Spanish]. Cad Saude Publica. 2008;24(Suppl 2):S303-11. [pmid: 18670710].
Engstrom EM, Castro IR, Portela M, et al. Effectiveness of daily and weekly iron supplementation in the prevention of anemia in infants. Revista de Saude Publica. 2008;42(5):786-95. [pmid: 18709235].
Ermis B, Demirel F, Demircan N, et al. Effects of three different iron supplementations in term healthy infants after 5 months of life. J Trop Pediatr. 2002;48(5):280-4. [pmid: 12405170].
Finkelstein Y, Wahl MS, Bentur Y, et al. Universal versus selective iron supplementation for infants and the risk of unintentional poisoning in young children: a comparative study of two populations. Ann Pharmacother. 2007;41(3):414-9. [pmid: 17341538].
Fischer Walker CL, Baqui AH, Ahmed S, et al. Low-dose weekly supplementation of iron and/or zinc does not affect growth among Bangladeshi infants. Eur J Clin Nutr. 2009;63(1):87-92. [pmid: 17882136].
Franco E, Hertrampf E, Hazbun J, et al. Iron supplementation in Chilean Mapuche infants of the Cautin Province, Chile. [Spanish]. Arch Latinoam Nutr. 1996;46(2):118-21. [pmid: 9239288].
Friel JK, Aziz K, Andrews WL, et al. A double-masked, randomized control trial of iron supplementation in early infancy in healthy term breast-fed infants. J Pediatr. 2003;143(5):582-6. [pmid: 14615726].
Ghorashi Z, Nezami N, Ghalehgolab Behbahan A, et al. Supplemental food may not prevent iron-deficiency anemia in infants. Indian J Pediatr. 2008;75(11):1121-4. [pmid: 18810337].
Gupta SK, Bansal D, Malhi P, et al. Developmental profile in children with iron deficiency anemia and its changes after therapeutic iron supplementation. Indian J Pediatr. 2010;77(4):375-9. [pmid: 20428973].
Halterman JS, Kaczorowski JM, Aligne CA, et al. Iron deficiency and cognitive achievement among school-aged children and adolescents in the United States. Pediatrics. 2001;107(6):1381-6. [pmid: 11389261].
Huang SC, Yang YJ, Cheng CN, et al. The etiology and treatment outcome of iron deficiency and iron deficiency anemia in children. J Pediatr Hematol Oncol. 2010;32(4):282-5. [pmid: 20404750].
Idjradinata P, Watkins WE, Pollitt E. Adverse effect of iron supplementation on weight gain of iron-replete young children. Lancet. 1994;343(8908):1252-4. [pmid: 7910275].
Kapur D, Sharma S, Agarwal KN. Effectiveness of nutrition education, iron supplementation or both on iron status in children. Indian Pediatr. 2003;40(12):1131-44. [pmid: 14722364].
Kordas K, Stoltzfus RJ, Lopez P, et al. Iron and zinc supplementation does not improve parent or teacher ratings of behavior in first grade Mexican children exposed to lead. J Pediatr. 2005;147(5):632-9. [pmid: 16291354].
Lind T, Lonnerdal B, Stenlund H, et al. A community-based randomized controlled trial of iron and zinc supplementation in Indonesian infants: interactions between iron and zinc. Am J Clin Nutr. 2003;77(4):883-90. [pmid: 12663287].
Lind T, Lönnerdal B, Stenlund H, et al. A community-based randomized controlled trial of iron and zinc supplementation in Indonesian infants: effects on growth and development. Am J Clin Nutr. 2004;80(3):729-36. [pmid: 15321815].
Lind T, Seswandhana R, Persson LA, et al. Iron supplementation of iron-replete Indonesian infants is associated with reduced weight-for-age. Acta Paediatrica. 2008;97(6):770-5. [pmid: 18422809].
Lopez de Romana G, Cusirramos S, Lopez de Romana D, et al. Efficacy of multiple micronutrient supplementation for improving anemia, micronutrient status, growth, and morbidity of Peruvian infants. J Nutr. 2005;135(3):646S-52. [pmid: 15735109].
Lozoff B, Brittenham GM, Viteri FE, et al. The effects of short-term oral iron therapy on developmental deficits in iron-deficient anemic infants. J Pediatr. 1982;100(3):351-7. [pmid: 6174719].
Lozoff B, Jimenez E, Hagen J, et al. Poorer behavioral and developmental outcome more than 10 years after treatment for iron deficiency in infancy. Pediatrics. 2000;105(4):E51. [pmid: 10742372].
Lukowski AF, Koss M, Burden MJ, et al. Iron deficiency in infancy and neurocognitive functioning at 19 years: evidence of long-term deficits in executive function and recognition memory. Nutr Neurosci. 2010;13(2):54-70. [pmid: 20406573].
Majumdar I, Paul P, Talib VH, et al. The effect of iron therapy on the growth of iron-replete and iron-deplete children. J Trop Pediatr. 2003;49(2):84-8. [pmid: 12729289].
Nagpal J, Sachdev HP, Singh T, et al. A randomized placebo-controlled trial of iron supplementation in breastfed young infants initiated on complementary feeding: effect on haematological status. J Health Popul Nutr. 2004;22(2):203-11. [pmid: 15473523].
Nogueira Arcanjo FP, Santos PR, Costa Arcanjo CP, et al. Daily and weekly iron supplementations are effective in increasing hemoglobin and reducing anemia in infants. J Trop Pediatr. 2013;59(3):175-9. [pmid: 23243082].
Olney DK, Pollitt E, Kariger PK, et al. Combined iron and folic acid supplementation with or without zinc reduces time to walking unassisted among Zanzibari infants 5- to 11-mo old. J Nutr. 2006;136(9):2427-34. [pmid: 16920865].
Pinsk V, Levy J, Moser A, et al. Efficacy and safety of intravenous iron sucrose therapy in a group of children with iron deficiency anemia. Isr Med Assoc J. 2008;10(5):335-8. [pmid: 18605353].
Pollitt E, Saco-Pollitt C, Jahari A, et al. Effects of an energy and micronutrient supplement on mental development and behavior under natural conditions in undernourished children in Indonesia. Eur J Clin Nutr. 2000;54(Suppl 2):S80-90. [pmid: 10902991].
Rosado JL, López P, Muñoz E, et al. Zinc supplementation reduced morbidity, but neither zinc nor iron supplementation affected growth or body composition of Mexican preschoolers. Am J Clin Nutr. 1997;65(1):13-9. [pmid: 8988907].
Sanad M, Osman M, Gharib A. Obesity modulate serum hepcidin and treatment outcome of iron deficiency anemia in children: a case control study. Ital J Pediatr. 2011;37:34. [pmid: 21771327].
Sankar MJ, Saxena R, Mani K, et al. Early iron supplementation in very low birth weight infants--a randomized controlled trial. Acta Paediatr. 2009;98(6):953-8. [pmid: 19484832].
Sankaranarayanan S, Untoro J, Erhardt J, et al. Daily iron alone but not in combination with multimicronutrients increases plasma ferritin concentrations in Indonesian infants with inflammation. J Nutr. 2004;134(8):1916-22. [pmid: 15284376].
Smuts CM, Lombard CJ, Benadé AJ, et al. Efficacy of a foodlet-based multiple micronutrient supplement for preventing growth faltering, anemia, and micronutrient deficiency of infants: the four country IRIS trial pooled data analysis. J Nutr. 2005;135(3):631S-8. [pmid: 15735107].
Soliman AT, Al Dabbagh MM, Habboub AH, et al. Linear growth in children with iron deficiency anemia before and after treatment. J Trop Pediatr. 2009;55(5):324-7. [pmid: 19261662].
Thorisdottir AV, Gunnarsdottir I, Palsson GI, et al. Iron status and developmental scores in 6-year-olds highlights ongoing need to tackle iron deficiency in infants. Acta Paediatr. 2013;102(9):914-9. [pmid: 23772831].
Tielsch JM, Khatry SK, Stoltzfus RJ, et al. Effect of routine prophylactic supplementation with iron and folic acid on preschool child mortality in southern Nepal: community-based, cluster-randomised, placebo-controlled trial. Lancet. 2006;367(9505):144-52. [pmid: 16413878].
Walter T, De Andraca I, Chadud P, et al. Iron deficiency anemia: adverse effects on infant psychomotor development. Pediatrics. 1989;84(1):7-17. [pmid: 2472596].
Yalcin SS, Tezel B, Yurdakok K, et al. A community-based iron supplementation program, “Iron-Like Turkey,” and the following prevalence of anemia among infants aged 12-23 months. Turk J Pediatr. 2013;55(1):16-28. [pmid: 23692828].
Yurdakok K, Temiz F, Yalcin SS, et al. Efficacy of daily and weekly iron supplementation on iron status in exclusively breast-fed infants. J Pediatr Hematol Oncol. 2004;26(5):284-8. [pmid: 15111779].
Ziegler EE, Nelson SE, Jeter JM. Iron status of breastfed infants is improved equally by medicinal iron and iron-fortified cereal. Am J Clin Nutr. 2009;90(1):76-87. [pmid: 19458014].
Ziegler EE, Nelson SE, Jeter JM. Iron supplementation of breastfed infants from an early age. Am J Clin Nutr. 2009;89(2):525-32. [pmid: 19073791].
Zlotkin S, Antwi KY, Schauer C, et al. Use of microencapsulated iron(II) fumarate sprinkles to prevent recurrence of anaemia in infants and young children at high risk. Bull World Health Organ. 2003;81(2):108-15. [pmid: 12756979].
Zlotkin S, Arthur P, Schauer C, et al. Home-fortification with iron and zinc sprinkles or iron sprinkles alone successfully treats anemia in infants and young children. J Nutr. 2003;133(4):1075-80. [pmid: 12672922].

### Wrong Intervention

Borigato EV, Martinez FE. Iron nutritional status is improved in Brazilian preterm infants fed food cooked in iron pots. J Nutr. 1998;128(5):855-9. [pmid: 9566993].
Chang S, Wang L, Wang Y, et al. Iron-deficiency anemia in infancy and social emotional development in preschool-aged Chinese children. Pediatrics. 2011;127(4):e927-33. [pmid: 21402624].
Christofides A, Schauer C, Sharieff W, et al. Acceptability of micronutrient sprinkles: a new food-based approach for delivering iron to First Nations and Inuit children in northern Canada. Chronic Dis Can. 2005;26(4):114-20. [pmid: 16390629].
Driva A, Kafatos A, Solman M. Iron deficiency and the cognitive and psychomotor development of children: a pilot study with institutionalised children. Early Child Dev Care. 1985;22(1):73-82.
Faber M, Kvalsvig JD, Lombard CJ, et al. Effect of a fortified maize-meal porridge on anemia, micronutrient status, and motor development of infants. Am J Clin Nutr. 2005;82(5):1032-9. [pmid: 16280435].
Geltman PL, Meyers AF, Bauchner H. Daily multivitamins with iron to prevent anemia in infancy: a randomized clinical trial. Clin Pediatr. 2001;40(10):549-54.
Gera T, Sachdev HP, Nestel P. Effect of combining multiple micronutrients with iron supplementation on Hb response in children: systematic review of randomized controlled trials. Public Health Nutr. 2009;12(6):756-73. [pmid: 18671894].
Honig AS, Oski FA. Developmental scores of iron deficient infants and the effects of therapy. Infant Behav Dev. 1978;1:168-76.
Jack SJ, Ou K, Chea M, et al. Effect of micronutrient sprinkles on reducing anemia: a cluster-randomized effectiveness trial. Arch Pediatr Adolesc Med. 2012;166(9):842-50. [pmid: 22801933].
Kimmons G, Moffatt M, Lonstaffe S, et al. Short term effects of intramuscular iron on the behavior of iron-deficient children: a clinical trial. Martins S, editor.
Oski FA, Honig AS. The effects of therapy on the developmental scores of iron-deficient infants. J Pediatr. 1978;92(1):21-5. [pmid: 338872].
Oski FA, Honig AS, Helu B, et al. Effect of iron therapy on behavior performance in nonanemic, iron-deficient infants. Pediatrics. 1983;71(6):877-80. [pmid: 6856400].
Power HM, Heese HD, Beatty DW, et al. Iron fortification of infant milk formula: the effect on iron status and immune function. Ann Trop Paediatr. 1991;11(1):57-66. [pmid: 1714697].
Wang Y, Chen C, Jia M, et al. Effect of complementary food supplements on anemia in infant and young children. [Chinese]. Wei Sheng Yen Chiu. 2004;33(3):334-6. [pmid: 15211807].

### Wrong Outcome

Carroll AE, Biondich PG, Anand V, et al. Targeted screening for pediatric conditions with the CHICA system. J Am Med Inform Assoc. 2011;18(4):485-90. [pmid: 21672910].
Halis H, Bor-Kucukatay M, Akin M, et al. Hemorheological parameters in children with iron-deficiency anemia and the alterations in these parameters in response to iron replacement. Pediatr Hematol Oncol. 2009;26(3):108-18. [pmid: 19382032].
Haschke F, Pietschnig B, Vanura H, et al. Iron intake and iron nutritional status of infants fed iron-fortified beikost with meat. Am J Clin Nutr. 1988;47(1):108-12. [pmid: 3337028].
Lozoff B, Castillo M, Clark KM, et al. Iron supplementation in infancy contributes to more adaptive behavior at 10 years of age. J Nutr. 2014;144(6):838-45. [pmid: 24717366].
Willows N, Dannenbaum D, Vadeboncoeur S. Prevalence of anemia among Quebec Cree infants from 2002 to 2007 compared with 1995 to 2000. Can Fam Physician. 2012;58(2):e101-6. [pmid: 22439171].

### Wrong Study Design

Abbott R. The effects of iron supplementation on cognitive function in infants and children. Bibl Nutr Dieta. 1998;(54):67-75. [pmid: 9597172].
Allen LH. Anemia and iron deficiency: effects on pregnancy outcome. Am J Clin Nutr. 2000;71(5 Suppl):1280S-4. [pmid: 10799402].
Azab SF, Abdelsalam SM, Saleh SH, et al. Iron deficiency anemia as a risk factor for cerebrovascular events in early childhood: a case-control study. Ann Hematol. 2014;93(4):571-6. [pmid: 24141332].
Carter RC, Jacobson JL, Burden MJ, et al. Iron deficiency anemia and cognitive function in infancy. Pediatrics. 2010;126(2):e427-34. [pmid: 20660551].
Corapci F, Calatroni A, Kaciroti N, et al. Longitudinal evaluation of externalizing and internalizing behavior problems following iron deficiency in infancy. J Pediatr Psychol. 2010;35(3):296-305. [pmid: 19736288].
Corapci F, Radan AE, Lozoff B. Iron deficiency in infancy and mother-child interaction at 5 years. J Dev Behav Pediatr. 2006;27(5):371-8. [pmid: 17041272].
Dube K, Schwartz J, Mueller MJ, et al. Iron intake and iron status in breastfed infants during the first year of life. Clin Nutr. 2010;29(6):773-8. [pmid: 20627488].
Hopkins D, Emmett P, Steer C, et al. Infant feeding in the second 6 months of life related to iron status: an observational study. Arch Dis Child. 2007;92(10):850-4. [pmid: 17537759].
Lozoff B, Brittenham GM, Wolf AW, et al. Iron deficiency anemia and iron therapy effects on infant developmental test performance. Pediatrics. 1987;79(6):981-95. [pmid: 2438638].
Mabry-Hernandez IR. Screening for iron deficiency anemia--including iron supplementation for children and pregnant women. Am Fam Physician. 2009;79(10):897-8. [pmid: 19496390].
Madan N, Rusia U, Sikka M, et al. Developmental and neurophysiologic deficits in iron deficiency in children. Indian J Pediatr. 2011;78(1):58-64. [pmid: 20953851].
Magge H, Sprinz P, Adams WG, et al. Zinc protoporphyrin and iron deficiency screening: trends and therapeutic response in an urban pediatric center. JAMA Pediatr. 2013;167(4):361-7. [pmid: 23420187].
Morais MB, Sigulem DM. Cow's milk, infant formula and iron-deficiency anemia. J Pediatr. 2006;82(2):161-2. author reply 2-3.
Peirano PD, Algarin CR, Garrido MI, et al. Iron deficiency anemia in infancy is associated with altered temporal organization of sleep states in childhood. Pediatr Res. 2007;62(6):715-9. [pmid: 17957147].
Shafir T, Angulo-Barroso R, Jing Y, et al. Iron deficiency and infant motor development. Early Hum Dev. 2008;84(7):479-85. [pmid: 18272298].
Walter T, Kovalskys J, Stekel A. Effect of mild iron deficiency on infant mental development scores. J Pediatr. 1983;102(4):519-22. [pmid: 6834185].
Watson H, Eisenhut M. Increased risk of pyrexial illness with higher doses of iron supplementation. J Pediatr. 2009;85(1):89. author reply 90.
White KC. Anemia is a poor predictor of iron deficiency among toddlers in the United States: for heme the bell tolls. Pediatrics. 2005;115(2):315-20. [pmid: 15687438].
Wu AC, Lesperance L, Bernstein H. Screening for iron deficiency. Pediatr Rev. 2002;23(5):171-8. [pmid: 11986493].

### Wrong Publication Type

Brown D. Link between iron and youth cognitive skills?. J Am Diet Assoc. 2001;101(11):1308-9. [pmid: 11716307].
Friel JK. Iron supplements do not always reduce erythrocyte copper-zinc superoxide dismutase activity in term, breastfed infants. Acta Paediatr. 2006;95(8):1019-20. author reply 20. [pmid: 16882584].
Gokcay G. Strategies for the prevention of iron deficiency anaemia in children. J Trop Pediatr. 2006;52(2):75-7. [pmid: 16582404].
Grantham-McGregor S, Ani C. A review of studies on the effect of iron deficiency on cognitive development in children. J Nutr. 2001;131(Suppl 2):649S-66. discussion 66S-8. [pmid: 11160596].
Kalhoff H, Dube K, Kersting M. Iron deficiency in infants fully breastfed for 6 months may not be transitory: first observations during the second half of infancy. Public Health Nutr. 2010;13(12):2130-1. discussion 1-2. [pmid: 20843398].

### Wrong Comparison

Bilenko N, Belmaker I, Vardi H, et al. Efficacy of multiple micronutrient supplementations on child health: study design and baseline characteristics. Isr Med Assoc J. 2010;12(6):342-7. [pmid: 20928987].
Geltman PL, Hironaka LK, Mehta SD, et al. Iron supplementation of low-income infants: a randomized clinical trial of adherence with ferrous fumarate sprinkles versus ferrous sulfate drops. J Pediatr. 2009;154(5):738-43. [pmid: 19111318].
Gondolf UH, Tetens I, Michaelsen KF, et al. Iron supplementation is positively associated with increased serum ferritin levels in 9-month-old Danish infants. Br J Nutr. 2013;109(1):103-10. [pmid: 22443990].
Ip H, Hyder SM, Haseen F, et al. Improved adherence and anaemia cure rates with flexible administration of micronutrient sprinkles: a new public health approach to anaemia control. Eur J Clin Nutr. 2009;63(2):165-72. [pmid: 17895911].
Jaber L, Rigler S, Taya A, et al. Iron polymaltose versus ferrous gluconate in the prevention of iron deficiency anemia of infancy. J Pediatr Hematol Oncol. 2010;32(8):585-8. [pmid: 20930652].
Lozoff B, Clark KM, Jing Y, et al. Dose-response relationships between iron deficiency with or without anemia and infant social-emotional behavior. J Pediatr. 2008;152(5):696-702. [pmid: 18410777].
Lozoff B, Smith JB, Clark KM, et al. Home intervention improves cognitive and social-emotional scores in iron-deficient anemic infants. Pediatrics. 2010;126(4):e884-94. [pmid: 20855384].
Parodi E, Giraudo MT, Davitto M, et al. Reticulocyte parameters: markers of early response to oral treatment in children with severe iron-deficiency anemia. J Pediatr Hematol Oncol. 2012;34(6):e249-52. [pmid: 22810756].
Rosado JL, Gonzalez KE, Caamano MD, et al. Efficacy of different strategies to treat anemia in children: a randomized clinical trial. Nutr J. 2010;9:40. [pmid: 20863398].
Steinmacher J, Pohlandt F, Bode H, et al. Randomized trial of early versus late enteral iron supplementation in infants with a birth weight of less than 1301 grams: neurocognitive development at 5.3 years' corrected age. Pediatrics. 2007;120(3):538-46. [pmid: 17766527].
Takala TI, Makela E, Suominen P, et al. Blood cell and iron status analytes of preterm and full-term infants from 20 weeks onwards during the first year of life. Clin Chem Lab Med. 2010;48(9):1295-301. [pmid: 20482297].
Walter T, Pino P, Pizarro F, et al. Prevention of iron-deficiency anemia: comparison of high- and low-iron formulas in term healthy infants after six months of life. J Pediatr. 1998;132(4):635-40. [pmid: 9580762].
Wright CM, Kelly J, Trail A, et al. The diagnosis of borderline iron deficiency: results of a therapeutic trial. Arch Dis Child. 2004;89(11):1028-31. [pmid: 15499056].

### Systematic Review, Not Directly Used

Gera T, Sachdev HP, Nestel P, et al. Effect of iron supplementation on haemoglobin response in children: systematic review of randomised controlled trials. J Pediatr Gastroenterol Nutr. 2007;44(4):468-86. [pmid: 17414146].
Hermoso M, Vucic V, Vollhardt C, et al. The effect of iron on cognitive development and function in infants, children and adolescents: a systematic review. Ann Nutr Metab. 2011;59(2-4):154-65. [pmid: 22142898].
Iannotti LL, Tielsch JM, Black MM, et al. Iron supplementation in early childhood: health benefits and risks. Am J Clin Nutr. 2006;84(6):1261-76. [pmid: 17158406].
Long H, Yi JM, Hu PL, et al. Benefits of iron supplementation for low birth weight infants: a systematic review. BMC Pediatr. 2012;12:99. [pmid: 22794149].
Martins S, Logan S, Gilbert RE. Iron therapy for improving psychomotor development and cognitive function in children under the age of three with iron deficiency anaemia. Cochrane Database Syst Rev. 2001;(2). CD001444.
Mills RJ, Davies MW. Enteral iron supplementation in preterm and low birth weight infants. Cochrane Database Syst Rev. 2012;(3). CD005095.
Sachdev H, Gera T, Nestel P. Effect of iron supplementation on physical growth in children: systematic review of randomised controlled trials. Public Health Nutr. 2006;9(7):904-20. [pmid: 17010257].
Szajewska H, Ruszczynski M, Chmielewska A. Effects of iron supplementation in nonanemic pregnant women, infants, and young children on the mental performance and psychomotor development of children: a systematic review of randomized controlled trials. Am J Clin Nutr. 2010;91(6):1684-90. [pmid: 20410098].

### Used Data from Another Source

Dewey KG, Domellof M, Cohen RJ, et al. Iron supplementation affects growth and morbidity of breast-fed infants: results of a randomized trial in Sweden and Honduras. J Nutr. 2002;132(11):3249-55. [pmid: 12421836].

## Appendix A5 USPSTF Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The USPSTF Methods Workgroup developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria that relate to internal validity, and the associated definitions of quality categories, at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### RCTs and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs

#### Definition of ratings based on above criteria

Good: Meets all criteria; comparable groups are assembled initially and maintained throughout the study (follow-up ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate ≥80%; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables

Fair: Recent, relevant, without major apparent selection or diagnostic workup bias but with response rate <80 %or attention to some but not all important confounding variables

Poor: Major selection or diagnostic workup biases, response rates <50%, or inattention to confounding variables

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance are especially important

#### Definition of ratings from above criteria

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Source: U.S. Preventive Services Task Force Procedure Manual. Available at: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual

## Appendix A6 Reviewers of the Draft Report

- Jane Brotanek, MD, MPH
  Pediatrician, Ridgefield Pediatrics
  Ridgefield, CT
- Rafael Flores-Ayala, DrPH, MAPST
  International Micronutrient Malnutrition Prevention and Control Program, Division of Nutrition, Physical Activity and Obesity, Centers for Disease Control and Prevention
  Atlanta, GA
- Michael Georgieff, MD
  Professor of Pediatrics and Child Psychology, University of Minnesota School of Medicine
  Minneapolis, MN
- Lauren Marcewicz, MD
  Medical Epidemiologist, Division of Blood Disorders, National Center for Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention
  Atlanta, GA
- Kimberly O'Brien, PhD
  Professor, Division of Nutritional Sciences, Cornell University
  Ithaca, NY
- Matthew Short, MD, FAAFP
  Family Medicine, Madigan Army Medical Center
  Tacoma, WA