# References

1 National Heart Lung, and Blood Institute. The Seventh Report on the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. NIH Publication No. 04-5230. Bethesda, MD. National Institutes of Health, U.S. Department of Health and Human Services. 2004. Accessed at http://www.nhlbi.nih.gov/health-pro/guidelines/current/hypertension-jnc-7/complete-report. 9 December 2014.
2 National Institute for Health and Care Excellence. Hypertension: Clinical Management of Primary Hypertension in Adults. Clinical Guideline 127. London. National Institute for Health and Care Excellence. 2011. Accessed at http://www.nice.org.uk/guidance/cg127. 9 December 2014.
3 Beevers G, Lip GY, O’Brien E. Blood pressure measurement, part I—sphygmomanometry: factors common to all techniques. BMJ. 2001;322(7292):981-5. [pmid: 11312235].
4 Pickering TG, Miller NH, Ogedegbe G, et al. Call to action on use and reimbursement for home blood pressure monitoring: a joint scientific statement from the American Heart Association, American Society of Hypertension, and Preventive Cardiovascular Nurses Association. Hypertension. 2008;52(1):10-29. [pmid: 18497370].
5 Ogedegbe G, Pickering T. Principles and techniques of blood pressure measurement. Cardiol Clin. 2010;28(4):571-86. [pmid: 20937442].
6 Lewington S, Clarke R, Qizilbash N, et al. Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903-13. [pmid: 12493255].
7 Weber MA, Townsend RR. Building the case for central blood pressure. J Am Coll Cardiol. 2013;62(19):1788-90. [pmid: 23850920].
8 James PA, Oparil S, Carter BL, et al. 2014 evidence-based guideline for the management of high blood pressure in adults: report from the panel members appointed to the Eighth Joint National Committee (JNC 8). JAMA. 2014;311(5):507-20. [pmid: 24352797].
9 Carretero OA, Oparil S. Essential hypertension, part I: definition and etiology. Circulation. 2000;101(3):329-35. [pmid: 10645931].
10 Intersalt Cooperative Research Group. Intersalt: an international study of electrolyte excretion and blood pressure. Results for 24 hour urinary sodium and potassium excretion. BMJ. 1988;297(6644):319-28. [pmid: 3416162].
11 Aronow WS, Fleg JL, Pepine CJ, et al. ACCF/AHA 2011 expert consensus document on hypertension in the elderly: a report of the American College of Cardiology Foundation Task Force on Clinical Expert Consensus Documents developed in collaboration with the American Academy of Neurology, American Geriatrics Society, American Society for Preventive Cardiology, American Society of Hypertension, American Society of Nephrology, Association of Black Cardiologists, and European Society of Hypertension. J Am Coll Cardiol. 2011;57(20):2037-114. [pmid: 21524875].
12 Centers for Disease Control and Prevention. High Blood Pressure Risk Factors. Atlanta. Centers for Disease Control and Prevention. 2010. Accessed at http://www.cdc.gov/bloodpressure/risk_factors.htm. 9 December 2014.
13 Viera AJ, Neutze DM. Diagnosis of secondary hypertension: an age-based approach. Am Fam Physician. 2010;82(12):1471-8. [pmid: 21166367].
14 Vasan RS, Beiser A, Seshadri S, et al. Residual lifetime risk for developing hypertension in middle-aged women and men: the Framingham Heart Study. JAMA. 2002;287(8):1003-10. [pmid: 11866648].
15 Korhonen PE, Kautiainen H, Järvenpää S, et al. Target organ damage and cardiovascular risk factors among subjects with previously undiagnosed hypertension. Eur J Prev Cardiol. 2013;21(8):980-8. [pmid: 23335655].
16 Nadar SK, Tayebjee MH, Messerli F, et al. Target organ damage in hypertension: pathophysiology and implications for drug therapy. Curr Pharm Des. 2006;12(13):1581-92. [pmid: 16729871].
17 Vasan RS, Massaro JM, Wilson PW, et al. Antecedent blood pressure and risk of cardiovascular disease: the Framingham Heart Study. Circulation. 2002;105(1):48-53. [pmid: 11772875].
18 Taylor BC, Wilt TJ, Welch HG. Impact of diastolic and systolic blood pressure on mortality: implications for the definition of “normal”. J Gen Intern Med. 2011;26(7):685-90. [pmid: 21404131].
19 Go AS, Mozaffarian D, Roger VL, et al. Heart disease and stroke statistics—2014 update: a report from the American Heart Association. Circulation. 2014;129(3):e28-292. [pmid: 24352519].
20 Yoon SS, Burt V, Louis T, et al. Hypertension among adults in the United States, 2009-2010. NCHS Data Brief. 2012;(107):1-8. [pmid: 23102115].
21 National Ambulatory Medical Care Survey: 2010 Summary Tables. Atlanta. Centers for Disease Control and Prevention. 2013. Accessed at http://www.cdc.gov/nchs/data/ahcd/namcs_summary/2010_namcs_web_tables.pdf. 9 December 2014.
22 Davis KE. Expenditures for Hypertension Among Adults Age 18 and Older, 2009: Estimates for the U.S. Civilian Non-institutionalized Population. Statistical Brief No. 404. Rockville, MD. Agency for Healthcare Research and Quality. 2013. Accessed at http://meps.ahrq.gov/data_files/publications/st404/stat404.shtml. 9 December 2014.
23 Yang Q, Cogswell ME, Flanders WD, et al. Trends in cardiovascular health metrics and associations with all-cause and CVD mortality among US adults. JAMA. 2012;307(12):1273-83. [pmid: 22427615].
24 Institute of Medicine. A Population-Based Policy and Systems Change Approach to Prevent and Control Hypertension. Washington, DC. National Academies Press. 2010. Accessed at http://www.iom.edu/Reports/2010/A-Population-Based-Policy-and-Systems-Change-Approach-to-Prevent-and-Control-Hypertension.aspx. 9 December 2014.
25 Lin JS, O’Connor E, Whitlock EP, et al. Behavioral counseling to promote physical activity and a healthful diet to prevent cardiovascular disease in adults: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(11):736-50. [pmid: 21135297].
26 Cook NR, Cutler JA, Obarzanek E, et al. Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the Trials of Hypertension Prevention (TOHP). BMJ. 2007;334(7599):885-8. [pmid: 17449506].
27 Sacks FM, Svetkey LP, Vollmer WM, et al., DASH-Sodium Collaborative Research Group. Effects on blood pressure of reduced dietary sodium and the Dietary Approaches to Stop Hypertension (DASH) diet. N Engl J Med. 2001;344(1):3-10. [pmid: 11136953].
28 Musini VM, Tejani AM, Bassett K, et al. Pharmacotherapy for hypertension in the elderly. Cochrane Database Syst Rev. 2009;(4):CD000028. [pmid: 19821263].
29 Turnbull F. Effects of different blood-pressure-lowering regimens on major cardiovascular events: results of prospectively-designed overviews of randomised trials. Lancet. 2003;362(9395):1527-35. [pmid: 14615107].
30 Verdecchia P. Prognostic value of ambulatory blood pressure: current evidence and clinical implications. Hypertension. 2000;35(3):844-51. [pmid: 10720605].
31 Gupta B. Invasive blood pressure monitoring. Update in Anaesthesia. 2007;23:36-42.
32 Jones DW, Appel LJ, Sheps SG, et al. Measuring blood pressure accurately: new and persistent challenges. JAMA. 2003;289(8):1027-30. [pmid: 12597757].
33 Pickering TG, Hall JE, Appel LJ, et al. Recommendations for blood pressure measurement in humans and experimental animals. Part 1: blood pressure measurement in humans. A statement for professionals from the Subcommittee of Professional and Public Education of the American Heart Association Council on High Blood Pressure Research. Circulation. 2005;111(5):697-716. [pmid: 15699287].
34 Reeves RA. Does this patient have hypertension? How to measure blood pressure. JAMA. 1995;273(15):1211-8. [pmid: 7707630].
35 Myers MG, Godwin M, Dawes M, et al. Measurement of blood pressure in the office: recognizing the problem and proposing the solution. Hypertension. 2010;55(2):195-200. [pmid: 20038756].
36 Ernst ME, Bergus GR. Favorable patient acceptance of ambulatory blood pressure monitoring in a primary care setting in the United States: a cross-sectional survey. BMC Fam Pract. 2003;4:15. [pmid: 14533981].
37 Uhlig K, Balk EM, Patel K, et al. Self-Measure Blood Pressure Monitoring: Comparative Effectiveness. AHRQ Publication No. 12-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012. [pmid: 22439158].
38 Vollmer WM, Appel LJ, Svetkey LP, et al. Comparing office-based and ambulatory blood pressure monitoring in clinical trials. J Hum Hypertens. 2005;19(1):77-82. [pmid: 15361888].
39 Powers BJ, Olsen MK, Smith VA, et al. Measuring blood pressure for decision making and quality reporting: where and how many measures?. Ann Intern Med. 2011;154(12):781-8. [pmid: 21690592].
40 Rosner B, Polk BF. Predictive values of routine blood pressure measurements in screening for hypertension. Am J Epidemiol. 1983;117(4):429-42. [pmid: 6837557].
41 Villegas I, Arias IC, Botero A, et al. Evaluation of the technique used by health-care workers for taking blood pressure. Hypertension. 1995;26(6 Pt 2):1204-6. [pmid: 7498997].
42 Stenehjem AE, Os I. Incidence of hypertension by alcohol consumption: is it modified by race?. Blood Press. 2004;13(4):214-24. [pmid: 15581335].
43 Parati G, Omboni S, Staessen J, et al. Limitations of the difference between clinic and daytime blood pressure as a surrogate measure of the “white-coat” effect. J Hypertens. 1998;16(1):23-9. [pmid: 9533413].
44 Ben-Dov IZ, Ben-Arie L, Mekler J, et al. Reproducibility of white-coat and masked hypertension in ambulatory BP monitoring. Int J Cardiol. 2007;117(3):355-9. [pmid: 16879886].
45 Muxfeldt ES, Fiszman R, de Souza F, et al. Appropriate time interval to repeat ambulatory blood pressure monitoring in patients with white-coat resistant hypertension. Hypertension. 2012;59(2):384-9. [pmid: 22215711].
46 O’Brien E, Sheridan J, O’Malley K. Dippers and non-dippers. Lancet. 1988;2(8607):397. [pmid: 2899801].
47 Hansen TW, Li Y, Boggia J, et al. Predictive role of the nighttime blood pressure. Hypertension. 2011;57(1):3-10. [pmid: 21079049].
48 Hinderliter AL, Routledge FS, Blumenthal JA, et al. Reproducibility of blood pressure dipping: relation to day-to-day variability in sleep quality. J Am Soc Hypertens. 2013;7(6):432-9. [pmid: 23850195].
49 Parati G, Staessen JA. Day-night blood pressure variations: mechanisms, reproducibility and clinical relevance. J Hypertens. 2007;25(12):2377-80. [pmid: 17984656].
50 Stergiou GS, Asayama K, Thijs L, et al. Prognosis of white-coat and masked hypertension: international database of home blood pressure in relation to cardiovascular outcome. Hypertension. 2014;63:675-82. [pmid: 24420553].
51 Pierdomenico SD, Cuccurullo F. Prognostic value of white-coat and masked hypertension diagnosed by ambulatory monitoring in initially untreated subjects: an updated meta analysis. Am J Hypertens. 2011;24(1):52-8. [pmid: 20847724].
52 Pierdomenico SD, Cuccurullo F. Ambulatory blood pressure monitoring in type 2 diabetes and metabolic syndrome: a review. Blood Press Monit. 2010;15(1):1-7. [pmid: 20071977].
53 ANSI/AAMI/IEC. Medical Electrical Equipment—Part 2-30: Particular Requirements for the Basic Safety and Essential Performance of Automated Noninvasive Sphygmomanometers. Arlington, VA. Association for the Advancement of Medical Instrumentation. 2014.
54 ANSI/AAMI/IEC. Non-Invasive Sphygmomanometers, Part 1: Requirements and Test Methods for Non-Automated Measurement Type. Arlington, VA. Association for the Advancement of Medical Instrumentation. 2014.
55 ANSI/AAMI/IEC. Non-Invasive Sphygmomanomters, Part 2: Clinical Validation of Automated Measurement Type. Arlington, VA. Association for the Advancement of Medical Instrumentation. 2014.
56 Association for the Advancement of Medical Instrumentation. Manual, Electronic, or Automated Sphygmomanometers. Arlington, VA. Association for the Advancement of Medical Instrumentation. 2012.
57 White JR, Schick J. Home blood pressure monitoring and diabetes. Clin Diabetes. 2004;22:28-31.
58 O’Brien E, Petrie J, Littler W, et al. The British Hypertension Society protocol for the evaluation of blood pressure measuring devices. J Hypertens. 1993;11(Suppl 2):S43-62.
59 O’Brien E, Atkins N, Stergiou G, et al. European Society of Hypertension international protocol revision 2010 for the validation of blood pressure measuring devices in adults. Blood Press Monit. 2010;15(1):23-38. [pmid: 20110786].
60 Association for the Advancement of Medical Instrumentation. Manual, Electronic, or Automated Sphygmomanometers. AAMI/CDV-1 SP 10. Arlington, VA. Association for the Advancement of Medical Instrumentation. 2002.
61 Mion D, Pierin AM. How accurate are sphygmomanometers?. J Hum Hypertens. 1998;12(4):245-8. [pmid: 9607693].
62 Skirton H, Chamberlain W, Lawson C, et al. A systematic review of variability and reliability of manual and automated blood pressure readings. J Clin Nurs. 2011;20(5-6):602-14. [pmid: 21320189].
63 Turner MJ, Speechly C, Bignell N. Sphygmomanometer calibration—why, how and how often?. Aust Fam Physician. 2007;36(10):834-8. [pmid: 17925905].
64 Pickering TG, Hall JE, Appel LJ, et al. Recommendations for blood pressure measurement in humans: an AHA scientific statement from the Council on High Blood Pressure Research Professional and Public Education Subcommittee. J Clin Hypertens (Greenwich). 2005;7(2):102-9. [pmid: 15722655].
65 Graves JW, Sheps SG. Does evidence-based medicine suggest that physicians should not be measuring blood pressure in the hypertensive patient?. Am J Hypertens. 2004;17(4):354-60. [pmid: 15062890].
66 Scherwitz LW, Evans LA, Hennrikus DJ, et al. Procedures and discrepancies of blood pressure measurements in two community health centers. Med Care. 1982;20(7):727-38. [pmid: 7121092].
67 Burgess SE, MacLaughlin EJ, Smith PA, et al. Blood pressure rising: differences between current clinical and recommended measurement techniques. J Am Soc Hypertens. 2011;5(6):484-8. [pmid: 22015319].
68 Minor DS, Butler KR Jr, Artman KL, et al. Evaluation of blood pressure measurement and agreement in an academic health sciences center. J Clin Hypertens (Greenwich). 2012;14(4):222-7. [pmid: 22458743].
69 Kay LE. Accuracy of blood pressure measurement in the family practice center. J Am Board Fam Pract. 1998;11(4):252-8. [pmid: 9719346].
70 Hodgkinson J, Wood S, Martin U, et al. ABPM is best for diagnosing hypertension in primary care. Practitioner. 2011;255(1744):21-3. [pmid: 23251987].
71 Weber MA, Schiffrin EL, White WB, et al. Clinical practice guidelines for the management of hypertension in the community: a statement by the American Society of Hypertension and the International Society of Hypertension. J Hypertens. 2014;32(1):3-15. [pmid: 24270181].
72 Canadian Hypertension Education Program. 2013 Recommendations. Markham, Ontario. Canadian Hypertension Education Program. 2013. Accessed at https://www.hypertension.ca/images/CHEP_2013/2013_CompleteCHEPRecommendations_EN_HCP1009-1.pdf. 10 December 2014.
73 Parati G, Stergiou GS, Asmar R, et al. European Society of Hypertension guidelines for blood pressure monitoring at home: a summary report of the Second International Consensus Conference on Home Blood Pressure Monitoring. J Hypertens. 2008;26(8):1505-26. [pmid: 18622223].
74 Ogihara T, Kikuchi K, Matsuoka H, et al. The Japanese Society of Hypertension guidelines for the management of hypertension (JSH 2009). Hypertens Res. 2009;32(1):3-107. [pmid: 19300436].
75 Michigan Quality Improvement Consortium. Adult Preventive Services (Ages 18-49). Southfield, MI. Michigan Quality Improvement Consortium. 2012.
76 Michigan Quality Improvement Consortium. Adult Preventive Services (Ages 50-65+). Southfield, MI. Michigan Quality Improvement Consortium. 2012.
77 Institute for Clinical Systems Improvement. Preventive Services for Adults. Bloomington, MN. Institute for Clinical Systems Improvement. 2011.
78 Takahashi O, Glasziou PP, Perera R, et al. Blood pressure re-screening for healthy adults: what is the best measure and interval?. J Hum Hypertens. 2012;26(9):540-6. [pmid: 21814284].
79 Wolff T, Miller T. Evidence for the reaffirmation of the U.S. Preventive Services Task Force recommendation on screening for high blood pressure. Ann Intern Med. 2007;147(11):787-91. [pmid: 18056663].
80 Wolff T, Miller T. Evidence for the Reaffirmation of the U.S. Preventive Services Task Force Recommendation on Screening for High Blood Pressure. AHRQ Publication No. 08-05105-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2007. [pmid: 20722151].
81 Verberk WJ, Kroon AA, Kessels AG, et al. Home blood pressure measurement: a systematic review. J Am Coll Cardiol. 2005;46(5):743-51. [pmid: 16139119].
82 Wallace BC, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium. 2012:819-24.
83 Uen S, Fimmers R, Brieger M, et al. Reproducibility of wrist home blood pressure measurement with position sensor and automatic data storage. BMC Cardiovasc Disord. 2009;9:20. [pmid: 19473485].
84 British Hypertension Society. BP Monitors. Leicester, England. British Hypertension Society. 2012. Accessed at http://www.bhsoc.org/bp-monitors/bp-monitors/. 10 December 2014.
85 Scolaro KL, Stamm PL, Lloyd KB. Devices for ambulatory and home monitoring of blood pressure, lipids, coagulation, and weight management, part 1. Am J Health Syst Pharm. 2005;62(17):1802-12. [pmid: 16120741].
86 Human Development Report 2013. The Rise of the South: Human Progress in a Diverse World. New York. United Nations Development Programme. 2013. Accessed at http://hdr.undp.org/en/2013-report. 10 December 2014.
87 Boggia J, Li Y, Thijs L, et al. Prognostic accuracy of day versus night ambulatory blood pressure: a cohort study. Lancet. 2007;370(9594):1219-29. [pmid: 17920917].
88 Boggia J, Thijs L, Hansen TW, et al. Ambulatory blood pressure monitoring in 9357 subjects from 11 populations highlights missed opportunities for cardiovascular prevention in women. Hypertension. 2011;57(3):397-405. [pmid: 21263119].
89 Hansen TW, Kikuya M, Thijs L, et al. Prognostic superiority of daytime ambulatory over conventional blood pressure in four populations: a meta-analysis of 7,030 individuals. J Hypertens. 2007;25(8):1554-64. [pmid: 17620947].
90 Kikuya M, Hansen TW, Thijs L, et al. Diagnostic thresholds for ambulatory blood pressure monitoring based on 10-year cardiovascular risk. Circulation. 2007;115(16):2145-52. [pmid: 17420350].
91 Fan HQ, Li Y, Thijs L, et al. Prognostic value of isolated nocturnal hypertension on ambulatory measurement in 8711 individuals from 10 populations. J Hypertens. 2010;28(10):2036-45. [pmid: 20520575].
92 Thijs L, Hansen TW, Kikuya M, et al. The International Database of Ambulatory Blood Pressure in Relation to Cardiovascular Outcome (IDACO): protocol and research perspectives. Blood Press Monit. 2007;12(4):255-62. [pmid: 17760218].
93 Niiranen TJ, Asayama K, Thijs L, et al. Outcome-driven thresholds for home blood pressure measurement: International Database of Home Blood Pressure in Relation to Cardiovascular Outcome. Hypertension. 2013;61(1):27-34. [pmid: 23129700].
94 Niiranen TJ, Thijs L, Asayama K, et al. The International Database of Home Blood Pressure in Relation to Cardiovascular Outcome (IDHOCO): moving from baseline characteristics to research perspectives. Hypertens Res. 2012;35(11):1072-9. [pmid: 22763485].
95 Fagard RH, Thijs L, Staessen JA, et al. Prognostic significance of ambulatory blood pressure in hypertensive patients with history of cardiovascular disease. Blood Press Monit. 2008;13(6):325-32. [pmid: 18756173].
96 Fagard RH, Celis H, Thijs L, et al. Daytime and nighttime blood pressure as predictors of death and cause-specific cardiovascular events in hypertension. Hypertension. 2008;51(1):55-61. [pmid: 18039980].
97 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
98 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
99 Hayden JA, van der Windt DA, Cartwright JL, et al. Assessing bias in studies of prognostic factors. Ann Intern Med. 2013;158(4):280-6. [pmid: 23420236].
100 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analysis. Ottawa, Ontario. Ottawa Hospital Research Institute. 2014. Accessed at http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. 10 December 2014.
101 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
102 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996;15(6):619-29. [pmid: 8731004].
103 Rohatgi A. WebPlotDigitizer. Version 3.4. 2014. Accessed at http://arohatgi.info/WebPlotDigitizer/. 10 December 2014.
104 Kaczorowski J, Chambers LW, Dolovich L, et al. Improving cardiovascular health at population level: 39 community cluster randomised trial of Cardiovascular Health Awareness Program (CHAP). BMJ. 2011;342:d442. [pmid: 21300712].
105 Ostchega Y, Nwankwo T, Sorlie PD, et al. Assessing the validity of the Omron HEM-907XL oscillometric blood pressure measurement device in a national survey environment. J Clin Hypertens (Greenwich). 2010;12(1):22-8. [pmid: 20047626].
106 Handler J, Zhao Y, Egan BM. Impact of the number of blood pressure measurements on blood pressure classification in US adults: NHANES 1999-2008. J Clin Hypertens (Greenwich). 2012;14(11):751-9. [pmid: 23126346].
107 Kroke A, Fleischhauer W, Mieke S, et al. Blood pressure measurement in epidemiological studies: a comparative analysis of two methods. Data from the EPIC-Potsdam Study. J Hypertens. 1998;16(6):739-46. [pmid: 9663913].
108 Lim YH, Choi SY, Oh KW, et al. Comparison between an automated device and a manual mercury sphygmomanometer in an epidemiological survey of hypertension prevalence. Am J Hypertens. 2014;27(4):537-45. [pmid: 23764377].
109 Pavlik VN, Hyman DJ, Toronjo C. Comparison of automated and mercury column blood pressure measurements in health care settings. J Clin Hypertens (Greenwich). 2000;2(2):81-6. [pmid: 11416630].
110 Peters GL, Binder SK, Campbell NR. The effect of crossing legs on blood pressure: a randomized single-blind cross-over study. Blood Press Monit. 1999;4(2):97-101. [pmid: 10450120].
111 Pincomb GA, Lovallo WR, McKey BS, et al. Acute blood pressure elevations with caffeine in men with borderline systemic hypertension. Am J Cardiol. 1996;77(4):270-4. [pmid: 8607407].
112 Asayama K, Ohkubo T, Kikuya M, et al. Prediction of stroke by home “morning” versus “evening” blood pressure values: the Ohasama study. Hypertension. 2006;48(4):737-43. [pmid: 16952977].
113 Bobrie G, Chatellier G, Genes N, et al. Cardiovascular prognosis of “masked hypertension” detected by blood pressure self-measurement in elderly treated hypertensive patients. JAMA. 2004;291(11):1342-9. [pmid: 15026401].
114 Celis H, Staessen JA, Thijs L, et al. Cardiovascular risk in white-coat and sustained hypertensive patients. Blood Press. 2002;11(6):352-6. [pmid: 12523678].
115 Clement DL, De Buyzere ML, De Bacquer DA, et al. Prognostic value of ambulatory blood-pressure recordings in patients with treated hypertension. N Engl J Med. 2003;348(24):2407-15. [pmid: 12802026].
116 Dolan E, Stanton A, Thijs L, et al. Superiority of ambulatory over clinic blood pressure measurement in predicting mortality: the Dublin outcome study. Hypertension. 2005;46(1):156-61. [pmid: 15939805].
117 Fagard RH, van den Broeke C, de Cort P. Prognostic significance of blood pressure measured in the office, at home and during ambulatory monitoring in older patients in general practice. J Hum Hypertens. 2005;19(10):801-7. [pmid: 15959536].
118 Gasowski J, Li Y, Kuznetsova T, et al. Is “usual” blood pressure a proxy for 24-h ambulatory blood pressure in predicting cardiovascular outcomes?. Am J Hypertens. 2008;21(9):994-1000. [pmid: 18600212].
119 Hansen TW, Jeppesen J, Rasmussen S, et al. Ambulatory blood pressure and mortality: a population-based study. Hypertension. 2005;45(4):499-504. [pmid: 15753229].
120 Hermida RC, Ayala DE, Ýn A, et al. Decreasing sleep-time blood pressure determined by ambulatory monitoring reduces cardiovascular risk. J Am Coll Cardiol. 2011;58(11):1165-73. [pmid: 21884956].
121 Ingelsson E, Bjorklund-Bodegard K, Lind L, et al. Diurnal blood pressure pattern and risk of congestive heart failure. JAMA. 2006;295(24):2859-66. [pmid: 16804152].
122 Mesquita-Bastos J, Bertoquini S, Polonia J. Cardiovascular prognostic value of ambulatory blood pressure monitoring in a Portuguese hypertensive population followed up for 8.2 years. Blood Press Monit. 2010;15(5):240-6. [pmid: 20616705].
123 Niiranen TJ, Hanninen MR, Johansson J, et al. Home-measured blood pressure is a stronger predictor of cardiovascular risk than office blood pressure: the Finn-Home study. Hypertension. 2010;55(6):1346-51. [pmid: 20385970].
124 Ohkubo T, Imai Y, Tsuji I, et al. Home blood pressure measurement has a stronger predictive power for mortality than does screening blood pressure measurement: a population-based observation in Ohasama, Japan. J Hypertens. 1998;16(7):971-5. [pmid: 9794737].
125 Ohkubo T, Kikuya M, Metoki H, et al. Prognosis of “masked” hypertension and “white-coat” hypertension detected by 24-h ambulatory blood pressure monitoring: 10-year follow-up from the Ohasama study. J Am Coll Cardiol. 2005;46(3):508-15. [pmid: 16053966].
126 Staessen JA, Thijs L, Fagard R, et al. Predicting cardiovascular risk using conventional vs ambulatory blood pressure in older patients with systolic hypertension. JAMA. 1999;282(6):539-46. [pmid: 10450715].
127 Hozawa A, Ohkubo T, Kikuya M, et al. Blood pressure control assessed by home, ambulatory and conventional blood pressure measurements in the Japanese general population: the Ohasama study. Hypertens Res. 2002;25(1):57-63. [pmid: 11924727].
128 Andreadis EA, Angelopoulos ET, Tsakanikas AP, et al. Automated office versus home measurement of blood pressure in the assessment of morning hypertension. Blood Press Monit. 2012;17(1):24-34. [pmid: 22218221].
129 Cuspidi C, Sala C, Valerio C, et al. Nocturnal blood pressure in untreated essential hypertensives. Blood Press. 2011;20(6):335-41. [pmid: 21651423].
130 Fogari R, Corradi L, Zoppi A, et al. Repeated office blood pressure controls reduce the prevalence of white-coat hypertension and detect a group of white-coat normotensive patients. Blood Press Monit. 1996;1(1):51-4. [pmid: 10226202].
131 Gerc V, Favrat B, Brunner HR, et al. Is nurse-measured blood pressure a valid substitute for ambulatory blood pressure monitoring?. Blood Press Monit. 2000;5(4):203-9. [pmid: 11035861].
132 Graves JW, Grossardt BR. Discarding the first of three nurse-auscultatory or oscillometric blood pressure measurements does not improve the association of office blood pressure with ABPM. Blood Press Monit. 2010;15(3):146-51. [pmid: 20407368].
133 Gustavsen PH, Hoegholm A, Bang LE, et al. White coat hypertension is a cardiovascular risk factor: a 10-year follow-up study. J Hum Hypertens. 2003;17(12):811-7. [pmid: 14704724].
134 Hond ED, Celis H, Fagard R, et al. Self-measured versus ambulatory blood pressure in the diagnosis of hypertension. J Hypertens. 2003;21(4):717-22. [pmid: 12658017].
135 Inden Y, Tsuda M, Hayashi H, et al. Relationship between Joint National Committee-VI classification of hypertension and ambulatory blood pressure in patients with hypertension diagnosed by casual blood pressure. Clin Cardiol. 1998;21(11):801-6. [pmid: 9825191].
136 Kario K. Diagnosis of true uncontrolled hypertension using both home and ambulatory blood pressure monitoring. J Hum Hypertens. 2014;28(3):176-9. [pmid: 23924872].
137 Khoury S, Yarows SA, O’Brien TK, et al. Ambulatory blood pressure monitoring in a nonacademic setting: effects of age and sex. Am J Hypertens. 1992;5(9):616-23. [pmid: 1418850].
138 Licitra R, Acconcia MC, Puddu PE, et al. Ambulatory blood pressure monitoring in prehypertensive subjects. Cardiovasc Hematol Disord Drug Targets. 2012;12(1):44-50. [pmid: 22524174].
139 Manning G, Rushton L, Millar-Craig MW. Clinical implications of white coat hypertension: an ambulatory blood pressure monitoring study. J Hum Hypertens. 1999;13(12):817-22. [pmid: 10618670].
140 Martinez MA, Garcia-Puig J, Martin JC, et al. Frequency and determinants of white coat hypertension in mild to moderate hypertension: a primary care-based study. Am J Hypertens. 1999;12(3):251-9. [pmid: 10192226].
141 Myers MG. A proposed algorithm for diagnosing hypertension using automated office blood pressure measurement. J Hypertens. 2010;28(4):703-8. [pmid: 20150823].
142 Nasothimiou EG, Tzamouranis D, Rarra V, et al. Diagnostic accuracy of home vs. ambulatory blood pressure monitoring in untreated and treated hypertension. Hypertens Res. 2012;35(7):750-5. [pmid: 22357523].
143 Pierdomenico SD, Mezzetti A, Lapenna D, et al. “White-coat” hypertension in patients with newly diagnosed hypertension: evaluation of prevalence by ambulatory monitoring and impact on cost of health care. Eur Heart J. 1995;16(5):692-7. [pmid: 7588903].
144 Radi S, Lang T, Lauwers-Cances V, et al. One-year hypertension incidence and its predictors in a working population: the IHPAF study. J Hum Hypertens. 2004;18(7):487-94. [pmid: 14961044].
145 Talleruphuus U, Bang LE, Wiinberg N, et al. Isolated systolic hypertension in an elderly Danish population: prevalence and daytime ambulatory blood pressure. Blood Press. 2006;15(6):347-53. [pmid: 17472025].
146 Tanabe P, Persell SD, Adams JG, et al. Increased blood pressure in the emergency department: pain, anxiety, or undiagnosed hypertension?. Ann Emerg Med. 2008;51(3):221-9. [pmid: 18207606].
147 Toyama H, Hasegawa Y, Ejima Y, et al. Characteristics of young-onset white coat hypertension identified by targeted screening for hypertension at a university health check-up. Hypertens Res. 2008;31(6):1063-8. [pmid: 18716352].
148 Ungar A, Pepe G, Monami M, et al. Isolated ambulatory hypertension is common in outpatients referred to a hypertension centre. J Hum Hypertens. 2004;18(12):897-903. [pmid: 15241442].
149 Verdecchia P, Schillaci G, Borgioni C, et al. White coat hypertension and white coat effect: similarities and differences. Am J Hypertens. 1995;8(8):790-8. [pmid: 7576395].
150 Zabludowski JR, Rosenfeld JB. Evaluation of clinic blood pressure measurements: assessment by daytime ambulatory blood pressure monitoring. Isr J Med Sci. 1992;28(6):345-8. [pmid: 1607269].
151 Zawadzka A, Bird R, Casadei B, et al. Audit of ambulatory blood pressure monitoring in the diagnosis and management of hypertension in practice. J Hum Hypertens. 1998;12(4):249-52. [pmid: 9607694].
152 Pessanha P, Viana M, Ferreira P, et al. Diagnostic value and cost-benefit analysis of 24 hours ambulatory blood pressure monitoring in primary care in Portugal. BMC Cardiovasc Disord. 2013;13:57. [pmid: 23937261].
153 Apostolides AY, Cutter G, Daugherty SA, et al. Three-year incidence of hypertension in thirteen U.S. communities. Prev Med. 1982;11(5):487-99. [pmid: 7156059].
154 Arima H, Kiyohara Y, Kato I, et al. Alcohol reduces insulin-hypertension relationship in a general population: the Hisayama study. J Clin Epidemiol. 2002;55(9):863-9. [pmid: 12393073].
155 Bakx JC, Seidell JC, Deurenberg P, et al. Development of hypertension in obese subjects seen in general practice. Fam Pract. 1987;4(1):11-8. [pmid: 3569720].
156 Boyko EJ, Barr EL, Zimmet PZ, et al. Two-hour glucose predicts the development of hypertension over 5 years: the AusDiab study. J Hum Hypertens. 2008;22(3):168-76. [pmid: 18046430].
157 Brantsma AH, Bakker SJ, de ZD, et al. Urinary albumin excretion as a predictor of the development of hypertension in the general population. J Am Soc Nephrol. 2006;17(2):331-5. [pmid: 16434504].
158 Cacciolati C, Hanon O, Dufouil C, et al. Categories of hypertension in the elderly and their 1-year evolution: the Three-City Study. J Hypertens. 2013;31(4):680-9. [pmid: 23412428].
159 Cheung BM, Ong KL, Tso AW, et al. C-reactive protein as a predictor of hypertension in the Hong Kong Cardiovascular Risk Factor Prevalence Study (CRISPS) cohort. J Hum Hypertens. 2012;26(2):108-16. [pmid: 21270838].
160 Dernellis J, Panaretou M. Aortic stiffness is an independent predictor of progression to hypertension in nonhypertensive subjects. Hypertension. 2005;45(3):426-31. [pmid: 15710784].
161 Everson SA, Kaplan GA, Goldberg DE, et al. Hypertension incidence is predicted by high levels of hopelessness in Finnish men. Hypertension. 2000;35(2):561-7. [pmid: 10679498].
162 Fagot-Campagna A, Balkau B, Simon D, et al. Is insulin an independent risk factor for hypertension? The Paris Prospective Study. Int J Epidemiol. 1997;26(3):542-50. [pmid: 9222779].
163 Fitchett G, Powell LH. Daily spiritual experiences, systolic blood pressure, and hypertension among midlife women in SWAN. Ann Behav Med. 2009;37(3):257-67. [pmid: 19662465].
164 Giubertoni E, Bertelli L, Bartolacelli Y, et al. Parity as predictor of early hypertension during menopausal transition. J Hypertens. 2013;31(3):501-7. [pmid: 23196900].
165 Juhaeri, Stevens J, Chambless LE, et al. Associations between weight gain and incident hypertension in a bi-ethnic cohort: the Atherosclerosis Risk in Communities Study. Int J Obes Relat Metab Disord. 2002;26(1):58-64. [pmid: 11791147].
166 Kim J, Kim E, Yi H, et al. Short-term incidence rate of hypertension in Korea middle-aged adults. J Hypertens. 2006;24(11):2177-82. [pmid: 17053538].
167 Kim SJ, Lee J, Nam CM, et al. Progression rate from new-onset pre-hypertension to hypertension in Korean adults. Circ J. 2011;75(1):135-40. [pmid: 21099126].
168 Kivimaki M, Batty GD, Singh-Manoux A, et al. Validating the Framingham Hypertension Risk Score: results from the Whitehall II study. Hypertension. 2009;54(3):496-501. [pmid: 19597041].
169 Klein R, Klein BE, Moss SE, et al. The relationship of retinopathy in persons without diabetes to the 15-year incidence of diabetes and hypertension: Beaver Dam Eye Study. Trans Am Ophthalmol Soc. 2006;104:98-107. [pmid: 17471330].
170 Lakoski SG, Cushman M, Siscovick DS, et al. The relationship between inflammation, obesity and risk for hypertension in the Multi-Ethnic Study of Atherosclerosis (MESA). J Hum Hypertens. 2011;25(2):73-9. [pmid: 20944659].
171 Lee DH, Ha MH, Kim KY, et al. Gamma-glutamyltransferase: an effect modifier in the association between age and hypertension in a 4-year follow-up study. J Hum Hypertens. 2004;18(11):803-7. [pmid: 15141269].
172 Lee JH, Yang DH, Park HS, et al. Incidence of hypertension in Korea: 5-year follow-up study. J Korean Med Sci. 2011;26(10):1286-92. [pmid: 22022179].
173 Lee JS, Kawakubo K, Kashihara H, et al. Effect of long-term body weight change on the incidence of hypertension in Japanese men and women. Int J Obes Relat Metab Disord. 2004;28(3):391-5. [pmid: 14724660].
174 Levine DA, Lewis CE, Williams OD, et al. Geographic and demographic variability in 20-year hypertension incidence: the CARDIA study. Hypertension. 2011;57(1):39-47. [pmid: 21135358].
175 Matsuo T, Sairenchi T, Suzuki K, et al. Long-term stable obesity increases risk of hypertension. Int J Obes (Lond). 2011;35(8):1056-62. [pmid: 21042324].
176 Morikawa Y, Nakagawa H, Miura K, et al. Relationship between shift work and onset of hypertension in a cohort of manual workers. Scand J Work Environ Health. 1999;25(2):100-4. [pmid: 10360464].
177 Nakanishi N, Suzuki K, Tatara K. Clustering of cardiovascular risk factors and risk of development of hypertension in Japanese male office workers. J Cardiovasc Risk. 2003;10(3):213-20. [pmid: 12775955].
178 Okubo Y, Suwazono Y, Kobayashi E, et al. An association between smoking habits and blood pressure in normotensive Japanese men: a 5-year follow-up study. Drug Alcohol Depend. 2004;73(2):167-74. [pmid: 14725956].
179 Satoh H, Saijo Y, Kishi R, et al. Brachial-ankle pulse wave velocity is an independent predictor of incident hypertension in Japanese normotensive male subjects. Environ Health Prev Med. 2011;16(4):217-23. [pmid: 21431793].
180 Schulz M, Liese AD, Boeing H, et al. Associations of short-term weight changes and weight cycling with incidence of essential hypertension in the EPIC-Potsdam Study. J Hum Hypertens. 2005;19(1):61-7. [pmid: 15343355].
181 Shook RP, Lee DC, Sui X, et al. Cardiorespiratory fitness reduces the risk of incident hypertension associated with a parental history of hypertension. Hypertension. 2012;59(6):1220-4. [pmid: 22585947].
182 Tozawa M, Iseki K, Iseki C, et al. Impact of multiple risk factor clustering on the elevation of blood pressure. Hypertens Res. 2002;25(6):811-6. [pmid: 12484502].
183 Vasan RS, Larson MG, Leip EP, et al. Assessment of frequency of progression to hypertension in non-hypertensive participants in the Framingham Heart Study: a cohort study. Lancet. 2001;358(9294):1682-6. [pmid: 11728544].
184 Yamada Y, Ishizaki M, Kido T, et al. Alcohol, high blood pressure, and serum gamma-glutamyl transpeptidase level. Hypertension. 1991;18(6):819-26. [pmid: 1683858].
185 Yambe M, Tomiyama H, Yamada J, et al. Arterial stiffness and progression to hypertension in Japanese male subjects with high normal blood pressure. J Hypertens. 2007;25(1):87-93. [pmid: 17143178].
186 Sung KC, Wild SH, Byrne CD. Development of new fatty liver, or resolution of existing fatty liver, over five years of follow-up, and risk of incident hypertension. J Hepatol. 2014;60(5):1040-5. [pmid: 24445219].
187 Jung DH, Kim JY, Kim JK, et al. Relative contribution of obesity and serum adiponectin to the development of hypertension. Diabetes Res Clin Pract. 2014;103(1):51-6. [pmid: 24398319].
188 Kubo T, Fujino Y, Nakamura T, et al. An industry-based cohort study of the association between weight gain and hypertension risk among rotating shift workers. J Occup Environ Med. 2013;55(9):1041-5. [pmid: 23969502].
189 Okubo Y, Sairenchi T, Irie F, et al. Association of alcohol consumption with incident hypertension among middle-aged and older Japanese population: the Ibarakai Prefectural Health Study (IPHS). Hypertension. 2014;63(1):41-7. [pmid: 24126168].
190 Zambrana RE, Lopez L, Dinwiddie GY, et al. Prevalence and incident prehypertension and hypertension in postmenopausal Hispanic women: results from the Women’s Health Initiative. Am J Hypertens. 2014;27(3):372-81. [pmid: 24480867].
191 Volzke H, Fung G, Ittermann T, et al. A new, accurate predictive model for incident hypertension. J Hypertens. 2013;31(11):2142-50. [pmid: 24077244].
192 Ameling EH, de Korte DF, Man in ’t Veld A. Impact of diagnosis and treatment of hypertension on quality of life: a double-blind, randomized, placebo-controlled, cross-over study of betaxolol. J Cardiovasc Pharmacol. 1991;18(5):752-60. [pmid: 1723773].
193 Haynes RB, Sackett DL, Taylor DW, et al. Increased absenteeism from work after detection and labeling of hypertensive patients. N Engl J Med. 1978;299(14):741-4. [pmid: 692548].
194 Mann AH. The psychological effect of a screening programme and clinical trial for hypertension upon the participants. Psychol Med. 1977;7(3):431-8. [pmid: 905459].
195 Spruill TM, Feltheimer SD, Harlapur M, et al. Are there consequences of labeling patients with prehypertension? An experimental study of effects on blood pressure and quality of life. J Psychosom Res. 2013;74(5):433-8. [pmid: 23597332].
196 Verdecchia P, Angeli F, Borgioni C, et al. Ambulatory blood pressure and cardiovascular outcome in relation to perceived sleep deprivation. Hypertension. 2007;49(4):777-83. [pmid: 17261645].
197 Viera AJ, Lingley K, Esserman D. Effects of labeling patients as prehypertensive. J Am Board Fam Med. 2010;23(5):571-83. [pmid: 20823351].
198 Viera AJ, Lingley K, Hinderliter AL. Tolerability of the Oscar 2 ambulatory blood pressure monitor among research participants: a cross-sectional repeated measures study. BMC Med Res Methodol. 2011;11:59. [pmid: 21524301].
199 Manning G, Rushton L, Donnelly R, et al. Variability of diurnal changes in ambulatory blood pressure and nocturnal dipping status in untreated hypertensive and normotensive subjects. Am J Hypertens. 2000;13(9):1035-8. [pmid: 10981556].
200 Nasothimiou EG, Karpettas N, Dafni MG, et al. Patients’ preference for ambulatory versus home blood pressure monitoring. J Hum Hypertens. 2014;28(4):224-9. [pmid: 24152822].
201 Khattar RS, Senior R, Lahiri A. Cardiovascular outcome in white-coat versus sustained mild hypertension: a 10-year follow-up study. Circulation. 1998;98(18):1892-7. [pmid: 9799210].
202 Leitschuh M, Cupples LA, Kannel W, et al. High-normal blood pressure progression to hypertension in the Framingham Heart Study. Hypertension. 1991;17(1):22-7. [pmid: 1986979].
203 Sung KC, Lim S, Rosenson RS. Hyperinsulinemia and homeostasis model assessment of insulin resistance as predictors of hypertension: a 5-year follow-up study of Korean sample. Am J Hypertens. 2011;24(9):1041-5. [pmid: 21614095].
204 Taylor DW, Haynes RB, Sackett DL, et al. Longterm follow-up of absenteeism among working men following the detection and treatment of their hypertension. Clin Invest Med. 1981;4(3-4):173-7. [pmid: 7337988].
205 Sheridan S, Pignone M, Donahue K. Screening for high blood pressure: a review of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2003;25(2):151-8. [pmid: 12880884].
206 U.S. Preventive Services Task Force. Screening for high blood pressure: recommendations and rationale. Am Fam Physician. 2003;68(10):2019-22. [pmid: 14655813].
207 U.S. Preventive Services Task Force. Screening for high blood pressure: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2007;147(11):783-6. [pmid: 18056662].
208 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
209 Ye C, Foster G, Kaczorowski J, et al. The impact of a Cardiovascular Health Awareness Program (CHAP) on reducing blood pressure: a prospective cohort study. BMC Public Health. 2013;13:1230. [pmid: 24369050].
210 Record NB, Harris DE, Record SS, et al. Mortality impact of an integrated community cardiovascular health program. Am J Prev Med. 2000;19(1):30-8. [pmid: 10865161].
211 Hodgkinson J, Mant J, Martin U, et al. Relative effectiveness of clinic and home blood pressure monitoring compared with ambulatory blood pressure monitoring in diagnosis of hypertension: systematic review. BMJ. 2011;342:d3621. [pmid: 21705406].
212 Appel LJ, Miller ER III, Charleston J. Improving the measurement of blood pressure: is it time for regulated standards?. Ann Intern Med. 2011;154(12):838-40. [pmid: 21690599].
213 Millar JA, Accioly JM. Measurement of blood pressure may be affected by an interaction between subject and observer based on gender. J Hum Hypertens. 1996;10(7):449-53. [pmid: 8880558].
214 Myers MG, McInnis NH, Fodor GJ, et al. Comparison between an automated and manual sphygmomanometer in a population survey. Am J Hypertens. 2008;21(3):280-3. [pmid: 18219304].
215 Mancia G, Ulian L, Parati G, et al. Increase in blood pressure reproducibility by repeated semi-automatic blood pressure measurements in the clinic environment. J Hypertens. 1994;12(4):469-73. [pmid: 8064172].
216 Rotch AL, Dean JO, Kendrach MG, et al. Blood pressure monitoring with home monitors versus mercury sphygmomanometer. Ann Pharmacother. 2001;35(7-8):817-22. [pmid: 11485126].
217 Landgraf J, Wishner SH, Kloner RA. Comparison of automated oscillometric versus auscultatory blood pressure measurement. Am J Cardiol. 2010;106(3):386-8. [pmid: 20643251].
218 Whincup PH, Bruce NG, Cook DG, et al. The Dinamap 1846SX automated blood pressure recorder: comparison with the Hawksley random zero sphygmomanometer under field conditions. J Epidemiol Community Health. 1992;46(2):164-9. [pmid: 1583434].
219 Jones D, Engelke MK, Brown ST, et al. A comparison of two noninvasive methods of blood pressure measurement in the triage area. J Emerg Nurs. 1996;22(2):111-5. [pmid: 8716299].
220 Nelson D, Kennedy B, Regnerus C, et al. Accuracy of automated blood pressure monitors. J Dent Hyg. 2008;82(4):35. [pmid: 18755068].
221 Mourad A, Carney S, Gillies A, et al. Arm position and blood pressure: a risk factor for hypertension?. J Hum Hypertens. 2003;17(6):389-95. [pmid: 12764401].
222 Schulze MB, Kroke A, Bergmann MM, et al. Differences of blood pressure estimates between consecutive measurements on one occasion: implications for inter-study comparability of epidemiologic studies. Eur J Epidemiol. 2000;16(10):891-8. [pmid: 11338119].
223 Czarkowski M, Zajac K, Rozanowski K. Can the pressor response accompanying blood pressure measurement be limited in young, normotensive women?. Blood Press Monit. 2008;13(1):1-5. [pmid: 18199917].
224 Slaby A, Josifko M. Does sequential automated measurement improve the estimate of resting blood pressure?. J Hum Hypertens. 1992;6(1):31-4. [pmid: 1583628].
225 Widener J, Yang C, Costello P, et al. Modifications to standard guidelines and changes in blood pressure readings: use of an automatic blood pressure device. AAOHN J. 1999;47(3):107-13. [pmid: 10347396].
226 Goodman M, Dembroski TM, Herbst JH. How many sphygmomanometric cuff inflations are necessary to obtain a hemodynamic baseline?. Biofeedback Self Regul. 1996;21(3):207-16. [pmid: 8894054].
227 Dieterle T, Schuurmans MM, Strobel W, et al. Moderate-to-severe blood pressure elevation at ED entry: hypertension or normotension?. Am J Emerg Med. 2005;23(4):474-9. [pmid: 16032614].
228 Chiolero A, Witteman JC, Viswanathan B, et al. No further decrease in blood pressure when the interval between readings exceeds one hour. Blood Press Monit. 2008;13(2):85-9. [pmid: 18347442].
229 Gerin W, Ogedegbe G, Schwartz JE, et al. Assessment of the white-coat effect. J Hypertens. 2006;24(1):67-74. [pmid: 16331103].
230 Hodgkinson JA, Sheppard JP, Heneghan C, et al. Accuracy of ambulatory blood pressure monitors: a systematic review of validation studies. J Hypertens. 2013;31(2):239-50. [pmid: 23303347].
231 Gerin W, Marion RM, Friedman R, et al. How should we measure blood pressure in the doctor’s office?. Blood Press Monit. 2001;6(5):257-62. [pmid: 12055421].
232 Clark CE, Horvath IA, Taylor RS, et al. Doctors record higher blood pressures than nurses: systematic review and meta-analysis. Br J Gen Pract. 2014;64(621):e223-32. [pmid: 24686887].
233 Kahan E, Yaphe J, Knaani-Levinz H, et al. Comparison of blood pressure measurements on the bare arm, below a rolled-up sleeve, or over a sleeve. Fam Pract. 2003;20(6):730-2. [pmid: 14701900].
234 Holleman DR Jr, Westman EC, McCrory DC, et al. The effect of sleeved arms on oscillometric blood pressure measurement. J Gen Intern Med. 1993;8(6):325-6. [pmid: 8320577].
235 Zheng D, Amoore JN, Mieke S, et al. How important is the recommended slow cuff pressure deflation rate for blood pressure measurement?. Ann Biomed Eng. 2011;39(10):2584-91. [pmid: 21735319].
236 Aylett M, Marples G, Jones K, et al. Evaluation of normal and large sphygmomanometer cuffs using the Omron 705CP. J Hum Hypertens. 2001;15(2):131-4. [pmid: 11317193].
237 Guagnano MT, Pace-Palitti V, Murri R, et al. The prevalence of hypertension in gynaecoid and android obese women. J Hum Hypertens. 1996;10(9):619-24. [pmid: 8953208].
238 Bakx C, Oerlemans G, Hoogen H, et al. The influence of cuff size on blood pressure measurement. J Hum Hypertens. 1997;11:439-45. [pmid: 9283061].
239 Taleyarkhan PR, Geddes LA, Kemeny AE, et al. Loose cuff hypertension. Cardiovasc Eng. 2009;9(3):113-8. [pmid: 19662531].
240 Clark CE, Powell RJ. The differential blood pressure sign in general practice: prevalence and prognostic value. Fam Pract. 2002;19(5):439-41. [pmid: 12356690].
241 Cassidy P, Jones K. A study of inter-arm blood pressure differences in primary care. J Hum Hypertens. 2001;15:519-22. [pmid: 11494088].
242 Grossman A, Prokupetz A, Gordon B, et al. Inter-arm blood pressure differences in young, healthy patients. J Clin Hypertens (Greenwich). 2013;15(8):575-8. [pmid: 23889720].
243 Pavek K, Taube A. Interchangeability of ambulatory and office blood pressure: limitations of reproducibility and agreement. Blood Press. 2000;9(4):192-9. [pmid: 11055471].
244 Terent A, Breig-Asberg E. Parathyroid hormone and the risk of incident hypertension. Blood Press. 1994;3(3):156-63. [pmid: 8069403].
245 Pickering TG, Hall JE, Appel LJ, et al. Recommendations for blood pressure measurement in humans and experimental animals. Part 1: blood pressure measurement in humans: a statement for professionals from the Subcommittee of Professional and Public Education of the American Heart Association Council on High Blood Pressure Research. Hypertension. 2005;45(1):142-61. [pmid: 15611362].
246 Dawes MG, Coats AJ, Juszczak E. Daytime ambulatory systolic blood pressure is more effective at predicting mortality than clinic blood pressure. Blood Press Monit. 2006;11(3):111-8. [pmid: 16702819].
247 Shimada K, Fujita T, Ito S, et al. The importance of home blood pressure measurement for preventing stroke and cardiovascular disease in hypertensive patients: a sub-analysis of the Japan Hypertension Evaluation with Angiotensin II Antagonist Losartan Therapy (J-HEALTH) study, a prospective nationwide observational study. Hypertens Res. 2008;31(10):1903-11. [pmid: 19015598].
248 Ohkubo T, Asayama K, Kikuya M, et al. How many times should blood pressure be measured at home for better prediction of stroke risk? Ten-year follow-up results from the Ohasama study. J Hypertens. 2004;22(6):1099-104. [pmid: 15167443].
249 Stergiou GS, Nasothimiou EG, Kalogeropoulos PG, et al. The optimal home blood pressure monitoring schedule based on the Didima outcome study. J Hum Hypertens. 2010;24(3):158-64. [pmid: 19587701].
250 National Clinical Guideline Centre (UK). Hypertension: The Clinical Management of Primary Hypertension in Adults: Update of Clinical Guidelines 18 and 34. London. National Institute for Health and Care Excellence. 2011. [pmid: 22855971].
251 Asayama K, Thijs L, Brguljan-Hitij J, et al. Risk stratification by self-measured home blood pressure across categories of conventional blood pressure: a participant-level meta-analysis. PLoS Med. 2014;11(1):e1001591. [pmid: 24465187].
252 Mallion JM. Clinical significance and treatment requirements in white coat and masked hypertension. Berbari AE, Mancia G. Special Issues in Hypertension. Milan. Springer. 2012:13-24.
253 de la Sierra A, Banegas JR, Segura J, et al. Ambulatory blood pressure monitoring and development of cardiovascular events in high-risk patients included in the Spanish ABPM registry: the CARDIORISC Event study. J Hypertens. 2012;30(4):713-9. [pmid: 22306850].
254 Echouffo-Tcheugui JB, Batty GD, Kivimaki M, et al. Risk models to predict hypertension: a systematic review. PLoS One. 2013;8(7):e67370. [pmid: 23861760].
255 Egan BM, Zhao Y, Axon RN. US trends in prevalence, awareness, treatment, and control of hypertension, 1988-2008. JAMA. 2010;303(20):2043-50. [pmid: 20501926].
256 Dyer AR, Elliott P. The INTERSALT study: relations of body mass index to blood pressure. J Hum Hypertens. 1989;3(5):299-308. [pmid: 2810326].
257 Albanes D, Jones DY, Micozzi MS, et al. Associations between smoking and body weight in the US population: analysis of NHANES II. Am J Public Health. 1987;77(4):439-44. [pmid: 3493709].
258 John U, Meyer C, Hanke M, et al. Smoking status, obesity and hypertension in a general population sample: a cross-sectional study. QJM. 2006;99(6):407-15. [pmid: 16687420].
259 Julius S, Nesbitt SD, Egan BM, et al. Feasibility of treating prehypertension with an angiotensin-receptor blocker. N Engl J Med. 2006;354(16):1685-97. [pmid: 16537662].
260 National Heart, Lung, and Blood Institute. Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents: Summary Report. NIH Publication No. 12-7486A. Bethesda, MD. National Heart, Lung, and Blood Institute. 2013. Accessed at http://www.nhlbi.nih.gov/health-pro/guidelines/current/cardiovascular-health-pediatric-guidelines. 10 December 2014.
261 Hackam DG, Quinn RR, Ravani P, et al. The 2013 Canadian Hypertension Education Program recommendations for blood pressure measurement, diagnosis, assessment of risk, prevention, and treatment of hypertension. Can J Cardiol. 2013;29(5):528-42. [pmid: 23541660].
262 Hicks KA, Hung HM, Mahaffey KW, et al. Standardized Definitions for End Point Events in Cardiovascular Trials. Standardized Data Collection for Cardiovascular Trials Initiative. 2010.
263 Center for the Evaluative Clinical Sciences, Dartmouth Medical School. The Dartmouth Atlas of Cardiovascular Health Care. Chicago. AHA Press. 1999.
264 Chan PS, Patel MR, Klein LW, et al. Appropriateness of percutaneous coronary intervention. JAMA. 2011;306(1):53-61. [pmid: 21730241].
265 Patel MR, Dehmer GJ, Hirshfeld JW, et al. ACCF/SCAI/STS/AATS/AHA/ASNC 2009 appropriateness criteria for coronary revascularization: a report by the American College of Cardiology Foundation Appropriateness Criteria Task Force, Society for Cardiovascular Angiography and Interventions, Society of Thoracic Surgeons, American Association for Thoracic Surgery, American Heart Association, and the American Society of Nuclear Cardiology, endorsed by the American Society of Echocardiography, the Heart Failure Society of America, and the Society of Cardiovascular Computed Tomography. J Am Coll Cardiol. 2009;53(6):530-53. [pmid: 19195618].
266 O’Connor GT, Olmstead EM, Nugent WC, et al. Appropriateness of coronary artery bypass graft surgery performed in northern New England. J Am Coll Cardiol. 2008;51(24):2323-8. [pmid: 18549917].
267 Leape LL, Park RE, Bashore TM, et al. Effect of variability in the interpretation of coronary angiograms on the appropriateness of use of coronary revascularization procedures. Am Heart J. 2000;139(1 Pt 1):106-13. [pmid: 10618570].
268 Fagard RH. Dipping pattern of nocturnal blood pressure in patients with hypertension. Expert Rev Cardiovasc Ther. 2009;7(6):599-605. [pmid: 19505275].
269 Alpert BS. Are kiosk blood pressure readings trustworthy?. Blood Press Monit. 2012;17(6):257-8. [pmid: 23147536].
270 Canadian Agency for Drugs and Technologies in Health. Blood Pressure Monitoring Chairs to Identify Hypertension: A Review of the Clinical Effectiveness and Guidelines. Ottawa, Ontario. Canadian Agency for Drugs and Technologies in Health. 2011. Accessed at http://www.cadth.ca/en/products/rapid-response/publication/2980. 10 December 2014.
271 Buxton IL, Adams JQ, Gore M, et al. Validation of the CSI health station 6K blood pressure kiosk. Proc West Pharmacol Soc. 2007;50:181-3. [pmid: 18605260].
272 Lewis JE, Boyle E, Magharious L, et al. Evaluation of a community-based automated blood pressure measuring device. CMAJ. 2002;166(9):1145-8. [pmid: 12000246].
273 Van Durme DJ, Goldstein M, Pal N, et al. The accuracy of community-based automated blood pressure machines. J Fam Pract. 2000;49(5):449-52. [pmid: 10836778].
274 Viera AJ, Cohen LW, Mitchell CM, et al. Hypertensive patients’ use of blood pressure monitors stationed in pharmacies and other locations: a cross-sectional mail survey. BMC Health Serv Res. 2008;8:216. [pmid: 18945355].
275 Hamilton W, Round A, Goodchild R, et al. Do community based self-reading sphygmomanometers improve detection of hypertension? A feasibility study. J Public Health Med. 2003;25(2):125-30. [pmid: 12848401].
276 Skorupa S. Development of a screening instrument to identify risk for the white coat effect in rural and non-rural patients. [Dissertation]. Binghamton, NY. State University of New York at Binghamton. 2007.
277 McEniery CM, Cockcroft JR, Roman MJ, et al. Central blood pressure: current evidence and clinical importance. Eur Heart J. 2014;35(26):1719-25. [pmid: 24459197].
278 Cheng HM, Lang D, Tufanaru C, et al. Measurement accuracy of non-invasively obtained central blood pressure by applanation tonometry: a systematic review and meta-analysis. Int J Cardiol. 2013;167(5):1867-76. [pmid: 22622052].
279 Cavalcante JL, Lima JA, Redheuil A, et al. Aortic stiffness: current understanding and future directions. J Am Coll Cardiol. 2011;57(14):1511-22. [pmid: 21453829].
280 Kim DH, Braam B. Assessment of arterial stiffness using applanation tonometry. Can J Physiol Pharmacol. 2013;91(12):999-1008. [pmid: 24289069].
281 Bilo G, Giglio A, Styczkiewicz K, et al. How to improve the assessment of 24-h blood pressure variability. Blood Press Monit. 2005;10(6):321-3. [pmid: 16496448].
282 Floras JS. Blood pressure variability: a novel and important risk factor. Can J Cardiol. 2013;29(5):557-63. [pmid: 23618505].
283 O’Brien E, Parati G, Stergiou G, et al. European Society of Hypertension position paper on ambulatory blood pressure monitoring. J Hypertens. 2013;31(9):1731-68. [pmid: 24029863].
284 Kollias A, Stergiou GS. Automated measurement of office, home and ambulatory blood pressure in atrial fibrillation. Clin Exp Pharmacol Physiol. 2014;41(1):9-15. [pmid: 23647092].
285 Stergiou GS, Kollias A, Destounis A, et al. Automated blood pressure measurement in atrial fibrillation: a systematic review and meta-analysis. J Hypertens. 2012;30(11):2074-82. [pmid: 22914573].
286 Allen NB, Siddique J, Wilkins JT, et al. Blood pressure trajectories in early adulthood and subclinical atherosclerosis in middle age. JAMA. 2014;311(5):490-7. [pmid: 24496536].
287 Jimbo M, Barrie WE, Borsch MP, et al. Essential Hypertension. UMHS Hypertension Guideline. Ann Arbor, MI. University of Michigan. 2009.
288 Luehr D, Woolley T, Burke R, et al. Hypertension Diagnosis and Treatment. Bloomington, MN. Institute for Clinical Systems Improvement. 2012.
289 American Academy of Family Physicians. Clinical Preventive Services Recommendations: Hypertension. Leawood, KS. American Academy of Family Physicians. 2007. Accessed at http://www.aafp.org/patient-care/clinical-recommendations/all/hypertension.html. 10 December 2014.
290 American Congress of Obstetricians and Gynecologists. Well-Woman Recommendations. Washington, DC. American Congress of Obstetricians and Gynecologists. 2014. Accessed at http://www.acog.org/About-ACOG/ACOG-Departments/Annual-Womens-Health-Care/Well-Woman-Recommendations. 10 December 2014.
291 American Heart Association. Heart-Health Screenings. Dallas, TX. American Heart Association. 2014. Accessed at http://www.heart.org/HEARTORG/Conditions/Heart-Health-Screenings_UCM_428687_Article.jsp#. 10 December 2014.
292 Lee DH, Ha MH, Kim JR, et al. Effects of smoking cessation on changes in blood pressure and incidence of hypertension: a 4-year follow-up study. Hypertension. 2001;37(2):194-8. [pmid: 11230270].
293 Aihara A, Imai Y, Sekino M, et al. Discrepancy between screening blood pressure and ambulatory blood pressure: a community-based study in Ohasama. Hypertens Res. 1998;21(2):127-36. [pmid: 9661809].
294 Player MS, King DE, Mainous AG III, et al. Psychosocial factors and progression from prehypertension to hypertension or coronary heart disease. Ann Fam Med. 2007;5(5):403-11. [pmid: 17893381].
295 Muntner P, Woodward M, Mann DM, et al. Comparison of the Framingham Heart Study hypertension model with blood pressure alone in the prediction of risk of hypertension: the Multi-Ethnic Study of Atherosclerosis. Hypertension. 2010;55(6):1339-45. [pmid: 20439822].
296 Schulze MB, Hoffmann K, Kroke A, et al. Risk of hypertension among women in the EPIC-Potsdam Study: comparison of relative risk estimates for exploratory and hypothesis-oriented dietary patterns. Am J Epidemiol. 2003;158(4):365-73. [pmid: 12915502].
297 Grondal N, Sogaard R, Henneberg EW, et al. The Viborg Vascular (VIVA) screening trial of 65-74 year old men in the central region of Denmark: study protocol. Trials. 2010;11:67. [pmid: 20507582].
298 Goyal T. Prehypertension Labeling. New York. Columbia University. 2011. Accessed at https://clinicaltrials.gov/ct2/show/NCT01434953. 10 December 2014.