# Discussion

## Context for This Review

This evidence review for the USPSTF addresses the overall benefits and harms of screening for high BP. This review also examines evidence gaps identified by the authors of the previous report regarding the optimal methods and protocols for initial BP screening, the predictive capacity for CV and mortality outcomes and the diagnostic accuracy of ABPM and HBPM, and optimal rescreening intervals.79,205

The 2003 and 2007 USPSTF recommendation statements affirmed and reaffirmed, respectively, that treatment of high BP in adults substantially decreases the incidence of CV events, thus completing the chain of evidence for BP screening.206,207 Therefore, this review did not address questions regarding approaches or thresholds for treatment of hypertension.

The JNC 8 panel recently updated its guidelines for hypertension treatment.8 It used a modified Delphi technique to identify the three highest-ranked questions that addressed BP thresholds and goals for pharmacological treatment of patients with hypertension. It also addressed whether particular antihypertensive drugs or drug classes improve important health outcomes compared with others. These guidelines were developed to meet the needs of the primary care clinician and were based on a rigorous assessment of the available RCT evidence on treatment of high BP.

The JNC 7 guidelines were published in 2003.^208^ The main difference between the JNC 7 and JNC 8 recommendations is whether BP treatment thresholds and targets should be more conservative (i.e., set higher) in older populations, persons with diabetes, and persons with nondiabetic chronic kidney disease. In addition, JNC 7 addressed multiple issues, including BP measurement methods, that JNC 8 elected not to readdress so as to limit their systematic review to only the highest-priority questions.

The topics considered in the current review update and expand on similar sections of the JNC 7 guidelines. This review provides information complementary to the JNC 8 guidelines. In particular, current recommendations advise treating patients in order to reach specific BP target levels.8 If goals are not reached within 1 month, additional medications are recommended. Thus, accurate BP measurement at appropriate intervals is necessary to identify and ensure timely treatment of patients with sustained BP elevation, while avoiding unnecessary treatment of those who may not actually benefit. Table 36 provides a summary of the evidence.

Table 36 Overall Summary of Evidence

Key Question | Studies (k) | Overall Quality | Limitations | Consistency | Primary Care Applicability | Summary of Findings
KQ 1 Screening and CVD and mortality | k=1 | Good, limited to 1 trial | Evidence limited to results from 1 good-quality study | NA (1 study) | Moderate Appropriate to an elderly primary care population; screening program evaluated within the context of a universal payer | A cluster randomized, controlled trial (39 clusters; n=140,642) of a BP screening program in Ontario, Canada, targeted to those age ≥65 years, reported a statistically significant 9% relative reduction in the number of composite cardiovascular events (rate ratio, 0.91 [95% CI, 0.86 to 0.97]; p=0.002). There were 3.02 fewer annual hospital admissions per 1,000 persons for CV disease in the intervention group than the no screening group. When analyzed by number of unique residents with hospital admissions, there was a significant relative reduction only in the individual outcome of acute MI.
KQ 2a Diagnostic accuracy of clinic-based blood pressure measurement methods | k=4 | Fair to Good | Differences in study design; clinically unrealistic design in 1 study; use of different automated devices in 1 study without attempt to ensure comparability or validity | Inconsistent Sensitivity differs greatly in 1 study | High 3 of 4 studies used clinically applicable protocols to measure the diagnostic accuracy of automated oscillometric BP devices | 1 unique study that likely minimized human error more than can be achieved in the typical clinical setting compared manual BP measurement by sphygmomanometer (reference standard) to automated oscillometric measurement, reporting 91% sensitivity, 96% specificity, 88% PPV, and 97% NPV. 3 studies of similar comparisons but with more clinically applicable study designs reported much lower sensitivities (51%-68%) and lower PPVs (76%-84%).
KQ 2b Diagnostic accuracy of protocol characteristics | k=3 | Fair to Good | Different protocol characteristics addressed; populations not uniformly representative of screening populations; in 1 study, a carefully controlled protocol may limit applicability | NA Each study evaluated a different component of BP measurement | Moderate Studies addressed basic questions regarding BP measurement methods | 1 study showed that the first of 3 BP measurements had a high sensitivity (0.95) but only a moderate PPV (0.76) for detecting hypertension compared with the average of the 2nd and 3rd measurements, suggesting that the main value of repeated measurements is in confirming initially elevated results. In a study of normotensive persons, different leg positions, including leg crossing, did not result in reclassification to hypertensive BP. BP measured after double-blind administration of oral caffeine resulted in reclassification of 17% of persons who ingested caffeine from normotensive to hypertensive.
KQ 3a Prediction of events | k=15 | Fair to Good | No U.S.-based study populations; limited data for HBPM; only 1 study compared all 3 methods | High | ABPM independently predicts CV outcomes compared with OBPM and can be considered the reference method for BP measurement | 24-hour ABPM predicted stroke and other CV fatal and nonfatal events significantly and independently of OBPM. When both were in the model, OBPM added no significant predictive capacity. Results were inconsistently significant for cardiac events, CHF, and all-cause mortality. The pattern of results was similar for nighttime and daytime ABPM compared with OBPM; no single ABPM protocol appeared best. Results of 5 studies suggest that HBPM predicts CV outcomes significantly and independently of OBPM but too few studies are available for firm conclusions. Only 1 study compared ABPM with HBPM; evidence was insufficient for conclusions. Limited evidence suggests that CV outcomes for the subgroup with isolated clinic HTN at baseline are more similar to those of normotensive than sustained hypertensive persons.
KQ 3b Diagnostic accuracy to confirm diagnosis | k=27 | Fair to Good | Factors influencing variability in the proportion of persons with isolated clinic HTN are not apparent | Limited | High Persons with false-positive BP results by OBPM and without confirmation (isolated clinic hypertension) could be misdiagnosed and unnecessarily treated | Initial screening by office-based methods variably predicts true HTN, defined primarily by ABPM; the proportion of persons with an elevated screen who are normotensive upon confirmatory testing by ABPM (or HBPM) ranges from 5 to 65% across all studies; this population has isolated clinic hypertension
KQ 3c Diagnostic accuracy to confirm diagnosis in subpopulations | k=27 | Fair to Good | As above | As above | As above No additional subpopulations identified by the available data. Confirmation near threshold for hypertension most important | The subpopulation of isolated clinic hypertensives was identified in KQ 3b. No associations between reported race/ethnicity, sex, or smoking were qualitatively detected. Increasing baseline BP associated with increasing positive predictive value (i.e., lower likelihood of misdiagnosis).
KQ 4a Shortest rescreening interval | k=39 | Fair to Good | Only 1 study reporting rescreening incidence at <1 year and most studies at 5 years; majority of studies conducted in Asia | Moderate | High Rescreening without confirmation may result in overestimation of HTN incidence and misdiagnosis in persons | In a small number of studies that used a separate confirmation step, a significant proportion of incident HTN cases were not confirmed. Thus, estimates of the weighted mean incidence of HTN at yearly intervals <6 years derived from a small number of studies (except at 5 years) with highly variable results are likely to be overestimates, since most studies did not include a confirmation step. For example, the weighted mean incidence at 5 years of 14% actually ranged from 2% to 28%. Variation results from criteria for diagnosis and also from study population characteristics.
KQ 4b Shortest rescreening interval by patient characteristics | k=39 | Fair to Good | As above Limited subgroup reporting | Moderate | High Higher incidence of HTN was seen in persons with BP in the high-normal range, the elderly, those with BMI above normal, and African Americans; much lower incidence was seen in those without risk factors | HTN incidence increases as much as 2- to 4-fold moving from the 18 to 40/45 age category to 40/45 to 60/65 years. HTN incidence consistently triples between optimal and normal BP categories within each study and approximately doubles between normal and high-normal categories. Incidence is generally higher in males than females, but is especially higher among males in younger populations. Incidence was 2-fold higher in overweight and 3-fold higher in obese persons compared with those of normal weight, but not increased in smokers compared with nonsmokers or former smokers. There was consistently higher incidence of HTN at rescreening in African American than white participants.
KQ 5 Adverse effects | k=9 | Fair to Good | Different study designs, different outcomes assessed, difficult to compare results across studies | NA Studies addressed different outcomes | Moderate Sleep disturbance and physical discomfort are associated with ABPM use | 3 trials found no significant differences in psychological distress or quality of life after persons were labeled as hypertensive or prehypertensive. 1 trial reported significantly decreased mood, general physical state, sexual functioning, and sleep quality after labeling. 1 cohort study reported significantly increased absenteeism up to 4 years after labeling compared with the year before. 3 cohort studies reported significant sleep disturbances associated with ABPM use and 2 studies reported that significant proportions of ABPM users experienced pain, skin irritation, and overall discomfort.

Abbreviations: ABPM = ambulatory blood pressure monitoring; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; KQ = Key Question; HBPM = home blood pressure monitoring; HTN = hypertension; NA = not applicable; NPV = negative predictive value; OBPM = office-based blood pressure measurement; PPV = positive predictive value.

## Discussion of Findings

### BP Screening, CVD, and Mortality (KQ 1)

We found one trial addressing the overarching issue of whether BP screening reduces CVD and mortality in adults (KQ 1). This good-quality cluster RCT, conducted primarily in Canadians age 65 years and older, was a pharmacy-based screening program (CHAP) that included an on-call nurse to reassess high-risk participants and trained volunteer health educators to support self-management. The trial demonstrated that screening was associated with significant reductions in hospital admissions for acute MI. Moreover, a recent study has shown that CHAP can significantly reduce BP levels in participants with high BP at enrollment.209 While direct evidence of benefit is reassuring, the evidence is not clearly applicable to all age groups. Additionally, this trial employed support interventions that may confound the results of simple screening.

The Franklin County study conducted in rural Maine, although not included in this review (not an RCT), also screened for BP in the context of a community program integrated with primary medical care and educational, counseling, and tracking support.210 During the screening phase of the program, heart, coronary, and stroke death rates in Franklin County were significantly less than in one of two comparison counties not administering the program, and significantly less than in the state of Maine. Overall, while evidence addressing the overarching question is insufficient, it appears to be supportive of BP screening programs.

### Diagnostic Accuracy of Clinic-Based Measurement (KQ 2)

Evidence addressing the diagnostic accuracy of clinic-based BP measurements in a single visit was surprisingly sparse, due in part to our predefined requirement of an enrolled screening population. In addition, few studies reported necessary data to evaluate the diagnostic accuracy of specific BP measurement methods or protocols. Excluded studies either enrolled a predominantly hypertensive population undergoing treatment or only compared mean BP values obtained for cohorts measured with different methods or protocols. In the few included studies, oscillometric office BP measurements showed a range of sensitivity (51% to 68%) for elevated BP, defined by manual mercury sphygmomanometry, but more consistent specificity (97% to 98%) and PPV (76% to 84%). These data omit one study for which the manual reference standard was automated in a manner not routinely used in the clinic.107 Variation in sensitivity could reflect reference standard protocols and their effects on the patient and use of different oscillometric devices without clear documentation of their validity or calibration. Variable performance in automated BP devices is widely recognized, and reference listings of minimally valid instruments are in the public domain (www.dableducational.org).

Studies that also incorporated ABPM, which could be used as the better reference standard instead of auscultatory sphygmomanometry, did not clearly show advantage to either manual or automated OBPM, mainly because of the lack of sufficient studies and data.

We found only three diagnostic accuracy studies that examined the effects of all aspects of recommended protocols for OBPM. Again, this yield was likely limited by our requirement for enrollment of screening populations. In one study, a single BP measurement performed by a trained observer using a strict protocol had high sensitivity (0.95) but only moderate PPV (0.76) compared with the average of second and third measurements, which suggests that the main value of repeated measurements is in confirming initial elevated results.106 This study did not include a separate reference standard and all measurements were conducted by the same unblinded observer, according to protocol. Two small studies in normotensive subjects found that leg crossing elevated SBP and DBP measurements within the normal range and that caffeine ingestion falsely elevated BP measurements above the hypertensive threshold in 17 percent of participants. Although not extensive, these data confirm several recommended protocol approaches for accurate BP measurement.

Another recent systematic review examining the relative effectiveness of OBPM and HBPM compared with ABPM in the diagnosis of hypertension also found relatively few diagnostic accuracy studies (20 total) despite accepting nonprimary care settings, addressing high-risk populations in primary care, and not explicitly distinguishing initial screening studies from those confirming the diagnosis.211 Similar to our review, it had stringent criteria for quality and reporting data to allow calculation of diagnostic accuracy measures (i.e., sensitivity, PPV, specificity, NPV). It also found considerable clinical and methodological variability among studies, and each study was also limited by methodological weaknesses or poor reporting. Nonetheless, it similarly reported that OBPM was variably sensitive (38% to 80% for two or three measurements in a primary care/general population) and specific (84% to 98%), concluding that OBPM was not sufficiently sensitive and specific to perform as a single diagnostic test.212

We excluded a much larger body of evidence that compared different BP measurement methods or protocols by calculating mean BP values for a cohort measured with both methods, but did not provide information regarding diagnostic reclassification. Although these studies did not provide information on diagnostic accuracy, we discuss them briefly in order to ground the included studies in the larger body of available evidence.

While mean BP values varied between measurement methods when both automated oscillometric device and mercury sphygmomanometer measurements were taken in the same cohorts, these variations did not occur in a consistent pattern. Among 11 studies comparing mean BP values using different measurement methods, six reported lower mean levels of BP when measured by automated oscillometric devices compared with mercury sphygmomanometers.141, 213-217 Several studies, however, reported higher mean levels of BP132,218-220 or comparable BP221 when measured with automated versus mercury devices. Some of this variability may be related to variations in the algorithms oscillometric devices use to estimate SBP and DBP and lack of consistent validation. Because these devices are automated and can take several successive measurements without attendant medical personnel, they have the potential to reduce misclassification due to isolated clinic hypertension, correct errors in measurement technique such as rapid cuff deflation, and eliminate observer bias. However, it is important to base selection of oscillometric devices on rigorous independent validation and testing for accuracy in the widest possible variety of patients and practice settings.

Among excluded studies, several examined how the number of BP measurements conducted within a single session affected mean BP levels.132,222-225 Most studies of automated oscillometric devices found that the first BP measurement was higher than subsequent measurements, which suggests that the simple procedure of automatic cuff inflation may induce an initial increase in BP that subsides with longer duration of rest before measurement and as the subject becomes accustomed to the device. The moderately low PPV of a single measurement suggests that the same may be true of manual BP measurement.106 Two other studies of manual auscultatory measurement reported either higher first measurements213 or no difference between first and subsequent measurements.132 The duration of time required for BP to stop decreasing with subsequent measurements ranged from 6.5 minutes to 1 hour.226-228 BP was lower when measured in a nonclinical versus clinical setting,229,230 in a waiting versus examination room,229 and by a nurse versus physician.231,232

Among three studies that examined the mean BP effect of placing the cuff over a sleeve up to the thickness of a sweatshirt versus a bare arm, none showed a significant difference in BP.225,233,234 Fast cuff deflation was found to underestimate SBP and overestimate DBP.235 Higher BP was observed when small cuffs were used compared with larger cuffs,236-238 but studies disagreed about whether cuff looseness affected BP.225,239

There was disagreement about the prevalence of within-group BP differences in studies providing only cohort-level mean BP analyses, with two studies showing a high frequency of differences greater than 10 mm Hg240,241 and two studies showing little difference.242,243 Studies of arm position showed that BP taken in the upper arm was lower when the arm was supported at the level of the heart in about 50 degrees of shoulder flexion (at about the mid-sternum or the fourth intercostal space) than when the shoulder was in a neutral nonflexed position and the arm was resting alongside the body in a dependent position or supported by the arm of a chair.221,225, 244 In terms of the measuring environment, one study found higher BP when it was measured during talking versus no talking.225

Thus, included diagnostic accuracy studies of BP measurement protocols, supported by excluded mean BP comparisons from cohort analyses, support many aspects of the recommended protocol for BP measurement,245 except the requirement to place the cuff over a bare arm. The aspects of the recommended protocol for which evidence supports effectiveness include: 1) avoidance of caffeine ingestion before BP screening is performed, 2) seating the patient in a chair with the back supported and with both feet placed flat on the floor, 3) using a cuff that is properly sized for the patient’s arm circumference, 4) avoiding rapid cuff deflation, 5) avoiding talking during measurement, 6) positioning the arm so that the shoulder is flexed and the outstretched upper arm is supported at the level of the mid-sternum, rather than resting alongside the body or supported by a chair arm, and, to some extent, 7) resting prior to BP measurement.

### Measurement Methods and Prediction of CV Outcomes (KQ 3a)

Mercury sphygmomanometers, followed by aneroid sphygmomanometers, have long been the standard method for measuring BP in a clinical setting. Higher BP results measured with mercury sphygmomanometers are associated with increased vascular and overall mortality.6 More recently, nonoffice-based methods, such as ABPM, have been considered to provide more accurate prediction of long-term CV outcomes; ABPM has been identified in many clinical studies as the reference standard for BP measurement. To answer KQ 3, we addressed the ability of ABPM and HBPM results to predict long-term CV outcomes compared with standard office-based results. Based on the available evidence, we found that ABPM predicts long-term outcomes better than OBPM in comparative studies. As such, ABPM is the most accurate reference standard for confirming an initial elevated BP measurement.

Included studies approximately reproduced the previously reported association between OBPM (e.g., using a sphygmomanometer) and CV outcomes, although these studies were relatively small and risk estimates were low. Twenty-four-hour systolic ABPM, however, consistently and significantly predicted stroke and other CV outcomes independent of OBPM. Additionally, ABPM apparently has greater predictive value compared with OBPM. Diastolic results were similar although predictive value was attenuated. Because too few studies were available for each outcome category to conduct a meta-analysis, data synthesis was qualitative. While there were fewer data for cardiac, CHF, and all-cause mortality outcomes, 24-hour ABPM appeared to be less consistently predictive for these outcomes.

Results for daytime and nighttime ABPM appeared to follow the same prediction patterns as 24-hour ABPM, and an exploratory meta-analysis comparing these three protocols found no differences. One additional study, which we excluded because results were reported for categories of baseline BP level, also reported that daytime systolic ABPM was more predictive of all-cause mortality than OBPM, although only at higher levels of baseline BP.246 The available evidence does not permit any qualitative distinctions among the three ABPM protocols (24-hour, daytime, or nighttime).

While available data suggest that HBPM predicts outcomes similarly to ABPM and independently of OBPM, there were few studies reporting this data. We excluded an additional study because the results were reported for categories of baseline BP level. This study also identified HBPM as a better predictor of stroke and MI at lower baseline levels of BP compared with OBPM, but these differences were not significant.247 In general, data on HBPM were insufficient for firm conclusions regarding prediction of CV outcomes.248,249 Only one study compared ABPM with HBPM, which is insufficient for conclusions regarding the direct comparison of HBPM and ABPM for prediction of long-term CV outcomes.

The National Institute for Health and Care Excellence (NICE) previously compared ABPM, HBPM, and OBPM in an analysis of prognosis.250 We included seven of the 14 studies included in the NICE review in our review of prognosis, as well as eight additional studies, for a total of 15 studies. The NICE review included both meta-analyses and individual studies, with some overlapping populations. Our evidence review was limited to original studies, which we closely reviewed to avoid double counting for each outcome category. We also restricted the use of composite outcomes, which resulted in some study exclusions that were included in the NICE review. In addition, studies that reported predictive results only by categorized BP levels were not included in this review because of lack of comparability, but were included in the NICE review. Finally, we converted all HR results to consistent increments of expression for the BP predictor variable, which allowed direct comparison among studies. Despite some methodological differences between our reviews, the NICE report concluded that ABPM was most often the best predictor of clinical outcomes. With no clear data distinguishing among 24-hour, daytime, or nighttime ABPM, daytime ABPM was chosen pragmatically because it allowed for easy comparison with office-based or home BP measures. The report further stated that obtaining multiple BP measurements away from the clinic setting (potentially including HBPM, despite sparse data) is the best predictor of BP-related clinical outcomes. It also recommends offering ABPM (or HBPM if ABPM is declined or not tolerated) following an elevated BP measurement (≥140/90 to <180/110 mm Hg; any result above the latter threshold requires immediate medical attention),2 and recommended additional prospective studies comparing OBPM, HBPM, and ABPM.

Numerous IPD meta-analyses have addressed the predictive value of BP measurement methods. Five IPD meta-analyses reported that ABPM is a significant predictor of CV death.88-90, 95,96 Of these studies, three reported that ABPM was a better predictor than OBPM.89,90,95 In two of these IPD meta-analyses, nighttime ABPM was a better predictor of CV death than daytime ABPM in persons with or without a history of CVD.95,96 Another IPD meta-analysis, however, reported that whether daytime or nighttime ABPM was the better predictor depended on the outcome studied.87 One study reported a significantly greater risk for CV mortality in women than men using 24-hour ABPM,88 and daytime and 24-hour ABPM were better predictors of CV death in two studies using the same database.89,90 In general, these studies support the choice of ABPM (no specific protocol) as an appropriate reference standard for measurement of BP.251

### Diagnostic Accuracy of Confirming a Hypertension Diagnosis (KQ 3b)

We found that OBPM variably predicted true hypertension, as defined by the reference standard of ABPM (not distinguishing among 24-hour, daytime, or nighttime), and that ABPM confirmatory testing identified a significant proportion of persons with isolated clinic hypertension, ranging from as low as 5 percent to as high as 65 percent. When HBPM was used for confirmatory testing, the proportion ranged from 16 to 55 percent. For either confirmatory method, the high variability may be based on population characteristics that predict likely hypertension (older age, higher baseline BP) and the stringency of the protocol for initial office-based measurement. Several studies indicated that screening BP was based on repeat measurements taken at each visit and at more than one visit prior to confirmatory testing. Studies based on multiple initial screening measurements appeared to better confirm an initial elevated OBPM. However, this was contradicted by one study that formally evaluated multiple office-based measurements at two separate screenings, in which the second visit confirmed the initial elevation with a predictive value of only 58 percent.

The importance of confirmatory measurements depends on the long-term outcomes in persons whose initial elevated BP results are not confirmed (i.e., patients with isolated clinic hypertension). Therefore, we examined studies reporting long-term CV outcomes for results limited to this subpopulation. Although the evidence from seven studies is not consistently presented or directly comparable, it suggests that patients with isolated clinic hypertension have long-term outcomes more similar to those with normotensive BP than sustained hypertension. These limited data are generally consistent with other authoritative conclusions that persons with isolated clinic hypertension or normotensive BP have more similar CV prognoses than those with isolated clinic hypertension or sustained hypertension.252 Nonetheless, persons with isolated clinic hypertension have a higher risk for developing sustained elevated BP and should be monitored. We could make no distinction between using ABPM and HBPM to identify persons with isolated clinic hypertension and risk for long-term outcomes because only one study used HBPM.

Given the high degree of variability of OBPM to predict hypertension and the importance of distinguishing between persons with higher and lower risk for long-term CV outcomes, confirmatory measurement is needed for persons with initial elevated BP. This appears to be particularly true for those with screening BP levels nearer the threshold for diagnosing hypertension. ABPM has the largest evidence base supporting prediction of long-term CV outcomes and, thus, the most supportive evidence as a confirmatory test. HBPM may also be a satisfactory confirmatory test, but its evidence base for predicting long-term CV outcomes is much smaller, with too few studies for each type of outcome. ABPM provides multiple measurements over time in a nonmedical setting, potentially avoiding the white coat effect. In the absence of ABPM for confirmation, additional OBPM may improve diagnostic accuracy, especially if repeated within a single visit and across multiple visits. As noted, automated OBPM, using a valid device, can provide multiple accurate measurements without the need for attendant health care personnel, which may mitigate the white coat effect. This is consistent with JNC 8 recommendations on the use of oscillometric methods (when properly calibrated and validated) or two to three carefully performed manual measurements.8

The overall clinical value of confirmatory testing is avoiding misdiagnosis in normotensive persons who have isolated clinic hypertension in medical settings, which would avoid the harms of unnecessary treatment. In a large cohort of Spanish patients, for example, resistant hypertension (defined as persistent OBPM >140/90 mm Hg and treatment with three or more antihypertensives, including a diuretic) was fairly common (12.2%). Based on ABPM, more than one third (37.5%) of these patients were found to have isolated clinic hypertension.253

### Rescreening Interval (KQ 4)

As shown in the Analytic Framework, persons who are screened and found to have BP levels within normal limits cycle back to the beginning of the screening process. The appropriate interval for the next screening visit (rescreening), however, is not clearly evidence-based. We summarized studies that followed screened, normotensive persons over time and reported incident hypertension at rescreening intervals up to 6 years (KQ 4). We found that estimates of hypertension incidence following a normal BP level were highly variable, ranging from 2.5 to 4.4 percent at 1 year, 1.2 to 12.3 percent at 2 years, and 6.6 to 24.9 percent at 3 years. Point estimates and ranges were similar at 3, 4, and 5 years. Studies that required confirmation of elevated BP measurements at rescreening confirmed fewer than half of initial cases, suggesting that confirmatory measurement at rescreening may reduce misdiagnosis and overtreatment.

Risk for incident hypertension varies by population subgroups as well as rescreening interval. A recent meta-analysis of risk prediction models for hypertension found that age, sex, BMI, baseline BP, and cigarette smoking were the most common predictors.254 In general, our findings on incident hypertension rates at rescreening identified similar subgroups and are consistent with data showing that hypertension is more prevalent in older adults, men, and African Americans.19 It is important to recognize that hypertension is more prevalent in men than women before age 65 years. In older age groups, however, it is more prevalent in women.19 Included studies likely do not reflect this because the mean age was typically well below 65 years and study age ranges often did not include participants older than 69 years, where reported. While our review included only one study reporting on the incidence of hypertension in Hispanics, U.S. population data suggest that the prevalence is similar to that of non-Hispanic whites.255

Our findings are consistent with international prevalence data that BMI has a strong influence on the incidence of hypertension.256 Our finding of lower incidence of hypertension in current smokers, who tend to have lower weight and BMI than nonsmokers or former smokers,257 is also consistent with a cross-sectional study conducted in the German general population on the epidemiological relationship between smoking and hypertension. The authors reported no association between never or former smokers and hypertension among persons of normal weight, but reported strong associations between obese former smokers and normal weight current smokers.258

Our data also confirm that any BP above the optimal level of less than 120/80 mm Hg conferred a graded risk, with those closest to the threshold for a diagnosis of hypertension (i.e., those with high-normal BP of 130–139/85–89 mm Hg) having the highest incidence. These findings are supported by incidence rates in the untreated group of the Trial of Preventing Hypertension study, which found that about 40 percent of participants with high-normal BP progressed to hypertension at 2 years and 63 percent at 4 years.259 This was a placebo-controlled trial investigating whether pharmacological treatment of high-normal BP prevents or postpones hypertension. It was not included in our review because we did not consider hypertension intervention trials.

Based on higher incidence of hypertension in subpopulations at high risk for incident hypertension, ensuring rescreening at short-term intervals in particular groups is prudent, especially in older adults (particularly if age ≥60 years), persons with BP greater than 120/80 mm Hg (particularly if >130/85 mm Hg), overweight persons (particularly if obese), and African Americans. Adults ages 18 to 40 years with no other risk factors have a low incidence of hypertension (e.g., about 1% to 6% at 2 years, without confirmation of initial BP). We found only one study that examined a rescreening interval shorter than 1 year.155 Although only two organizations recommend screening for high BP at all health care visits (one in ages 18 to 21 years and one in all adults),260,261 national data show that BP is measured at nearly 60 percent of all adult clinic visits in the United States.21 With an average of 1.8 primary care visits per person per year in the United States and an average of 90.8 percent of all adult primary care provider visits recording BP, overscreening is clearly possible, particularly in low-risk persons.21 If this is the case, then available time and resources might be better directed toward improved measurement accuracy in higher-risk persons.

Clinic-based BP measurements must be taken accurately to avoid misclassification and potential overtreatment or undertreatment at any visit.41 Newer methods of BP measurement are available that may improve current levels of diagnostic accuracy by reducing observer error, reducing the white coat effect, and increasing the aggregate number of measurements. These include automated methods for clinical settings, such as HBPM and ABPM.

### Harms of Screening (KQ 5)

Evidence from four studies indicated no changes in psychological distress or quality of life before versus after persons were labeled as hypertensive or prehypertensive. One study documented increased absenteeism due to illness after persons were labeled as hypertensive that remained significant for up to 4 years. Four studies addressed the comfort and convenience of ABPM devices, consistently reporting poor sleep quality and minor physical reactions. Tolerability of the device was correlated with an overall health assessment in one study. In general, the direct evidence on harms of screening is inconsistent, and any harms appear to be relatively minor.

As noted in the discussion of KQ 3b, some persons with an elevated BP measurement who are not confirmed with an additional BP measurement may be misdiagnosed and could suffer the more serious harms of unnecessary treatment. Therefore, we emphasize the need for confirmatory testing to avoid such harms.

## Limitations of the Review

We excluded revascularization and angina from individual or composite prognostic outcomes. Angina alone, as opposed to hospitalization for angina, is not included in the Clinical Trials Initiative “Standardized Definitions for End Point Events in Cardiovascular Trials.”262 Revascularization outcomes are subject to numerous limitations, including variation in procedures, substantial practice variation, and mixed evidence on the appropriate use of these procedures. Reports have shown a five-fold variability in population-based rates of coronary artery bypass grafts in the Medicare population,263 as well as hospital-to-hospital variation in percutaneous coronary interventions.264 There are also concerns regarding the appropriate use of these interventions in nonacute settings.264-266 Leape and colleagues have noted substantial variation in the interpretation of coronary angiography; such disparities can lead to overuse of coronary artery bypass grafts and percutaneous transluminal coronary angioplasty.267 Both outcomes were included in many study composite outcomes, however, making those studies ineligible for this review (Appendix Table 1). As a result, many of our remaining eligible composite outcomes included only fatal events. This does not affect the value of the prognostic outcome assessments, primarily for KQ 3a, but likely enhances their precision and validity by removing outcome measurement variability. This requirement, however, limited the number of studies we could include, and our findings do not represent the full range of nonfatal CV events.

For KQ 3a, we did not conduct a new literature search specific for the prognosis of persons with isolated clinic hypertension. As noted in the discussion, our findings are generally consistent with other recent evidence-based guidance.

For KQ 3b, we did not address the reproducibility of isolated clinic hypertension (either by home or office methods) over a short time frame following the initial diagnosis. Studies included for KQ 3b enrolled some patients who may have been treated with antihypertensive medications and who had stopped treatment for a washout period of at least 2 weeks prior to BP measurement. It is possible, however, that the lingering effects of the medication could have altered results. We determined that only six of 26 included studies allowed treated patients with a washout period. Of these, one study stipulated a washout period of 2 weeks, another study stipulated 3 weeks, three studies required 4 weeks or longer, and another study required 24 weeks. Thus, any effect is likely to be minimal.

For KQ 4, the best evidence on rescreening intervals came from studies that evaluated participants at specific time intervals and reported incidence of new hypertension cases at that interval (e.g., the study by Dernellis and colleagues160). Some studies evaluated patients across a range of time, but reported only the mean or median followup without reporting the range. For these studies, it is not clear where along the spectrum of followup the incident cases actually occurred, and the interval assignment is somewhat inaccurate.

Some experts consider dipping versus nondipping status to be an important predictor of CV events.268 Others have reported that it adds little to the prognostic value of 24-hour BP.47 Moreover, it is not clear that dipping is a stable characteristic.48 We did not systematically review this literature.

## Limitations of the Body of Evidence

Despite recent emphasis on the instability of single BP measurements and the need for multiple, valid measurements to assess a patient’s actual elevated BP exposure, high-quality comparable diagnostic accuracy studies are not common. Given recent recognition of the impact of overdiagnosis in many diseases, the widespread availability of automated BP devices with variable performance, and the prevalence of essential hypertension in the United States, further research to guide primary care clinicians and consumers would be beneficial.

## Future Research Needs

Self-use BP kiosks placed in community settings, such as pharmacies and grocery stores, are frequently used by the general public. Kiosks are not regulated by the FDA, and a recent survey of seven leading North American manufacturers of BP kiosks reported that only one had satisfactory validation data.269 A report by the Canadian Agency for Drugs and Technologies in Health found no systematic reviews, meta-analyses, or RCTs of BP kiosks and only one North American guideline that incorporated information on BP kiosks.270 The report concluded that very little data were available to support the use of BP kiosks and their results are considered too variable and insufficiently researched to be incorporated into guidelines. One validation study reported results within the AAMI SP10 accuracy and reproducibility standards,271 while another validation study of a different device reported acceptable reproducibility but unacceptable SBP accuracy.272 A third study found acceptable accuracy only in persons with medium arm sizes. Persons with small or large arm sizes had BP results that were overestimated or underestimated, respectively.273 One study addressed the characteristics of kiosk users by conducting a cross-sectional survey of adult patients seen in a primary practice network of clinics within a 4-week period.274 The questionnaire response rate was 76 percent out of a random sample of 700. Sixty-three percent of respondents checked their BP at locations other than their physician’s office or at home. Of these, about two thirds used pharmacy kiosks. Respondents ages 45 to 65 years were more likely to use kiosks than those older than 65 years, and were more likely to have a high school education but no advanced education. Persons with diabetes, heart disease, or a history of stroke were not more likely to use kiosks. Results were similar for persons taking antihypertensive medications. Finally, one study reported the results of a community-based program for hypertension detection using open-access kiosks placed in low socioeconomic areas of Exeter, Devon, United Kingdom.275 Authors followed up with all users with an Exeter address and, if permission was granted, accessed their medical records. Overall, the program detected new hypertension cases in 1.4 percent of 58 responders (out of 122 with an Exeter address). Contrary to the intent of the program, the study found that there was preferential use of the kiosks by persons with an existing diagnosis of hypertension.

The availability of protocols other than lengthy confirmatory BP measurement (e.g., ABPM) for identifying patients who are likely to have isolated clinic hypertension would be helpful for primary care and BP screening programs. One study reported on the development and testing of a screening tool to identify rural and nonrural patients at risk for the white coat effect.276 The development cohort included 36 hypertensive or borderline hypertensive adults and the testing cohort included a sample of 104 patients. The screening tool was not predictive of systolic or diastolic white coat effect. No other tools for identifying isolated clinic hypertension were noted for this report.

High-quality studies are needed to confirm the best office-based protocols for initial screening and the most applicable and efficient postscreening confirmatory diagnostic methods for different levels of elevated BP and patient subgroups. Ideally, all studies would use ABPM as a reference standard.

In lieu of prospective diagnostic accuracy studies to compare office-based protocols for initial screening, consideration of published diagnostic accuracy studies and protocol comparison studies that enrolled treated hypertensive patients is needed. If deemed appropriate, these may substantially augment the evidence for KQ 2, which was limited in this review to screening populations only.

Identification of an ABPM standard allows investigation of literature comparing HBPM and ABPM and defining the characteristics of the best HBPM protocol—for example, whether there is any advantage to measuring BP in both the morning and evening versus one or the other, the optimal number of days to measure BP, or whether the first day of measurements should be discarded.

Further research is needed to predict future hypertension and CVD, including among the treatment-resistant segment of the hypertensive population. Standardized reporting of these outcomes is also needed.

Research is also needed on alternative methods to validly confirm hypertension diagnosis in screen-detected patients.

This review focused on brachial measures of central BP, as these are most commonly used in primary care settings. There are new devices and techniques available to noninvasively measure BP (e.g., central vascular pressure by applanation tonometry, pulse wave analysis), and some evidence suggests that these provide better prognostic data.277 However, accuracy and reproducibility may need improvement.278 These methods can also be used to calculate arterial stiffness, which may also improve predictive value.279,280 High BP variability has also been associated with poorer CV outcomes.281,282 Another form of new technology is conventional BP measurement using a wireless brachial BP monitor that connects to a smart phone via the Internet to save results for trend analysis and/or export to health care providers. Whether and how to incorporate these new devices and measurements into primary prevention requires further analysis.

AF occurs in 1 to 2 percent of the general population, particularly the elderly, and often coexists with hypertension, both of which are strong risk factors for stroke. Single BP measurements in patients with AF are prone to systematic error due to increased beat-to-beat variability. Automated measurement methods, including ABPM, may address this problem, but evidence is scarce because patients with AF are usually excluded from studies.283 Current guidelines recommend repeated auscultatory measurements in patients with AF, but question the accuracy of automated oscillometric devices, although without evidence-based review.284 A recent meta-analysis of the small number of studies of automated BP measurement in patients with AF suggests that oscillometric methods may in fact be accurate, particularly for SBP (but may overestimate DBP), and be acceptable for home and ambulatory use, although not recommended for clinical settings.285 More information is needed on the accuracy and reproducibility of both manual and automated devices, including ABPM, in patients with AF.

Recently, embedded algorithms for detecting asymptomatic AF have been developed for some automated BP devices for use in general screening, including ABPM devices. At least five studies have evaluated the diagnostic accuracy of automated BP devices for home use with the AF detection algorithm—four by testing the device in a clinical setting and one at home. Results have been evaluated as satisfactory.284 The NICE Medical Technology Guidance Committee evaluated the WatchBP® Home A device (Microlife, Tampa, FL), an oscillometric BP monitor that also detects pulse irregularity by means of an embedded algorithm. The device may also be used for 24-hour ABPM. Clinical evidence was based on five studies conducted in a hospital setting and focused mainly on the diagnostic accuracy of the device in detecting AF. Evidence that the device could detect AF in persons undergoing 24-hour ABPM was limited to a small case-series and an unpublished study. The NICE Committee recommended AF screening with the device in a primary care setting under the supervision of a clinician in patients with suspected hypertension or those being screened or monitored for hypertension. The Committee considered potential benefits to be an increase in the rate of detection and a reduction in stroke incidence, although there were limited data to support clinical utility. The totality of the available evidence for automated devices requires evaluation, including use of ABPM for screening for AF.

Finally, BP trajectories throughout young adulthood may better predict risk for coronary artery disease in middle age and potentially long-term CV outcomes.286

## Conclusion

ABPM (24-hour, daytime, or nighttime) is a better predictor of long-term CV outcomes than OBPM (manual sphygmomanometry) and should be considered the reference standard for evaluating noninvasive BP measurements. A small body of evidence suggests, but does not confirm, that HBPM can similarly predict outcomes. Initial screening with office-based methods (manual sphygmomanometry or automated oscillometric methods) variably predicts hypertension, as defined by ABPM, resulting in a significant population with isolated clinic hypertension. Limited evidence suggests that persons with isolated clinic hypertension have outcomes more similar to normotensive than hypertensive persons. Failure to confirm initial elevated OBPM results may result in misdiagnosis and overtreatment. Limited evidence suggests that repeated measurements and improved procedural control (e.g., automation) may improve the diagnostic accuracy of OBPM when used to screen for high BP or confirm hypertension. Studies of rescreening intervals at up to 6 years found a higher incidence of hypertension overall and at shorter intervals for persons with BP in the high-normal range, older adults, persons with an above normal BMI, and African Americans. These studies showed much lower incidence at longer rescreening intervals (up to 6 years) in persons without these risk factors.