# Results

## Literature Search

We reviewed 19,309 abstracts and 1,171 full-text articles. This review included 96 studies that were reported in 152 publications (Appendix A Figure 1). We identified one trial examining the benefits of screening for high BP (KQ 1),104 seven studies examining the diagnostic accuracy of clinic-based BP measurements and protocols (KQ 2),105-111 15 studies examining the predictive value of clinic-based and other BP measurements (i.e., ABPM and HBPM) (KQ 3a),112-126 27 studies examining the diagnostic accuracy of other BP measurement methods (KQs 3b and 3c),114,127-152 40 studies evaluating rescreening for high BP in adults (KQ 4),144,153-191 and nine studies examining the harms of screening for high BP (KQ 5).192-200

## KQ 1 Does Screening for High BP Reduce CVD and Mortality in Adults Age 18 Years or Older?

We identified one good-quality cluster RCT (39 clusters; n=140,642) of a BP screening program that reported eligible CV outcomes (Appendix C Tables 1–3).104 Clusters were randomly assigned to the Cardiovascular Health Awareness Program (CHAP) or no intervention. The CHAP intervention was a Canadian community-based program for CV risk assessment and education targeted at adults age 65 years or older. Although CHAP included other elements of risk assessment, BP was the primary component of the intervention and was the only measured biological characteristic, which makes this study eligible for inclusion.

The CHAP intervention involved community pharmacy-based BP screenings using an automated instrument (BpTRU®, VSM MedTech, Coquitlam, BC) and risk profiles conducted by interview over a period of 10 weeks. Results from screenings were rank-ordered by SBP within diagnostic groups and provided to family physicians. An on-call nurse reassessed participants identified as high-risk (i.e., SBP of 180 or DBP of 110 mm Hg). Trained volunteer health educators also provided participants with educational materials and resources to support self-management. This study was conducted in community residents age 65 years or older (mean age, 74.8 years), of whom 57.2 percent were women. Twelve percent of the participants had a previous history of CHF and 22 percent had diabetes. Although the latter slightly exceeded the acceptability limit of our inclusion criteria (20%), the deviation was minor.

This study’s primary outcome was a composite of hospital admissions for acute MI, CHF, or stroke in all community residents age 65 years or older in the year before versus after implementation of the intervention. CHAP resulted in a statistically significant 9-percent relative reduction in the number of hospital admissions for composite events (rate ratio, 0.91 [95% CI, 0.86 to 0.97]; p=0.002). In absolute terms, there were 3.02 fewer annual hospital admissions for CVD per 1,000 persons in the intervention group compared with the group that did not receive the intervention. When analyzed by number of unique persons admitted to the hospital (not counting additional admissions for more than one event per person), there were fewer composite events, acute MIs, and CHF admissions in the intervention group. The reduction in acute MI was marginally statistically significant (rate ratio, 0.89 [95% CI, 0.79 to 0.99]; p=0.03). While the secondary outcomes—all-cause mortality (33.98 vs. 34.55) and in-hospital CV mortality (3.88 vs. 4.66)—showed lower rates per 1,000 in the intervention group, the reductions were not significant (p=0.38 and 0.06, respectively). The number of participants who initiated antihypertensive treatment was 10 percent higher in the intervention group than in the group that did not receive the intervention (95% CI, 1.02 to 1.20; p=0.02).

## KQ 2 What Is the Best Way to Screen for High BP in Adults in the Primary Care Setting?

We identified seven fair- to good-quality studies examining the diagnostic accuracy of OBPM devices (k=4; n=2,528)105,107-109 or protocols (k=3; n=20,253) (Appendix C Tables 4–9).106,110, 111

## KQ 2a How Accurate Are Clinic-Based BP Measurement Methods in Provisionally Diagnosing Hypertension Within a Single Visit?

Initially, we only included studies comparing manual versus automated OBPM for diagnosing hypertension in adult screening populations. The manual device was chosen as the reference standard. Studies were required to provide diagnostic accuracy data or characteristics rather than mean BP comparisons. We found four fair- to good-quality studies providing evidence on sensitivity, specificity, and predictive value (Table 5).105,107-109 Three of the four studies used a threshold of 140/90 mm Hg or greater to define hypertension; the other study used a higher threshold (≥160/95 mm Hg). Studies did not use a consistent reference standard for hypertension diagnosis and used different comparator devices. Sensitivity ranged from 51 to 91 percent, although specificity and predictive value were in closer agreement.

Table 5 Diagnostic Accuracy of Automated vs. Manual OBPM Devices

Author, Year Quality | n | Population | Mean Age (y) | % Female | Mean Office SBP/DBP (mm Hg) | Definition of BP | Diagnostic Threshold | Sens (calc) | Spec (calc) | PPV (calc) | NPV (calc) | Manual BP Device | Automated BP Device
Kroke, 1998^107^ Good | 399 | Women (ages 35-65 years) and men (aged 40-65 years) | NR | 64.4 | 139.2/86.4 | Mean of second and third BP measurement | ≥160/95 mm Hg | 0.907 | 0.960 | 0.880 | 0.970 | BOSO Roid II Aneroid | BOSO Oscillomat
Lim, 2013^108^ Good | 454 | Age ≥20 years | 50.7 | 52.8 | 117.3/75.3 | Mean of second and third BP measurement (assumed) | ≥140/90 mm Hg | 0.590 | 0.982 | 0.837 | 0.939 | Mercury | A&D UA-767PC
Ostchega, 2010^105^ Good | 509 | Adults age ≥18 years meeting the inclusion criteria set by the AAMI | 49.4 | 39.5 | 122.3/69.8 | Mean of first, second, and third BP measurement | ≥140/90 mm Hg | 0.679 | 0.959 | 0.792 | 0.929 | Mercury | OMRON HEM-907XL
Pavlik, 2000^109^ Fair | 1166 | Patients presenting to the ER or medical clinic during study days | 48.5 | 59.9 | 129.5/79.6 | Single BP measurement | ≥140/90 mm Hg | 0.509 | 0.972 | 0.761 | 0.918 | Mercury | Critikon Dinamap Plus Model 8710 or 1846SX

Abbreviations: AAMI = Association for the Advancement of Medical Instrumentation; BP = blood pressure; calc = calculated; DBP = diastolic blood pressure; ER = emergency room; NPV = negative predictive value; PPV = positive predictive value; SBP = systolic blood pressure; sens = sensitivity; spec = specificity; y = years.

One good-quality study compared a manual anaeroid sphygmomanometer with an automated oscillometric device in 399 middle-aged men and women from the population-based European Prospective Investigation into Cancer and Nutrition-Potsdam Study.107 Participants were randomly selected, with oversampling of those with higher BP. One trained observer performed three auscultatory measurements 2 minutes apart using the aneroid device; these measurements were performed simultaneously with the oscillometric measurement by connecting both devices to a single cuff with a T-tube. Cuff inflation and deflation were controlled by the automated device. Using the anaeroid measurement as the reference, sensitivity of the oscillometric device was 91 percent, specificity 96 percent, PPV 88 percent, and NPV 97 percent. This study’s limitations include the use of a higher than usual threshold for classifying hypertension (SBP ≥160 mm Hg or DBP ≥ 95 mm Hg) and automated inflation and deflation of the (usually) manual sphygmomanometer cuff by the oscillometric device. This unique feature of the study design may have minimized human error in the manual anaeroid measurement.

Two good-quality studies compared a manual mercury sphygmomanometer with an automated oscillometric device in 454 Korean men and women ages 20 to 95 years108 and 509 adults recruited from the 2006 and 2007 NHANES.105 Diagnostic accuracy results were somewhat similar (sensitivity, 59% and 68%; specificity, 98% and 96%; PPV, 84% and 79%; NPV, 94% and 93%, respectively). These studies also provided similar kappa results for manual versus automated methods (0.68 for the NHANES study105 and 0.65 for the Korean study108 [95% CI, 0.5436 to 0.7641]; p<0.0015).

A fourth fair-quality study compared a mercury sphygmomanometer with an automated oscillometric device in the emergency room and general medicine clinic at an urban hospital.109 Sensitivity of the oscillometric device was 51 percent, specificity 97 percent, PPV 76 percent, and NPV 92 percent. Although this study used three different oscillometric devices with no attempt to ensure comparability or validity among them, the results may be generalizable to a typical practice setting.

The results of KQ 3a indicate that ABPM is a better reference standard than manual sphygmomanometry. Thus, a better study design would compare manual versus automated OBPM using ABPM as the reference standard. We found three studies with this design132,141,150 among those included for KQ 3b and evaluated them for KQ 2a. Results were limited since all enrollees had an elevated OBPM per inclusion criteria. One study only presented kappa statistics, reporting a kappa of 0.44 for the comparison of systolic manual OBPM versus ABPM and 0.25 for systolic automated OBPM versus ABPM.132 Calculated PPV was 0.78 and 0.93 for the two comparisons, respectively, in the second study,141 and 0.39 and 0.58 in the third.150 Thus, reference to ABPM does not clearly favor either manual or automated OBPM in these few studies.

## KQ 2b What Screening Protocol Characteristics Within a Single Visit Define the Best Diagnostic Accuracy?

Although we searched for evidence on any aspect of BP measurement protocol (e.g., resting time before measurement, number of measurements, time between measurements, body position, setting), the stringency of our predefined criteria, which limited studies to those enrolling untreated screening populations, resulted in few included studies. Only three fair- to good-quality studies provided evidence on using variations in office-based screening protocols for diagnosing hypertension in adults not on antihypertensive treatment (Table 6).106,110,111 All included studies used a threshold of SBP ≥140 mm Hg or DBP ≥ 90 mm Hg to define hypertension.

Table 6 Diagnostic Reclassifications of OBPM Protocol Characteristics

Author, Year Quality | N | Population | Mean Age (y) | % Female | Mean Office SBP/DBP (mm Hg) | Diagnostic Threshold | Comparison | Diagnostic Reclassification | BP Measurement Device
Peters, 1999^110^ Fair | 50 | Normotensives | 25.1 | 54 | 105/59 | ≥140/90 mm Hg | Legs crossed vs. legs uncrossed | None | Omron HEM 706^*^
Pincomb, 1996^111^ Fair | 48 | Healthy white men ages 20-39 years, caffeine use (50-800 mg/day) within 30% of normal weight according to Metropolitan Life Insurance Company norms, no aerobic functional impairment during exercise | NR | 0 | NR/NR | ≥140/90 mm Hg | Caffeine vs. no caffeine | 17% reclassified as hypertensive with caffeine | Dinamap Vital Signs Monitor model 1896
Handler, 2012^106^ Good | 20,155 | Adults age ≥18 years in NHANES 1999-2008 with three BP measurements (all participants excluding treated hypertensives) | 45.3 | 51.42 | 124.3/72.1 | ≥140/90 mm Hg | 1 reading vs. 1+2 readings | 20.0% Stage I hypertensives reclassified as normal | Mercury
Handler, 2012^106^ Good | 20,155 | Adults age ≥18 years in NHANES 1999-2008 with three BP measurements (all participants excluding treated hypertensives) | 45.3 | 51.42 | 124.3/72.1 | ≥140/90 mm Hg | 1 reading vs. 1+2+3 readings | 27.5% Stage I hypertensives reclassified as normal | Mercury
Handler, 2012^106^ Good | 20,155 | Adults age ≥18 years in NHANES 1999-2008 with three BP measurements (all participants excluding treated hypertensives) | 45.3 | 51.42 | 124.3/72.1 | ≥140/90 mm Hg | 1 reading vs. 2+3 readings | 35.5% Stage I hypertensives reclassified as normal | Mercury

* Device validation reported in study.

Abbreviations: BP = blood pressure; calc = calculated; DBP = diastolic blood pressure; NHANES = National Health and Nutrition Examination Survey; NR = not reported; SBP = systolic blood pressure; y = years.

One very large good-quality study compared the effect of one versus multiple BP measurements on the diagnostic accuracy of auscultatory BP measurement performed by trained physicians using mercury sphygmomanometers in the NHANES population in 1999 to 2008.^106^ Three measurements were performed according to a standardized protocol in 20,155 adults. Among 3,454 participants with Stage I hypertension according to the first BP measurement, 20.0 percent were reclassified as normal when the mean of the first two BP measurements was used to diagnose participants, 27.5 percent were reclassified using the mean of all three BP measurements for diagnosis, and 35.5 percent were reclassified using the mean of the second and third BP measurements for diagnosis. A limitation of the results is potential bias due to lack of observer blinding. In addition, because BP measurement was performed using a carefully controlled protocol, the results may not apply in ordinary practice settings.

A fair-quality study examined the effect of leg crossing on the accuracy of BP measurement in 50 normotensive men and women with baseline BP far from the diagnostic threshold.110 A blinded observer recorded BP measured 5 minutes after subjects assumed three leg positions in random order: feet flat on the floor, legs crossed at the knee, and ankle resting on the opposite knee. None of the subjects were reclassified as hypertensive. This study’s primary limitations were low power and the potential selection of a sample that does not represent a typical screening population.

A fair-quality study compared BP following double-blind administration of oral caffeine (3.3 mg/kg, equivalent to two or three cups of coffee) or placebo in 47 healthy male volunteers who habitually consumed caffeine.111 After overnight caffeine abstinence, three BP measurements were taken with an automated oscillometric device at 2-minute intervals before and 40 minutes after ingestion of placebo or caffeine. Baseline BP was less than 140/90 mm Hg in all participants, but eight (17%) had BP in the hypertensive range (SBP ≥140 mm Hg or DBP ≥ 90 mm Hg) after administration of caffeine. These eight participants constituted 33 percent of the 24 subjects who had baseline BP of 135/85 to less than 140/90 mm Hg. Participants who received placebo remained normotensive. This study’s key limitation was that it included only a homogeneous population of young Caucasian men and, as such, does not represent the range of responses that might be seen in a screening population.

## KQ 3 What Is the Best Way to Confirm Hypertension in Adults Who Initially Screen Positive for High BP?

We identified 40 fair- to good-quality studies examining the prognostic value (k=15; n=29,142)112-126 and/or the diagnostic accuracy of BP measurement methods used to confirm the diagnosis of hypertension (k=27; n=17,233).114,127-152 Study details and results are provided in Appendix C Tables 10–34.

## KQ 3a How Well Do HBPM and ABPM Methods Predict CV Events Compared With Clinic-Based Methods? What Confirmation Protocol Characteristics Define the Best Prediction of CV Events? Which Methods and Associated Protocols Best Predict CV Events?

For KQ 3a we sought to identify the BP measurement method category that best predicts long-term CV, stroke, cardiac, and all-cause mortality events. We then used the method identified as the best predictor as the reference method for consistent evaluation of diagnostic accuracy studies of BP measurement methods in KQs 3b and 3c.

Ten good-quality112,113,115,117,120,121,123-126 and five fair-quality114,116,118,119,122 studies met the inclusion criteria for this KQ (Appendix C Tables 10–12). None were conducted in the United States; most were conducted in Europe and some in Japan. Spacelabs ABPM devices (Spacelabs Healthcare, Snoqualmie, WA) were the most commonly used and cited models and are still available in the United States. Studies used other ABPM devices that have subsequently been discontinued, but at the time of use appear to have been validated against at least one of the recognized protocols. Studies used HBPM devices exclusively manufactured by Omron (Omron Healthcare, Lake Forest, IL). While some models have been discontinued, similar Omron devices are currently available in the United States.

One included study was conducted in countries in western and eastern Europe.126 Studies used a prospective cohort design, and one study followed a cohort of participants in a placebo-controlled RCT taking a calcium channel blocker as an antihypertensive to compare the prognostic significance of OBPM and ABPM.126 For this study, we abstracted combined (placebo and treatment arms) results, as these are more representative of a general population, a significant proportion of which would be treated over time.

A total of 26,132 participants were characterized at baseline. The percentage of participants diagnosed with hypertension at baseline ranged from 15 percent124 to 100 percent113-116,122,126 and was not reported in four studies.119,120,123,124 The percentage of participants treated with antihypertensive medication at baseline ranged from 0 to 100 percent, with one study not reporting.120

Included studies compared the prognostic value of different methods of measuring BP at baseline by following patients over time for major CV, stroke, cardiac events, and all-cause mortality events and reported HRs by measurement method. HRs were adjusted for relevant covariates in regression models and preferably included the comparative method as a covariate to determine if one method had additional prognostic value beyond its comparator. Items reported as covariates tended to be similar across studies, always including age, sex, and smoking and usually including BMI, diabetes, cholesterol levels, and previous history of CVD.

Table 7 shows the number of studies reporting various BP measurement method comparisons and the outcomes these studies addressed. It does not include the two studies reporting the cardiac end points of fatal/nonfatal CHF, fatal/nonfatal MI, and sudden death, which were grouped together.116,126 It also does not show one study that reported CHF outcomes.121

Table 7 Number of Included Studies Reporting Eligible Outcomes for Key Question 3a

Comparison | k | All-Cause Mortality | | | | CV Mortality | | | | CV Events | | | | Fatal or Nonfatal Stroke | | | | Cardiac Events
Comparison | k | Systolic | | Diastolic | | Systolic | | Diastolic | | Systolic | | Diastolic | | Systolic | | Diastolic | | Systolic | | Diastolic
Comparison | k | A | U | A | U | A | U | A | U | A | U | A | U | A | U | A | U | A | U | A | U
ABPM (24-hr) vs. OBPM | 9 | 4 | 4 | 3 | 3 | 5 | 4 | 3 | 2 | 2 | 2 | 2 | 2 | 5 | 2 | 3 | 0 | 2 | 2 | 1 | 1
ABPM (daytime) vs. OBPM | 10 | 3 | 4 | 2 | 3 | 3 | 2 | 2 | 2 | 4 | 4 | 4 | 4 | 4 | 2 | 3 | 0 | 2 | 2 | 1 | 1
ABPM (nighttime) vs. OBPM | 9 | 3 | 4 | 2 | 3 | 3 | 2 | 2 | 2 | 3 | 3 | 3 | 3 | 4 | 2 | 3 | 0 | 2 | 2 | 1 | 1
HBPM vs. OBPM | 5 | 1 | 3 | 1 | 3 | 1 | 2 | 1 | 2 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0
ABPM (daytime) vs. HBPM | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
ABPM (nighttime) vs. HBPM | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
ABPM (daytime) vs. ABPM (nighttime) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
ABPM (nighttime) vs. ABPM (daytime) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

Note: Clement 2003 is not in the stroke plot, as it provides a p-value rather than hazard ratio for the between-group comparison; Hansen 2005 does the same for all-cause mortality.

Abbreviations: APBM = ambulatory blood pressure monitoring; A = adjusted for comparison blood pressure measurement; CV = cardiovascular; HBPM = home blood pressure monitoring; U = unadjusted for comparison blood pressure measurement.

### ABPM vs. OBPM

#### Summary of Findings

Eleven studies compared ABPM with OBPM (Appendix C Tables 10–12).114-122,125,126 Studies used various ABPM protocols, including 24-hour ABPM,115,116,118,119,121,122,125,126 48-hour ABPM (one study, combined with 24-hour ABPM for analysis),120 daytime ABPM,115-117,119-122, 125,126 and nighttime ABPM.115-117,119-122,125,126 These time periods were either specifically derived from patient diaries or were predetermined in each study protocol. Twenty-four-hour ABPM, daytime ABPM, and nighttime ABPM were considered separate measurement protocols for comparison with OBPM and for analysis.

Each 10-mm Hg increase in systolic ABPM at baseline, controlling for OBPM, was associated with a moderately increased risk (in most cases statistically significant) for fatal and nonfatal stroke or CV events in 11 good- or fair-quality studies. No summary meta-analysis estimates of risk were generated because of the small number of studies for each outcome (two to seven studies), variability in how outcomes were reported across studies (e.g., fatal vs. fatal or nonfatal stroke), and variability in study size by as much as a factor of six. Nevertheless, these results are consistent and within a small range of HR values. An exploratory meta-analysis to compare ABPM protocols showed that estimates for CV events or mortality are very similar whether ABPM is 24-hour, daytime, or nighttime. The results were consistent despite enrollment of participants from different geographic regions and who had different baseline characteristics. Thus, ABPM methods add additional and significant predictive information to OBPM methods for CV and cerebrovascular outcomes. For this reason, ABPM was chosen as the reference standard for KQs 3b and 3c in this review.

Risk estimates were lower and less consistent for outcomes that were limited to cardiac end points (i.e., CHF, MI, sudden death) and all-cause mortality. Diastolic ABPM results followed a similar pattern to that of systolic results for all outcomes, although the HR estimates were lower. Thus, diastolic ABPM appears to contribute less predictive information.

Each 10-mm Hg increase in systolic ABPM, not controlling for OBPM, was also consistently and significantly associated with an increased risk for stroke and CV outcomes. The parallel results for OBPM, on the other hand, showed generally lower predictive risks. These results support the conclusion that ABPM provides predictive information in addition to OBPM.

#### Study Details

24-Hour ABPM vs. OBPM. Nine studies (including one study of 48-hour ABPM) compared baseline 24-hour systolic ABPM and OBPM for predicting long-term outcomes. The number of participants at baseline ranged from 808 to 5,292 and mean followup ranged from 4.4 to 13 years. Mean/median age of participants at baseline ranged from approximately 50 to 60 years, except for two studies that had mean participant ages of about 70 years.121,126 Details can be found in Tables 8 to 12, where the data are arranged by major outcome category. Appendix Tables 13 to 17 display the original data.

Table 8 24-hr ABPM vs. OBPM: Fatal and Nonfatal Strokes

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment | ABPM (24-hr) HR (95% CI) | ABPM (24-hr) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (24-hr) | Additional Model Covariates^†^
SBP
Clement, 2003^115^ Good | Belgium | 1963 | 36 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | NR | NR, NS | 1.21 (1.04 to 1.42) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry, OBPM
Mesquita-Bastos, 2010^122^ Fair | Portugal | 1200 | 79^*^ | 100 52.42 | 154.85/95.27 | 8.2 | 10 mm Hg | NR | 1.37 (1.20 to 1.56) | NR | NR | BMI, DM, anti-HTN treatment, OBPM
Ohkubo, 2005^125^ Good | Japan | 1332 | 112 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.40 (1.21 to 1.62) | NR | 1.04 (0.94 to 1.15) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
Staessen, 1999^126^ Good | Multi-national (western and eastern Europe) | 808 | 30 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.40 (1.12 to 1.76) | 1.36 (1.04 to 1.79) | 1.29 (0.98 to 1.71) | NR | Previous CV complications, residence in western Europe
Dolan, 2005^116^ Fair | Ireland | 5292 | 103^†^ | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.27 (1.15 to 1.40)^†^ | 1.28 (1.15 to 1.43)^†^ | 1.07 (1.00 to 1.15)^†^ | NR | BMI, DM, history of CV events, OBPM
DBP
Mesquita-Bastos, 2010^122^ Fair | Portugal | 1200 | 79^*^ | 100 52.42 | 154.85/95.27 | 8.2 | 5 mm Hg | NR | 1.24 (1.09 to 1.42) | NR | NR | BMI, DM, anti-HTN treatment, OBPM
Ohkubo, 2005^125^ Good | Japan | 1332 | 112 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.32(1.16 to 1.49) | NR | 1.03(0.95-1.13) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
Dolan, 2005^116^ Fair | Ireland | 5292 | 103^†^ | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.13 (1.05 to 1.22)^†^ | 1.12 (1.03 to 1.22)^†^ | 1.06 (0.99 to 1.12)^†^ | NR | BMI, DM, history of CV events, OBPM

* Strokes also available by hemorrhagic, ischemic, and undetermined type.

† Fatal strokes only.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 9 24-hr ABPM vs. OBPM: Fatal and Nonfatal Cardiovascular Events

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | ABPM (24-hr) HR (95% CI) | ABPM (24-hr) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (24-hr) | Additional Model Covariates^‡^
SBP
MI or stroke, fatal or nonfatal | Clement, 2003111 Good | Belgium | 1963 | 77 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | 1.30 (1.12 to 1.51) | 1.30 (1.10 to 1.55) | 1.10 (0.98 to 1.25) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
CV events (CV death, MI or stroke) | Hermida, 2011^120^║ Good | Spain | 3344 | NR | NR NR | 150.8/85.9 | 5.6 | 10 mm Hg | 1.45 (1.31 to 1.60) | 1.33 (1.17 to 1.52) | 1.30 (1.19 to 1.42) | NR | DM
CV mortality | Dolan, 2005^116^ Fair | Ireland | 5292 | 389 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.19 (1.14 to 1.26) | 1.19 (1.13 to 1.27) | 1.06 (1.02 to 1.10) | NR | BMI, DM, history of CV events
CV mortality | Gasowski, 2008^118^ Fair | Belgium | 1167 | 50 | 22.88 14.82 | 126/77 | 13 | 10 mm Hg | 1.38 (1.14 to 1.68) | 1.42 (1.14 to 1.77) | 1.10 (0.94 to 1.29) | 0.96 (0.79 to 1.16) | BMI, anti-HTN treatment, TC, drinking
CV mortality | Hansen, 2005^119^ Fair | Denmark | 1700 | 63 | NR 9.41 | 128/82 | 9.5 | 10 mm Hg | 1.51 (1.28 to 1.77)^*^ | NR, p=0.0003 | 1.25 (1.10 to 1.42)^*^ | NR, p=0.96 | NR
CV mortality | Ohkubo, 2005^125^ Good | Japan | 1332 | 67 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.27 (1.04 to 1.55) | NR | 1.04 (0.91 to 1.19) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
CV mortality | Staessen, 1999^126^ Good | Multi-national (western and eastern Europe) | 808 | 36 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.20 (0.98 to 1.49) | 1.11 (0.88 to 1.40) | 1.32 (1.03 to 1.68) | NR | Previous CV complications, residence in western Europe
DBP
MI or stroke, fatal or nonfatal | Clement, 2003^115^ Good | Belgium | 1963 | 77 | 100 100 | 155.01/93.06 | 5 | 5 mm Hg | 1.17 (1.04 to 1.30) | 1.17 (1.04 to 1.32) | 1.06 (0.93 to 1.21) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
CV events (CV death, MI or stroke) | Hermida, 2011^120^║Good | Spain | 3344 | NR | NR NR | 150.8/85.9 | 5.6 | 5 mm Hg | 1.22 (1.10 to 1.34) | 1.18 (1.04 to 1.33) | 1.14 (1.05 to 1.24) | NR | DM
CV mortality | Dolan, 2005^116^ Fair | Ireland | 5292 | 389 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.07 (1.03 to 1.12) | 1.09 (1.02 to 1.11) | 1.03 (1.00 to 1.07) | NR | BMI, DM, history of CV events
CV mortality | Hansen, 2005^119^ Fair | Denmark | 1700 | 63 | NR 9.41 | 128/82 | 9.5 | 5 mm Hg | 1.43 (1.26 to 1.61) | NR, p<0.0001 | 1.21 (1.08 to 1.35)^*^ | NR, p=0.49 | NR
CV mortality | Ohkubo, 2005^125^ Good | Japan | 1332 | 67 | 15.17 30.41 | 131.2/74.1 | 10.2 | 5 mm Hg | NR | 1.13 (0.94 to 1.34) | NR | 1.00 (0.89 to 1.12) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia

* Relative risk.

‡ All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (24-hr) or OBPM.

§ See Appendix C for original data.

║ ABPM 48-hr.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure; TC = total cholesterol.

Table 10 24-hr ABPM vs. OBPM: Fatal and Nonfatal Cardiac Endpoints

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | ABPM (24-hr) HR (95% CI) | ABPM (24-hr) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (24-hr) | Additional Model Covariates^‡^
SBP
Cardiac endpoint, fatal and nonfatal | Staessen, 1999^126^ Good | Multi-national (western and eastern Europe) | 808 | 69 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.12 (0.96 to 1.31) | 1.11 (0.93 to 1.31) | 1.11 (0.91 to 1.35) | NR | Previous CV complications, residence in western Europe
Cardiac endpoints, fatal | Dolan, 2005^116^ Fair | Ireland | 5292 | 254 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.17 (1.09 to 1.24) | 1.16 (1.07 to 1.25) | 1.06 (1.01 to 1.10) | NR | BMI, DM, history of CV events
DBP
Cardiac endpoints, fatal | Dolan, 2005^116^ Fair | Ireland | 5292 | 254 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.05 (1.00 to 1.10) | 1.05 (0.99 to 1.11) | 1.02 (0.98 to 1.09) | NR | BMI, DM, history of CV events

‡ All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (24-hr) or OBPM.

§ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 11 24-hr ABPM vs. OBPM: Congestive Heart Failure

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | ABPM (24-hr) HR (95% CI) | ABPM (24-hr) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (24-hr) | Additional Model Covariates
Ingelsson, 2006^121^ Good | Sweden | 951 | 70 | 49.2 32.6 | 146/84 | 9.1 | 10 mm Hg | 1.08 (0.94 to 1.24) | 1.01 (0.85 to 1.19) | 1.13 (0.99 to 1.29) | 1.12 (0.95 to 1.32) | BMI, smoking, DM, prior MI, anti-HTN treatment, cholesterol
Ingelsson, 2006^121^ Good | Sweden | 951 | 70 | 49.2 32.6 | 146/84 | 9.1 | 5 mm Hg | 1.08 (0.94 to 1.25) | 1.03 (0.86 to 1.23) | 1.09 (0.95 to 1.25) | 1.06 (0.90 to 1.26) | BMI, smoking, DM, prior MI, anti-HTN treatment, cholesterol

§ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 12 24-hr ABPM vs. OBPM: All-Cause Mortality

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^‡^ | ABPM (24-hr) HR (95% CI) | ABPM (24-hr) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (24-hr) | Additional Model Covariates^†^
SBP
Clement, 2003^115^ Good | Belgium | 1963 | 78 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | 1.11 (0.96 to 1.28) | 1.02 (0.86 to 1.20) | 1.17 (1.05 to 1.32) | NR | BMI, DM, cholesterol, CV complications at entry, use of lipid-lowering drugs
Dolan, 2005^116^ Fair | Ireland | 5292 | 646 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.11 (1.07 to 1.16) | 1.13 (1.08 to 1.19) | 1.02 (0.99 to 1.05) | NR | BMI, DM, history of CV events
Hansen, 2005^119^ Fair | Denmark (population-based) | 1700 | 174 | NR 9.41 | 128/82 | 9.5 | 10 mm Hg | 1.18 (1.06 to 1.31)^*^ | NR, p=0.001 | 1.05 (0.96 to 1.14)^*^ | NR, p=0.23 | NR
Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 68 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.16 (0.99 to 1.35) | 1.09 (0.92 to 1.29) | 1.24 (1.03 to 1.49) | NR | Previous CV complications, residence in western Europe
DBP
Clement, 2003^115^ Good | Belgium | 1963 | 78 | 100 100 | 155.01/93.06 | 5 | 5 mm Hg | 1.09 (0.98 to 1.22) | 1.07 (0.95 to 1.20) | 1.11 (0.99 to 1.25) | NR | BMI, DM, cholesterol, CV complications at entry, use of lipid-lowering drugs
Dolan, 2005^116^ Fair | Ireland | 5292 | 646 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.06 (1.02 to 1.09) | 1.05 (1.02 to 1.09) | 1.01 (0.99 to 1.04) | NR | BMI, DM, history of CV events
Hansen, 2005^119^ Fair | Denmark (population-based) | 1700 | 174 | NR 9.41 | 128/82 | 9.5 | 5 mm Hg | 1.18 (1.09 to 1.28)^*^ | NR, p<0.0001 | 1.06 (0.99 to 1.14)^*^ | NR, p=0.17 | NR

* Relative risk.

† All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (24-hr) or OBPM.

‡ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Unadjusted HRs for systolic OPBM were not consistently significant and ranged from 1.07 to 1.29 for stroke and 1.06 to 1.32 for CV events or mortality (Figure 2). These results are similar to those of the Prospective Studies Collaboration IPD meta-analysis, which reported a range of risk estimates, from 1.22 to 1.41 for CV mortality and 1.22 to 1.62 for fatal stroke^‡^, across age categories.6 This pattern of results for OBPM is similar across all ABPM versus OBPM comparisons and outcomes. Because of this similarity, we do not discuss OBPM results in the following sections. Details of results can be found in Tables 8 to 12.

‡ Results of the IPD analysis were originally reported as HRs per 20-mm Hg decrease in SBP and were converted to HRs per 10-mm Hg increase in SBP for consistency and comparability.

Figure 2 Risk for Cardiovascular and Mortality Outcomes: OBPM, Not Adjusted for 24-hr ABPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HF = heart failure; HR = hazard ratio; MI = myocardial infarction.

Figure 2 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported office blood pressure measurement not adjusted for 24-hour ambulatory blood pressure monitoring

Each 10-mm Hg increase in 24-hour systolic ABPM, adjusting for OPBM, was consistently associated with increased risk for fatal and nonfatal stroke events in four studies (Figure 3).116, 122,125,126 The number of reported events per study ranged from 30 in the smallest study with the shortest followup126 to 112 in the study with the longest followup.125 Risk estimates ranged from an HR of 1.28 to 1.40 and were all statistically significant, indicating that systolic ABPM predicts stroke events significantly and independently of OBPM. The largest risk estimate (HR, 1.40 [95% CI, 1.21 to 1.62]) was reported for a community-based study in rural Japan, which enrolled 1,332 participants who were followed for a mean of 10.2 years.125 This study was the only study of the four that did not limit participation to those with hypertension and had by far the lowest mean baseline OBPM (131/74 mm Hg). One study reported nonsignificant results for OBPM-adjusted ABPM without reporting an estimate. The number of events analyzed in this study was small at 36 out of a total population of 1,963, and analysis of stroke outcomes alone was not prespecified.115 Unadjusted risk estimates for systolic 24-hour ABPM were reported in two studies and both were significant (HR, 1.27 [95% CI, 1.15 to 1.40] and 1.40 [95% CI, 1.12 to 1.76]) (Figure 4).116,126

Figure 3 Risk for Cardiovascular and Mortality Outcomes: Systolic 24-hr ABPM, Adjusted for OBPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HF = heart failure; HR = hazard ratio; MI = myocardial infarction.

Figure 3 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported systolic 24-hour ambulatory blood pressure monitoring adjusted for office blood pressure measurement

Figure 4 Risk for Cardiovascular and Mortality Outcomes: Systolic 24-hr ABPM, Not Adjusted for OBPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HF = heart failure; HR = hazard ratio; MI = myocardial infarction.

Figure 4 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported systolic 24-hour ambulatory blood pressure monitoring not adjusted for office blood pressure measurement

While risk estimates for fatal and nonfatal stroke were slightly lower for each 5-mm Hg increase in diastolic 24-hour ABPM, adjusted for OBPM, they were significant in three studies.116,122,124 Results for diastolic ABPM are provided in Table 8; forest plots are not shown because fewer studies reported diastolic APBM and because results were similar to those of systolic ABPM, although more attenuated.

One study also estimated risk for stroke events for systolic OPBM, adjusted for 24-hour ABPM (Figure 5). This result was a nonsignificant HR of 1.04 (95% CI, 0.94 to 1.15), which indicates that OBPM adds no significant predictive capacity for stroke events when 24-hour ABPM is in the model.125

Figure 5 Risk for Cardiovascular and Mortality Outcomes: Systolic OBPM, Adjusted for 24-hr ABPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HF = heart failure; HR = hazard ratio; MI = myocardial infarction.

Figure 5 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported office blood pressure measurement adjusted for 24-hour ambulatory blood pressure monitoring

Each 10-mm Hg increase in 24-hour systolic ABPM, adjusted for OBPM, was associated with an increased risk for fatal and nonfatal CV events (Table 9). Six studies reported an elevated risk, with five studies reporting statistically significant results115,116,118,120,125 (Figure 3).126 The number of CV events per study ranged from 36 in the smallest study with the shortest followup126 to 389 in the largest study.116 HRs ranged from 1.11 to 1.42. Only the lowest estimate was not statistically significant and was reported for the smallest and oldest cohort with the highest baseline BP (173/86 mm Hg; n=808; mean age, 70 years), who were participants in a trial of antihypertensive medication.126 One additional study only reported ABPM as a significant predictor of CV mortality when entered in a model with OBPM (p=0.0003).119 Results for studies reporting only CV mortality were not different from those reporting a combination of fatal and nonfatal CV events, with the one exception already described.126 Unadjusted risk estimates were all statistically significant, with the same exception (Figure 2).126 In five studies reporting this outcome, estimates of CV-related risks for 24-hour diastolic ABPM, adjusted for OBPM, tended to be smaller than for systolic ABPM but remained statistically significant, except for one study (Table 9).125

Two studies reported risk estimates for fatal and nonfatal cardiac events (Table 10).116,126 Each 10-mm Hg increase in 24-hour systolic ABPM, adjusted for OBPM, was associated with increased risk (HR, 1.11 [95% CI, 0.93 to 1.31] and 1.16 [95% CI, 1.07 to 1.25]), but did not consistently reach conventional statistical significance (Figure 3). One study evaluated CHF outcomes (70 events in 951 participants) and found a nonsignificant increase in risk (HR, 1.01 [95% CI, 0.85 to 1.19]) (Table 11).121

Finally, four studies evaluated risk for all-cause mortality (Table 12).115,116,119,126 The number of events per study ranged from 68 in the smallest study (which had the shortest followup)126 to 646 in the largest study.116 Risk for all-cause mortality tended to modestly increase (2% to 13%) in three studies with each 10-mm Hg increase in 24-hour ABPM, controlling for OBPM. A fourth study provided no estimate, only reporting that ABPM independently predicted risk after controlling for OBPM (p=0.001).119

Nighttime ABPM vs. OBPM. Nine studies compared baseline nighttime systolic ABPM and OBPM for predicting long-term outcomes.115-117,119-122,125,126 The number of participants at baseline ranged from 391 to 5,292. The mean followup ranged from 4.4 to 10.9 years. Mean/median age of study participants at baseline ranged from approximately 50 to 70 years.117, 121,126 Additional study details can be found in Tables 13 to 17, where the results are arranged by major outcome category. Appendix Tables 18 to 22 display the original data.

Table 13 Nighttime ABPM vs. OBPM: Fatal and Nonfatal Strokes

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment | ABPM (night) HR (95% CI) | ABPM (night) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (night) | Additional Model Covariates^†^
SBP
Mesquita-Bastos, 2010^122^ Fair | Portugal | 1200 | 79 | 100 52.42 | 154.85/95.27 | 8.2 | 10 mm Hg | NR | 1.43 (1.25 to 1.64) | NR | NR | BMI, DM, anti-HTN treatment, OBPM
Ohkubo, 2005^125^ Good | Japan | 1332 | 112 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.26 (1.10 to 1.43) | NR | 1.08 (0.98 to 1.19) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 30 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.35 (1.11 to 1.65) | 1.31 (1.06 to 1.62) | 1.29 (0.98 to 1.71) | NR | Previous CV complications, residence in western Europe
Dolan, 2005^116^ Fair | Ireland | 5292 | 103^*^ | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.30 (1.19 to 1.40) | 1.30 (1.19 to 1.42) | 1.07 (1.00 to 1.15) | NR | BMI, DM, history of CV events
DBP
Mesquita-Bastos, 2010^122^ Fair | Portugal | 1200 | 79 | 100 52.42 | 154.85/95.27 | 8.2 | 5 mm Hg | NR | 1.24 (1.10 to 1.38) | NR | NR | BMI, DM, anti-HTN treatment, OBPM
Ohkubo, 2005^125^ Good | Japan | 1332 | 112 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.21 (1.08 to 1.36) | NR | 1.07 (0.98 to 1.16) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
Dolan, 2005^116^ Fair | Ireland | 5292 | 103^*^ | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.14 (1.07 to 1.22) | 1.14 (1.06 to 1.22) | 1.06 (0.99 to 1.12) | NR | BMI, DM, history of CV events

* Fatal strokes only.

† All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (nighttime) or OBPM.

‡ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 14 Nighttime ABPM vs. OBPM: Fatal and Nonfatal Cardiovascular Events

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | ABPM (night) HR (95% CI) | ABPM (night) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (night) | Additional Model Covariates^‡^
SBP
MI or stroke, fatal and nonfatal | Clement, 2003^115^ Good | Belgium | 1963 | 77 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | 1.16 (1.02 to 1.33) | 1.13 (0.98 to 1.31) | 1.10 (0.98 to 1.25) | NR | BMI, smoking, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
Major CV events | Fagard, 2005^117^ Good | Belgium | 391 | 86 | 61.89 32.23 | 142.8/77.5 | 10.9 | 10 mm Hg | 1.22 (1.09 to 1.38) | 1.23 (1.07 to 1.40) | 1.06 (0.94 to 1.18) | 0.98 (0.86 to 1.12) | BMI, smoking, DM, anti-HTN treatment, smoking, serum TC
Major CV events | Hermida, 2011^120^ Good | Spain | 3344 | NR | NR NR | 150.8/85.9 | 5.6 | 10 mm Hg | 1.45 (1.33 to 1.57) | 1.37 (1.24 to 1.53) | 1.30 (1.19 to 1.42) | NR | DM
CV mortality | Dolan, 2005^116^ Fair | Ireland | 5292 | 389 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.21 (1.16 to 1.27) | 1.21 (1.15 to 1.27) | 1.06 (1.02 to 1.10) | NR | BMI, smoking, DM, history of CV events
CV mortality | Hansen, 2005^119^ Fair | Denmark | 1700 | 63 | NR 9.41 | 128/82 | 9.5 | 10 mm Hg | 1.41 (1.23 to 1.62)^*^ | NR | 1.25 (1.10 to 1.42) | NR | NR
CV mortality | Ohkubo, 2005^125^ Good | Japan | 1332 | 67 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.33 (1.11 to 1.58) | NR | 1.05 (0.92 to 1.20) | Smoking, DM, history of CVD, anti-HTN treatment, hypercholesterolemia
CV mortality | Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 36 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.23 (1.03 to 1.46) | 1.18 (0.98 to 1.42) | 1.32 (1.03 to 1.68) | NR | Smoking, previous CV complications, residence in western Europe
DBP
MI or stroke, fatal and nonfatal | Clement, 2003^115^ Good | Belgium | 1963 | 77 | 100 100 | 155.01/93.06 | 5 | 5 mm Hg | 1.11 (1.00 to 1.22) | 1.09 (0.98 to 1.22) | 1.06 (0.93 to 1.21) | NR | BMI, smoking, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
Major CV events | Fagard, 2005^117^ Good | Belgium | 391 | 86 | 61.89 32.23 | 142.8/77.5 | 10.9 | 5 mm Hg | 1.18 (1.06 to 1.32) | 1.22 (1.08 to 1.38) | 1.02 (0.92 to 1.14) | 0.91 (0.80 to 1.03) | BMI, smoking, DM, anti-HTN treatment, smoking, serum TC
Major CV events | Hermida, 2011^120^ Good | Spain | 3344 | NR | NR NR | 150.8/85.9 | 5.6 | 5 mm Hg | 1.27 (1.17 to 1.39) | 1.26 (1.14 to 1.39) | 1.14 (1.05 to 1.24) | NR | DM
CV mortality | Dolan, 2005^116^ Fair | Ireland | 5292 | 389 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.09 (1.05 to 1.13) | 1.09 (1.04 to 1.13) | 1.03 (1.00 to 1.07) | NR | BMI, smoking, DM, history of CV events
CV mortality | Hansen, 2005^119^ Fair | Denmark | 1700 | 63 | NR 9.41 | 128/82 | 9.5 | 5 mm Hg | 1.36 (1.22 to 1.51) | NR | 1.21 (1.08 to 1.35) | NR | NR
CV mortality | Ohkubo, 2005^125^ Good | Japan | 1332 | 67 | 15.17 30.41 | 131.2/74.1 | 10.2 | 5 mm Hg | NR | 1.20 (1.02 to 1.41) | NR | 0.99 (0.89 to 1.11) | Smoking, DM, history of CVD, anti-HTN treatment, hypercholesterolemia

* Relative risk.

‡ All adjusted for age and sex. All covariates are from the model adjusted for ABPM (nighttime) or OBPM.

§ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure; TC = total cholesterol.

Table 15 Nighttime ABPM vs. OBPM: Fatal and Nonfatal Cardiac Endpoints

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^*^ | ABPM (night) HR (95% CI) | ABPM (night) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (night) | Additional Model Covariates^‡^
SBP
Cardiac endpoint, fatal and nonfatal | Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 69 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.17 (1.03 to 1.33) | 1.16 (1.02 to 1.33) | 1.11 (0.91 to 1.35) | NR | Previous CV complications, residence in western Europe
Cardiac endpoints, fatal | Dolan, 2005^116^ Fair | Ireland | 5292 | 254 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.16 (1.10 to 1.23) | 1.15 (1.04 to 1.23) | 1.06 (1.01 to 1.10) | NR | BMI, DM, history of CV events
DBP
Cardiac endpoints, fatal | Dolan, 2005^116^ Fair | Ireland | 5292 | 254 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.06 (1.01 to 1.11) | 1.06 (1.01 to 1.11) | 1.02 (0.98 to 1.09) | NR | BMI, DM, history of CV events

* See Appendix C for original data.

‡ All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (nighttime) or OBPM.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 16 Nighttime ABPM vs. OBPM: Congestive Heart Failure

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^*^ | ABPM (night) HR (95% CI) | ABPM (night) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (night) | Additional Model Covariates
SBP
Ingelsson, 2006^121^ Good | Sweden | 951 | 70 | 49.2 32.6 | 146/84 | 9.1 | 10 mm Hg | 1.11 (0.99 to 1.25) | 1.08 (0.94 to 1.22) | 1.13 (0.99 to 1.29) | NR | BMI, smoking, DM, prior MI, anti-HTN treatment, cholesterol
DBP
Ingelsson, 2006^121^ Good | Sweden | 951 | 70 | 49.2 32.6 | 146/84 | 9.1 | 5 mm Hg | 1.14 (1.01 to 1.28) | 1.12 (0.98 to 1.29) | 1.09 (0.95 to 1.25) | NR | BMI, smoking, DM, prior MI, anti-HTN treatment, cholesterol

* See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 17 Nighttime ABPM vs. OBPM: All-Cause Mortality

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^‡^ | ABPM (night) HR (95% CI) | ABPM (night) HR (95% CI), adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), adj. for ABPM (night) | Additional Model Covariates^†^
SBP
Clement, 2003^115^ Good | Belgium | 1963 | 78 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | 1.10 (0.97 to 1.25) | 1.03 (0.89 to 1.19) | 1.17 (1.05 to 1.32) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry, OBPM
Dolan, 2005^116^ Fair | Ireland | 5292 | 646 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.14 (1.10 to 1.18) | 1.15 (1.11 to 1.20) | 1.02 (0.99 to 1.05) | NR | BMI, DM, history of CV events, OBPM
Hansen, 2005^119^ Fair | Denmark | 1700 | 174 | NR 9.41 | 128/82 | 9.5 | 10 mm Hg | 1.19 (1.08 to 1.30)^*^ | NR | 1.05 (0.96 to 1.14)^*^ | NR | NR
Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 68 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.17 (1.03 to 1.33) | 1.14 (1.00 to 1.30) | 1.24 (1.03 to 1.49) | NR | Previous CV complications, residence in western Europe
DBP
Clement, 2003^115^ Good | Belgium | 1963 | 78 | 100 100 | 155.01/93.06 | 5 | 5 mm Hg | 1.08 (0.98 to 1.20) | 1.07 (0.96 to 1.18) | 1.11 (0.99 to 1.25) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry, OBPM
Dolan, 2005^116^ Fair | Ireland | 5292 | 646 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.07 (1.04 to 1.10) | 1.08 (1.04 to 1.11) | 1.01 (0.99 to 1.04) | NR | BMI, DM, history of CV events, OBPM
Hansen, 2005^119^ Fair | Denmark | 1700 | 174 | NR 9.41 | 128/82 | 9.5 | 5 mm Hg | 1.16 (1.08 to 1.25)^*^ | NR | 1.06 (0.99 to 1.14)^*^ | NR | NR

* Relative risk.

† All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (nighttime) or OBPM.

‡ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Four studies reported risk for fatal and nonfatal stroke events for nighttime systolic ABPM, adjusted for systolic OBPM (Table 13).116,122,125,126 The number of events per study ranged from 30 to 112. Only the study by Ohkubo and colleagues was not restricted to participants who were hypertensive at baseline.125 Each 10-mm Hg increase in ABPM was statistically significantly associated with increased risk for a stroke event (HR, 1.26 to 1.43), similar to the results for 24-hour ABPM (Figure 6). Results for each 5-mm Hg increase in nighttime diastolic ABPM, adjusted for OBPM, showed a consistently and significantly elevated risk in three studies (Table 13), although this increase was less pronounced than for systolic results.116,122,125

Figure 6 Risk for Cardiovascular and Mortality Outcomes: Systolic Nighttime ABPM, Adjusted for OBPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HF = heart failure; HR = hazard ratio; MI = myocardial infarction.

Figure 6 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported systolic nighttime ambulatory blood pressure monitoring adjusted for office blood pressure measurement

Six studies evaluated nighttime systolic ABPM, adjusted for systolic OBPM, and reported risk estimates for CV event or mortality (Table 14).115-117,120,125,126 The number of events per study ranged from 36 to 389. In four of six studies, each 10-mm Hg increase in ABPM was statistically significantly associated with increased risk;116,117,120,125 two studies reporting nonsignificant increased risk had shorter followup times and smaller numbers of events.115,126 Overall, estimates ranged from an HR of 1.13 to 1.37. One additional study reported only unadjusted HRs for ABPM (1.41 [95% CI, 1.23 to 1.62]) and OPBM (1.25 [95% CI, 1.10 to 1.42]).119

For the combined fatal and nonfatal cardiac endpoints, each 10-mm Hg increase in nighttime systolic ABPM was significantly associated with increased risk (HR, 1.16 [95% CI, 1.02 to 1.33] and 1.15 [95% CI, 1.04 to 1.23]) (Table 15).116,126 For CHF outcomes, each 10-mm Hg increase in nighttime systolic ABPM suggested slightly increased risk (HR, 1.08 [95% CI, 0.94 to 1.22]) (Table 16).121 For all-cause mortality, each 10-mm Hg increase in nighttime ABPM was associated with increased risk.115,116,126 While HRs ranged from 1.03 to 1.15, results were statistically significant in only the largest study (Table 17).116

Daytime ABPM vs. OBPM. Ten studies compared daytime systolic ABPM and systolic OBPM results at baseline for predicting long-term outcomes.114-117,119-122,125,126 The number of participants at baseline ranged from 391 to 5,292. Mean followup ranged from 4.4 to 10.9 years. Mean/median age of study participants at baseline ranged from approximately 50 to 70 years.117, 121,126 Details can be found in Tables 18 to 22, arranged by major outcome category. Appendix Tables 23 to 27 display original data. The pattern of results for all outcomes was very similar to that described for nighttime ABPM versus OBPM. Results are presented in Figure 7.

Figure 7 Risk for Cardiovascular and Mortality Outcomes: Systolic Daytime ABPM, Adjusted for OBPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HF = heart failure; HR = hazard ratio; MI = myocardial infarction.

Figure 7 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported systolic daytime ambulatory blood pressure monitoring adjusted for office blood pressure measurement

Table 18 Daytime ABPM vs. OBPM: Fatal and Nonfatal Strokes

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment | ABPM (Day) HR (95% CI) | ABPM (Day) HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for ABPM (Day) | Additional Model Covariates^‡^
SBP
Mesquita-Bastos, 2010^122^ Fair | Portugal | 1200 | 79^*^ | 100 52.42 | 154.85/95.27 | 8.2 | 10 mm Hg | NR | 1.33 (1.13 to 1.55) | NR | NR | BMI, DM, anti-HTN treatment, OBPM
Ohkubo, 2005^125^ Good | Japan | 1332 | 112 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.37 (1.19 to 1.57) | NR | 1.03 (0.93 to 1.15) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 30 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.30 (1.05 to 1.62) | 1.25 (0.97 to 1.61) | 1.29 (0.98 to 1.71) | NR | Previous CV complications, residence in western Europe
Dolan, 2005^116^ Fair | Ireland | 5292 | 103^†^ | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.18 (1.08 to 1.30)^†^ | 1.17 (1.05 to 1.30)^†^ | 1.07 (1.00 to 1.15) | NR | BMI, DM, history of CV events, OBPM
DBP
Mesquita-Bastos, 2010^122^ Fair | Portugal | 1200 | 79^*^ | 100 52.42 | 154.85/95.27 | 8.2 | 5 mm Hg | NR | 1.24 (1.07 to 2.43) | NR | NR | BMI, DM, anti-HTN treatment, OBPM
Ohkubo, 2005^125^ Good | Japan | 1332 | 112 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.29 (1.15 to 1.45) | NR | 1.03 (0.95 to 1.12) | DM, history of CVD, anti-HTN treatment, hypercholesterolemia
Dolan, 2005^116^ Fair | Ireland | 5292 | 103^†^ | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.09 (1.01 to 1.17)^†^ | 1.07 (0.99 to 1.16)^†^ | 1.06 (0.99 to 1.12) | NR | BMI, DM, history of CV events, OBPM

* Strokes also available by hemorrhagic, ischemic, and undetermined type.

† Fatal strokes only.

‡ All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (daytime) or OBPM.

§ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 19 Daytime ABPM vs. OBPM: Fatal and Nonfatal Cardiovascular Events

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | ABPM (Day) HR (95% CI) | ABPM (Day) HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for ABPM (Day) | Additional Model Covariates^‡^
SBP
MI or stroke, fatal or nonfatal | Clement, 2003^115^ Good | Belgium | 1963 | 77 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | 1.30 (1.12 to 1.51) | 1.31 (1.11 to 1.55) | 1.10 (0.98 to 1.25) | NR | BMI, smoking, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
Major CV events | Celis, 2002^114^ Fair | Belgium | 419 | 20 | 100 0 | 164.7/103.4 | 5.3 | 10 mm Hg | 1.51 (1.19 to 1.88) | 1.51 (1.13 to 2.01) | 1.17 (0.94 to 1.42) | NR | Smoking, anti-HTN treatment
Major CV events | Fagard, 2005^117^ Good | Belgium | 391 | 86 | 61.89 32.23 | 142.8/77.5 | 10.9 | 10 mm Hg | 1.23 (1.05 to 1.43) | 1.27 (1.05 to 1.54) | 1.06 (0.94 to 1.18) | 0.96 (0.86 to 1.14) | BMI, smoking, DM, anti-HTN treatment, smoking, serum TC
Major CV events | Hermida, 2011^120^ Good | Spain | 3344 | NR | NR NR | 150.8/85.9 | 5.6 | 10 mm Hg | 1.38 (1.25 to 1.54) | 1.23 (1.08 to 1.41) | 1.30 (1.19 to 1.42) | NR | DM
CV mortality | Dolan, 2005^116^ Fair | Ireland | 5292 | 389 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.15 (1.10 to 1.21) | 1.12 (1.06 to 1.18) | 1.06 (1.02 to 1.10) | NR | BMI, smoking, DM, history of CV events
CV mortality | Hansen, 2005^119^ Fair | Denmark | 1700 | 63 | NR 9.41 | 128/82 | 9.5 | 10 mm Hg | 1.50 (1.27 to 1.76)^*^ | NR | 1.25 (1.10 to 1.42)^*^ | NR | NR
CV mortality | Ohkubo, 2005^125^ Good | Japan | 1332 | 67 | 15.17 30.41 | 131.2/74.1 | 10.2 | 10 mm Hg | NR | 1.17 (0.97 to 1.41) | NR | 1.06 (0.93 to 1.21) | Smoking, DM, history of CVD, anti-HTN treatment, hypercholesterolemia
CV mortality | Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 36 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.17 (0.96 to 1.44) | 1.07 (0.85 to 1.34) | 1.32 (1.03 to 1.68) | NR | Smoking, previous CV complications, residence in western Europe
DBP
MI or stroke, fatal or nonfatal | Clement, 2003^115^ Good | Belgium | 1963 | 77 | 100 100 | 155.01/93.06 | 5 | 5 mm Hg | 1.17 (1.05 to 1.30) | 1.18 (1.05 to 1.32) | 1.06 (0.93 to 1.21) | NR | BMI, smoking, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry, OBPM
Major CV events | Celis, 2002^114^ Fair | Belgium | 419 | 20 | 100 0 | 164.7/103.4 | 5.3 | 5 mm Hg | 1.28 (1.07 to 1.53) | 1.34 (1.07 to 1.68) | 1.09 (0.87 to 1.36) | NR | Smoking, anti-HTN treatment
Major CV events | Fagard, 2005^117^ Good | Belgium | 391 | 86 | 61.89 32.23 | 142.8/77.5 | 10.9 | 5 mm Hg | 1.14 (1.00 to 1.29) | 1.22 (1.05 to 1.42) | 1.02 (0.92 to 1.14) | 0.91 (0.80 to 1.03) | BMI, smoking, DM, anti-HTN treatment, smoking, serum TC
Major CV events | Hermida, 2011^120^ Good | Spain | 3344 | NR | NR NR | 150.8/85.9 | 5.6 | 5 mm Hg | 1.16 (1.05 to 1.27) | 1.08 (0.96 to 1.23) | 1.14 (1.05 to 1.24) | NR | DM
CV mortality | Dolan, 2005^116^ Fair | Ireland | 5292 | 389 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.04 (1.00 to 1.08) | 1.03 (0.99 to 1.07) | 1.03 (1.00 to 1.07) | NR | BMI, smoking, DM, history of CV events
CV mortality | Hansen, 2005^119^ Fair | Denmark | 1700 | 63 | NR 9.41 | 128/82 | 9.5 | 5 mm Hg | 1.40 (1.24 to 1.58)^*^ | NR | 1.21 (1.08 to 1.35)^*^ | NR | NR
CV mortality | Ohkubo, 2005^125^ Good | Japan | 1332 | 67 | 15.17 30.41 | 131.2/74.1 | 10.2 | 5 mm Hg | NR | 1.07 (0.91 to 1.26) | NR | 1.01 (0.90 to 1.13) | Smoking, DM, history of CVD, anti-HTN treatment, hypercholesterolemia

* Relative risk.

‡ All adjusted for age and sex. All covariates are from the model adjusted for ABPM (daytime) or OBPM.

§ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure; TC = total cholesterol.

Table 20 Daytime ABPM vs. OBPM: Fatal and Nonfatal Cardiac Endpoints

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^*^ | ABPM (Day) HR (95% CI) | ABPM (Day) HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for ABPM (Day) | Additional Model Covariates^‡^
SBP
Cardiac endpoint, fatal and nonfatal | Staessen, 1999^126^ Good | Multi-national (western and eastern Europe) | 808 | 69 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.06 (0.91 to 1.23) | 1.03 (0.87 to 1.21) | 1.11 (0.91 to 1.35) | NR | Previous CV complications, residence in western Europe
Cardiac endpoints, fatal | Dolan, 2005^116^ Fair | Ireland | 5292 | 254 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.12 (1.06 to 1.19) | 1.11 (1.04 to 1.19) | 1.06 (1.01 to 1.10) | NR | BMI, DM, history of CV events
DBP
Cardiac endpoints, fatal | Dolan, 2005^116^ Fair | Ireland | 5292 | 254 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.03 (0.98 to 1.07) | 1.02 (0.97 to 1.07) | 1.02 (0.98 to 1.09) | NR | BMI, DM, history of CV events

* See Appendix C for original data.

‡ All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (daytime) or OBPM.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 21 Daytime ABPM vs. OBPM: Congestive Heart Failure

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^*^ | ABPM (Day) HR (95% CI) | ABPM (Day) HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for ABPM (Day) | Additional Model Covariates
SBP
Ingelsson, 2006^121^ Good | Sweden | 951 | 70 | 49.2 32.6 | 146/84 | 9.1 | 10 mm Hg | 1.05 (0.90 to 1.21) | 0.96 (0.80 to 1.15) | 1.13 (0.99 to 1.29) | NR | BMI, smoking, DM, prior MI, anti-HTN treatment, cholesterol
DBP
Ingelsson, 2006^121^ Good | Sweden | 951 | 70 | 49.2 32.6 | 146/84 | 9.1 | 5 mm Hg | 0.99 (0.86 to 1.16) | 0.92 (0.77 to 1.10) | 1.09 (0.95 to 1.25) | NR | BMI, smoking, DM, prior MI, anti-HTN treatment, cholesterol

* See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; DM = diabetes mellitus; HR = hazard ratio; HTN = hypertension; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 22 Daytime ABPM vs. OBPM: All-Cause Mortality

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^‡^ | ABPM (Day) HR (95% CI) | ABPM (Day) HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for ABPM (Day) | Additional Model Covariates^†^
SBP
Clement, 2003^115^ Good | Belgium | 1963 | 78 | 100 100 | 155.01/93.06 | 5 | 10 mm Hg | 1.11 (0.96 to 1.28) | 1.02 (0.87 to 1.20) | 1.17 (1.05 to 1.32) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
Dolan, 2005^116^ Fair | Ireland | 5292 | 656 | 100 0 | 162.3/93.1 | 7.9 | 10 mm Hg | 1.09 (1.04 to 1.13) | 1.07 (1.03 to 1.12) | 1.02 (0.99 to 1.05) | NR | BMI, DM, history of CV events, OBPM
Hansen, 2005^119^ Fair | Denmark | 1700 | 174 | NR 9.41 | 128/82 | 9.5 | 10 mm Hg | 1.15 (1.04 to 1.28)^*^ | NR | 1.05 (0.96 to 1.14) | NR | NR
Staessen, 1999^126^ Good | Multinational (western and eastern Europe) | 808 | 68 | 100 42.6 | 173.3/86.0 | 4.4 | 10 mm Hg | 1.07 (0.91 to 1.24) | 0.98 (0.83 to 1.17) | 1.24 (1.03 to 1.49) | NR | Previous CV complications, residence in western Europe
DBP
Clement, 2003^115^ Good | Belgium | 1963 | 78 | 100 100 | 155.01/93.06 | 5 | 5 mm Hg | 1.09 (0.98 to 1.21) | 1.06 (0.95 to 1.19) | 1.11 (0.99 to 1.25) | NR | BMI, DM, cholesterol, use of lipid-lowering drugs, CV complications at entry
Dolan, 2005^116^ Fair | Ireland | 5292 | 656 | 100 0 | 162.3/93.1 | 7.9 | 5 mm Hg | 1.02 (0.99 to 1.06) | 1.02 (0.99 to 1.05) | 1.01 (0.99 to 1.04) | NR | BMI, DM, history of CV events, OBPM
Hansen, 2005^119^ Fair | Denmark | 1700 | 174 | NR 9.41 | 128/82 | 9.5 | 5 mm Hg | 1.16 (1.08 to 1.26)^*^ | NR | 1.06 (0.99 to 1.14) | NR | NR

* Relative risk.

† All adjusted for age, sex, and smoking. All covariates are from the model adjusted for ABPM (daytime) or OBPM.

‡ See Appendix C for original data.

Abbreviations: ABPM = ambulatory blood pressure monitoring; adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

24-Hour vs. daytime vs. nighttime ABPM. In order to compare ABPM measurement protocols, we conducted exploratory meta-analyses for the outcome of CV events or mortality. Using the DerSimonian and Laird random-effects method, HRs for each 10-mm Hg increase in SBP were 1.24 (95% CI, 1.17 to 1.30; I^2^=8.7%) for 24-hour ABPM, 1.20 (95% CI, 1.12 to 1.28; I^2^=33.3%) for daytime ABPM, and 1.24 (95% CI, 1.17 to 1.31; I^2^=25.6%) for nighttime ABPM, all controlled for OBPM. Sensitivity analyses using profile likelihood and Knapp-Hartung meta-analysis methods resulted in nearly or exactly the same estimates with slightly wider confidence limits (data not shown). While the narrower CIs for the DerSimonian and Laird estimates make it more likely that differences in estimates will be detected, no differences were detected. As such, it appears that there are no measurement differences among the three protocols.

### HBPM vs. OBPM

Five studies examined HBPM (Appendix C Tables 10–12) results at baseline as a predictor of CV events or mortality (Table 23), fatal and nonfatal stroke (Table 24), or all-cause mortality (Table 25) (see Appendix Tables 28–30 for original data).112,113,117,123,124 Studies enrolled 391 to 4,939 participants whose mean ages ranged from about 50 to 70 years. Where reported, studies enrolled a significant proportion of participants (if not all) with hypertension at baseline, of whom at least half were being treated with antihypertensive medications. The number of events per study ranged from 85 to 160. In four studies, systolic HBPM, adjusted for OBPM, was consistently associated with increased risk,112,117,123,124 ranging from an HR of 1.17 (95% CI, 1.02 to 1.33) to 1.39 (95% CI, 1.22 to 1.59) (Figure 8).112,117,123 Results for a slightly different set of four studies reporting systolic HBPM, not controlled for OBPM, showed smaller, less consistent effects (Figure 9).113,117,123,124 These results suggest that HBPM, like ABPM, may contribute predictive information that is significant and independent of that contributed by OBPM. Too few studies, however, were available for each category of outcomes to confidently reach conclusions.

Figure 8 Risk for Cardiovascular and Mortality Outcomes: Systolic HBPM, Adjusted for OBPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HR = hazard ratio; MI = myocardial infarction; TIA = transient ischemic attack.

Figure 8 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported systolic home blood pressure monitoring adjusted for office blood pressure measurement

Figure 9 Risk for Cardiovascular and Mortality Outcomes: Systolic HBPM, Not Adjusted for OBPM

Abbreviations: CI = confidence interval; CV = cardiovascular; HR = hazard ratio; MI = myocardial infarction.

Figure 9 displays a forest plot of the hazard ratios of the risk of cardiovascular and mortality outcomes among studies that reported systolic home blood pressure monitoring not adjusted for office blood pressure measurement

Table 23 HBPM vs. OBPM: Fatal and Nonfatal Cardiovascular Events

Outcome | Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | HBPM HR (95% CI) | HBPM HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for HBPM | Additional Model Covariates^‡^
SBP
CV events (stroke, MI, CV death) | Fagard, 2005^117^ Good | Belgium | 391 | 86 | 61.89 32.23 | 142.8/77.5 | 10.9 | 10 mm Hg | 1.13 (1.03 to 1.24) | 1.17 (1.02 to 1.33) | 1.06 (0.94 to 1.18) | 0.96 (0.83 to 1.11) | BMI, DM, serum TC
CV mortality | Bobrie, 2004^113^ Good | France | 4939 | 85 | 100 100 | 152/85 | 3.2 | 10 mm Hg | 1.10 (0.90 to 1.22) | NR | 1.00 (0.82 to 1.10) | NR | NR
CV mortality | Ohkubo, 1998^124^ Good | Japan | 1789 | NR | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 10 mm Hg | 1.23 (1.01 to 1.49)^*^ | 1.1 (0.98 to 1.34)^*^ | 1.05 (0.90 to 1.22) | 1.02 (0.88 to 1.20) | History of CVD
CV mortality | Ohkubo, 1998^124^ Good | Japan | 1789 | NR | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 10 mm Hg | 1.014 (0.96 to 1.034)^†^ | 1.23 (1.00 to 1.51) † | 1.05 (0.90 to 1.22) | 1.00 (0.85 to 1.17) | History of CVD
DBP
CV events (stroke, MI, CV death) | Fagard, 2005^117^ Good | Belgium | 391 | 86 | 61.89 32.23 | 142.8/77.5 | 10.9 | 5 mm Hg | 1.18 (1.07 to 1.31) | 1.24 (1.11 to 1.40) | 1.02 (0.92 to 1.14) | 0.91 (0.81 to 1.03) | BMI, DM, serum TC
CV mortality | Bobrie, 2004^113^ Good | France | 4939 | 85 | 100 100 | 152/85 | 3.2 | 5 mm Hg | 1.10 (0.95 to 1.22) | NR | 0.95 (0.86 to 1.10) | NR | NR
CV mortality | Ohkubo, 1998^124^ Good | Japan | 1789 | NR | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 5 mm Hg | 1.07 (0.95 to 1.20)^*^ | 1.06 (0.94 to 1.20)^*^ | 1.04 (0.92 to 1.18) | 1.03 (0.91 to 1.16) | History of CVD
CV mortality | Ohkubo, 1998^124^ Good | Japan | 1789 | NR | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 5 mm Hg | 1.08 (0.93 to 1.25)^†^ | 1.07 (0.91 to 1.24)^†^ | 1.04 (0.92 to 1.18) | 1.03 (0.90 to 1.16) | History of CVD

* Initial HBPM.

† Multiple HBPM.

‡ All adjusted by age, sex, smoking, and anti-HTN treatment. All covariates are from the model adjusted for HBPM or OBPM.

§ See Appendix C for original data.

Abbreviations: adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; HBPM = home blood pressure monitoring; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 24 HBPM vs. OBPM: All-Cause Mortality

Study, Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | HBPM HR (95% CI) | HBPM HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for HBPM | Additional Model Covariates^‡^
SBP
Bobrie, 2004^113^ Good | France | 4939 | 205 | 100 100 | 152/85 | 3.2 | 10 mm Hg | 1.00 (1.00 to 1.10) | NR | 0.90 (0.90 to 1.00) | NR | NR
Niiranen, 2010^123^ Good | Finland | 2081 | 118 | NR 22.68 | 137.4/83.7 | 6.8 | 10 mm Hg | 1.11 (1.01 to 1.23) | 1.22 (1.09 to 1.37) | 1.05 (0.96 to 1.15) | 1.01 (0.92 to 1.12) | Age, sex, smoking, DM, history of CV events, anti-HTN treatment, hypercholesterolemia
Ohkubo, 1998^124^ Good | Japan | 1789 | 160 | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 10 mm Hg | 1.15 (1.03 to 1.28)^*^ | NR | 1.01 (0.92 to 1.09) | NR | NR
Ohkubo, 1998^124^ Good | Japan | 1789 | 160 | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 10 mm Hg | 1.12 (1.02 to 1.23)^†^ | NR | 1.01 (0.92 to 1.09) | NR | NR
DBP
Bobrie, 2004^113^ Good | France | 4939 | 205 | 100 100 | 152/85 | 3.2 | 5 mm Hg | 1.05 (0.95 to 1.10) | NR | 0.95 (0.86 to 1.05) | NR | NR
Niiranen, 2010^123^ Good | Finland | 2081 | 118 | NR 22.68 | 137.4/83.7 | 6.8 | 5 mm Hg | 1.08 (0.98 to 1.12) | 1.15 (1.05 to 1.26) | 0.95 (0.87 to 1.04) | 1.06 (0.97 to 1.16) | Age, sex, smoking, DM, history of CV events, anti-HTN treatment, hypercholesterolemia
Ohkubo, 1998^124^ Good | Japan | 1789 | 160 | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 5 mm Hg | 1.06 (0.98 to 1.15)^*^ | NR | 1.01 (0.95 to 1.08) | NR | NR
Ohkubo, 1998^124^ Good | Japan | 1789 | 160 | NR 32.53 | 133.3/75.9 | 6.6 (2.3) | 5 mm Hg | 1.07 (1.00 to 1.14)^†^ | NR | 1.01 (0.95 to 1.08) | NR | NR

* Multiple HBPM measurements.

† Initial HBPM measurement only.

‡ All covariates are from the model adjusted for HBPM or OBPM.

§ See Appendix C for original data.

Abbreviations: adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HBPM = home blood pressure monitoring; HTN = hypertension; HR = hazard ratio; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

Table 25 HBPM vs. OBPM: Fatal and Nonfatal Strokes

Study Quality | Country | N at BL | # of Events | % HTN at BL, % Treated | Mean BL Office SBP/DBP (mm Hg) | Mean Followup (y) | Cox Regression Model, BP Variable Increment^§^ | HBPM HR 95% CI) | HBPM HR (95% CI), Adj. for OBPM | OBPM HR (95% CI) | OBPM HR (95% CI), Adj. for HBPM | Additional Model Covariates^‡^
SBP
Asayama, 2006^112^ Good | Japan | 1766 | 156 | 54.3, 28.54 | NR/NR | 10.6 | 10 mm Hg | NR | 1.34 (1.18 to 1.51)^*^ | NR | 1.00 (0.91 to 1.10)^*^ | Age, sex, BMI, smoking, DM, past history of CVD, hypercholesterolemia
Asayama, 2006^112^ Good | Japan | 1766 | 156 | 54.3, 28.54 | NR/NR | 10.6 | 10 mm Hg | NR | 1.36 (1.19 to 1.54)^†^ | NR | 1.00 (0.91 to 1.09)^†^ | Age, sex, BMI, smoking, DM, past history of CVD, hypercholesterolemia
Asayama, 2006^112^ Good | Japan | 1766 | 156 | 54.3, 28.54 | NR/NR | 10.6 | 10 mm Hg | NR | 1.39 (1.22 to 1.59) | NR | 0.99 (0.90 to 1.09) | Age, sex, BMI, smoking, DM, past history of CVD, hypercholesterolemia
DBP
Asayama, 2006^112^ Good | Japan | 1766 | 156 | 54.3, 28.54 | NR/NR | 10.6 | 5 mm Hg | NR | 1.23 (1.12 to 1.36)^*^ | NR | 0.99 (0.92 to 1.07) | Age, sex, BMI, smoking, DM, past history of CVD, hypercholesterolemia
Asayama, 2006^112^ Good | Japan | 1766 | 156 | 54.3, 28.54 | NR/NR | 10.6 | 5 mm Hg | NR | 1.27 (1.14 to 1.40)^†^ | NR | 0.98 (0.91 to 1.06)^†^ | Age, sex, BMI, smoking, DM, past history of CVD, hypercholesterolemia
Asayama, 2006^112^ Good | Japan | 1766 | 156 | 54.3, 28.54 | NR/NR | 10.6 | 5 mm Hg | NR | 1.28 (1.15 to 1.41) | NR | 0.98 (0.91 to 1.06) | Age, sex, BMI, smoking, DM, past history of CVD, hypercholesterolemia

* Morning HBPM.

† Evening HBPM.

‡ All covariates are from the model adjusted for HBPM or OBPM.

§ See Appendix C for original data.

Abbreviations: adj = adjusted; BL = baseline; BMI = body mass index; BP = blood pressure; CI = confidence interval; CV = cardiovascular; DBP = diastolic blood pressure; DM = diabetes mellitus; HBPM = home blood pressure monitoring; HTN = hypertension; HR = hazard ratio; MI = myocardial infarction; NR = not reported; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure.

### ABPM vs. HBPM

Only one study compared ABPM with HBPM and OBPM for predicting CV outcomes (stroke, MI, and CV death).117 Each increase in daytime and nighttime ABPM, controlled for HBPM, was associated with increased risk (HR, 1.13 [95% CI, 0.93 to 1.38] and 1.16 [95% CI, 1.01 to 1.34], respectively). The magnitude of increase was somewhat smaller when ABPM was compared with OBPM in the same study (daytime ABPM, adjusted for OBPM: HR, 1.27 [95% CI, 1.05 to 1.54]; nighttime ABPM, adjusted for OBPM: HR, 1.23 [95% CI, 1.07 to 1.40]).

### ABPM or HBPM for Predicting Isolated Clinic Hypertension Outcomes

Six studies reporting ABPM or HBPM predictive value for long-term CV outcomes in general populations also reported risk specifically for the subgroup of participants with isolated clinic hypertension, which was most often defined as OBPM of 140/90 mm Hg or greater and ABPM or HBPM of less than 135/85 mm Hg at baseline (Appendix D Table 1).113,114,117,121,125 One additional study, which we excluded from the main body of evidence for KQ 3a because it did not report risk estimates, is also reviewed here.201 Participants with isolated clinic hypertension were compared with either normotensive participants or those with sustained hypertension.

In three studies, risk for CV disease, mortality, or CHF in participants with isolated clinic hypertension at baseline was elevated, but not statistically significantly different compared with normotensive participants (HR for CVD mortality, 1.54 [95% CI, 0.73 to 3.21]; HR for stroke, 1.07 [95% CI, 0.58 to 2.07];125 HR for CHF, 2.01 [95% CI, 0.82 to 4.91];121 p=0.85 for CV events [no estimate reported]).117 Five studies reported on comparisons between participants with sustained hypertension and those with isolated clinic hypertension.113-115,117,201 The method of reporting results varied across studies.

In general, all studies reported lower event rates or risk estimates for participants with isolated clinic hypertension than for those with sustained hypertension. One study reported a higher risk for sustained hypertension versus isolated clinic hypertension (HR, 2.16 [95% CI, 1.16 to 4.01]); results were similar whether or not treated participants were included in the analysis.117 In one study, all 22 major CV events occurred in participants with sustained hypertension, while no events occurred in those with isolated clinic hypertension.114 Similarly, a different study reported smaller numbers of events in participants with isolated clinic hypertension (1.32 per 100 patient-years) than those with sustained hypertension (2.56 per 100 patient-years; p<0.001).201 Another study reported similar numbers of CV events in participants with isolated clinic hypertension (12.1 per 1,000 patient-years) or controlled hypertension (11.1 per 1,000 patient-years), but a larger number of events in those with uncontrolled hypertension (25.6 per 1,000 patient-years).113 Finally, one study reported ABPM results for participants with baseline systolic OBPM greater than 140 mm Hg. For SBP of 140–159 mm Hg, the adjusted risk for an event among those with sustained hypertension compared with normotensive ABPM was 1.82 (95% CI, 0.92 to 3.56); for SBP of 160 mm Hg or greater, the risk was 2.31 (95% CI, 1.26 to 4.22).115

## KQ 3b How Accurate Are Other Noninvasive BP Measurement Methods in Establishing or Confirming the Diagnosis of Hypertension Compared With These Best Methods and Associated Protocols? Does Diagnostic Accuracy Vary by Protocol Characteristics?

We included 27 good- and fair-quality diagnostic accuracy studies (seven good-quality and 20 fair-quality) evaluating a total of 17,233 participants (87 to 4,263 enrolled per study) for KQ 3b (Appendix C Tables 31–33).114,127-151 Studies were conducted in North America (four studies), western Europe (18 studies), Israel (one study), and Japan (four studies).

We required that all study participants had elevated, untreated OBPM. Screening results were confirmed with ABPM (24 studies),114,127-143,145,148-152 HBPM (seven studies),127,128,134,136,142,146,147 or repeat OBPM at a second visit (three studies).130,144,152 Selected study characteristics are summarized in Table 26.

Table 26 Selected Characteristics of Studies Reporting the Positive Predictive Value of OBPM for Selected Confirmatory Measurement Methods

Author, Year Quality | Inclusion Criteria | # OBPM Measurements [Interventionist] | Diagnostic Accuracy N (% Female) | Mean Age, y (Range) | Mean BL Office SBP/DBP (mm Hg) | BP Threshold (mm Hg) if Different From Standard^*^ | Reference | Definition of ABPM or HBPM | PPV of (1st) OBPM for Reference (95% CI)
ABPM
Kario, 2013^136^ Fair | Patients diagnosed as having HTN by a clinical practitioner | 1 BP measurement (method NR) [clinical practitioner] | 239 (47) | 66.3 | 157/89 | ABPM ≥130 | ABPM (24-hr) | Average over 24 hours | 0.89 (0.85 to 0.93)
Inden, 1998^135^ Fair | Essential HTN patients who visited the HTN clinic of Nagoya Daini Red Cross Hospital; elevated BP by screening | Average of 2 (manual) [NR] | 232 (53) | 54.2 (18-80) | 167/98 | ABPM nighttime ≥120/75 | ABPM (24-hr) | Average after removing the first 2 measurements | 0.88 (0.83 to 0.92)
Pierdomenico, 1995^143^ Fair | Untreated consecutive patients with newly diagnosed arterial HTN | Average of 3 (manual) [NR] | 255 (47) | 49 (33-65) | 162/99 | NA | ABPM (24-hr) | Average over 24 hours | 0.79 (0.74 to 0.84)
Khoury, 1992^137^ Fair | ≥2 previous BP measurements showed DBP>90 mm Hg but <115 mm Hg. | 1 on day of ABPM and any from previous 12 months averaged (manual) [Nurses] | 131 (47) | 53.9 | 155/93 | NA | ABPM (24-hr) | Average over 24 hours | 0.52 (0.43 to 0.60)
Hozawa, 2002^127^ Fair | Subpopulation of Ohasama community study; age ≥40 years, untreated | Average of 2 (automated) [nurse or technician] | 150 (68) | NR (≥40) | 154/84 | NA | ABPM (24-hr) | Average over 24 hours | 0.35 (0.27 to 0.42)
Myers, 2010^141^ Good | Consecutive untreated patients referred to ABPM by physician | Average of 5 (automated) [NR] | 69 52) | 56.8 | 150/89 | ABPM ≥130/80 | ABPM (daytime) | Mean calcuated for the awake period from patient diary | 0.93 (0.87 to 0.99)
Hond, 2003b134 Fair | HTN patients whose sitting DBP was ≥95 mm Hg on conventional measurement | Average of last 2 measurements of each of 2 visits (manual) [physician] | 247 (54) | 50.4 | 155/100 | NA | ABPM (daytime) | Daytime time-weighted means 10 am to 8 pm | 0.92 (0.89 to 0.96)
Gustavsen, 2003^133^ Fair | Ages 18-80 years, newly diagnosed grade I or II (mild to moderate) HTN | Average of ≥3 BP measurements taken ≥1 week apart (manual) [physician] | 420 (53) | 47.7 (18-80) | 156/100 | NA | ABPM (daytime) | Average daytime BP 8 am to 10 pm | 0.90 (0.88 to 0.93)
Zawadzka, 1998^151^ Fair | Consecutive untreated patients with mean of 3 DBP measurements on different occasions | Average of 3 (automated) [physician, clinic nurse] | 410 (NR) | NR | 168/107 | NA | ABPM (daytime) | NR | 0.86 (0.83 to 0.90)
Verdecchia, 1995^149^ Fair | Essential HTN, previous anti-HTN medications withdrawn for ≥4 weeks; agreement within 5 mm Hg between mercury column and automatic recorder in ≥3 consecutive measurements taken simultaneously in each arm before ABPM | Average of 3 (automated) [physician] | 1333 (51) | 50.6 | 156/98 | Daytime ABPM ≥131/86 (women) or ≥136/87 (men) | ABPM (daytime) | Average daytime BP 6 am to 10 pm | 0.81 (0.79 to 0.83)
Graves, 2010^132^ Fair | Mild to moderate HTN requiring therapy | Average of 3 (manual) [NR] | 313 (42) | 51 (26-79) | 150/97 | Daytime ABPM ≥135/90 | ABPM (daytime) | Average daytime BP 9 am to 9 pm | 0.79 (0.74 to 0.83)
Celis, 2002^114^ Fair | Patients previously participating in APTH trial whose office DBP was ≥95 mm Hg while off treatment; age ≥18 years | Average of 2 visit mean BPs (3 readings per visit) [NR] | 419 (54) | 52.6 (≥18) | 165/103 | OBPM DBP>95; daytime ABPM ≥140/90 | ABPM (daytime) | Daytime time-weighted mean 10 am to 8 pm | 0.78 (0.74 to 0.82)
Nasothimiou, 2012^142^ Good | Referral for elevated BP, untreated | Average of the 2nd and 3rd clinic BPs from each of 3 visits (manual) [physician] | 361 (41) | 49 | 143/94 | NA | ABPM (daytime) | Determined according to diary | 0.77 (0.73 to 0.81)
Manning, 1999^139^ Fair | Patients referred to outpatient HTN unit who were not currently on anti-HTN meds and had not been in past year | Average of 3 visit mean BPs (3 readings per visit) (manual) [NR] | 186 (49) | 46 (18-71) | 161/101 | NA | ABPM (daytime) | Determined according to diary | 0.77 (0.71 to 0.83)
Ungar, 2004^148^ Good | Consecutive patients referred to HTN center | Average of 2 to 3 (manual) [physician] | 388 (51) | 60 (21-95) | 151/93 | NA | ABPM (daytime) | Average daytime BP 7 am to 10 pm | 0.74 (0.70 to 0.78)
Fogari, 1996^130^ Fair | Consecutive men with newly diagnosed, never-treated essential HTN | Average of 2 (manual) [physician] | 221 (NR) | NR (31-60) | 164/104 | Daytime ABPM ≥134/90 | ABPM (daytime) | Average daytime BP 6 am to 10 pm | 0.74 (0.68 to 0.80)
Gerc, 2000^131,‡^ Fair | Patients classified with elevated BP in physician's office and referred to HTN clinic for confirmation of diagnosis | Average of 3 (manual) [nurse] | 1466 (42) | 46.9 (13-85) | 141/91 | Daytime ABPM ≥140/90 | ABPM (daytime) | “12-hour daytime period” | 0.65 (0.62 to 0.67)
Pessanha, 2013^152^ | Newly diagnosed HTN patients from July 2006 to November 2007 without anti-HTN treatment | Average of 3 clinical readings [NR] | 336 (57) | 51 (NR) | 158/93 | NA | ABPM (daytime) | Average daytime BP 7 am to 11 pm | 0.61 (0.56 to 0.67)
Martinez, 1999^140^ Fair | Ages 18-75 years, diagnosis of mild to moderate essential HTN according to JNC 1993; no previous HTN treatment or none within 3 weeks | Average of 3 visit mean BPs (2 readings per visit) (manual) [nurses and doctors] | 345 (52) | 51.8 (18-75) | NR | NA | ABPM (daytime) | Average daytime BP 10 am to 8 pm | 0.61 (0.55 to 0.66)
Talleruphuus, 2006^145^ Fair | Living persons born between April 1, 1916 and September 30, 1926 from community registers; screened with isolated systolic hypertension | Average of 3 consecutive measurements on arm with highest BP (manual) [technician] | 108 (49) | 75 (70-82) | 173/81 | OBPM ≥160/90 Daytime ABPM ≥154/87 | ABPM (daytime) | Median daytime BP 7 am to 11 pm | 0.54 (0.44 to 0.63)
Zabludowski, 1992^150^ Fair | Untreated borderline HTN (DBP occasionally, but not consistently >90 mm Hg) | Average of 3 (manual) [physician or nurse] | 171 (67) | 48 | 159/91 | Daytime ABPM DBP>90 mm Hg | ABPM (daytime) | Average daytime BP 6 am to 12 am | 0.47 (0.40 to 0.55)
Cuspidi, 2011^129^ Good | Grade 1 or 2 HTN diagnosed in the previous 12 months and confirmed during 2 visits at the outpatient clinic | Average of 3 (manual) [NR] | 658 (48) | 46 | 145/96 | Nighttime ABPM ≥120/70 | ABPM (nighttime) | Average nighttime 11 pm to 7 am | 0.95 (0.93 to 0.97)
HBPM
Hond, 2003b134 Fair | HTN on conventional measurement | Average of last 2 measurements of each of 2 visits (manual) [physician] | 247 (54) | 50.4 | 155/100 | NA | HBPM | 3 morning, 3 evening for 1 week | 0.84 (0.80 to 0.89)
Kario, 2013^136^ Fair | Patients diagnosed with HTN by a clinical practitioner | 1 BP measurement (method NR) [clinical practitioner] | 239 (47) | 66.3 | 157/89 | NA | HBPM | 1 morning, 1 evening for 3 days | 0.84 (0.79 to 0.88)
Toyama, 2008^147^ Fair | Students of Tohoku University with 3 previous positive BP screens | Above threshold in 3 screens; last screen (1 measurement) used as office BP (automated) [physician] | 100 (NR) | 21.6 (<30) | 156/91 | NA | HBPM | Mean of at least 7 morning measurements | 0.83 (0.76 to 0.90)
Nasothimiou, 2012^142^ Good | Referral for elevated BP, untreated subpopulation only | Average of the 2nd and 3rd clinic BP from each of 3 visits (manual) [physician] | 361 (41) | 49 | 143/94 | NA | HBPM | Duplicate morning and evening measurements for 6 days | 0.76 (0.72 to 0.81)
Tanabe, 2008^146^ Fair | Age ≥18 years, spoke English, elevated initial and repeated ED BP, ≥4 home BPs stored in the monitor | 2 BP measurements (method NR) [research assistant] | 156 (52) | 47.5 (≥18) | 153/93^†^ | HBPM ≥140/90 | HBPM | 1 morning, 1 evening for 1 week | 0.51 (0.43 to 0.58)
Hozawa, 2002^127^ Fair | Subpopulation of Ohasama community study; age ≥40 years, untreated | Average of 2 (automated) [nurse or technician] | 150 (NR) | NR (≥40) | 154/84 | NA | HBPM (morning) | 2 morning, 2 evening for 4 weeks | 0.45 (0.37 to 0.53)
OBPM
Fogari, 1996^130^ Fair | Consecutive male patients with newly diagnosed, never-treated essential HTN (DBP>90 mm Hg) ages 31-60 years | Average of 2 (manual) [physician] | 221 (0) | 31-60 | 164.1/103.5 | DBP>90 mm Hg | OBPM (2nd screen) | NA | 0.96 (NR)
Pessanha, 2013^152^ | Newly diagnosed hypertensive patients from July 2006 to November 2007 without anti-HTN treatment | Average of 3 clinical readings [NR] | 336 (57) | 51 (NR) | 158/93 | NA | OBPM (2nd screen | NA | 0.93 (NR)
Nasothimiou, 2012^142^ Good | Referral for elevated BP, untreated subpopulation only | Average of the 2nd and 3rd clinic BP from each of 3 visits (manual) [physician] | 361 (41) | 49 | 143/94 | NA | OBPM (2nd screen) | NA | 0.83 (NR)
Ungar, 2004^148^ Good | Consecutive patients referred to HTN center | Average of 2 to 3 (manual) [physician] | 388 (51) | 60(21-95) | 151/93 | NA | OBPM (2nd screen | NA | 0.82 (NR)
Khoury, 1992^137^ Fair | ≥2 previous BPs showed DBP>90 but <115 mm Hg | 1 on day of ABPM and any from previous 12 months averaged (manual) [nurses] | 131 (47) | 53.9 | 155/93 | DBP ≥90 mm Hg | OBPM (2nd screen | NA | 0.76 (NR)
Zabludowski, 1992^150^ Fair | Untreated borderline HTN (DBP occasionally, but not consistently >90 mm Hg) | Average of 3 (manual) [physician or nurse] | 171 (67) | 48 | 159/91 | NA | OBPM (2nd screen | NA | 0.67 (NR)
Radi, 2004^144^ Good | Working population from any sector besides agricultural, enrolled by occupational physicians; untreated subpopulation | Average of 3 (automated) [NR] | 3464 (NR) | 15-69 | NR | NA | OBPM (2nd screen) | NA | 0.58 (NR)

* OBPM: 140/90 mm Hg; ABPM and HBPM: 135/85 mm Hg.

† Mean of medians.

‡ The numbers in this study do not add up (among the untreated, 520 (35%) had white coat HTN and 971 (65%) had sustained HTN, which does not = 1,466, as reported). We used 520 as the accurate number and calculates backwards.

Abbreviations: ABPM = ambulatory blood pressure monitoring; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; ED = emergency department; HBPM = home blood pressure monitoring; HTN = hypertension; NA = not applicable; NR = not reported; OBPM = office-based blood pressure measurement; PPV = positive predictive value.

We used ABPM, where measured, as the reference standard (i.e., “true” BP classification). Because all study participants screened positive for elevated BP at baseline, only the PPV of each screening-confirmatory combination could be calculated for diagnostic accuracy (Table 26). It is important to note that in this scenario, persons with false-positive results are referred to as having isolated clinic hypertension, although this category could also include measurement error and regression to the mean.

Five studies measured 24-hour ABPM in 131 to 255 participants per study.127,135-137,143 The PPV of elevated OBPM for elevated ABPM ranged from 0.35 (95% CI, 0.27 to 0.42) to 0.89 (95% CI, 0.85 to 0.93) (Figure 10). That is, the proportion of participants with elevated OBPM and true hypertension (according to the ABPM reference standard) ranged from 35 to 89 percent. Factors that may have influenced the prevalence of true hypertension in the population, and thus PPV, were an older population in the study with the highest PPV136 and higher baseline OBPM in the three studies with the higher PPVs (Table 26).135,136,143 The study with the lowest PPV of 0.35 was a community-based study in rural Japan with a higher percentage of female participants (68%) than the other four studies (47% to 53%).127

Figure 10 Proportion of Elevated Office-Based Screening Results That Are Confirmed Hypertension by ABPM

Abbreviations: ABPM = ambulatory blood pressure monitoring; CI = confidence interval; hr = hour; PPV = positive predictive value.

Figure 10 plots the proportion (or positive predictive value) of elevated blood pressure screening results that are confirmed hypertensive by ambulatory blood pressure monitoring

Daytime ABPM was measured in 18 nonoverlapping studies that evaluated diagnostic accuracy in 69 to 1,466 participants per study.114,128,130-134,138-142,145,148-152 The proportion of participants with elevated OBPM and true hypertension (as measured by daytime ABPM) ranged from 0.47 (95% CI, 0.40 to 0.55) to 0.93 (95% CI, 0.87 to 0.99) (Figure 10). Two other studies reported diagnostic comparisons of OBPM and ABPM, but are not included in Table 26 or Figure 10. Licitra and colleagues used an unusually low OBPM threshold of 120/80 mm Hg, but a standard ABPM threshold of 135/85 mm Hg. Not surprisingly, the resulting PPV was low (0.20).138 Andreadis and colleagues reported only a kappa result of 0.32, but did not report results that could be used to calculate PPV.128 In general, no qualitatively examined factors clearly influenced hypertension prevalence in the population (Table 26). However, OBPM that was repeated within a single visit and/or across more than one visit before referral to ABPM appeared to be more frequently associated with higher ABPM PPVs. The study with the lowest PPV (0.47 [95% CI, 0.40 to 0.55]) also had the highest percentage of women in the study population (67%).150

Cuspidi and colleagues confirmed 658 participants with elevated OBPM using nighttime ABPM, reporting 95 percent as hypertensive (95% CI, 93% to 97%).129 These patients had been diagnosed and confirmed using office-based methods during two visits in the previous 12 months, which may have helped select for likely true hypertension. Additionally, the threshold for nighttime ABPM confirmation was low at 120/70 mm Hg, which may have allowed more patients to be confirmed and helped to increase the PPV.

Seven studies conducted HBPM after OBPM in 100 to 361 participants per study.127,128,134,136,142, 146,147 Participants whose elevated OBPM was confirmed with HBPM represented 45 (95% CI, 37 to 53) to 84 percent (95% CI, 80 to 89) of the population (Figure 11; Table 26). One additional study reported only a kappa result of 0.32.^128^ Three of four studies with higher PPV results measured OBPM on more than one visit, and two of these studies repeated measurements at each visit.134,142,147 The fourth study only measured OBPM once, but the study population was noticeably older than in other studies, which could have increased hypertension prevalence.136 Finally, four studies formally confirmed participants with initial elevated BP (range, 221 to 3,464 participants) using the same office-based methods at a second visit137,144,152 or during multiple visits.130 Of those participants with initial elevated BP, 58 to 96 percent were confirmed using the BP measurement results of the additional visit(s).Three other studies also confirmed participants with initial elevated BP; however, it was unclear if the same office-based methods were used at the second visit.142,148,150 Study participants whose elevated OBPM was confirmed by a second OBPM comprised 67 to 82 percent of the population.

Figure 11 Proportion of Elevated Office-Based Screening Results That Are Confirmed Hypertension by HBPM

Abbreviations: CI = confidence interval; HBPM = home blood pressure monitoring; PPV = positive predictive value.

Figure 11 plots the proportion (or positive predictive value) of elevated blood pressure screening results that are confirmed hypertensive by home blood pressure monitoring

In summary, initial screening using OBPM methods variably predicted true hypertension, as defined by ABPM or confirmation with HBPM. Factors influencing this variability may include population characteristics that influence hypertension prevalence, such as age or baseline BP, but these characteristics do not appear to explain all variability. These results suggest that repeating initial screening BP measurements over more than one visit may improve PPV, but this is not clearly demonstrated. Finally, the proportion of study participants who had initial elevated OBPM but were diagnosed as normotensive using the reference method varied, ranging from 5 to 65 percent across all studies. We further investigate this variability in the next section of this report.

## KQ 3c Does Changing the Measurement Method From That Used During the Initial Screening Improve Diagnostic Accuracy for Some Specific Patient Subgroups?

The study design necessary to answer this question would enroll participants with elevated BP detected by an office-based screening method. Followup BP measurements would include both ABPM and repeat OBPM at a separate visit (and ideally HBPM as well). This design allows direct comparison of confirmatory measurement methods and results within the same population. While we found five studies that used this design,130,137,142,148,150 only two studies clearly reported use of the same OBPM method for the prestudy and first OBPM visits (Table 27; Appendix C Tables 31–33).130,137 One study used only one additional OBPM visit; the prestudy OBPM predicted the first OBPM visit result with a PPV of 76 percent, but the prestudy and first OBPM visit measurements predicted the reference ABPM result with PPVs of only 52 and 56 percent, respectively, suggesting that changing the measurement method to ABPM improved diagnostic accuracy in this study.137 The other study included four additional OBPM visits using the same method.130 The prestudy OBPM predicted the first OBPM visit result with a PPV of 96 percent; the PPV for the final OBPM visit decreased to 82 percent. The prestudy OBPM predicted the reference ABPM result with a PPV of 74 percent. Again, although the percentage of patients with confirmed elevated BP decreased with repeat OBPM, the percentage was lowest with followup ABPM.

Table 27 Studies Reporting the Positive Predictive Value of OBPM for Selected Confirmatory Measurement Methods

Author, Year | OBPM | Confirmatory BP | PPV of OBPM for Confirmatory BP
Khoury, 1992^137^ | Prestudy visit | First OBPM visit | 0.76
Khoury, 1992^137^ | Prestudy visit | ABPM | 0.52
Khoury, 1992^137^ | First study OBPM visit | ABPM | 0.56
Fogari, 1996^130^ | Prestudy visit | First OBPM visit | 0.96
Fogari, 1996^130^ | Prestudy visit | Final OBPM visit | 0.82
Fogari, 1996^130^ | Prestudy visit | ABPM | 0.74

Abbreviations: ABPM = ambulatory blood pressure monitoring; BP = blood pressure; OBPM = office-based blood pressure measurement; PPV = positive predictive value.

While one other study found a similar pattern of results,150 the PPVs in two other studies were much more similar to each other.142,148 However, we cannot draw conclusions from these three additional studies without knowing the office methods used at each visit. The results from KQ 3b indicate that use of a confirmatory BP measurement method can identify a subpopulation of persons with isolated clinic hypertension. These results, however, do not conclusively show whether the use of a different confirmatory measurement from the screening method improves diagnostic accuracy.

We also examined the same studies from KQ 3b by subpopulations, where available, to determine any qualitatively consistent association with higher versus lower PPV (Appendix C Table 34). There did not appear to be any association between reported age, race/ethnicity, sex, or smoking and PPV. Increasing stage of hypertension was clearly associated with increasing PPV. In one study, for example, hypertension classified as JNC 5 stages I, II, III, and IV was associated with PPVs of 0.74, 0.88, 0.97, and 1.0, respectively.149 Thus, the likelihood of confirmation is greater when the initial elevated BP is well above the threshold for a diagnosis of hypertension than when it is closer to the threshold.

## KQ 4 What Is the Clinically Appropriate Rescreening Interval for Patients Who Have Previously Been Screened and Found to Have Normal BP?

We identified 40 fair- to good-quality studies for KQ 4 (Appendix C Tables 35–37).144,153-191 Thirty-nine studies were relevant to KQ 4a and 39 were relevant to KQ 4b. Some studies contributed to both subquestions and some contributed to just one. Details are addressed in each subquestion below.

## KQ 4a What Is the Shortest Interval in Which Clinically Significant, Diagnosed Hypertension May Develop?

We identified 43 articles (17 good-quality and 26 fair-quality) reporting results from 39 individual studies that provided evidence for this KQ.144,153-168,170-191

Study enrollment at baseline ranged from 275 to 115,736 participants. We evaluated screening intervals of less than 6 years. Most studies (k=16) reported results for a 5-year interval. Two studies provided data at more than one rescreening interval.155,174 Most studies used a diagnostic threshold of 140/90 mm Hg or greater, but some used thresholds of 160/95 mm Hg or greater,154,161,162,171,173,184 and two studies used diastolic-only thresholds of 95 mm Hg or greater or greater than 100 mm Hg.153,155 Many studies considered the use of antihypertensive medications equivalent to a BP level exceeding the diagnostic threshold. One study defined incident hypertension by self-report with physician confirmation of diagnosis or use of antihypertensive treatment.180 Studies were conducted in Asia (19 studies), the United States (eight studies), Europe (10 studies), the United Kingdom, and Australia. Of the Asian studies, 12 were conducted in Japan, primarily in workplace settings. Twenty-one studies were community-based, 12 were employment-based, and six were clinic-based. Two clinics were specialized—one was an outpatient cardiology department160 and another was a women’s health clinic.164

Table 28 shows the weighted mean incidence of hypertension at intervals of less than 6 years; results were 2.5 percent at 1 year (range, 2.5% to 4.4%; k=2; n=17,740), 7.7 percent at 2 years (range, 1.2% to 12.3%; k=6; n=76,753), and 16.6 percent at 3 years (range, 6.6% to 24.9%; k=7; n=20,822). At 4 years, the weighted mean incidence of 34.4 percent (range, 2.1% to 39.2%; k=6; n=141,514) was strongly influenced by one study, which reported an unusually high incidence of 39.2 percent and contributed the vast majority of observations (n=115,736). We could find no characteristics of this study or its enrolled population to clearly explain the high incidence.189 In a sensitivity analysis excluding this study, the annual incidence plateaued at 12.4 percent at 4 years (range, 2.1% to 23.7%; k=5; n=25,778) and 13.7 percent at 5 years (range, 2.1% to 28.4%; k=16; n=54,964).

Table 28 Weighted Mean Hypertension Incidence by Rescreening Interval

| 1 Year | 2 Years | 3 Years | 4 Years | 5 Years
Weighted mean incidence, % (range) | 2.5% (2.5 to 4.4)^*^ | 7.7% (1.2 to 12.3) | 16.6% (6.6 to 24.9) | 34.4% (2.1 to 39.2)^†^ | 13.7% (2.1 to 28.4)
Number of studies (N) | 2 (17,740) | 6 (76,753) | 7 (20,822) | 6 (141,514)^†^ | 16 (54,964)

* If the incidence rate based on one visit in Radi, 2004 is used instead of the incidence rate based on two visits, the mean weighted incidence is 5.4% (range, 4.4 to 5.4).

† If Okubo, 2014 (n=115,736) is not included in the 4-year interval, the weighted mean incidence is 12.4% (range, 2.1 to 23.7) in 5 studies (N=25,778).

Characteristics of the included studies are presented in Table 29. Figure 12 shows a plot of hypertension incidence by rescreening interval. Notably, at each interval there was a wide range of incidence estimates among studies, showing that weighted mean incidence values are not sufficiently informative. Each of the six studies indicated by the circular symbols based hypertension incidence on multiple visits, either by use of a confirmation visit or by averaging BP measurements across two or more visits. Only one study, however, actually reported hypertension incidence based on one versus two visits per screening.144 Hypertension incidence decreased by about half when incidence was based on two visits versus one (2.5% vs. 5.4%).144 It is important to note that the confirmed incidence from this study was used for calculating weighted mean incidence at 1 year (Table 28) and considerably affected that estimate.

Figure 12 Scatterplot of Hypertension Incidence by Rescreening Interval

Abbreviation: HTN = hypertension.

* The size of the symbol represents the number of participants in the study.

Figure 12 is a scatterplot of hypertension incidence by rescreening interval differentiating between those who are confirmed with a second measurement or not; those with longer followup have higher incidence rates

Table 29 Hypertension Incidence at Various Rescreening Intervals (Sorted by Interval)

Author, Year Quality | Country | N | Mean Age, y; Range | Mean BL Office SBP/DBP (mm Hg) | % Female | Mean BMI; % With BMI >30 kg/m^2^ if Reported | % Smokers | Interval, y | Unadjusted Incidence, % | Diagnostic Threshold
Bakx, 1987^155^ Fair | The Netherlands | 1953 followed for max 17 years; N at 0.5 years NR | NR; 20-50 | NR | 61.0 | NR | NR | 0.5 | 2.0^*^ | DBP ≥100 mm Hg
Cacciolati, 2013^158^ Fair | France | 275 | 77.8; ≥73 | 133.0/72.8 | 67.6 | 24.4 | NR | 1 | 4.4^†^ | ≥140/90 mm Hg in office and ≥135/85 mm Hg at home
Kubo, 2013^188^ Fair | Japan | 10173 followed for max 27.5 years; N at 1 year NR | 23.6; <30 | 118.9/67.2 | 0 | 21.7 | 49.37 | 1 | 4.3^*^ | ≥140/90 mm Hg
Radi, 2004^144^ Fair | France | 17465 | 38.2; 15-69 | 119.5/75.3 | 44.5 | 23.9; 5.95% | 33.47 | 1 | 2.5^†^ | ≥140/90 mm Hg or meds
Radi, 2004^144^ Fair | France | 16655 | 38.2; 15-69 | 119.5/75.3 | 44.5 | 23.9; 5.95% | 33.47 | 1 | 5.4^‡^ | ≥140/90 mm Hg or meds
Bakx, 1987^155^ Fair | The Netherlands | 1953 followed for max 17 years; N at 1.5 years NR | NR; 20-50 | NR | 61.0 | NR | NR | 1.5 | 3.6^*^ | DBP ≥100 mm Hg
Fitchett, 2009^163^ Fair | United States | 1001 | 50.0; 42-52 | 118.4/NR | 100 | 30.1 | NR | 2 | 8.9 | ≥140/90 mm Hg or meds
Kim, 2006^166^ Good | Korea | 5869 | 50.8; 40-69 | 113.1/75.3 | 52.4 | 24.2 | 26.07 | 2 | 12.3 | ≥140/90 mm Hg or meds
Kim, 2011^167^ Fair | Korea | 49228 | 37.9; 30-54 | 112.4/72.8 | 32.7 | 22.3 | 40.32 | 2 | 9.2 | ≥140/90 mm Hg
Kubo, 2013^188^ Fair | Japan | 10173 followed for max 27.5 years; N at 2 years NR | 23.6; <30 | 118.9/67.2 | 0 | 21.7 | 49.37 | 2 | 7.5^*^ | ≥140/90 mm Hg
Levine, 2011^174^ Good | United States | 3436 | 25.1; 18-30 | 109.5/68.1 | 57.1 | 24.3; 10.62% | 26.27 | 2 | 1.2 | ≥140/90 mm Hg or meds
Schulz, 2005^180^ Fair | Germany | 12362 | 47.5; 19-69 | 119/78 | 69.1 | 24.9; 8.51% | 22.18 | 2 | 1.4 | Self-reported diagnosis or meds verified by doctor
Tozawa, 2002^182^ Fair | Japan | 4857 | 46; NR | 115/71 | 36.0 | 31% with BMI ≥25 kg/m^2^ | 30 | 2 | 7.4 | ≥140/90 mm Hg
Bakx, 1987^155^ Fair | The Netherlands | 1953 followed for max 17 years; N at 2.5 years NR | NR; 20-50 | NR | 61.0 | NR | NR | 2.5 | 4.8^*^ | DBP ≥100 mm Hg
Jung, 2014^187^ Good | South Korea | 1553 | 53.9; 40-70 | 116.9/73.8 | 62.4 | NR; 32.52 | 16.74 | 2.6 | 11.5 | ≥140/90 mm Hg or meds
Matsuo, 2011^175^ Fair | Japan | 5201 | 41.2; 30-59 | 121.8/73.8 | 0 | 23.7 | 41.9 | 2.9 | 17.2 | ≥140/90 mm Hg or meds
Apostolides, 1982^153^ Fair | United States | 2738 | NR; 30-69 | NR | 52.7 | NR | NR | 3 | 14.9 | DBP>95 mm Hg or meds
Juhaeri, 2002^165^ Good | United States | 9319 | 53.4; 46-65 | 113.6/70.0 | 55.1 | 26.7 | 25.9 | 3 | 10.4 | ≥140/90 mm Hg or meds
Kubo, 2013^188^ Fair | Japan | 10173 followed for max 27.5 years; N at 3 years NR | 23.6; <30 | 118.9/67.2 | 0 | 21.7 | 49.37 | 3 | 10.0^*^ | ≥140/90 mm Hg
Satoh, 2010^179^ Fair | Japan | 2278 | 46; 35-55 | 117/74 | 0 | 23.7 | 51.1 | 3 | 6.6 | ≥140/90 mm Hg or meds
Yambe, 2007^185^ Good | Japan | 1758 | 40.6; NR to <64 | 117.9/73.6 | 0 | 23.3 | 41.13 | 3 | 8.9 | ≥140/90 mm Hg or meds
Zambrana, 2014^190^ Fair | United States | 3145 | NR; 50-79 | NR | 100 | NR; 30.52 | 7.22 | 3 | 19.8 | ≥140/90 mm Hg, self-reported physician diagnosis, or meds
Fagot-Campagna, 1997^162^ Fair | France | 4149 | 49.3^§^; 43-54 | 130/80^§^ | 0 | 25.3 | NR | 3.16 | 24.9 | ≥160/95 mm Hg or meds
Bakx, 1987^155^ Fair | The Netherlands | 1953 followed for max 17 years; N at 3.5 years NR | NR; 20-50 | NR | 61.0 | NR | NR | 3.5 | 6.0^*^ | DBP ≥100 mm Hg
Okubo, 2014^189^ Fair | Japan | 115,736 | 54.5; 40-79 | 120.9/73.3 | 67.76 | 22.8 | 21.57 | 3.9 | 39.2 | >140/90 mm Hg or meds
Dernellis, 2005^160^ Fair | Greece | 2512 | 64.6; 35-94 | 119.8/77.2 | 57.3 | 26.8 | 20.98 | 4 | 23.7^†^ | ≥140/90 mm Hg
Kubo, 2013^188^ Fair | Japan | 10,173 followed for max 27.5 years; N at 4 years NR | 23.6; <30 | 118.9/67.2 | 0 | 21.7 | 49.37 | 4 | 12.5^*^ | ≥140/90 mm Hg
Lee, 2004a171 Good | Korea | 8170 | 38.7; 25-50 | 114.9/72.7 | 0 | 22.5 | NR | 4 | 2.1 | ≥160/95 mm Hg
Vasan, 2001^183^ Good | United States | 9845 | 52.1; 35-94 | 118.5/74 | 57.3 | 25.8 | 26.4 | 4 | 19.4 | ≥140 mm Hg or meds
Brantsma, 2006^157^ Good | The Netherlands | 4635 | 45.2; 28-75 | 119.1/69.6 | 54.4 | 25.1 | 39.31 | 4.2 | 8.9^†^ | ≥140/90 mm Hg or meds
Everson, 2000^161^ Good | Finland | 616 | 50.4; 42-60 | 126.4/83.2 | 0 | 25.9 | 33.12 | 4.2 | 20.4 | ≥165/95 mm Hg or meds as confirmed during medical exam
Bakx, 1987^155^ Fair | The Netherlands | 1953 followed for max 17 years; N at 4.5 years NR | NR; 20-50 | NR | 61.0 | NR | NR | 4.5 | 7.1^*^ | DBP ≥100 mm Hg
Shook, 2012^181^ Fair | United States | 6278 | 44.7; 20-80 | 115.1/76.9 | 23.9 | 25.2 | 11.6 | 4.7 | 24.6 | ≥140/90 mm Hg
Arima, 2002^154^ Fair | Japan | 1133 | 56; 40-79 | 124.7/74.4 | 64.3 | 22.7 | 20.56 | 5 | 16.4 | ≥160/95 mm Hg or meds
Boyko, 2008^156^ Fair | Australia | 4306 | 47.6; ≥25 to NR | 120.2/67.0 | 57.0 | 26.1 | 12.63 | 5 | 14.0 | ≥140/90 mm Hg or meds
Kubo, 2013^188^ Fair | Japan | 10,173 followed for max 27.5 years; N at 5 years NR | 23.6; <30 | 118.9/67.2 | 0 | 21.7 | 49.37 | 5 | 15.0^*^ | ≥140/90 mm Hg
Lakoski, 2011^170^ Good | United States | 3543 | 59; 45-84 | NR | 51.2 | 27.4 | 14.56 | 5 | 20.2 | ≥140/90 mm Hg or history of HTN and meds
Lee, 2004b173 Fair | Japan | 5840 | 48.6; 30-69 | 110.5/69.8 | 41.3 | 22.9; 1.18% | 35.58 | 5 | 10.5^†^ | ≥160/95 mm Hg more than once or meds
Lee, 2011^172^ Fair | Korea | 730 | 56.6; ≥20 to NR | 119.8/75.8 | 63.7 | 23.2 | 24.66 | 5 | 26.7 | ≥140/90 mm Hg or meds
Levine, 2011^174^ Good | United States | 3436 | 25.1; 18-30 | 109.5/68.1 | 57.1 | 24.3;10.62% | 26.27 | 5 | 3.23 | ≥140/90 mm Hg or meds
Morikawa, 1999^176^ Good | Japan | 1551 | 34.7; 18-49 | 117.7/69.4 | 0 | 22.2 | 66.2 | 5 | 7.0 | ≥140/90 mm Hg
Nakanishi, 2003^177^ Good | Japan | 3784 | 42.0; 23-59 | 121.3/72.9 | 0 | 23.0 | 48.97 | 5 | 28.4 | ≥140/90 mm Hg or meds
Okubo, 2004^178^ Fair | Japan | 2107 | 45.8; 40-54 | 122.10/73.29 | 0 | 23.1 | 60.13 | 5 | 3.1 | ≥140/90 mm Hg
Sung, 2014^186^ Fair | South Korea | 11448 | 40.6; NR | 111.4/72.0 | 30.64 | 23.6 | 48.88 | 5 | 8.0 | ≥140/90 mm Hg or meds
Yamada, 1991^184^ Good | Japan | 1393 | 42.4; 35-54 | 119.2/73.5 | 0 | 23.1 | NR | 5 | 2.1^†^ | >160/95 mm Hg during annual checkup and confirmed by average of 3 or 4 subsequent visits
Giubertoni, 2013^164^ Fair | Italy | 640 | 55.2; NR to <65 | NR/NR | 100 | 26.3 | 17.7 | 5.25 | 17.0 | >140/90 mm Hg (med status in definition NR)
Cheung, 2012^159^ Fair | Hong Kong | 1115 | 48.3; 25-74 | 113.9/72.2 | 56.6 | 23.6 | 16.32 | 5.3 | 21.2 | ≥140/90 mm Hg or meds
Volzke, 2013^191^ Good | Germany | 1605 | 42.9; 20-79 | 120.5/76.8 | 63.05 | 25.4 | 30.34 | 5.3 | 20.1 | ≥140/90 mm Hg or meds
Bakx, 1987^155^ Fair | The Netherlands | 1953 followed for max 17 years; N at 5.5 years NR | NR; 20-50 | NR | 61.0 | NR | NR | 5.5 | 8.6^*^ | DBP ≥100 mm Hg
Kivimaki, 2009^168^ Fair | United Kingdom | 6055 | 44.6; 35-55 | 118.9/74.6 | 31.1 | 24.3 | 15.69 | 5.6 | 11.8 | ≥140/90 mm Hg or meds

* Not included in plots or pooled estimates because estimated from figure; N at specified interval NR.

† Measure based on more than 1 visit or involved additional confirmation step.

‡ Not included in pooled estimates (Radi, 2004 incidence based on 2 visits was pooled); included for illustration only.

§ Median.

Abbreviations: BL = baseline; BMI = body mass index; DBP = diastolic blood pressure; HTN = hypertension; NR = not reported; SBP = systolic blood pressure.

Another study examining hypertension incidence at a 3-year rescreening interval found that only 44 percent of apparent incident hypertension cases based on one screening (14.9%) were confirmed in a second visit.153 We included only the incidence based on one screening in our analysis because of incomplete data reporting. Five other studies defined incident hypertension based on measurements taken at more than one visit or required confirmation.157,158,160,173,184 One study, for example, required both elevated office and home BP measurements (1-year incidence, 4.4%),158 another required elevated BP or use of antihypertensive medications at more than one annual checkup (5-year incidence, 10.5%),173 and another required confirmation of elevated BP using the average of three or four subsequent visits (5-year incidence, 2.1%).184 Except for the study by Dernellis and colleagues, studies defining hypertension based on multiple visits or confirmation generally showed lower incidence than studies using just one visit. This may be confounded, however, by varying population characteristics across studies, and the direct evidence is limited to one study.144 The study by Dernellis and colleagues evaluated an older population attending the cardiology outpatient department of a hospital.

In summary, a substantial proportion of incident hypertension cases were not confirmed in a small number of studies that used a separate confirmation step. Therefore, estimates of the weighted mean incidence of hypertension are likely to be overestimates since most studies did not include a confirmation step. Estimates of the weighted mean incidence of hypertension at yearly intervals less than 6 years (Table 28) were derived from a small number of studies (except at 5 years) and showed highly variable results. For example, while the weighted mean incidence at 5 years was about 14 percent, there was a wide range of results—from as low as 2 percent to as high as 28 percent. Some of this variation is related to the criteria used to diagnose and, in some studies, confirm incident hypertension. Some variation likely also arises from differences in the study populations. The wide variation in hypertension incidence highlights the importance of identifying subpopulations with a higher risk for incident hypertension that may benefit from targeted or more intensive rescreening. The following subquestion investigates this further.

## KQ 4b Does the Rescreening Interval Vary by Patient Characteristics?

Evidence for this KQ was provided by 44 articles reporting results from 39 individual studies.144, 153-180,182-191,202 There were 18 good-quality and 26 fair-quality articles. All but one article evaluated for KQ 4a provided information on subgroups for this KQ.181 Two additional articles completed the evidence base.169,202

Table 30 shows weighted mean hypertension incidence across studies at rescreening intervals of 1 to 5 years stratified by a priori subgroups (age, BP level, sex, BMI category, smoking status, and race/ethnicity). While this provides an overall summary and suggests some trends (e.g., increased incidence with age and BP level within the normal range at longer rescreening intervals), we focused our detailed evaluation on those studies that provided within-study comparisons directly addressing each subgroup category of interest.

Table 30 Weighted Mean Hypertension Incidence at Various Rescreening Intervals in a Priori Identified Subgroups

Subgroup | 1 Year | | | 2 Years | | | 3 Years | | | 4 Years | | | 5 Years
Subgroup | k (N) | %^*^ | Range | k (N) | %^*^ | Range | k (N) | %^*^ | Range | k (N) | %^*^ | Range | k (N) | %^*^ | Range
Age
18 to 40/45 years | 1^†^ (9617) | 1.0 | -- | 1 (3436) | 1.2 | -- | -- | -- | -- | 1 (7797) | 1.8 | -- | 3 (4568) | 4.1 | 3.2 to 17.8
40/45 to 60/65 years | 1^†^ (5805) | 4.0 | -- | 1 (1001) | 8.9 | -- | 2 (13,468) | 14.9 | 10.4 to 24.9 | 2 (989) | 15.3 | 6.7 to 20.4 | 3 (3052) | 7.1 | 3.1 to 23.7
60/65 years or older | 1 (275) | 4.4 | -- | -- | -- | -- | -- | -- | -- | 2 (2858) | 37.5 | 35.4 to 40.3 | 1 (204) | 37.7 | --
BP level
High-normal | -- | -- | -- | 2 (5000) | 27.7 | 26.7 to 31.3 | 3 (3323) | 26.7 | 21.0 to 30.4 | 2 (4736) | 50.3 | 42.8 to 58.0 | 2 (1544) | 46.4 | 32.7 to 52.2
Normal | -- | -- | -- | 2 (50,117) | 7.7 | 7.6 to 7.8 | 3 (4318) | 7.0 | 4.4 to 9.0 | 1 (7443) | 11.8 | -- | 2 (2970) | 18.6 | 16.6 to 18.8
Sex
Male | 1^†^ (9691) | 3.4 | -- | 4 (40,519) | 10.6 | 1.8 to 13.0 | 7 (19,447) | 15.4 | 6.6 to 24.9 | 5 (49,283)^‡^ | 34.6 | 2.1 to 43.3 | 14 (31,153) | 13.0 | 2.1 to 28.4
Female | 1^†^ (7774) | 1.5 | -- | 5 (23,872) | 6.0 | 0.9 to 11.6 | 5 (19,308) | 7.8 | 1.4 to 19.8 | 3 (82,386)^‡^ | 36.0 | 8.7 to 37.3 | 11 (17,533) | 11.2 | 2.5 to 28.8
BMI
18.5 to <25 kg/m^2^ | 1 (11,751) | 1.5 | -- | 1 (3351) | 5.5 | -- | 1 (3521) | 13.8 | -- | -- | -- | -- | -- | -- | --
≥25 to 29.9 kg/m^2^ | 1 (4674) | 3.9 | -- | -- | -- | -- | 1 (1456) | 24.9 | -- | -- | -- | -- | -- | -- | --
≥30 kg/m^2^ | 1 (1040) | 7.6 | -- | 1 (1039) | 3.8 | -- | 1 (138) | 32.6 | -- | -- | -- | -- | -- | -- | --
Smoking
Current | 1 (5845) | 2.8 | -- | 1 (1457) | 5.4 | -- | 1 (1164) | 5.8 | -- | 2 (7194) | 3.4 | 1.8 to 8.3 | 6 (5288) | 10.6 | 3.0 to 22.0
Non or former smoker | 1 (11,620) | 2.4 | -- | 1 (3400) | 8.3 | -- | 1 (1114) | 7.5 | -- | 2 (5611) | 6.0 | 2.6 to 9.3 | 6 (13,222) | 15.1 | 3.4 to 21.0

* Weighted mean incidence.

† Incidence based on two visits; incidence based on one visit also reported but not pooled (Radi, 2004).144

‡ Okubo189 categorized in 4-year interval based on overall mean followup of 3.9 years; mean followup for women was 4.1 years and 3.4 years for men. If Okubo, 2014 (n=115,736) is not included in the 4-year interval, the weighted mean incidence for men is 7.3% with a range of 2.1% to 35.6% in 4 studies (N=11,973) and the weighted mean incidence for women is 10.9% with a range of 8.7% to 14.8% in 2 studies (N=3,960).

Abbreviations: BMI = body mass index; BP = blood pressure.

Four studies reported incidence by age strata (Table 31).144,171,172,176 In each study, incidence increased as much as two- to four-fold from the younger to older age categories. In three studies, hypertension incidence in the youngest stratum (18 to 40/45 years) ranged from 1.0 percent at 1 year to 5.5 percent at 5 years.144,171,176 The fourth study reporting age strata reported a high incidence of 17.9 percent in participants ages 20 to 45 years at 5 years. Incidence may be higher in this community-based study in rural Korea because of a smaller number of participants and a high proportion of prehypertensive participants (41%) enrolled in this age category.172

Table 31 Hypertension Incidence by Age Category at Various Rescreening Intervals (Sorted by Interval)

Author, Year Quality | Mean Age, y; Range | Country | N (% Ages 18 to 40/45 y) | Diagnostic Threshold | Mean BL Office SBP/DBP (mm Hg) | % Female | Interval, y | Unadjusted Incidence (Ages 18 to 40/45 y) | Unadjusted Incidence (Ages 40/45 to 60/65 y) | Unadjusted Incidence (Age ≥60/65 y)
Radi, 2004^144^ Fair | 38.2; 15-69 | France | 17,465 (55.1) | ≥140/90 mm Hg or meds | 119.5/75.3 | 44.5 | 1 | 1.0^*^ | 4.4^*,†^ | NR
Lee, 2004a171 Good | 38.7; 25-50 | Korea | 8170 (95.4) | ≥160/95 mm Hg | 114.9/72.7 | 0 | 4 | 1.8 | 6.7 | NA
Lee, 2011^172^ Fair | 56.6; ≥20 | Korea | 730 (15.3) | ≥140/90 mm Hg or meds | 119.8/75.8 | 63.7 | 5 | 17.9 | 23.7 | 37.7
Morikawa, 1999^176^ Good | 34.7; 18-49 | Japan | 1551 (65.8) | ≥140/90 mm Hg | 117.7/69.4 | 0 | 5 | 5.5 | 10.0 | NA

Note: Baseline characteristics are reported for the overall study population and are not further stratified by the identified subgroup.

* Includes persons ages 40 to 69 years.

† Measure based on more than one visit or involved additional confirmation step.

‡ Median.

Abbreviations: BL = baseline; DBP = diastolic blood pressure; HTN = hypertension; NA = not applicable; NR = not reported; SBP = systolic blood pressure.

Five studies reported hypertension incidence for three categories of normal BP—optimal (<120/80 mm Hg), normal (120–129/80–84 mm Hg), and high-normal (130–139/85–89 mm Hg) (Table 32).166,167,177,183,185 Hypertension incidence consistently tripled between optimal and normal BP categories within each study and approximately doubled between normal and high-normal categories (Figure 13). Participants with optimal BP had a very low probability (2% to 9%) of developing hypertension over a 5-year period.

Figure 13 Hypertension Incidence by Rescreening Interval, Stratified by Baseline Blood Pressure Level

Figure 13 is plots hypertension incidence by rescreening interval and stratified by baseline blood pressure level; those with highest blood pressure have higher incidence rates

Table 32 Hypertension Incidence by Blood Pressure Strata in Studies Reporting Three Strata

Study | Categories | Cases/N | Unadjusted Incidence, %
Kim, 2006^166^ 2-year interval | Optimal BP: <120/80 mm Hg | 158/3302 | 4.8
Kim, 2006^166^ 2-year interval | Normal: 120-129/80-84 mm Hg | 217/1485 | 14.6
Kim, 2006^166^ 2-year interval | High-normal: 130-139/85-89 mm Hg | 345/1102 | 31.3
Kim, 2011^167^ 2-year interval | Optimal BP: <120/80 mm Hg | 1671/32929 | 5.1
Kim, 2011^167^ 2-year interval | Normal: 120-129/80-84 mm Hg | 1800/12401 | 14.5
Kim, 2011^167^ 2-year interval | High-normal: 130-139/85-89 mm Hg | 1040/3898 | 26.7
Yambe, 2007^185^ 3-year interval | Optimal BP: <120/80 mm Hg | 17/702 | 2.4
Yambe, 2007^185^ 3-year interval | Normal: 120-129/80-84 mm Hg | 40/581 | 6.9
Yambe, 2007^185^ 3-year interval | High-normal: 130-139/85-89 mm Hg | 100/475 | 21.0
Vasan, 2001^183^ 4-year interval | Optimum: <120/80 mm Hg | 286/4499 | 6.4
Vasan, 2001^183^ 4-year interval | Normal: 120-129/80-84 mm Hg | 592/2944 | 20.1
Vasan, 2001^183^ 4-year interval | High-normal: 130-139/85-89 mm Hg | 1029/2402 | 42.8
Nakanishi, 2003^177^ 5-year interval | Low-normal: <120/80 mm Hg | 130/1418 | 9.2
Nakanishi, 2003^177^ 5-year interval | Normal: 120-129/80-84 mm Hg | 379/1281 | 29.6
Nakanishi, 2003^177^ 5-year interval | High-normal: 130-139/85-89 mm Hg | 567/1085 | 52.2

Abbreviation: BP = blood pressure.

Hypertension incidence was reported separately by sex in 21 studies (Table 33). In general, incidence tended to be higher in men than women. In six studies, however, the ratio of hypertension incidence for men versus women was especially high at 1.7 or higher.144,160,167,174, 186,203 In five of six studies, this elevated ratio was associated with a population mean age of about 40 years or younger, whereas all other studies with more similar hypertension incidence between men and women had population mean ages of about 45 years or older. One study with a high male-to-female hypertension incidence ratio enrolled a much older population with a mean age of 64.6 years. This study was conducted in the cardiology outpatient department of a hospital.160

Table 33 Hypertension Incidence by Sex at Various Rescreening Intervals (Sorted by Interval)

Author, Year Quality | Country | N (% Female) | Mean Age, y; Range | Diagnostic Threshold | Mean BL Office SBP/DBP (mm Hg) | Interval, y | Male Unadjusted Incidence, % | Female Unadjusted Incidence, % | Incidence Ratio Male:Female
Radi, 2004^144^ Fair | France | 17,465 (44.5) | 38.2; 15-69 | ≥140/90 mm Hg or meds | 119.5/75.3 | 1 | 3.4^*^ | 1.5^*^ | 2.3
Kim, 2006^166^ Good | Korea | 5869 (52.4) | 50.8; 40-69 | ≥140/90 mm Hg or meds | 113.1/75.3 | 2 | 13.0 | 11.6 | 1.1
Kim, 2011^167^ Fair | Korea | 49,228 (32.7) | 37.9; 30-54 | ≥140/90 mm Hg | 112.4/72.8 | 2 | 11.0 | 5.4 | 2.0
Levine, 2011^174^ Good | United States | 3436 (57.1) | 25.1; 18-30 | ≥140/90 mm Hg or meds | 109.5/68.1 | 2 | 1.8 | 0.9 | 2.0
Tozawa, 2002^182^ Fair | Japan | 4857 (36.0) | 46; NR | ≥140/90 mm Hg | 115/71 | 2 | 8.0 | 6.3 | 1.3
Jung, 2014^187^ Good | Korea | 1553 (62.4) | 53.9; 40-70 | ≥140/90 or meds | 116.9/73.8 | 2.6 | 13.5 | 10.2 | 1.3
Apostolides, 1982^153^ Fair | United States | 2738 (52.7) | NR; 30-69 | DBP>95 mm Hg or meds | NR | 3 | 14.8 | 15.0 | 1.0
Juhaeri, 2002^165^ Good | United States | 9319 (55.1) | 53.4; 46-65 | ≥140/90 mm Hg or meds | 113.6/70.0 | 3 | 11.6 | 9.4 | 1.2
Okubo, 2014^189^ Fair | Japan | 115,736 (67.76) | 54.5; 40-79 | >140/90 mm Hg or meds | 120.9/73.3 | 3.9 (3.4 for men, 4.1 for women) | 43.3 | 37.3 | 1.2
Dernellis, 2005^160^ Fair | Greece | 2512 (57.3) | 64.6; 35-94 | ≥140/90 mm Hg | 119.8/77.2 | 4 | 35.6^*^ | 14.8^*^ | 2.4
Brantsma, 2006^157^ Good | Netherlands | 4635 (54.4) | 45.2; 28-75 | ≥140/90 mm Hg or meds | 119.1/69.6 | 4.2 | 9.2^*^ | 8.7^*^ | 1.1
Arima, 2002^154^ Fair | Japan | 1133 (64.3) | 56; 40-79 | ≥160/95 mm Hg or meds | 124.7/74.4 | 5 | 16.0 | 16.6 | 1.0
Boyko, 2008^156^ Fair | Australia | 4306 (57.0) | 47.6; ≥25 to NR | ≥140/90 mm Hg or meds | 120.2/67.0 | 5 | 15.6 | 12.7 | 1.2
Klein, 2006^169,‡^ Good | United States | NR (56.8) | 57.6; 43-84 | ≥140/90 mm Hg or meds | 119/74 | 5 | 19 | 16.6 | 1.1
Lakoski, 2011^170^ Good | United States | 3543 (51.2) | 59; 45-84 | ≥140/90 mm Hg or history of HTN and meds | NR | 5 | 19.6 | 20.7 | 0.9
Lee, 2004b173 Fair | Japan | 5840 (41.3) | 48.6; 30-69 | ≥160/95 mm Hg more than once or meds | 110.5/69.8 | 5 | 11.7^*^ | 8.9^*^ | 1.3
Lee, 2011^172^ Fair | Korea | 730 (63.7) | 56.6; ≥20 to NR | ≥140/90 mm Hg or meds | 119.8/75.8 | 5 | 23.0 | 28.8 | 0.8
Levine, 2011^174^ Good | United States | 3436 (57.1) | 25.1; 18-30 | ≥140/90 mm Hg or meds | 109.5/68.1 | 5 | 4.2 | 2.5 | 1.7
Sung, 2014^186^ Fair | Korea | 11448 (30.64) | 40.6; NR | ≥140/90 mm Hg or meds | 111.4/72.0 | 5 | 9.7 | 4.0 | 2.4
Cheung, 2012^159^ Fair | China (Hong Kong) | 1115 (56.6) | 48.3; 25-74 | ≥140/90 mm Hg or meds | 113.9/72.2 | 5.3 | 22.5 | 20.1 | 1.1
Volzke, 2013^191^ Good | Germany | 1605 (63.05) | 42.9; 20-79 | ≥140/90 mm Hg or meds | 120.5/76.8 | 5.3 | 23.9 | 17.9 | 1.3
Kivimaki, 2009^168^ Fair | United Kingdom | 6055 (31.1) | 44.6; 35-55 | ≥140/90 mm Hg or meds | 118.9/74.6 | 5.6 | 12.6 | 10.2 | 1.2

Note: Baseline characteristics are reported for the overall study population and are not further stratified by the identified subgroup.

* Measure based on more than one visit or involved additional confirmation step.

† Median.

‡ Not included in plots because estimated from figure; N at specified interval NR.

Abbreviations: BMI = body mass index; DBP = diastolic blood pressure; HTN = hypertension; NR = not reported.

Two studies reported hypertension incidence data by BMI category—one study at a 1-year rescreening interval and another study at a 3-year rescreening interval.144,175 Within each study, incidence nearly doubled between normal weight and overweight participants, and increased again for the obese category (Figure 14). In each study reporting on BMI, a significant proportion of participants were current smokers. Twelve studies reported hypertension incidence by smoking status. Interestingly, the incidence of hypertension appeared to be similar or lower in current smokers than nonsmokers and former smokers at all rescreening intervals (Table 34).

Figure 14 Hypertension Incidence by Rescreening Interval, Stratified by Baseline Body Mass Index

Abbreviation: BMI = body mass index.

Figure 14 is a bar graph of hypertension incidence by baseline body mass index; those with higher body mass indexes have higher incidence rates

Table 34 Hypertension Incidence by Smoking Status at Various Rescreening Intervals (Sorted by Interval)

Author, Year Quality | Country | N (% Smokers) | Mean Age, y; Range | Diagnostic Threshold | Mean BL Office SBP/DBP (mm Hg) | % Female | Mean BMI; % With BMI >30 kg/m^2^ | Interval, y | Incidence, % in Current Smokers | Incidence, % in Non- and Ex-Smokers
Radi, 2004^144^ Fair | France | 17,465 (33.47) | 38.2; 15-69 | ≥140/90 mm Hg or meds | 119.5/75.3 | 44.5 | 23.9; 5.95% | 1 | 2.8^*^ | 2.4^*^
Tozawa, 2002^182^ Fair | Japan | 4857 (30) | 46; NR | ≥140/90 mm Hg | 115/71 | 36.0 | NR; 31% with BMI ≥25 kg/m^2^ | 2 | 5.4 | 8.3
Satoh, 2010^179^ Fair | Japan | 2278 (51.1) | 46; 35-55 | ≥140/90 mm Hg or meds | 117/74 | 0 | 23.7 | 3 | 5.8 | 7.5
Lee, 2001^293^ Good | Japan | 8161 (65.75) | 34.7; NR | ≥160/95 mm Hg | 114.9/72.7 | 0 | 22.5 | 4 | 1.8 | 2.6
Brantsma, 2006^157^ Good | Netherlands | 4635 (39.31) | 45.2; 28-75 | ≥140/90 mm Hg or meds | 119.1/69.6 | 54.4 | 25.1 | 4.2 | 8.3^*^ | 9.3^*^
Boyko, 2008^156^ Fair | Australia | 4306 (12.63) | 47.6; ≥25 to NR | ≥140/90 mm Hg or meds | 120.2/67.0 | 57.0 | 26.1 | 5 | 12.1 | 14.2
Cheung, 2012^159^ Fair | China (Hong Kong) | 1115 (16.32) | 48.3; 25-74 | ≥140/90 mm Hg or meds | 113.9/72.2 | 56.6 | 23.6 | 5.3 | 22.0 | 21.0
Lakoski, 2011^170^ Good | United States | 3537^†^ (14.56) | 59; 45-84 | ≥140/90 mm Hg or history of HTN and meds | NR | 51.2 | 27.4 | 5 | 19.6 | 20.3
Lee, 2004b173 Fair | Japan | 5840 (35.58) | 48.6; 30-69 | ≥160/95 mm Hg more than once or meds | 110.5/69.8 | 41.3 | 22.9; 1.18% | 5 | 9.9^*^ | 10.9^*^
Okubo, 2004^178^ Fair | Japan | 2107 (60.13) | 45.8; 40-54 | ≥140/90 mm Hg | 122.10/73.29 | 0 | 23.10 | 5 | 3.0 | 3.4
Sung, 2011^203^ Fair | Korea | 10,894 (30.33) | 40.4; NR | ≥140/90 mm Hg or history of HTN in 2003-2008 | 111.3/72.0 | 31.1 | 23.5 | 5 | 9.7 | 7.4
Volzke, 2013^191^ Good | Germany | 1605 (30.34) | 42.9; 20-79 | ≥140/90 mm Hg or meds | 120.5/76.8 | 63.05 | 25.4 | 5.3 | 18.3 | 20.9

Note: Baseline characteristics are reported for the overall study population and are not further stratified by the identified subgroup.

* Measure based on more than one visit or involved additional confirmation step.

† Smoking status not reported for six participants.

Abbreviations: BMI = body mass index; DBP = diastolic blood pressure; HTN = hypertension; NR = not reported.

Six studies reported hypertension incidence at rescreening intervals by race/ethnicity. All were conducted in the United States (Table 35).153,163,165,170,174 Only one study reported results for more than two categories.170 Lakoski and colleagues reported higher incidence rates for African Americans at 5 years (27.5%) than for Asians, whites, or Hispanics (16.2% to 21.2%). One U.S. study conducted in Hispanic women ages 50 to 79 years reported a 3-year incidence of 19.8 percent, but within-study comparisons with other racial/ethnic subgroups were not reported.190 The remaining studies only reported results for African Americans and whites at 2, 3, and 5 years. Hypertension incidence in African Americans was nearly two or more times higher than in whites at all intervals. This was true even for a very young population with a mean age of 25 years (range, 18 to 30 years) that reported hypertension incidence at 2 and 5 years.174

Table 35 Hypertension Incidence by Race/Ethnicity at Various Rescreening Intervals (Sorted by Interval)

Author, Year^*^ Quality | Mean Age, y; Range | Diagnostic Threshold | Mean BL Office SBP/DBP (mm Hg) | Interval, y | N | Race/Ethnicity | Unadjusted Incidence, %
Fitchett, 2009^163^ Fair | 50.0; 42-52 | ≥140/90 mm Hg or meds | 118.4/NR | 2 | 262 | African American | 17.9
Fitchett, 2009^163^ Fair | 50.0; 42-52 | ≥140/90 mm Hg or meds | 118.4/NR | 2 | 739 | White | 5.7
Levine, 2011^174^ Good | 25.1; 18-30 | ≥140/90 mm Hg or meds | 109.5/68.1 | 2 | 1582 | African American | 1.8
Levine, 2011^174^ Good | 25.1; 18-30 | ≥140/90 mm Hg or meds | 109.5/68.1 | 2 | 1854 | White | 0.8
Juhaeri, 2002^165^ Good | 53.4; 46-65 | ≥140/90 mm Hg or meds | 113.6/70.0 | 3 | 1567 | African American | 16.4
Juhaeri, 2002^165^ Good | 53.4; 46-65 | ≥140/90 mm Hg or meds | 113.6/70.0 | 3 | 7752 | White | 9.2
Apostolides, 1982^153^ Fair | NR; 30-69 | DBP >95 mm Hg or meds | NR | 3 | 1222 | African American | 24.5
Apostolides, 1982^153^ Fair | NR; 30-69 | DBP >95 mm Hg or meds | NR | 3 | 1516 | White | 7.1
Levine, 2011^174^ Good | 25.1; 18-30 | ≥140/90 mm Hg or meds | 109.5/68.1 | 5 | 1582 | African American | 4.7
Levine, 2011^174^ Good | 25.1; 18-30 | ≥140/90 mm Hg or meds | 109.5/68.1 | 5 | 1854 | White | 2.0
Lakoski, 2011^170^ Good | 59; 45-84 | ≥140/90 mm Hg or history of HTN and meds | NR | 5 | 470 | Asian | 16.2
Lakoski, 2011^170^ Good | 59; 45-84 | ≥140/90 mm Hg or history of HTN and meds | NR | 5 | 713 | African American | 27.5
Lakoski, 2011^170^ Good | 59; 45-84 | ≥140/90 mm Hg or history of HTN and meds | NR | 5 | 1552 | White | 17.5
Lakoski, 2011^170^ Good | 59; 45-84 | ≥140/90 mm Hg or history of HTN and meds | NR | 5 | 808 | Hispanic | 21.2

Note: Baseline characteristics are reported for the overall study population and are not further stratified by the identified subgroup.

* All studies were conducted in the United States.

† Measure based on more than one visit or involved additional confirmation step.

Abbreviations: BMI = body mass index; DBP = diastolic blood pressure; HTN = hypertension; NR = not reported.

## KQ 5 What Are the Adverse Effects of Screening for High BP in Adults?

We identified nine fair- to good-quality studies—four RCTs192,194,195,197 and five prospective cohort studies193,196,198-200 (n=4,634)—examining the adverse effects of screening for high BP in adults (Appendix C Tables 38–41). Four trials examined the quality of life of patients after being labeled as hypertensive192,194 or prehypertensive.195,197 One good-quality trial195 and three fair-quality trials192,194,197 found no significant differences in psychological distress (General Health Questionnaire)192,194 or quality of life (Short-Form Health Survey) over short-term followup (2 weeks to 3 months) (Appendix C Table 41).192,195,197 Another fair-quality cohort study examined absenteeism from work before and after labeling as hypertensive over 1 to 4 years.193 The number of days absent per year, the number of days absent because of illness, the number of illness episodes, and the duration of illness episodes significantly increased from the year before compared with the year after labeling in those previously unaware of their hypertension status193 and remained significant up to 4 years of followup (p<0.01).204 Absenteeism increased the most among those who were least compliant with treatment for their hypertension. The reasons for this association cannot be determined from the study; one possibility suggested by the authors is an inappropriate response to diagnosis and labeling in a portion of the study population.204

Three fair-quality cohort studies reported significant sleep disturbances attributed to an ABPM device used for diagnosis confirmation, including less than usual sleep duration,196 poor sleep quality,199 frequent arousal from sleep, and subsequent removal of the device (Appendix C Table 41).198 Only one fair-quality study considered the physical consequences of ABPM, reporting that a third of the participants experienced pain (32%) or skin irritation (37%) when wearing an ABPM device, and the overall comfort of the monitor was rated poorly.198 Moderate to severe discomfort was more frequently reported during the use of an ABPM device than a HBPM device (p<0.0001), as well as greater restriction in daily activities (p<0.0001) in one fair-quality cohort study.200 Of the 104 participants, 41 and 70 percent had previously undergone ABPM or HBPM, respectively, which could have biased their opinion of the devices.