# Methods

## Scope and Purpose

The Agency for Healthcare Research and Quality (AHRQ) requested an updated evidence review on screening for high BP in adults. The USPSTF will use this report to update the 2007 recommendation on screening for high BP in adults.79 Questions on the role of confirming hypertension diagnoses, rescreening intervals, and ABPM and HBPM are central to this review and are addressed in new Key Questions (KQs). The USPSTF has not addressed ABPM and HBPM, confirmation of diagnosis, or rescreening interval in previous recommendations.

## KQs and Analytic Framework

We developed an Analytic Framework (Figure 1) and five KQs in consultation with the AHRQ Medical Officer and USPSTF members. KQs 1 and 5 were adapted from questions addressed in the previous review.80

1. Does screening for high BP reduce CVD and mortality in adults age 18 years or older?
2. What is the best way to screen for high BP in adults in the primary care setting?
  a. How accurate (i.e., sensitivity, specificity, predictive value) are clinic-based BP measurement methods (e.g., manual vs. automated) in provisionally diagnosing hypertension within a single visit?
  b. What screening protocol characteristics within a single visit (e.g., sitting quietly for 5 minutes, number of readings) define the best diagnostic accuracy?
3. What is the best way to confirm hypertension in adults who initially screen positive for high BP?
  a. How well do ABPM and HBPM methods predict CV events compared with clinic-based methods? What confirmation protocol characteristics define the best prediction of CV events? Which methods and associated protocols best predict CV events^*^?
    * The BP measurement method that best predicts long-term CV outcomes will be used as the reference standard for KQs 3b and 3c.
  b. How accurate are other noninvasive BP measurement methods in establishing or confirming the diagnosis of hypertension compared with these best methods and associated protocols? Does diagnostic accuracy vary by protocol characteristics (i.e., number of visits)?
  c. Does changing the measurement method from that used during the initial screening improve diagnostic accuracy for some specific patient subgroups (e.g., those with suspected white coat hypertension^†^)?
    † A key assumption underlying the Analytic Framework is that in the United States, BP screening occurs only in primary care settings and does not involve HBPM or ABPM. Thus, false-negatives, or “masked hypertension” (defined as normal office BP that is elevated only in out-of-office settings), is not addressed in this review, as patients with normal BP at screening would not proceed to the next step of confirmation through either additional office measures or home or ambulatory methods. Patients who have isolated clinic hypertension, however, may be detected by an initial elevated screen and would proceed to confirmation.
4. What is the clinically appropriate rescreening interval for patients who have previously been screened and found to have normal BP?
  a. What is the shortest interval in which clinically significant, diagnosed hypertension may develop?
  b. Does the rescreening interval vary by patient characteristics (e.g., age, sex, race/ethnicity, CV risk, BP level, screening history)?
5. What are the adverse effects of screening for high BP in adults?

Figure 1 Analytic Framework

Abbreviations: ABPM = ambulatory blood pressure monitoring; BP = blood pressure; CHD = coronary heart disease; CVD = cardiovascular disease; ESKD = end-stage kidney disease; HBPM = home blood pressure monitoring; HF = heart failure.

This figure is an analytic framework that depicts the five Key Questions described in the Method section. In general, it illustrates the overarching question of whether screening for high blood pressure in adults leads to improved health outcomes or potential harms. The analytic framework also illustrates the intermediate steps and Key Questions related to methods and protocols for the initial screening encounter that identifies individuals with elevated blood pressure, methods and protocols for confirmation (or no confirmation) of the diagnosis of hypertension at a subsequent encounter, and treatment of identified hypertensive patients, leading to improved outcomes. The analytic framework also identifies an interval after which individuals with normal blood pressure levels would be rescreened.

## Data Sources and Searches

We conducted a comprehensive literature search for existing systematic reviews in the following databases: MEDLINE, PubMed, the Database of Abstracts and Reviews of Effects, AHRQ, BMJ Clinical Evidence, the Canadian Agency for Drugs and Technologies in Health, Health Technology Assessment (Centre for Reviews and Dissemination), the Institute for Clinical Systems Improvement, the Institute of Medicine, the National Health Services Health Technology Assessment Programme, and the National Institute for Health and Clinical Excellence from January 1, 2005 to March 19, 2013.

For KQs 1 and 5, we searched the following databases from 2003 to February 24, 2014 to identify RCTs and controlled clinical trials (KQs 1 and 5) and cohort studies (KQ 5 only) to update evidence on benefits and harms of screening for high BP in adults: MEDLINE, PubMed, Cochrane Central Register for Controlled Clinical Trials, and Cumulative Index to Nursing and Allied Health. For KQs 2 and 3, we searched the following databases from January 1, 1992 (to allow for implementation of first guidelines for validation of BP monitoring devices81) to February 24, 2014 to identify diagnostic accuracy studies: MEDLINE, PubMed, and Cochrane Central Register for Controlled Clinical Trials. For KQ 4, we searched MEDLINE and PubMed from January 1, 1966 (beginning of MEDLINE) to February 24, 2014 to identify longitudinal cohort studies for high BP rescreening. We limited all searches to articles published in the English language and studies that enrolled human populations. All literature search strategies were designed by a research librarian. A second librarian reviewed each strategy (Appendix A).

We also reviewed reference lists of included studies, systematic reviews, and meta-analyses and the online publication lists of highly referenced studies (e.g., Framingham Heart Study) to identify potentially relevant studies that may not have been identified in our literature searches. We obtained additional references from bibliographies of other sources (e.g., guidelines). Literature search results were managed using Reference Manager® version 12.0 (Thomson Reuters, New York, NY), a bibliographic management software program.

## Study Selection

Two investigators independently reviewed 19,309 titles and abstracts and 1,171 full-text articles (Appendix A Figure 1) against prespecified inclusion and exclusion criteria (Appendix A Table 1). We used Abstrackr, a Web application, to manage the title and abstract dual-review screening process.82 Excluded studies and reasons for their exclusion are listed in Appendix B.

We required studies to be conducted in adult populations (i.e., >80% of the study population was age ≥18 years) or, if conducted in adults and children, we required results to be stratified by age group. Participants must not have been taking antihypertensive medications (except for KQ 3a). We excluded pregnant women, institutionalized persons, inpatients, and persons with an underlying cause of high BP. We excluded studies that enrolled a highly selected group of participants, such as renal transplant recipients or those with chronic kidney disease.

We required BP measurements to be taken on the upper arm (forearm cuffing was not acceptable). Although wrist devices can provide accurate BP results, their use is discouraged because the arm position may not be carefully controlled.83,84 Measurements taken closer to the periphery of appendages may overestimate vascular resistance changes and BP.33,85 Thus, we excluded wrist, ankle, finger, and toe BP monitors and measurements. We also excluded any BP measurement methods not commonly used in routine screening practices, such as invasive methods or noninvasive central BP measurements. Use of HBPM and ABPM was eligible for KQ 3 only, to confirm elevated BP detected by office-based methods.

We required that included studies be conducted in eligible primary care settings, which we defined as having personnel trained in BP measurement, established BP measurement protocols, and ongoing documentation procedures for each. These settings include (but are not limited to) primary care clinics, school-based health clinics, dental offices, retail and mobile clinics, and pharmacies. We excluded settings that were not likely to have the aforementioned criteria, as well as correctional and inpatient or residential facilities. We also restricted studies to those conducted in countries rated as “Very High” on the 2013 Human Development Index.86

### KQs 1 and 5 (Benefits and Harms of Screening)

For KQ 1 (benefits of screening), we only included RCTs that reported changes in health outcomes as a result of screening for hypertension compared with no screening. Screening had to occur during a single encounter. Screening could have been conducted as part of a multicomponent CV risk assessment as long as the BP measurement was the initial and sole factor that determined whether a patient proceeded to additional assessment.

Acceptable health outcomes included mortality, CVD, and end-stage renal disease. For mortality, we accepted all-cause or CV-related death. We defined CVD by fatal and nonfatal CV events, including myocardial infarction (MI), sudden cardiac death, stroke, CHF, hospitalization for coronary heart disease, atrial fibrillation (AF), and transient ischemic attack (TIA). Composite outcomes were eligible if they did not contain any excluded health outcomes, such as CV symptoms (e.g., palpitations), angina pectoris, revascularization, carotid intima-media thickness, and left ventricular hypertrophy. Doubling of serum creatinine, halving of glomerular filtration rate, or transition to dialysis or transplant were also acceptable outcomes for end-stage renal disease.

For KQ 5 (harms of screening), we included RCTs and cohort studies that reported on the harms of screening, including any psychological effects, absenteeism, and changes in quality of life as a result of being labeled as hypertensive. We also included studies that examined the adverse effects of subsequent BP measurement methods to confirm the initial diagnosis (i.e., ABPM or HBPM), such as sleep disturbance or discomfort in continuously wearing a BP monitor.

### KQ 2 (Diagnostic Accuracy of OBPM)

For KQ 2, we included any study design that compared noninvasive OBPM methods differing either by device (KQ 2a) or protocol (KQ 2b). We excluded within-class comparison of devices (e.g., automated vs. automated) with identical screening protocols. We also excluded any validation or accuracy studies of devices compared with standards or using specific protocols (e.g., British Hypertension Society Protocol, AAMI).

We required that studies report the diagnostic accuracy (i.e., sensitivity, specificity, positive predictive value [PPV], negative predictive value [NPV], or comparable statistics) of the comparison. Concordance (e.g., kappa statistic) was also acceptable. We also required that studies report directionality with a change in hypertension diagnosis in order to calculate the diagnostic accuracy, if the latter was not directly reported. We excluded studies that did not provide diagnostic accuracy or comparable data, even if they compared the mean differences in BP levels between devices or protocols or other correlations based on numeric BP values.

### KQ 3a (Prediction of CV Events)

Eligible studies followed a cohort of subjects over time and reported the association of each of two or more BP measurement methods at baseline with overall mortality or fatal or nonfatal CV events during followup. This was the only question for which participant treatment with antihypertensive medications was allowable at baseline. Inclusion of treated participants increased generalizability, recognizing that some proportion of adults followed over time will be treated for hypertension. This inclusion also expanded an otherwise severely limited evidence base.

In addition to our systematic bibliographic database search, we also examined the reference lists of relevant systematic reviews and individual patient data (IPD) meta-analyses to ensure we captured all relevant cohorts.2,87-96 Several long-term cohort studies had multiple associated publications. For each study, we carefully examined the various articles to select the most current publication with the longest followup and largest cohort for each outcome to ensure that participants would not be counted more than once for the same outcome.

Fatal and nonfatal CV events considered to be acceptable indicators of CVD were MI, sudden cardiac death, stroke, CHF, AF, and transient ischemic attack. Composite measures were also accepted if they did not contain excluded outcomes, which were CV symptoms (e.g., palpitations), angina pectoris (chest pain), revascularization, carotid intima-media thickness, and left ventricular hypertrophy.

We required that estimates of association be reported as hazard ratios (HRs) or risk ratios, preferably in a model with adjustment for modifiable and nonmodifiable risk factors, such as age, smoking, use of antihypertensive medication, and personal history of CVD (if not a study participant exclusion criterion). We also required that BP be entered in the model as a continuous variable. We excluded studies that categorized BP and reported individual risk estimates for each BP category compared with a reference category, as these studies could not be readily compared or combined with others. Although not an exclusion criterion, we preferentially abstracted data from models that estimated the independent predictive capacity of one method by also adjusting for its comparator BP measurement method (e.g., ABPM adjusted for OBPM). This direct comparison identified the method with predictive value “over and above” another. We also abstracted data when BP for each method was included in separate models. We excluded studies that included additional measures related to BP in a model with BP (e.g., adding pulse pressure to a model that already included SBP).

### KQs 3b and 3c (Diagnostic Accuracy of Other BP Measurement Methods)

For these questions, we required that all patients have an initial elevated OBPM to represent potentially hypertensive patients needing confirmation. Patients could not, however, be treated with antihypertensive medications unless there was a wash-out period of at least 2 weeks. Included studies confirmed the initial elevated BP using a measurement method that differed from the screening method either by device or protocol. We required that studies report at minimum the proportion of participants diagnosed with hypertension by the confirmatory method. We also required the same diagnostic accuracy reporting characteristics as for KQ 2.

### KQ 4 (Rescreening Interval)

Eligible studies followed a cohort of normotensive subjects over time and reported incidence of hypertension at rescreening intervals of less than 6 years. We considered 6 years a reasonable upper bound for a rescreening interval. We also accepted studies enrolling participants with BP that was high-normal—but below the accepted threshold for pharmacological therapy—and studies enrolling participants not previously confirmed as hypertensive (e.g., participants with isolated clinic hypertension).

We required that incident hypertension be identified through measured BP or physician diagnosis or prescription for antihypertensive medication (e.g., medical chart review). Studies were ineligible if they used only self-reported measures that were not verified, reported average change in BP without reporting change in diagnostic classification, or reported only incident antihypertensive drug use.

Several cohort studies had multiple publications. To avoid double counting, we selected the publication with the most participants for each rescreening interval. We accepted supplemental publications if they additionally reported on subgroups of interest, as specified in KQ 4b.

We accepted diagnostic thresholds as defined in individual studies and accepted BP measurements conducted in any eligible primary care setting. While we captured both unadjusted and adjusted incidence rates, unadjusted rates were more commonly reported. As such, we used unadjusted rates to generate weighted mean incidence of hypertension at various rescreening intervals. We did not accept data that were derived or extrapolated (i.e., deriving 1-, 2-, and 3-year incidence rates based on rescreening at 4 years).

For KQ 4b, we identified the following a priori subgroups of interest: age, sex, race/ethnicity, CV risk (e.g., body mass index [BMI]), BP level, and screening history. Where reported, incidence rates were captured for these groups in addition to those for the overall population.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of included studies using predefined criteria from the USPSTF97 and supplemented with criteria from the Quality Assessment of Studies of Diagnostic Accuracy II,98 the Quality in Prognosis Studies tool,99 and the Newcastle-Ottawa Scale100 for diagnostic accuracy (KQs 2, 3b, and 3c), prognostic (KQ 3a), and observational (KQs 4 and 5) studies, respectively (Appendix A Table 2). We assigned each study a final quality rating of good, fair, or poor. All quality ratings were entered into a database that electronically compared the two ratings and reported discrepancies. We resolved disagreements through discussion.

We excluded studies rated as poor quality (i.e., attrition >40%, differential attrition >10%, other “fatal flaws,” or the cumulative effects of multiple minor flaws and/or missing important information significant enough to limit our confidence in the validity of the results) from the review (Appendix B). Good-quality studies included blinding of outcome assessors, reliable outcome measures, comparable groups at baseline (with specified eligibility criteria) and followup, low attrition, adequate and faithful adherence to the intervention, and acceptable statistical methods. In addition, we also considered whether the study reported device calibration and maintenance protocols, as lack thereof can result in measurement inaccuracy. Studies were downgraded to fair quality if they did not meet the majority of the criteria for good-quality studies.

One investigator abstracted data from all included studies into a customized database. A second investigator checked the data for accuracy. We abstracted study design characteristics, population demographics, intervention details, health outcomes (e.g., mortality), diagnostic accuracy, and adverse events.

## Data Synthesis and Analysis

### KQs 1 and 5 (Benefits and Harms of Screening)

For KQs 1 and 5, we qualitatively described results because of the small number of included studies.

### KQ 2 (Diagnostic Accuracy of OBPM)

We initially calculated the diagnostic accuracy of OBPM devices and protocols using the most standard office-based device (i.e., manual mercury sphygmomanometer) or protocol component (e.g., no caffeine) as the reference standard. Subsequent to identification of ABPM as providing improved prediction of CV events and thus providing a better BP reference standard, we calculated OBPM diagnostic accuracy for a subset of included studies for KQ 3b that measured manual OBPM, automated OBPM, and ABPM in screening populations, using ABPM as the reference standard. Because of the small number of included studies, results are qualitatively described.

### KQ 3a (Prediction of CV Events)

The outcome of interest was risk for CV outcomes, as predicted by different methods of measuring BP at baseline in prospective cohort studies. Because a stronger relationship has been reported between baseline BP and vascular mortality than with nonvascular mortality,6 we grouped outcomes accordingly where possible. We combined fatal and nonfatal events within outcome categories (i.e., CV, stroke, and cardiac events).

Risk was consistently expressed as HRs, which were most often reported for each 10-mm Hg increase in SBP and 5-mm Hg increase in DBP. We converted results that were reported differently (e.g., 1 mm Hg, 1 standard deviation) to these common increments for consistency using the formula HR_c_=exp(ln(HR_o_)/I_o_*I_c_), where HR_c_ is the converted HR, HR_o_ is the originally reported HR, I_o_ is the original increment for HR calculation, and I_c_ is the increment to which the HR was converted. The CIs were also converted accordingly using the formula LB_c_=exp(ln(LB_o_)/I_o_*I_c_) and UB_c_=exp(ln(UB_o_)/I_o_*I_c_), where LB_o_ and LB_c_ are the original and converted lower bounds of the CI and UB_o_ and UB_c_ are the original and converted upper bounds of the CI, respectively.

Risk for CV outcomes by BP measurement method at baseline was visualized in forest plots of HRs. We conducted meta-analyses to obtain risk estimates for each measurement method, separated by outcome. However, if within each method-outcome category there were less than 10 studies (particularly if <5), if there were important identifiable sources of heterogeneity across studies, and if sample sizes varied across a wide range, then no meta-analysis was conducted. We conducted exploratory meta-analyses to compare ABPM results across measurement protocols (24-hour, daytime, or nighttime). For this comparison, we used the DerSimonian and Laird101 random-effects method to generate estimates of CV events or mortality risk per 10-mm Hg increase in SBP for each protocol. We used sensitivity analyses to compare these results with estimates generated using profile likelihood102 and Knapp-Hartung methods.102

### KQs 3b and 3c (Diagnostic Accuracy of Other BP Measurement Methods)

For diagnostic accuracy calculations, we used the BP measurement method identified in KQ 3a as best predicting CV outcomes as the reference standard. Since all study participants had an initial elevated BP, the 2x2 table was incomplete for most studies. Rather, a 1x2 table documenting true-positive results (sustained hypertension) and false-positive results (isolated clinic hypertension) according to the reference standard allowed calculation only of PPV. We qualitatively evaluated the influence of patient or study characteristics on PPV, as well as the association of subpopulations with higher or lower PPV.

### KQs 4a (Rescreening Interval) and 4b (Subgroups)

For KQ 4a, we pooled incidence rates for the overall populations in included studies to generate a weighted mean incidence at various rescreening intervals, which were categorized into 1, 2, 3, 4, and 5 years. Observations within 0.5 years were included for each time interval. For example, the 1-year interval includes observations from 0.5 to 1.5 years. We reported the ranges of incidence within each interval category from pooled studies.

We estimated incidence rates from figures using WebPlotDigitizer© version 2.6 when figures provided the only data source.103 These estimates are reported in tables but were not pooled for weighted mean incidence because the number of participants at specified rescreening intervals was not available.

For KQ 4b, we focused on a qualitative examination of direct evidence of subgroup results reported within studies (e.g., men vs. women, smokers vs. nonsmokers). We also constructed a summary table of evidence across studies by calculating weighted mean incidence rates for subgroups of interest as identified in the KQ. For smoking status, we categorized participants into current and nonsmokers, where nonsmokers were a combination of never and previous smokers. We used three age categories: 10 to 40/45 years, 40/45 years to 60/65 years, and 60/65 years or older. Cut point boundaries had a 5-year margin to enable as many subgroup observations as possible, since there was substantial heterogeneity of subgroup definitions across trials. For BP level subgroups (high-normal vs. normal), we used the cut point identified by the authors. Most often, this was 130–139/85–89 mm Hg, but some used 120–139/80–89 mm Hg and one study reported diastolic values only (80–94 mm Hg).

To maximize the number of subgroup categories, we combined subgroups (where possible) to correspond to our categories and cut points. For example, we combined never and previous smokers to form “nonsmokers,” combined ages younger than 30 and from 30 to 39 to form “age 39 years and younger,” and combined optimal (<120/80 mm Hg) and normal BP (120–129/80–84 mm Hg), if reported, versus high-normal BP (130–139/85–89 mm Hg).

## Expert Review and Public Comment

A draft version of the research plan was posted on the USPSTF Web site for public comment from June 20 to July 17, 2013. We received comments from 18 persons or organizations. All comments were reviewed and addressed as appropriate. The final research plan was posted on the USPSTF Web site on September 19, 2013. The full draft report was reviewed by invited experts and Federal partners in February 2014. We compiled and addressed (where appropriate) the comments received from the reviewers.

## USPSTF Involvement

We worked with three USPSTF liaisons during development of the research plan. USPSTF members approved the final research plan after we incorporated the public comments. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted with external review.