# Introduction

## Condition Definition

Blood pressure (BP) is the pressure the blood exerts against arterial walls as it circulates through the body. It is regulated by a variety of physiological systems, including neural and hormonal signals from the heart, vasculature, brain, kidneys, and gastrointestinal organs.1-5 BP is generally estimated by measuring systolic and diastolic components. Systolic blood pressure (SBP) is the maximal pressure in blood vessels during systole (heart contraction) and diastolic blood pressure (DBP) is the minimal pressure in blood vessels during diastole (heart relaxation between contractions). BP is most commonly measured peripherally in the upper arm.

Large prospective studies in diverse populations have demonstrated a strong positive association between BP and stroke, ischemic heart disease, and overall mortality. These studies have found no evidence of a threshold below which the association between BP and cardiovascular and stroke events and mortality is no longer evidence; this has been tested down to at least 115/75 mm Hg.6 In the absence of a clear threshold, hypertension may be defined pragmatically as the level of BP at which there is either experimental or epidemiological evidence that therapeutic interventions reduce cardiovascular (CV) event rates.7 Hypertension is most commonly defined as SBP of 140 mm Hg or greater and/or DBP of 90 mm Hg or greater (hereafter referred to as ≥140/90 mm Hg). Blood pressure classifications from the Seventh Report of the Joint National Committee on the Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC 7) are shown in Table 1.^1^ The JNC 8 did not redefine the threshold for a diagnosis of high BP in its recently published 2014 guidelines, although it did raise the treatment threshold for persons with diabetes or chronic kidney disease and those age 60 years and older.8

Table 1 JNC 7 Blood Pressure Classifications

Blood Pressure Classification | SBP (mm Hg) | DBP (mm Hg)
Normal | <120 | and <80
Prehypertension | 120-139 | or 80-89
Stage 1 hypertension | 140-159 | or 90-99
Stage 2 hypertension^*^ | ≥160 | or ≥100

* Previous definitions of Stage 2 and Stage 3 hypertension have been combined under Stage 2 hypertension.

Abbreviations: DBP = diastolic blood pressure; SBP = systolic blood pressure.

## Etiology and Natural History

Primary (or essential or idiopathic) hypertension is defined as high BP in the absence of a known secondary cause and accounts for 95 percent of all cases of hypertension.9 The pathogenesis of primary hypertension is multifactorial and imprecisely understood. Risk factors include age, African American race, genetic factors, excess weight and obesity, excess alcohol intake, and dietary habits (especially high sodium intake).10-12 Hypertension is common in persons with diabetes and dyslipidemia (including metabolic syndrome), but is still considered primary hypertension in these persons. Secondary causes of hypertension include chronic kidney disease, coarctation of the aorta, Cushing syndrome, use of certain drugs, obstructive uropathy, pheochromocytoma, primary aldosteronism, sleep apnea, and thyroid or parathyroid disease.1 Secondary hypertension may be suggested by symptoms, clinical or laboratory findings, resistance to treatment, or onset of hypertension at an unexpected age.13

BP increases progressively with age11 and hypertension develops in a high proportion of adults in the United States who survive into the eighth and ninth decades.14 In a younger population, hypertension can develop over a relatively short period when BP is at the higher end of the normal range.

Untreated hypertension tends to progress and cause damage to multiple organs, including the heart (left ventricular hypertrophy, coronary atherosclerosis), brain (stroke, vascular dementia), kidneys (nephrosclerosis, albuminuria, proteinuria), arteries (peripheral artery disease, atherosclerosis), and eyes (retinopathy).15,16 Damage to arteries and kidneys may culminate in a treatment resistant state.2 Measuring long-term average BP may improve its prognostic utility for cardiovascular disease (CVD) risk beyond risk assessments based on current BP measurement.17

Age also modifies the association between high BP and health risks. In adults age 50 years or older who participated in the first National Health and Nutrition Examination Survey (NHANES) and had their BP measured, SBP of 140 mm Hg or greater was associated with increased mortality, regardless of DBP. DBP was a stronger predictor of mortality in those younger than age 50 years, with elevated risk at levels greater than 100 mm Hg.18

## Prevalence and Burden of High BP

Based on 2009 to 2010 data, the overall age-adjusted prevalence of high BP (defined as ≥140/90 mm Hg or use of antihypertensive medication; or having been told at least twice by a health professional that one had high BP) among U.S. adults age 18 years or older was 28.6 percent.19 As shown in Table 2, although the prevalence of high BP tends to be higher in men than women at younger ages, it is higher in women than men at ages older than 65 years. Thus, the overall prevalence of high BP is similar among men (33.6%) and women (33.2%),19 but disparities are seen among different races and ethnicities. High BP is markedly more common in African Americans (42%) than whites (27.5%) or Hispanics (26.1%), and African American women have the highest prevalence of hypertension (47.0%) of any sex-specific race/ethnicity subgroup.20 There are also sex, racial, and ethnic differences in high BP awareness, treatment, and control.

Table 2 Prevalence of High Blood Pressure in Adults Age 20 Years and Older in the United States, 2010^*^

Demographic | Characteristic | Male | Female
Overall | All persons | 33.6 | 32.2
Age (years) | 20-34 | 9.1 | 6.7
Age (years) | 35-44 | 24.4 | 17.6
Age (years) | 45-54 | 37.7 | 34.0
Age (years) | 55-64 | 52.0 | 52.0
Age (years) | 65-74 | 63.9 | 70.8
Age (years) | 75+ | 72.1 | 80.1
Race | Non-Hispanic white | 33.4 | 30.7
Race | Non-Hispanic black | 42.6 | 47.0
Race | Mexican American | 30.1 | 28.8
Race | Asian | 21.2
Race | American Indian/Alaska Native | 24.8

* From reference 19.

Hypertension is the most commonly diagnosed condition at physician office visits (3.9%).21 In 2009, the estimated direct medical costs of treating hypertension in the United States was $47.5 billion, with prescription medications accounting for 45 percent of the costs ($21.4 billion).22 In 2010, there were 280,000 hospitalizations with a first-listed diagnosis of essential hypertension and more than 55 million physician office, emergency department, and outpatient visits with essential hypertension as the primary diagnosis code.19

Elevated BP is the largest contributing risk factor to all-cause and CVD mortality.23 Studies have shown that the excess proportion of mortality attributable to elevated BP is 40.6 percent (95% confidence interval [CI], 24.5 to 54.6) for CVD mortality and 30.4 percent for overall mortality (95% CI, 19.4 to 40.6).23 High BP is a major contributor to heart attack, stroke, and congestive heart failure (CHF). In 2010, high BP was listed as a primary or contributing cause of death for more than 362,000 Americans.19

## Rationale for Screening

There are generally no signs or symptoms associated with high BP.24 As a result, high BP is usually found through screening. BP can be modified with lifestyle interventions,25-27 and large good-quality randomized, controlled trials (RCTs) demonstrate the effectiveness of antihypertensive pharmacological treatments to reduce CV and total mortality.28,29 The same measurement techniques used for screening and confirmation are also used for BP monitoring after a diagnosis to monitor treatment effectiveness and BP control.

BP control rates remain low despite substantial improvements since the 1970s in the awareness, treatment, and control of hypertension.1 Between 2009 and 2010, 81.9 percent of U.S. adults with hypertension were aware of their status and 76.4 percent were taking medication to lower their BP. Only 53.3 percent, however, had their BP controlled to less than 140/90 mm Hg.20

## Screening/Measurement Modalities to Detect High BP

### Intra-Arterial Monitoring

Direct intra-arterial measurement is considered the gold standard for BP measurement.30 During intra-arterial BP monitoring, a catheter is inserted into an artery and pressure waves are displayed on a monitor. This method provides a beat-to-beat record of BP and is used in the intensive care unit and during surgery.31 Because of its invasive nature, however, this technique is not suitable for use in screening or in noncritical care settings.30,32

### Clinic Measurement

There are several methods and devices for measuring BP in routine clinic settings, which are briefly described below. Screening for high BP should be done by trained personnel. The standard method is to measure BP in the upper arm at the brachial artery, as devices and techniques for measuring BP at alternate sites like the wrist and finger are highly prone to error and are not recommended in guidelines. As such, we do not include these devices in this review.33

#### Auscultatory Method

The manual auscultatory method involves a trained observer using a stethoscope to detect Korotkoff sounds, which are made by the turbulent flow of blood past the restricted area created by the inflated cuff. The readings are made using a mercury or aneroid sphygmomanometer at the brachial artery. Sources of observer error and bias in the auscultatory method include differences in auditory acuity and terminal digit rounding.5 Detailed guidelines outline recommendations for the positioning of the patient and arm, cuff size and placement, cuff inflation and deflation, number and timing of measurements, and distinguishing Korotkoff sounds. These guidelines, however, are not based on a systematic review of the literature.33 Even considering these many potential sources of error, the auscultatory method using a mercury sphygmomanometer correlates well with simultaneous intra-arterial BP (r=0.94 to 0.98) when performed correctly and was considered the gold standard for clinic-based measurements for many years.34 However, environmental concerns about the potential for mercury spillage and the banned use of mercury sphygmomanometers have diminished the role of this method. Aneroid sphygmomanometers use a lever and bellows system (as opposed to a mercury column) to measure pressure and have been used as a mercury-free alternative. “Hybrid” sphygmomanometers are newer devices with an electronic pressure gauge in place of the mercury column, but BP is still determined using the auscultatory method.5

#### Oscillometric Method

Oscillometric sphygmomanometers use a pressure transducer to assess the oscillations of pressure in a cuff during gradual deflation. The point of maximum oscillation corresponds to the mean intra-arterial pressure. Systolic and diastolic measurements are then calculated based on an empirically derived algorithm.5 Investigators have cited several advantages to these devices, especially when they are fully automated and can be programmed to complete several measurements after a period of rest at appropriate intervals without requiring the presence of medical personnel. The ability to obtain multiple readings while a patient rests alone in a quiet room may mitigate the increased BP seen in some persons only when in medical settings (isolated clinic hypertension).33,35

## Measurement Modalities to Confirm a Diagnosis of Hypertension

In addition to the clinic-based measurement modalities discussed above, two additional nonclinic-based BP measurements may be used to confirm the diagnosis of hypertension: ambulatory BP monitoring (ABPM) and home BP monitoring (HBPM).

### ABPM

ABPM devices are small portable machines connected to a BP cuff worn by patients that record BP at regular intervals over 24 to 48 hours while patients go about their normal activities, including sleep. Measurements are typically taken at 20- to 30-minute intervals.5 Results may be reported for 24 hours, daytime (awake), and nighttime (asleep). Modern ambulatory devices use oscillometric techniques and have replaced use of a microphone to measure Korotkoff sounds.1 Frequent indications for ABPM use is the evaluation of initial borderline office hypertension (25%) or suspected isolated clinic hypertension (24%), as well as monitoring of active antihypertensive treatment.36

### HBPM

HBPM devices are typically fully automated oscillometric devices that record pressure from the brachial artery.5 Many home measurement devices are commercially available, and some have undergone technical validation according to recommended protocols.37 Indications for HBPM are similar to those for ABPM. In addition, self-monitoring may improve adherence to treatment and has been associated with small improvements in BP control, even in the absence of additional self-management support interventions.37

## Limitations of Screening With Manual Methods

BP is affected by numerous short-term internal and environmental factors, such as emotions, pain, eating, voiding, mental activity, physical activity, temperature, and drugs (including caffeine and nicotine). It may vary markedly with posture and over the course of a 24-hour day. This within-person variability presents challenges when characterizing someone’s usual BP.38-40

In addition to biological and temporal within-person variability, it is well documented that BP can increase substantially in the medical setting and in the presence of medical personnel, a phenomenon called the “white coat effect,” or isolated clinic hypertension. Epidemiological data suggest that 15 to 30 percent of the population thought to have hypertension may have lower BP outside of the medical setting.2 Such persons with isolated clinic hypertension may require different measurement methods to resolve apparently increased BP at screening.2 Thus, the disadvantages of screening for high BP solely in the routine office setting include the limited number of measurements that can be performed conveniently, the high rate of observer error, and the potentially altering effects of the medical setting and medical personnel on BP.33,41

Limited evidence from small studies suggests that the white coat effect may have limited to moderate reproducibility. Studies examining isolated clinic hypertension continuously as a difference between BP measured in and out of the office show that the effect is significantly attenuated with repeat measurements.42,43 Other reports examining isolated clinic hypertension dichotomously show a wide range of reproducibility, from 45 percent in a combination of treated and untreated participants44 to 79 percent in highly-selected treatment-resistant participants.45 Thus, while elevated BP in clinic settings and normal BP in nonclinic settings could reflect “true” isolated clinic hypertension, it could also reflect measurement error or regression to the mean.42,44 For these reasons, we use the descriptive term isolated clinic hypertension rather than white coat hypertension in this report.

## Potential Methods for Screening Confirmation

Simply repeating a manual office-based BP measurement (OBPM) at a separate office visit to confirm initial elevated BP is subject to the same limitations as described above. Office-based confirmation also does not capture BP variations over time. Newer methods of BP measurement have become available, including automated measurement methods for clinical settings and HBPM and ABPM for nonclinical settings. These methods have made it possible to investigate and discover additional information about BP and may overcome some of the limitations of manual OBPM.

Automated OBPM with a valid and reliable device has the advantage of avoiding observer error and bias. HBPM has some of the same advantages, with the ability to record BP measurements at various times of day over an extended period outside of the medical setting. Automated 24-hour BP measurement has the potential to increase the accuracy of hypertension diagnosis beyond that of HBPM by performing representative BP measurements outside of the office setting across the full course of a day and night’s routine activities and sleep.

As assessed by 24-hour measurement, BP exhibits a diurnal pattern whereby pressure is generally the lowest during sleep, rises sharply and peaks after a person rises from bed, and then falls again during the day. Studies have shown that BP normally falls by 10 to 20 percent from daytime to nighttime, and this pattern may be more strongly related to physical activity than to a circadian rhythm.30 In 1988, O’Brien and colleagues named this pattern “dipping” and reported a cross-sectional association with stroke in patients with a less marked decrease in nighttime BP (“nondipping”).46

A recent 2011 meta-analysis by Hansen and colleagues concluded that nighttime BP is a stronger predictor of mortality and CV events than daytime BP.47 These authors further concluded that dipping status contributed little to prognostic value over and above 24-hour BP. For this reason, and because dipping status may have poor reproducibility, we do not address this issue in this review.48,49

The reverse phenomenon to isolated clinic hypertension, sometimes called “masked hypertension,” refers to persons with apparently nonhypertensive levels of BP at clinic visits who have elevated BP when it is measured outside of the medical setting.4 This condition is of interest because it has been associated with increased CV risk.50,51 We do not address masked hypertension further in this review, however, because it is not detectable using methods that begin with confirmation of elevated BP found by office-based screening. A practical method to detect masked hypertension at a population level remains to be established.52

## Device Regulation, Validation, and Calibration

Noninvasive BP monitors that use a cuff with an inflatable bladder in conjunction with another device, such as electronic or automated sphygmomanometers or standard oscillometric measurement methods, are classified as Class II devices by the U.S. Food and Drug Administration (FDA). While there are no mandatory performance standards, the FDA provides guidance for the safety, performance, and clinical validation of automated and nonautomated noninvasive sphygmomanometers.53-55 This guidance is equivalent to the SP10 standard developed by the Association for the Advancement of Medical Instrumentation (AAMI) for manual, electronic, or automated sphygmomanometers, including ABPM.56 Although a BP measurement device can be marketed without evidence of meeting AAMI standards, no claims can be made about its accuracy.57

In general, validation of devices requires independent assessment of accuracy of the device compared with a reference standard (mercury sphygmomanometry). This is especially important for oscillometric automated monitors, which use proprietary algorithms to calculate SBP and DBP. The three most widely used protocols are the British Hypertension Society Protocol, the AAMI Standard, and the International Protocol of the European Society of Hypertension.58-60 Many automated BP measuring devices intended for home use have not been independently validated. Even devices that have met validation standards in general populations may not provide similar measurements as a mercury sphygmomanometer in all patients, particularly in those with stiffness of the arteries (the elderly), advanced renal disease, and diabetes.33 A list of devices of various types, results of validation testing, special populations included in validation testing (children, pregnant women, the elderly), and recommendations can be found at www.dableducational.org.

All sphygmomanometers require regular calibration and maintenance to maintain accuracy, and devices randomly evaluated in clinical settings have often been found to be inaccurate.2,33,61,62 One review recommends calibration at 3-year intervals for mercury sphygmomanometers, 6-month intervals for anaeroid sphygmomanometers, and 12-month intervals for oscillometric or hybrid devices.63

## Current Clinical Practice

According to the 2010 National Ambulatory Medical Care Survey, BP was measured in 59.4 percent of clinic visits by patients age 18 years or older in the United States.21 The American Heart Association recommends that BP be measured after a patient sits comfortably and quietly for at least 5 minutes in a chair with back supported, both feet flat on the floor (i.e., legs not crossed or dangling), and the unbent arm supported at heart level at mid-sternum.64 The appropriate cuff size should be used on a bare arm (i.e., not over clothing) and the inflatable bladder should encircle 80 percent or more of the patient’s arm circumference. The average of at least two measurements should be recorded as the patient’s BP level for that visit. Other guidelines, such as those from JNC 8,^8^ have recommended similar procedures. While these procedures are typically used in research studies, they are rarely followed in routine health care settings.41,65-69 The reasons for not following recommended BP measurement guidelines are likely multifactorial and may include lack of information, training, and time.

Common clinical practice is to measure weight, BP, and pulse at every office visit and to record these measurements as “vital signs.” While BP may not be measured at certain types of primary care visits (e.g., dental or eye examinations) or at ambulatory visits with some specialists, these exceptions tend to be the minority. This suggests that rescreening is occurring opportunistically at most visits rather than at specified intervals and that the rescreening interval is determined primarily by the frequency of office visits. As such, persons who make infrequent visits may not be screened.

When screening BP results are elevated above the threshold for the normal range, some organizations also recommend ABPM to confirm the diagnosis (and for management) of hypertension (Table 3), although this is infrequent. In the United Kingdom, for example, only about one in every 20 hypertension diagnoses is made with ABPM because of limited availability of devices.70 Similarly, guidelines recommend the use of HBPM for diagnosis and management.2,71-74

Table 3 Recommendations for Diagnosing Hypertension From Other Organizations

Organization, Year | Indications | Diagnostic Protocol and Threshold
American Society of Hypertension, 2014^71^ | Hypertension, white-coat hypertension | Diagnosis of hypertension should be confirmed at an additional patient visit, usually 1-4 weeks after the first measurements. If white-coat hypertension is suspected, consider HBPM, taking the average blood pressure measured over 5-7 days, if possible in duplicate. ABPM is another approach if available. OBPM diagnostic threshold: ≥140/90 mm Hg HBPM diagnostic threshold: ≥135/85 mm Hg
Joint National Committee on Prevention, Detection, Evaluation and Treatment of Blood Pressure (JNC 7),^*^ 2004^1^ | Suspected white-coat hypertension among hypertensive patients and no target organ damage; hypotensive symptoms with antihypertensive medication; episodic hypertension and autonomic dysfunction | Stage 1 hypertension diagnosis should be confirmed within 2 months after initial elevated OBPM (no further protocol details reported). Stage 2 hypertension should be confirmed within 1 month; those with ≥180/110 mm Hg evaluate and treat immediately. ABPM diagnostic threshold: ≥135/85 mm Hg (awake), ≥120/75 mm Hg (asleep)
National Institute for Health and Care Excellence, 2011^2^ | Hypertension, white-coat hypertension | Adults aged 18-21 years only. Based on repeated measures in both arms followed by ABPM (at least 14 measurements) or HBPM (twice in morning and evening for at least 4 days, ideally 7 days) if ABPM not tolerable. OBPM diagnostic threshold: ≥140/90 mm Hg ABPM diagnostic threshold: ≥135/85 mm Hg (daytime)
National Heart, Lung, and Blood Institute, 2013^260^ | Hypertension, white-coat hypertension | Based on two OBPM measurements, confirm elevated reading with contralateral arm.
University of Michigan Health System, 2009^287^ | Hypertension, white-coat and masked hypertension | Based on taking mean blood pressure levels from recordings over several visits. Suspected white-coat hypertension: three or more OBPM >140/90 mm Hg and at least two ABPM <140/90 mm Hg.
Canadian Hypertension Education Program (CHEP), 2013^261^ | Hypertension, suspected white-coat hypertension, and masked hypertension | OBPM diagnostic threshold: ≥160/110 mm Hg averaged across three visits; or if ≥140/90 mm Hg averaged across five visits ABPM diagnostic threshold: ≥135/85 mm Hg (awake) or ≥130/80 mm Hg (24 hours) HBPM diagnostic threshold: ≥135/85 mm Hg
European Society of Hypertension, 2008^73^ | Sustained, masked or white-coat hypertension | ABPM diagnostic threshold: ≥135/85 mm Hg (awake), ≥120/70 mm Hg (asleep) and ≥130/80 mm Hg (24 hours) HBPM diagnostic threshold: 135/85 mm Hg
Institute for Clinical Systems Improvement, 2012^288^ | Confirming initial elevated BP; white-coat or masked hypertension | Based on a combination of one or more followup visits with at least two blood pressure readings at each visit and an out-of-office blood pressure measurement (e.g., HBPM) or 24 hour ABPM. ABPM diagnostic threshold: 140/85 mm Hg (awake), 120/70 mm Hg (asleep), and 130/80 mm Hg (24-hour)
Japanese Society of Hypertension, 2009^74^ | Diagnosis of essential, white-coat, and masked hypertension | Based on blood pressures measured on at least two different clinic-based occasions. OBPM diagnostic threshold: ≥140/90 mm Hg HBPM diagnostic threshold: ≥135/85 mm Hg ABPM diagnostic threshold: ≥130/80 mm Hg (24 hour), ≥135/85 mm Hg (day), ≥120/70 mm Hg (night)

* The JNC 8 Panel did not address diagnosis of hypertension in its 2014 guidelines. A supplement to the guidelines includes additional content not supported by a systematic review but that is intended to aid in implementing the main guidelines. In the supplement, the JNC 8 Panel recommends averaging 2-3 measurements at each visit to establish a diagnosis of hypertension. Definitions of hypertension were not addressed, but thresholds for pharmacological treatment were defined. HBPM and ABPM were not addressed.8

Abbreviations: ABPM = ambulatory blood pressure monitoring; HBPM = home blood pressure monitoring; NR = not reported; OBPM = office blood pressure measurement.

## Recommendations of Others

Recommendations of other organizations for high BP screening in clinical practice are presented in Table 4 and methods for confirming a diagnosis of hypertension are listed in Table 3. In some cases this division is arbitrary, as few guidelines specifically separate the concepts of or protocols for screening versus confirmation of hypertension.

Table 4 Recommendations for Blood Pressure Screening From Other Organizations

Organization, Year | Start Age (y) | Frequency | Additional Recommendations and Information
American Academy of Family Physicians (AAFP), 2007^289^ | 18 | Not stated | Based on the USPSTF recommendation.
American Congress of Obstetricians and Gynecologists (ACOG), 2013^290^ | 13 | Annual | Recommended as part of a woman’s annual health care visit.
American Heart Association (AHA), 2012^291^ | 20 | At least every 2 years | Recommended at each regular health care visit or at least once every 2 years if blood pressure <120/80 mm Hg.
Joint National Committee on Prevention, Detection, Evaluation and Treatment of Blood Pressure (JNC 7)^*^, 2004^1^ | Adult | At least every 2 years | Routine blood pressure measurements should be taken at least once every 2 years for adults with <120/80 mm Hg, and every year for those with 120-139/80-89 mm Hg.
Michigan Quality Improvement Consortium (MQIC), 2012^75,76^ | 18 | At least every 2 years | Screening every 2 years if blood pressure ≤120/80 mm Hg or annually if blood pressure 120-139/80-89 mm Hg and more frequently if warranted. Based on the USPSTF recommendation.
National Heart, Lung and Blood Institute (NHLBI), 2013^260^ | 18-21 | All health care visits | Measure blood pressure, evaluate and treat per JNC guidelines.
University of Michigan Health System, 2009^287^ | Adult | At least every 2 years | Recommended screening at least every 2 years for normotensives; annual for those with risk factors.
Canadian Hypertension Education Program (CHEP), 2013^72^ | Adult | All clinical visits | Measurement should be taken by health care professionals who have been specifically trained to measure blood pressure accurately using standardized measurement techniques; automated clinic blood pressure measurements can be used in the assessment of clinic-based pressure.
Institute for Clinical Systems Improvement (ICSI), 2012^77^ | 19 | At least every 2 years | Blood pressure must be measured at least every 2 years for adults with blood pressures <120/80 mm Hg and every year if blood pressure is 120-139/80-89 mm Hg. Higher blood pressures would be confirmed and managed per protocol. Most reliably implemented if blood pressure is measured at every patient visit.

* The JNC 8 Panel did not address diagnosis of hypertension in its 2014 guidelines. A supplement to the guidelines includes additional content not supported by a systematic review but that is intended to aid in implementing the main guidelines. In the supplement, the JNC 8 Panel recommends measuring blood pressure using procedures similar to the ones described in JNC 7. Rescreening intervals are not addressed.8

Abbreviations: JNC = Joint National Committee; USPSTF = U.S. Preventive Services Task Force; y = years.

Recommendations for rescreening intervals are also presented in Table 4. The Canadian Hypertension Education Program is the only organization that recommends screening for high BP at every clinical visit.72 Other guidelines recommend 1- to 2-year rescreening intervals, with most recommending the shorter interval for persons with BP of 120–139/80–89 mm Hg.1,75-77 However, these guidelines generally do not provide the basis for the interval recommended.78

## Previous Recommendation

In 1996, the U.S. Preventive Services Task Force (USPSTF) recommended screening for hypertension in adults. While no rescreening interval was recommended, the USPSTF noted that measurement every 2 years in persons with previously normal BP levels and every year in those with borderline levels “may be prudent.” In 2003, the evidence in support of screening for hypertension was again reviewed. There was high certainty that screening for high BP in adults has a substantial net benefit. Although no RCTs of screening were identified, the USPSTF concluded that substantial indirect evidence supported the effectiveness of screening adults to detect hypertension and treating them to reduce CVD. This recommendation was based on good evidence that BP measurement can identify adults at increased risk for CVD from high BP, that treatment of high BP substantially decreases the incidence of CV events, and that screening and treatment of high BP causes few serious harms. Rescreening was not addressed. In 2007, the USPSTF reaffirmed its 2003 recommendation supporting screening. The 2007 update also stated that evidence was lacking to recommend an optimal interval for screening, but referred to the JNC 7 recommendation of screening at 1- to 2-year intervals.

## Rationale for the Current Review

This report systematically reviews newer evidence relevant to screening for hypertension in adults, including RCTs that may provide direct evidence on the effectiveness and harms of screening for prevention of CVD and mortality. Newer BP measurement methods are available that may reduce measurement error, simplify performance of repeated measurements, allow measurement of BP throughout the 24-hour day, and allow measurement in nonmedical settings. Previous recommendations did not separate initial screening and confirmation of hypertension. For these two diagnostic steps, different measurement methods or protocols may be needed to improve accuracy of long-term CV outcome prediction, minimize misdiagnosis, and avoid unnecessary treatment. While the 2003 review sought evidence on the accuracy of HBPM and ABPM for cost-effectively diagnosing hypertension and predicting future CV events, these topics were identified as evidence gaps to be addressed in future systematic reviews. Finally, previous reports noted the lack of a systematically reviewed evidence base to support recommendations for appropriate rescreening intervals and to reconcile the varying recommendations from other groups.