# Ongoing Studies

We identified two potentially relevant ongoing or recently completed trials through four registries: ClinicalTrials.gov (http://clinicaltrials.gov), Current Controlled Trials (http://www.controlled-trials.com), Australian New Zealand Clinical Trials Registry (http://www.anzctr.org.au), and the World Health Organization’s International Clinical Trials Registry Platform (http://www.who.int/ictrp). We restricted our searches to high blood pressure screening and diagnostic studies only; intervention studies were not examined.

We identified one trial, the Viborg Vascular (VIVA) screening trial, in 50,000 men ages 65 to 74 years from Denmark who were randomized to vascular screening (i.e., screening for hypertension, lower limb atherosclerosis, and abdominal aortic aneurysm) or not.297 Nurses used a blood pressure cuff to screen for high blood pressure. All-cause mortality is the primary outcome; secondary outcomes include cardiovascular-related deaths, hospital services related to cardiovascular condition, health-related quality of life, and cost effectiveness. Followup will be performed at 3, 5, 10, and 15 years. The anticipated study completion date is December 2023.

We also identified a recently completed trial examining the harms of diagnostic labeling of prehypertension.298 One hundred adults age 18 years or older were randomized to labeled or unlabeled diagnostic groups. Physicians informed the labeled group of their blood pressure level after screening and those in the unlabeled group were not informed of their blood pressure status. Investigators examined changes in blood pressure and health-related quality of life after 3 months of followup. No publications were identified as of March 2013.

Study details provided by the trial registries are limited; many of the identified ongoing studies may be excluded for a variety of reasons upon publication of the methods and/or results.