# Prognosis of Isolated Clinic Hypertension From Included Studies in Key Question 3a

Study | N | Definition of Isolated Clinic Hypertension | Risk for CV Events: Isolated Clinic Hypertensives vs. Normotensives | Risk for CV Events: Sustained Hypertensives vs. Isolated Clinic Hypertensives | Risk for CV Events: Sustained Hypertensives vs Normotensives
Fagard, 2005^117^ | 391 | OBPM ≥140/90 mm Hg and daytime ABPM <135/85 mm Hg | HR^*^ (95% CI): NR; p=0.85 | HR^*^ (95% CI): 2.16 (1.16 to 4.01; p=0.01) (Similar results whether all participants or untreated only) | NR
Ohkubo, 2005^125^ | 1332 | OBPM ≥140/90 mm Hg and daytime ABPM <135/85 mm Hg | HR^*^ (95% CI) CVD Mortality: 1.54 (0.73 to 3.21) Stroke: 1.07 (0.58 to 2.07) CVD Mortality/Stroke: 1.28 (0.76 to 2.14) | NR | HR^*^ (95% CI): CVD Mortality: 1.94 (1.04 to 3.61) Stroke: 2.83 (1.77 to 4.54) CVD Mortality/Stroke: 2.26 (1.49 to 3.41)
Ingelsson, 2006^121^ | 951 | OBPM ≥140/90 mm Hg and daytime ABPM <135/85 mm Hg | HR for CHF (95% CI): 2.01 (0.82 to 4.91) | NR | NR HR^*^ (95% CI) for CHF: 1.75 (0.80 to 3.85)
Celis, 2002^114^ | 419 | Office DBP ≥95 mm Hg and daytime ABPM <140/90 mm Hg | NR | All 22 major CV events occurred in sustained hypertensives with none among white coat hypertensives; between-group difference p=0.02 | NR
Clement, 2003^115^ | 1963 | NR | NR | Patients with baseline office SBP 140-159 mm Hg: RR^*^ (95% CI): 1.82 (0.92 to 3.56) Patients with baseline office SBP ≥160 mm Hg: RR^*^ (95% CI): 2.31 (1.26 to 4.22) | NR
Bobrie, 2004^113^ | 4939 | OBPM ≥140/90 mm Hg and HBPM <135/85 mm Hg | NR | Incidence of CV events in ICH patients (12.1 [7.3 to 16.9] per 1000 patient-years) same as patients with controlled HTN (11.1 [6.5 to 15.6] per 1000 patient-years) and lower than patients with uncontrolled HTN (25.6 [22.4 to 28.9] per 1000 patient-years) | NR
Khattar, 1998^201^ Excluded study | 479 | Office SBP 140-180 mm Hg and 24-hour intra-arterial ABPM <140/90 mm Hg | NR | Events among isolated clinic hypertensives significantly lower than in sustained hypertensives (1.32 vs. 2.56 events per 100 patient-years; p <0.001) | NR

* Adjusted for baseline covariates

Abbreviations: ABPM = ambulatory blood pressure monitoring; CHF = congestive heart failure; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; HBPM = home blood pressure monitoring; HTN = hypertension; HR= hazard ratio; mm Hg = millimeters of mercury; NR = not reported; OBPM = office blood pressure measurement; RR = relative risk; SBP = systolic blood pressure; ICH=isolated clinic hypertension.