# Evidence Tables

Table 1 Study design characteristics of included studies for Key Question 1

Table 2 Baseline characteristics of included studies for Key Question 1

Table 3 Intervention characteristics of included studies for Key Question 1

Table 4 Study design characteristics of included studies for Key Question 2a

Table 5 Baseline characteristics of included studies for Key Question 2a

Table 6 Intervention characteristics of included studies for Key Question 2a

Table 7 Study design characteristics of included studies for Key Question 2b

Table 8 Baseline characteristics of included studies for Key Question 2b

Table 9 Intervention characteristics of included studies for Key Question 2b

Table 10 Study design characteristics of included studies for Key Question 3a

Table 11 Baseline characteristics of included studies for Key Question 3a

Table 12 Intervention characteristics of included studies for Key Question 3a

Table 13 Ambulatory (24hr) vs. office, all-cause mortality, results of included studies for Key Question 3a

Table 14 Ambulatory (24hr) vs. office, fatal and nonfatal CV events, results of included studies for Key Question 3a

Table 15 Ambulatory (24hr) vs. office, fatal and nonfatal strokes, results of included studies for Key Question 3a

Table 16 Ambulatory (24hr) vs. office, congestive heart failure, results of included studies for Key Question 3a

Table 17 Ambulatory (24hr) vs. office, fatal and nonfatal cardiac endpoints, results of included studies for Key Question 3a

Table 18 Ambulatory (nighttime) vs. office, all-cause mortality, results of included studies for Key Question 3a

Table 19 Ambulatory (nighttime) vs. office, fatal and nonfatal CV events, results of included studies for Key Question 3a

Table 20 Ambulatory (nighttime) vs. office, fatal and nonfatal strokes, results of included studies for Key Question 3a

Table 21 Ambulatory (nighttime) vs. office, congestive heart failure, results of included studies for Key Question 3a

Table 22 Ambulatory (nighttime) vs. office, fatal and nonfatal cardiac endpoints, results of included studies for Key Question 3a

Table 23 Ambulatory (daytime) vs. office, all-cause mortality, results of included studies for Key Question 3a

Table 24 Ambulatory (daytime) vs. office, fatal and nonfatal CV events, results of included studies for Key Question 3a

Table 25 Ambulatory (daytime) vs. office, fatal and nonfatal strokes, results of included studies for Key Question 3a

Table 26 Ambulatory (daytime) vs. office, congestive heart failure, results of included studies for Key Question 3a

Table 27 Ambulatory (daytime) vs. office, fatal and nonfatal cardiac endpoints, results of included studies for Key Question 3a

Table 28 HBPM vs. office, all-cause mortality, results of included studies for Key Question 3a

Table 29 HBPM vs. office, fatal and nonfatal CV events, results of included studies for Key Question 3a

Table 30 HBPM vs. OBPM, fatal and nonfatal strokes, results of included studies for Key Question 3a

Table 31 Study design characteristics of included studies for Key Question 3b and 3c

Table 32 Baseline characteristics of included studies for Key Question 3b and 3c

Table 33 Intervention characteristics of included studies for Key Question 3b and 3c

Table 34 Diagnostic accuracy results of included studies for Key Questions 3c

Table 35 Study design characteristics of included studies for Key Question 4a and 4b

Table 36 Baseline characteristics of included studies for Key Question 4a and 4b

Table 37 Intervention characteristics of included studies for Key Question 4a and 4b

Table 38 Study design characteristics of included studies for Key Question 5

Table 39 Baseline characteristics of included studies for Key Question 5

Table 40 Intervention characteristics of included studies for Key Question 5

Table 41 Results of included studies for Key Question 5