# Excluded Studies

Code | Reason for Exclusion
E1 | Wrong study aim/relevance
E2 | Wrong setting
E3 | Wrong comparator
E4 | No relevant outcomes
E4a | Composite outcome which includes excluded outcomes
E4b | Self-reported measures or anti-hypertensive use only to measure incidence of hypertension (KQ4)
E4c | Prevalence of hypertension or hypertension diagnoses provided, not enough data to complete 2x2 table (KQ2 and KQ3b/c)
E4d | Relevant outcomes in a non-relevant subgroup
E5 | Population
E5a | >20% of excluded populations and data not stratified
E5b | Patients with treatable high blood pressure within the current treatment guidelines (KQ4)
E5c | Patients without an initial elevated blood pressure screen (KQ3)
E6 | Wrong intervention
E6a | Unattended blood pressure measurement kiosks
E7 | Wrong study design
E7a | Cross-sectional study of screening harms (KQ5 only)
E7b | <2 week washout period for studies in treated hypertensives
E7c | Use of untreated placebo group or use of individuals from other intervention trials as a cohort study (KQ4) (e.g., TROPHY, TROP, SUVIMAX)
E7e | <1,000 non-hypertensive patients at baseline (KQ4)
E7f | <100 untreated individuals w/a previous elevated BP screen (KQ3b/c)
E8 | Non-English
E9 | Non-Very High HDI Country
E9a | Conducted in Brazil
E10 | Poor study quality
E10a | High or differential attrition (<60% of study population followed; >10% difference btwn groups on % followed up)
E10b | Other quality issue
E11 | Ongoing study, no outcomes published
E12 | Timing of outcome assessment ≥ 6 years (KQ4)
E13 | Unable to locate publication

1 Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. The Trials of Hypertension Prevention Collaborative Research Group. Arch Intern Med. Mar. 24. 1997;157(6):657-67. KQ4aE7c, KQ4bE7c. [pmid: 9080920].
2 -NCT00841308. Antihypertensive Drug Treatment Decisions Based on Home Blood Pressure Monitoring. ClinicalTrials gov. [http://clinicaltrials gov]. 2009. PMID: None. KQ3aE4, KQ3bE5a, KQ3cE5a.
3 Abdoh AA, Krousel-Wood MA, Re RN. Accuracy of telemedicine in detecting uncontrolled hypertension and its impact on patient management. Telemed J E Health. 2003;9(4):315-23. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 14980088].
4 Addison C, Varney S, Coats A. The use of ambulatory blood pressure monitoring in managing hypertension according to different treatment guidelines. J Hum Hypertens. Aug. 2001;15(8):535-8. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 11494091].
5 Adiyaman A, Verhoeff R, Lenders JW, et al. The position of the arm during blood pressure measurement in sitting position. Blood Press Monit. Dec. 2006;11(6):309-13. KQ2aE3, KQ2bE4. [pmid: 17106314].
6 Aeschbacher BC, Hutter D, Fuhrer J, et al. Diastolic dysfunction precedes myocardial hypertrophy in the development of hypertension. Am J Hypertens. Feb. 2001;14(2):106-13. KQ4aE7e, KQ4bE7e. [pmid: 11243300].
7 Agarwal R, Bunaye Z, Bekele DM. Prognostic significance of between-arm blood pressure differences. Hypertension. Mar. 2008;51(3):657-62. KQ2aE3, KQ2bE4, KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 18212263].
8 Aihara A, Imai Y, Sekino M, et al. Discrepancy between screening blood pressure and ambulatory blood pressure: a community-based study in Ohasama. Hypertens Res. Jun. 1998;21(2):127-36. KQ3aE4. [pmid: 9661809].
9 Aiyer AN, Kip KE, Mulukutla SR, et al. Predictors of significant short-term increases in blood pressure in a community-based population. Am J Med. Nov. 2007;120(11):960-7. KQ4aE7e, KQ4bE7e. [pmid: 17976423].
10 Aksoy I, Deinum J, Lenders JW, et al. Does masked hypertension exist in healthy volunteers and apparently well-controlled hypertensive patients?. Neth J Med. Mar. 2006;64(3):72-7. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 16547360].
11 Alderman MH, Charlson ME, Melcher LA. Labelling and absenteeism: the Massachusetts Mutual experience. Clin Invest Med. 1981;4(3-4):165-71. KQ5E5a. [pmid: 7337987].
12 Alderman MH, Melcher LA. Occupationally-sponsored, community-provided hypertension control. J Occup Med. Jun. 1983;25(6):465-70. KQ5E5a. [pmid: 6886849].
13 Alderman MH. Quality of life in hypertensive patients: does it matter and should we measure it?. J Hypertens. Sep. 2005;23(9):1635-6. KQ5E7. [pmid: 16093905].
14 Alli C, Avanzini F, Bettelli G, et al. The long-term prognostic significance of repeated blood pressure measurements in the elderly: SPAA (Studio sulla Pressione Arteriosa nell'Anziano) 10-year follow-up. Arch Intern Med. Jun. 14. 1999;159(11):1205-12. KQ3aE3, KQ3bE3, KQ3cE3, KQ4aE4, KQ4bE4. [pmid: 10371228].
15 Alli C, Mariotti G, Avanzini F, et al. Long-term prognostic impact of repeated measurements over 1 year of pulse pressure and systolic blood pressure in the elderly. J Hum Hypertens. May. 2005;19(5):355-63. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 15772693].
16 Almeida AE, Stein R, Gus M, et al. Improved diagnostic accuracy of a 3-day protocol of home blood pressure monitoring for the diagnosis of arterial hypertension. Blood Press Monit. Apr. 2013;18(2):119-26. KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 23406684].
17 Almgren T, Persson B, Wilhelmsen L, et al. Stroke and coronary heart disease in treated hypertension -- a prospective cohort study over three decades. J Intern Med. Jun. 2005;257(6):496-502. KQ4aE4, KQ4bE4. [pmid: 15910553].
18 Almoosawi S, Prynne CJ, Hardy R, et al. Time-of-day of energy intake: association with hypertension and blood pressure 10 years later in the 1946 British Birth Cohort. J Hypertens. May. 2013;31(5):882-92. KQ4aE12, KQ4bE12. [pmid: 23385650].
19 Alonso A, Beunza JJ, Delgado-Rodriguez M, et al. Low-fat dairy consumption and reduced risk of hypertension: the Seguimiento Universidad de Navarra (SUN) cohort. Am J Clin Nutr. Nov. 2005;82(5):972-9. KQ4aE4b, KQ4bE4b. [pmid: 16280427].
20 Altorf-van der Kuil W, Engberink MF, van Rooij FJ, et al. Dietary protein and risk of hypertension in a Dutch older population: the Rotterdam study. J Hypertens. Dec. 2010;28(12):2394-400. KQ4aE12, KQ4bE12. [pmid: 20827221].
21 Altorf-van der Kuil W, Engberink MF, De NM, et al. Dietary amino acids and the risk of hypertension in a Dutch older population: the Rotterdam Study. Am J Clin Nutr. Feb. 2013;97(2):403-10. KQ4aE12, KQ4bE12. [pmid: 23283504].
22 Altunkan S, Genc Y, Altunkan E. A comparative study of an ambulatory blood pressure measuring device and a wrist blood pressure monitor with a position sensor versus a mercury sphygmomanometer. Eur J Intern Med. Mar. 2007;18(2):118-23. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17338963].
23 Alves LM, Nogueira MS, Godoy S, et al. Prevalence of white coat hypertension in primary health care. Arq Bras Cardiol. Jul. 2007;89(1):28-35. KQ2aE9a, KQ2bE9a, KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 17768580].
24 Ambrosio GB, Dissegna L, Zamboni S, et al. Psychological effects of hypertension labelling during a community survey. A two-year follow-up. J Hypertens Suppl. Dec. 1984;2(3):S171-S173. KQ5E10b. [pmid: 6599664].
25 Andreadis EA, Agaliotis GD, Angelopoulos ET, et al. Automated office blood pressure and 24-h ambulatory measurements are equally associated with left ventricular mass index. Am J Hypertens. Jun. 2011;24(6):661-6. KQ3aE4, KQ3bE7f, KQ3cE4. [pmid: 21415839].
26 Andreadis EA, Angelopoulos ET, Tsakanikas AP, et al. Automated office versus home measurement of blood pressure in the assessment of morning hypertension. Blood Press Monit. Feb. 2012;17(1):24-34. KQ3aE4, KQ3cE4. [pmid: 22218221].
27 Antonicelli R, Partemi M, Spazzafumo L, et al. Blood pressure self-measurement in the elderly: differences between automatic and semi-automatic systems. J Hum Hypertens. Apr. 1995;9(4):229-31. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 7595903].
28 Aris IB, Wagie AA, Mariun NB, et al. An internet-based blood pressure monitoring system for patients. J Telemed Telecare. 2001;7(1):51-3. KQ2aE1, KQ2bE1, KQ3aE1, KQ3bE1, KQ3cE1. [pmid: 11265939].
29 Arnett DK, Tang W, Province MA, et al. Interarm differences in seated systolic and diastolic blood pressure: the Hypertension Genetic Epidemiology Network study. J Hypertens. Jun. 2005;23(6):1141-7. KQ2aE4, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 15894889].
30 Asagami T, Kushiro T, Inoue J, et al. Long-term reproducibility and usefulness of daytime recording of noninvasive 24-hour ambulatory blood pressure monitoring in borderline hypertension: a two-year follow-up study. Clin Exp Hypertens. Jul. 1996;18(5):637-57. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8781751].
31 Asayama K, Ohkubo T, Kikuya M, et al. Use of 2003 European Society of Hypertension-European Society of Cardiology guidelines for predicting stroke using self-measured blood pressure at home: the Ohasama study. Eur Heart J. Oct. 2005;26(19):2026-31. KQ3bE5a, KQ3cE5a. [pmid: 15917279].
32 Asayama K, Ohkubo T, Kikuya M, et al. Prediction of stroke by home "morning" versus "evening" blood pressure values: the Ohasama study. Hypertension. Oct. 2006;48(4):737-43. KQ3bE4, KQ3cE4. [pmid: 16952977].
33 Asayama K, Ohkubo T, Hara A, et al. Repeated evening home blood pressure measurement improves prognostic significance for stroke: a 12-year follow-up of the Ohasama study. Blood Press Monit. Jun. 2009;14(3):93-8. KQ3bE4, KQ3cE4. [pmid: 19359986].
34 Asayama K, Thijs L, Brguljan-Hitij J, et al. Risk stratification by self-measured home blood pressure across categories of conventional blood pressure: a participant-level meta-analysis. PLoS Medicine/Public Library of Science. Jan. 2014;11(1):e1001591. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 24465187].
35 Ascherio A, Rimm EB, Giovannucci EL, et al. A prospective study of nutritional factors and hypertension among US men. Circulation. Nov. 1992;86(5):1475-84. KQ4aE4b, KQ4bE4b. [pmid: 1330360].
36 Ascherio A, Hennekens C, Willett WC, et al. Prospective study of nutritional factors, blood pressure, and hypertension among US women. Hypertension. May. 1996;27(5):1065-72. KQ4aE4b, KQ4bE4b. [pmid: 8621198].
37 Asferg C, Mogelvang R, Flyvbjerg A, et al. Interaction between leptin and leisure-time physical activity and development of hypertension. Blood Press. Dec. 2011;20(6):362-9. KQ4aE12, KQ4bE12. [pmid: 22017362].
38 Asmar R, Nisse DS, Assaad M, et al. Quality of blood pressure measurement in the management of hypertension: A pilot study. Arch Mal Coeur Vaiss. 2001;94:885-8. KQ2aE8, KQ2bE8, KQ3aE8, KQ3bE8, KQ3cE8. [pmid: 11575224].
39 Aylett M. Use of home blood pressure measurements to diagnose "white coat hypertension' in general practice. J Hum Hypertens. Jan. 1996;10(1):17-20. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 8642185].
40 Aylett M, Marples G, Jones K, et al. Evaluation of normal and large sphygmomanometer cuffs using the Omron 705CP. J Hum Hypertens. Feb. 2001;15(2):131-4. KQ2aE3, KQ2bE4. [pmid: 11317193].
41 Babic BK, Bagatin J, Kokic S, et al. Comparison between continuous ambulatory arterial blood pressure monitoring and standard blood pressure measurements among patients of younger and older age group. Coll Antropol. Mar. 2009;33(1):65-70. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 19408605].
42 Backer HD, Decker L, Ackerson L. Reproducibility of increased blood pressure during an emergency department or urgent care visit. Ann Emerg Med. Apr. 2003;41(4):507-12. KQ2aE5, KQ2bE5, KQ3aE4, KQ3bE10b, KQ3cE4. [pmid: 12658251].
43 Baguet JP, Joseph X, Ormezzano O, et al. Ambulatory blood pressure variation in healthy subjects, hypertensive elderly and type 1 diabetic patients in relation to the sitting or standing position. Blood Press Monit. Aug. 2001;6(4):191-4. KQ2aE3, KQ2bE4, KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 11805467].
44 Bakx C, Oerlemans G, Hoogen H, et al. The influence of cuff size on blood pressure measurement. J Hum Hypertens. 1997;11:439-45. KQ2aE3, KQ2bE4. [pmid: 9283061].
45 Bakx JC, van den Hoogen HJ, van den Bosch WJ, et al. Development of blood pressure and the incidence of hypertension in men and women over an 18-year period: results of the Nijmegen Cohort Study. J Clin Epidemiol. Jun. 1999;52(6):531-8. KQ4aE12, KQ4bE12. [pmid: 10408992].
46 Banda JA, Clouston K, Sui X, et al. Protective health factors and incident hypertension in men. Am J Hypertens. Jun. 2010;23(6):599-605. KQ4aE12, KQ4bE12. [pmid: 20224555].
47 Banegas JR, Rodriguez-Artalejo F, Ruilope LM, et al. Hypertension magnitude and management in the elderly population of Spain. J Hypertens. Nov. 2002;20(11):2157-64. KQ4aE4b, KQ4bE4b. [pmid: 12409953].
48 Banegas JR, Guallar-Castillon P, Rodriguez-Artalejo F, et al. Association between awareness, treatment, and control of hypertension, and quality of life among older adults in Spain. Am J Hypertens. Jul. 2006;19(7):686-93. KQ5E5a. [pmid: 16814122].
49 Banegas JR, Messerli FH, Waeber B, et al. Discrepancies between office and ambulatory blood pressure: clinical implications. Am J Med. Dec. 2009;122(12):1136-41. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 19958892].
50 Barba G, Galletti F, Cappuccio FP, et al. Incidence of hypertension in individuals with different blood pressure salt-sensitivity: results of a 15-year follow-up study. J Hypertens. Jul. 2007;25(7):1465-71. KQ4aE7e, KQ4bE7e. [pmid: 17563570].
51 Barger SD, Muldoon MF. Hypertension labelling was associated with poorer self-rated health in the Third US National Health and Nutrition Examination Survey. J Hum Hypertens. Feb. 2006;20(2):117-23. KQ5E7a. [pmid: 16267563].
52 Barlow CE, LaMonte MJ, Fitzgerald SJ, et al. Cardiorespiratory fitness is an independent predictor of hypertension incidence among initially normotensive healthy women. Am J Epidemiol. Jan. 15. 2006;163(2):142-50. KQ4aE4b, KQ4bE4b. [pmid: 16293717].
53 Barry D, Hogan MJ. A comparison of responses to a health and lifestyle questionnaire completed before and then after blood pressure screening. J Expo Anal Environ Epidemiol. Jul. 2002;12(4):244-51. KQ5E1. [pmid: 12087430].
54 Bastos-Barbosa RG, Ferriolli E, Coelho EB, et al. Association of frailty syndrome in the elderly with higher blood pressure and other cardiovascular risk factors. Am J Hypertens. Nov. 2012;25(11):1156-61. KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 22810844].
55 Baumann BM, Abate NL, Cowan RM, et al. Differing prevalence estimates of elevated blood pressure in ED patients using 4 methods of categorization. Am J Emerg Med. Jun. 2008;26(5):561-5. KQ2aE3, KQ2bE5a. [pmid: 18534285].
56 Bayo J, Cos FX, Roca C, et al. Home blood pressure self-monitoring: diagnostic performance in white-coat hypertension. Blood Press Monit. Apr. 2006;11(2):47-52. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16534404].
57 Beckett L, Godwin M. The BpTRU automatic blood pressure monitor compared to 24 hour ambulatory blood pressure monitoring in the assessment of blood pressure in patients with hypertension. BMC Cardiovasc Disord. 2005;5(1):18. KQ2aE4, KQ2bE4, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 15985180].
58 Bell K, Hayen A, McGeechan K, et al. Effects of additional blood pressure and lipid measurements on the prediction of cardiovascular risk. Eur J Prev Cardiol. Dec. 2012;19(6):1474-85. KQ2aE4, KQ2bE4, KQ4aE4, KQ4bE4. [pmid: 21947629].
59 Beltman FW, Heesen WF, Kok RH, et al. Predictive value of ambulatory blood pressure shortly after withdrawal of antihypertensive drugs in primary care patients. BMJ. Aug. 17. 1996;313(7054):404-6. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 8761232].
60 Ben-Dov IZ, Ben-Arie L, Mekler J, et al. In clinical practice, masked hypertension is as common as isolated clinic hypertension: predominance of younger men. Am J Hypertens. May. 2005;18(5:Pt 1):589-93. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 15882539].
61 Ben-Dov IZ, Ben-Arie L, Mekler J, et al. Normal ambulatory blood pressure: a clinical-practice-based analysis of recent American Heart Association recommendations. Am J Med. Jan. 2006;119(1):69-8. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16431188].
62 Ben-Dov IZ, Ben-Arie L, Mekler J, et al. Reproducibility of white-coat and masked hypertension in ambulatory BP monitoring. Int J Cardiol. May. 2. 2007;117(3):355-9. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE5b, KQ4bE5b. [pmid: 16879886].
63 Ben-Dov IZ, Kark JD, Ben-Ishay D, et al. Predictors of all-cause mortality in clinical ambulatory monitoring: unique aspects of blood pressure during sleep. Hypertension. Jun. 2007;49(6):1235-41. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17389258].
64 Ben-Dov IZ, Mekler J, Ben-Arie L, et al. Lack of association between body-mass index and white-coat hypertension among referred patients. Blood Press Monit. Apr. 2007;12(2):95-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17353652].
65 Benediktsson R, Padfield PL. Maximizing the benefit of treatment in mild hypertension:three simple steps to improve diagnostic accuracy. QJM. Jan. 2004;97(1):15-20. KQ2aE5, KQ2bE5, KQ3aE4, KQ3bE4, KQ3cE3, KQ4aE4, KQ4bE4. [pmid: 14702507].
66 Berge HM, Andersen TE, Solberg EE, et al. High ambulatory blood pressure in male professional football players. Br J Sports Med. May. 2013;47(8):521-5. KQ3aE2, KQ3bE2, KQ3cE2. [pmid: 23501835].
67 Bertinieri G, Grassi G, Rossi P, et al. 24-hour blood pressure profile in centenarians. J Hypertens. Sep. 2002;20(9):1765-9. KQ3aE1, KQ3bE1, KQ3cE1. [pmid: 12195117].
68 Beunza JJ, Martinez-Gonzalez MA, Ebrahim S, et al. Sedentary behaviors and the risk of incident hypertension: the SUN Cohort. Am J Hypertens. Nov. 2007;20(11):1156-62. KQ4aE4b, KQ4bE4b. [pmid: 17954361].
69 Beunza JJ, Martinez-Gonzalez MA, Bes-Rastrollo M, et al. Aspirin, non-aspirin analgesics and the risk of hypertension in the SUN cohort. Rev Esp Cardiol. Mar. 2010;63(3):286-93. KQ4aE4b, KQ4bE4b. [pmid: 20196989].
70 Bitencourt F, Gottschall CA. Evaluation of accuracy of rastreometer: a new equipment for hypertension tracking. Arq Bras Cardiol. Feb. 2012;98(2):151-60. KQ2aE9a, KQ2bE9a. [pmid: 22286326].
71 Bjorklund K, Lind L, Lithell H. Twenty-four hour ambulatory blood pressure in a population of elderly men. J Intern Med. Dec. 2000;248(6):501-10. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 11155143].
72 Bjorklund K, Lind L, Zethelius B, et al. Isolated ambulatory hypertension predicts cardiovascular morbidity in elderly men. Circulation. Mar. 11. 2003;107(9):1297-302. KQ3aE4a, KQ3bE5c, KQ3cE5c. [pmid: 12628951].
73 Bjorklund K, Lind L, Zethelius B, et al. Prognostic significance of 24-h ambulatory blood pressure characteristics for cardiovascular morbidity in a population of elderly men. J Hypertens. Sep. 2004;22(9):1691-7. KQ3aE4a, KQ3bE4, KQ3cE4. [pmid: 15311096].
74 Bjornholt JV, Erikssen G, Kjeldsen SE, et al. Fasting blood glucose is independently associated with resting and exercise blood pressures and development of elevated blood pressure. J Hypertens. Jul. 2003;21(7):1383-9. KQ4aE12, KQ4bE12. [pmid: 12817188].
75 Blair SN, Goodyear NN, Gibbons LW, et al. Physical fitness and incidence of hypertension in healthy normotensive men and women. JAMA. Jul. 27. 1984;252(4):487-90. KQ4aE4b, KQ4bE4b. [pmid: 6737638].
76 Blendea D, Duncea C, Bedreaga M, et al. Abnormalities of left ventricular long-axis function predict the onset of hypertension independent of blood pressure: a 7-year prospective study. J Hum Hypertens. Jul. 2007;21(7):539-45. KQ4aE9, KQ4bE9. [pmid: 17361193].
77 Bloch MJ, Basile J. Routine office blood pressure measurements are often higher than standardized or ambulatory readings. J Clin Hypertens. Mar. 2006;8(3):225-7. KQ3aE7, KQ3bE7, KQ3cE7, KQ4aE7, KQ4bE7. [pmid: 16755706].
78 Bloom JR, Monterossa S. Hypertension labeling and sense of well-being. Am J Public Health. Nov. 1981;71(11):1228-32. KQ5E3. [pmid: 7294265].
79 Bo M, Comba M, Canade' A, et al. Clinical implications of white-coat effect among patients attending at a lipid clinic. Atherosclerosis. Apr. 2008;197(2):904-9. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 17897650].
80 Bobrie G, Day M, Tugaye A, et al. Self blood pressure measurement at home. Clin Exp Hypertens. Nov. 1993;15(6):1109-19. KQ3aE4, KQ3bE7f, KQ3cE4. [pmid: 8268878].
81 Bobrie G, Genes N, Vaur L, et al. Is “isolated home” hypertension as opposed to “isolated office” hypertension a sign of greater cardiovascular risk?. Arch Intern Med. Oct. 8. 2001;161(18):2205-11. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 11575977].
82 Bobrie G, Chatellier G, Genes N, et al. Cardiovascular prognosis of “masked hypertension” detected by blood pressure self-measurement in elderly treated hypertensive patients. JAMA. Mar. 17. 2004;291(11):1342-9. KQ3bE4, KQ3cE4. [pmid: 15026401].
83 Boggia J, Li Y, Thijs L, et al. Prognostic accuracy of day versus night ambulatory blood pressure: a cohort study. Lancet. Oct. 6. 2007;370(9594):1219-29. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 17920917].
84 Boggia J, Thijs L, Hansen TW, et al. Ambulatory blood pressure monitoring in 9357 subjects from 11 populations highlights missed opportunities for cardiovascular prevention in women. Hypertension. Mar. 2011;57(3):397-405. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 21263119].
85 Bombelli M, Sega R, Facchetti R, et al. Prevalence and clinical significance of a greater ambulatory versus office blood pressure ('reversed white coat' condition) in a general population. J Hypertens. Mar. 2005;23(3):513-20. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 15716691].
86 Bombelli M, Facchetti R, Sega R, et al. Impact of body mass index and waist circumference on the long-term risk of diabetes mellitus, hypertension, and cardiac organ damage. Hypertension. Dec. 2011;58(6):1029-35. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE12, KQ4bE12. [pmid: 22025375].
87 Bombelli M, Toso E, Peronio M, et al. The Pamela study: main findings and perspectives. Curr Hypertens Rep. Jun. 2013;15(3):238-43. KQ3aE7, KQ3bE7, KQ3cE7, KQ4aE7, KQ4bE7. [pmid: 23609611].
88 Bonnet F, Roussel R, Natali A, et al. Parental history of type 2 diabetes, TCF7L2 variant and lower insulin secretion are associated with incident hypertension. Data from the DESIR and RISC cohorts. Diabetologia. Aug. 14. 2013;56(11):2414-23. KQ4aE12, KQ4bE12. [pmid: 23942764].
89 Borghi C, Costa FV, Boschi S, et al. Predictors of stable hypertension in young borderline subjects: a five-year follow-up study. J Cardiovasc Pharmacol. 1986;8(Suppl 5):S138-S141. KQ4aE7e, KQ4bE7e. [pmid: 2427875].
90 Borghi C, Veronesi M, Bacchelli S, et al. Serum cholesterol levels, blood pressure response to stress and incidence of stable hypertension in young subjects with high normal blood pressure. J Hypertens. Feb. 2004;22(2):265-72. KQ4aE7e, KQ4bE7e. [pmid: 15076183].
91 Borghi C, Veronesi M, Bacchelli S, et al. Factors associated with the development of stable hypertension in young borderline hypertensives. J Hypertens. Feb. 2004;22(2):265-72. KQ4aE7e, KQ4bE7e. [pmid: 15076183].
92 Borghi C, Veronesi M, Cosentino E, et al. Interaction between serum cholesterol levels and the renin-angiotensin system on the new onset of arterial hypertension in subjects with high-normal blood pressure. J Hypertens. Oct. 2007;25(10):2051-7. KQ4aE7e, KQ4bE7e. [pmid: 17885547].
93 Borghi C, Cicero AF, Saragoni S, et al. Rate of control of LDL cholesterol and incident hypertension requiring antihypertensive treatment in hypercholesterolemic subjects in daily clinical practice. Ann Med. Mar. 2014;46(2):97-102. KQ4aE4b, KQ4bE4b. [pmid: 24460495].
94 Botomino A, Martina B, Ruf D, et al. White coat effect and white coat hypertension in community pharmacy practice. Blood Press Monit. Feb. 2005;10(1):13-8. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 15687869].
95 Bottini PB, Carr AA, Rhoades RB, et al. Variability of indirect methods used to determine blood pressure. Office vs mean 24-hour automated blood pressures. Arch Intern Med. Jan. 1992;152(1):139-44. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1728909].
96 Bovet P, Hungerbuhler P, Quilindo J, et al. Systematic difference between blood pressure readings caused by cuff type. Hypertension. Dec. 1994;24(6):786-92. KQ2aE3, KQ2bE4c, KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 7995638].
97 Bowman TS, Gaziano JM, Buring JE, et al. A prospective study of cigarette smoking and risk of incident hypertension in women. J Am Coll Cardiol. Nov 20. 2007;50(21):2085-92. KQ4aE2, KQ4bE2. [pmid: 18021879].
98 Braun HJ, Rabouw H, Werner H, et al. Measurements of blood pressure with various techniques in daily practice: uncertainty in diagnosing office hypertension with short-term in-hospital registration of blood pressure. Blood Press Monit. Apr. 1999;4(2):59-64. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 10450115].
99 Britton KA, Pradhan AD, Gaziano JM, et al. Hemoglobin A1c, body mass index, and the risk of hypertension in women. Am J Hypertens. 2011;24:328-34. KQ4aE4b, KQ4bE4b. [pmid: 21151012].
100 Brody S, Rau H. Behavioral and psychophysiological predictors of self-monitored 19 month blood pressure change in normotensives. J Psychosom Res. 1994;38:885-91. KQ4aE4, KQ4bE4. [pmid: 7722967].
101 Brown MA, Buddle ML, Martin A. Is resistant hypertension really resistant?. Am J Hypertens. Dec. 2001;14(12):1263-9. KQ3aE4, KQ3bE10b, KQ3cE10b. [pmid: 11775136].
102 Brueren MM, Dinant GJ, Schouten BJ, et al. Hypertension diagnosis by the family physician: measurements according to the NHG-standard (Dutch College of General Practitioners) compared with ambulatory blood pressure determination. Ned Tijdschr Geneeskd. Feb. 11. 1995;139(6):278-82. KQ2aE8, KQ2bE8, KQ3aE8, KQ3bE8, KQ3cE8. [pmid: 7862217].
103 Brueren MM, van LP, Schouten HJ, et al. Is a series of blood pressure measurements by the general practitioner or the patient a reliable alternative to ambulatory blood pressure measurement? A study in general practice with reference to short-term and long-term between-visit variability. Am J Hypertens. Aug. 1997;10(8):879-85. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9270082].
104 Brueren MM, Petri H, van WC, et al. How many measurements are necessary in diagnosing mild to moderate hypertension?. Fam Pract. Apr. 1997;14(2):130-5. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 9137951].
105 Brueren MM, Schouten HJ, de Leeuw PW, et al. A series of self-measurements by the patient is a reliable alternative to ambulatory blood pressure measurement. Br J Gen Pract. Sep. 1998;48(434):1585-9. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9830184].
106 Bur A, Herkner H, Vlcek M, et al. Classification of blood pressure levels by ambulatory blood pressure in hypertension. Hypertension. Dec. 2002;40(6):817-22. KQ3aE4a, KQ3bE5a, KQ3cE5a. [pmid: 12468563].
107 Burgess SE, MacLaughlin EJ, Smith PA, et al. Blood pressure rising: differences between current clinical and recommended measurement techniques. J Am Soc Hypertens. Nov. 2011;5(6):484-8. KQ2aE3, KQ2bE5a. [pmid: 22015319].
108 Burr ML, Dolan E, O'Brien EW, et al. The value of ambulatory blood pressure in older adults: the Dublin outcome study. Age Ageing. Mar. 2008;37(2):201-6. KQ3aE4d, KQ3bE7b, KQ3cE7b. [pmid: 18349014].
109 Byrd JB, Powers JD, Magid DJ, et al. Detection and recognition of hypertension in anxious and depressed patients. J Hypertens. Dec. 2012;30(12):2293-8. KQ4aE5, KQ4bE5. [pmid: 23032145].
110 Cahan A, Ben-Dov IZ, Mekler J, et al. The role of blood pressure variability in misdiagnosed clinic hypertension. Hypertens Res. Feb. 2011;34(2):187-92. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 21068739].
111 Calvo-Vargas C, Padilla R V, Troyo-Sanroman R, et al. Reproducibility and cost of blood pressure self-measurement using the 'Loaned Self-measurement Equipment Model'. Blood Press Monit. Oct. 2001;6(5):225-32. KQ3aE9, KQ3bE9, KQ3cE9. [pmid: 12055416].
112 Camoes M, Oliveira A, Pereira M, et al. Role of physical activity and diet in incidence of hypertension: a population-based study in Portuguese adults. Eur J Clin Nutr. Dec. 2010;64(12):1441-9. KQ4aE7e, KQ4bE7e. [pmid: 20808327].
113 Campbell NR, Myers MG, McKay DW. Is usual measurement of blood pressure meaningful?. Blood Press Monit. Apr. 1999;4(2):71-6. KQ2aE3, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 10450116].
114 Campbell NR, Milkovich L, Burgess E, et al. Self-measurement of blood pressure: accuracy, patient preparation for readings, technique and equipment. Blood Press Monit. Jun. 2001;6(3):133-8. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 11518835].
115 Campbell NR, Culleton BW, McKay DW. Misclassification of blood pressure by usual measurement in ambulatory physician practices. Am J Hypertens. Dec. 2005;18(12:Pt 1):1522-7. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16364819].
116 Campbell NR, Conradson HE, Kang J, et al. Automated assessment of blood pressure using BpTRU compared with assessments by a trained technician and a clinic nurse. Blood Press Monit. Oct. 2005;10(5):257-62. KQ2aE10b, KQ2bE6. [pmid: 16205444].
117 Cano-Pumarega I, Duran-Cantolla J, Aizpuru F, et al. Obstructive sleep apnea and systemic hypertension: longitudinal study in the general population: the Vitoria Sleep Cohort. Am J Respir Crit Care Med. Dec. 1. 2011;184(11):1299-304. KQ4aE12, KQ4bE12. [pmid: 21868499].
118 Canter D, Texter M, McLain R. Screening out 'white coat' hypertensives from clinical trials. PHARM MED. 1993;7:229-37. PMID: None. KQ3aE4, KQ3bE7f, KQ3cE4.
119 Cappellin E, Gatti R, Antonelli G, et al. Natriuretic peptide fragments as possible biochemical markers of hypertension in the elderly. J Cardiovasc Med (Hagerstown). Apr. 2013;14(4):308-13. KQ4aE7, KQ4bE7. [pmid: 22498997].
120 Cappuccio FP, Stranges S, Kandala NB, et al. Gender-specific associations of short sleep duration with prevalent and incident hypertension: the Whitehall II Study. Hypertension. Oct. 2007;50(4):693-700. KQ4aE4d, KQ4bE4d. [pmid: 17785629].
121 Carlsson AC, Johansson SE, Theobald H, et al. Blood pressure measures and their predictive ability of cardiovascular mortality: a 26-year follow-up. Blood Press Monit. Apr. 2013;18(2):72-7. KQ4aE4, KQ4bE4. [pmid: 23388402].
122 Carmelli D, Robinette D, Fabsitz R. Concordance, discordance and prevalence of hypertension in World War II male veteran twins. J Hypertens. Mar. 1994;12(3):323-8. KQ4aE12, KQ4bE12. [pmid: 8021487].
123 Carnethon MR, Evans NS, Church TS, et al. Joint associations of physical activity and aerobic fitness on the development of incident hypertension: coronary artery risk development in young adults. Hypertension. Jul. 2010;56(1):49-55. KQ4aE12, KQ4bE12. [pmid: 20516395].
124 Carr MJ, Bao Y, Pan J, et al. The predictive ability of blood pressure in elderly trial patients. J Hypertens. 2012;30:1725-33. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 22871888].
125 Carroll D, Smith GD, Shipley MJ, et al. Blood pressure reactions to acute psychological stress and future blood pressure status: a 10-year follow-up of men in the Whitehall II study. Psychosom Med. Sep. 2001;63(5):737-43. KQ4aE4, KQ4bE4. [pmid: 11573021].
126 Carson AP, Howard G, Burke GL, et al. Ethnic differences in hypertension incidence among middle-aged and older adults: the multi-ethnic study of atherosclerosis. Hypertension. Jun. 2011;57(6):1101-7. KQ4aE6, KQ4bE6. [pmid: 21502561].
127 Carter M, Karwalajtys T, Chambers L, et al. Implementing a standardized community-based cardiovascular risk assessment program in 20 Ontario communities. Health Promot Int. Dec. 2009;24(4):325-33. KQ1E4. [pmid: 19819896].
128 Casiglia E, Tikhonoff V, Caffi S, et al. Menopause does not affect blood pressure and risk profile, and menopausal women do not become similar to men. J Hypertens. Oct. 2008;26(10):1983-92. KQ4aE12, KQ4bE12. [pmid: 18806622].
129 Cassidy A, O'Reilly EJ, Kay C, et al. Habitual intake of flavonoid subclasses and incident hypertension in adults. Am J Clin Nutr. Feb. 2011;93(2):338-47. KQ4aE12, KQ4bE12. [pmid: 21106916].
130 Cassidy P, Jones K. A study of inter-arm blood pressure differences in primary care. J Hum Hypertens. 2001;15:519-22. KQ2aE3, KQ2bE4. [pmid: 11494088].
131 Cavelaars M, Tulen JH, Man in 't Veld AJ, et al. Assessment of body position to quantify its effect on nocturnal blood pressure under ambulatory conditions. J Hypertens. Dec. 2000;18(12):1737-43. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 11132596].
132 Cavelaars M, Tulen JH, van Bemmel JH, et al. Reproducibility of intra-arterial ambulatory blood pressure: effects of physical activity and posture. J Hypertens. Jun. 2004;22(6):1105-12. KQ2aE6, KQ2bE6, KQ3aE4, KQ3bE6, KQ3cE6. [pmid: 15167444].
133 Celis H, De CP, Fagard R, et al. For how many days should blood pressure be measured at home in older patients before steady levels are obtained?. J Hum Hypertens. Oct. 1997;11(10):673-7. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9400910].
134 Celis H, Staessen JA, Buntix F, et al. Antihypertensive treatment based on home or office blood pressure measurement: protocol of the randomized controlled THOP trial. Blood Press Monit. 1998;3:S29-S35. KQ3aE4, KQ3cE4.
135 Cesar CV, Victoria PR, Rogelio TS. Loaned self-measurement equipment model compared with ambulatory blood pressure monitoring. Blood Press Monit. Apr. 2003;8(2):63-70. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 12819557].
136 Chaney RH, Eyman RK. Blood pressure at rest and during maximal dynamic and isometric exercise as predictors of systemic hypertension. Am J Cardiol. Nov. 15. 1988;62(16):1058-61. KQ4aE7e, KQ4bE7e. [pmid: 3189168].
137 Charlson ME, Alderman M, Melcher L. Absenteeism and labeling in hypertensive subjects. Prevention of an adverse impact in those at high risk. Am J Med. 1982;73(2):165-70. KQ5E5a. [pmid: 7114071].
138 Chasan-Taber L, Willett WC, Manson JE, et al. Prospective study of oral contraceptives and hypertension among women in the United States. Circulation. Aug. 1. 1996;94(3):483-9. KQ4aE4b, KQ4bE4b. [pmid: 8759093].
139 Chase NL, Sui X, Lee DC, et al. The association of cardiorespiratory fitness and physical activity with incidence of hypertension in men. Am J Hypertens. Apr. 2009;22(4):417-24. KQ4aE12, KQ4bE12. [pmid: 19197248].
140 Chatellier G, Battaglia C, Pagny JY, et al. Decision to treat mild hypertension after assessment by ambulatory monitoring and World Health Organisation recommendations. BMJ. Oct. 31. 1992;305(6861):1062-6. KQ3aE4, KQ3bE3, KQ3cE4. [pmid: 1467686].
141 Chei CL, Iso H, Yamagishi K, et al. Body fat distribution and the risk of hypertension and diabetes among Japanese men and women. Hypertens Res. May. 2008;31(5):851-7. KQ4aE12, KQ4bE12. [pmid: 18712039].
142 Chen H, Burnett RT, Kwong JC, et al. Spatial association between ambient fine particulate matter and incident hypertension. Circulation. Feb. 4. 2014;129(5):562-9. KQ4aE12, KQ4bE12. [pmid: 24190962].
143 Cheng Y, Schwartz J, Sparrow D, et al. Bone lead and blood lead levels in relation to baseline blood pressure and the prospective development of hypertension: the Normative Aging Study. Am J Epidemiol. Jan. 15. 2001;153(2):164-71. KQ4aE7e, KQ4bE7e. [pmid: 11159162].
144 Chiolero A, Witteman JC, Viswanathan B, et al. No further decrease in blood pressure when the interval between readings exceeds one hour. Blood Press Monit. Apr. 2008;13(2):85-9. KQ2aE3, KQ2bE4. [pmid: 18347442].
145 Chonan K, Kikuya M, Araki T, et al. Device for the self-measurement of blood pressure that can monitor blood pressure during sleep. Blood Press Monit. Aug. 2001;6(4):203-5. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 11805470].
146 Choo EH, Ihm SH, Lim S, et al. A simple screening score for undiagnosed hypertension. Int J Cardiol. 2014. Jan. 23. KQ1E7. [pmid: 24485623].
147 Chrubasik S, Droste C, Glimm E, et al. Comparison of different methods of blood pressure measurements. Blood Press Monit. Jun. 2007;12(3):157-66. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17496465].
148 Chun H, Park SK, Ryoo JH. Association of serum -glutamyltransferase level and incident prehypertension in Korean men. J Korean Med Sci. Nov. 2013;28(11):1603-8. KQ4aE4, KQ4bE4. [pmid: 24265522].
149 Cicolini G, Gagliardi G, Ballone E. Effect of Fowler's body position on blood pressure measurement. J Clin Nurs. Dec. 2010;19(23-24):3581-3. KQ2aE3, KQ2bE4. [pmid: 21083782].
150 Cicolini G, Pizzi C, Palma E, et al. Differences in blood pressure by body position (supine, Fowler's, and sitting) in hypertensive subjects. Am J Hypertens. Oct. 2011;24(10):1073-9. KQ2aE3, KQ2bE5a. [pmid: 21677699].
151 Clark CE, Powell RJ. The differential blood pressure sign in general practice: prevalence and prognostic value. Fam Pract. Oct. 2002;19(5):439-41. KQ2aE3, KQ2bE4. [pmid: 12356690].
152 Clark S, Fowlie S, Pannarale G, et al. Age and blood pressure measurement: experience with the TM2420 ambulatory blood pressure monitor and elderly people. Age Ageing. Nov. 1992;21(6):398-403. KQ3aE3, KQ3bE3, KQ3cE3, KQ5E10b. [pmid: 1471576].
153 Clement DL, De Buyzere ML, De Bacquer DA, et al. Prognostic value of ambulatory blood-pressure recordings in patients with treated hypertension. N Engl J Med. Jun. 12. 2003;348(24):2407-15. KQ3bE4, KQ3cE4. [pmid: 12802026].
154 Coats AJ, Radaelli A, Clark SJ, et al. The influence of ambulatory blood pressure monitoring on the design and interpretation of trials in hypertension. J Hypertens. Apr. 1992;10(4):385-91. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1316405].
155 Cohen L, Curhan GC, Forman JP. Influence of age on the association between lifestyle factors and risk of hypertension. J Am Soc Hypertens. Jul. 2012;6(4):284-90. KQ4aE12, KQ4bE12. [pmid: 22789880].
156 Cohen L, Curhan G, Forman J. Association of sweetened beverage intake with incident hypertension. J Gen Intern Med. Sep. 2012;27(9):1127-34. KQ4aE12, KQ4bE12. [pmid: 22539069].
157 Coll de TG, Llibre JB, Poncelas AR, et al. Isolated clinical hypertension diagnosis: self-home BP, ambulatory BP monitoring, or both simultaneously?. Blood Press Monit. Feb. 2011;16(1):11-5. KQ3aE4, KQ3bE6, KQ3cE6. [pmid: 21183853].
158 Collins K, Gough S, Clancy M. Screening for hypertension in the emergency department. Emerg Med J. Apr. 2008;25(4):196-9. KQ1E4, KQ2aE4, KQ2bE4. [pmid: 18356346].
159 Conen D, Ridker PM, Buring JE, et al. Risk of cardiovascular events among women with high normal blood pressure or blood pressure progression: prospective cohort study. BMJ. Sep. 1. 2007;335(7617):432. KQ4aE4b, KQ4bE4b. [pmid: 17704543].
160 Conen D, Glynn RJ, Buring JE, et al. Natriuretic peptide precursor a gene polymorphisms and risk of blood pressure progression and incident hypertension. Hypertension. Dec. 2007;50(6):1114-9. KQ4aE12, KQ4bE12. [pmid: 17984371].
161 Conen D, Glynn RJ, Buring JE, et al. Association of renin-angiotensin and endothelial nitric oxide synthase gene polymorphisms with blood pressure progression and incident hypertension: prospective cohort study. J Hypertens. Sep. 2008;26(9):1780-6. KQ4aE4b, KQ4bE4b. [pmid: 18698212].
162 Conen D, Glynn RJ, Ridker PM, et al. Socioeconomic status, blood pressure progression, and incident hypertension in a prospective cohort of female health professionals. Eur Heart J. 2009;30:1378-84. KQ4aE2, KQ4bE2. [pmid: 19297384].
163 Conen D, Cheng S, Steiner LL, et al. Association of 77 polymorphisms in 52 candidate genes with blood pressure progression and incident hypertension: the Women's Genome Health Study. J Hypertens. Mar. 2009;27(3):476-83. KQ4aE4b, KQ4bE4b. [pmid: 19330901].
164 Coogan PF, White LF, Jerrett M, et al. Air pollution and incidence of hypertension and diabetes mellitus in black women living in Los Angeles. Circulation. Feb. 14. 2012;125(6):767-72. KQ4aE12, KQ4bE12. [pmid: 22219348].
165 Cornoni-Huntley J, Lacroix AZ, Havlik RJ. Race and sex differentials in the impact of hypertension in the United States. The National Health and Nutrition Examination Survey I Epidemiologic Follow-up Study. Arch Intern Med. Apr. 1989;149(4):780-8. KQ4aE12, KQ4bE12. [pmid: 2784957].
166 Cox J, Amery A, Clement D, et al. Relationship between blood pressure measured in the clinic and by ambulatory monitoring and left ventricular size as measured by electrocardiogram in elderly patients with isolated systolic hypertension. J Hypertens. Mar. 1993;11(3):269-76. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8387084].
167 Cozier Y, Palmer JR, Horton NJ, et al. Racial discrimination and the incidence of hypertension in US black women. Ann Epidemiol. Sep. 2006;16(9):681-7. KQ4aE4b, KQ4bE4b. [pmid: 16458539].
168 Cramer K, Dahlberg L. Incidence of hypertension among lead workers. A follow-up study based on regular control over 20 years. Br J Ind Med. Apr. 1966;23(2):101-4. KQ4aE7e, KQ4bE7e. [pmid: 5929682].
169 Culleton BF, McKay DW, Campbell NR. Performance of the automated BpTRU measurement device in the assessment of white-coat hypertension and white-coat effect. Blood Press Monit. Feb. 2006;11(1):37-42. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16410740].
170 Curhan GC, Willett WC, Rosner B, et al. Frequency of analgesic use and risk of hypertension in younger women. Arch Intern Med. Oct. 28. 2002;162(19):2204-8. KQ4aE4b, KQ4bE4b. [pmid: 12390063].
171 Curtis AB, James SA, Strogatz DS, et al. Alcohol consumption and changes in blood pressure among African Americans. The Pitt County Study. Am J Epidemiol. Nov. 1. 1997;146(9):727-33. KQ4aE7e, KQ4bE7e. [pmid: 9366620].
172 Cuspidi C, Meani S, Salerno M, et al. Reproducibility of nocturnal blood pressure fall in early phases of untreated essential hypertension: a prospective observational study. J Hum Hypertens. Jul. 2004;18(7):503-9. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 14749713].
173 Cuspidi C, Meani S, Sala C, et al. How reliable is isolated clinical hypertension defined by a single 24-h ambulatory blood pressure monitoring?. J Hypertens. Feb. 2007;25(2):315-20. KQ3aE4, KQ3cE4. [pmid: 17211238].
174 Cuspidi C, Sala C, Valerio C, et al. Nocturnal blood pressure in untreated essential hypertensives. Blood Press. Dec. 2011;20(6):335-41. KQ3aE4, KQ3cE4. [pmid: 21651423].
175 Czarkowski M, Zajac K, Rozanowski K. Can the pressor response accompanying blood pressure measurement be limited in young, normotensive women?. Blood Press Monit. Feb. 2008;13(1):1-5. KQ2aE3, KQ2bE4. [pmid: 18199917].
176 Czernichow S, Bertrais S, Blacher J, et al. Effect of supplementation with antioxidants upon long-term risk of hypertension in the SU.VI.MAX study: association with plasma antioxidant levels. J Hypertens. Nov. 2005;23(11):2013-8. KQ4aE12, KQ4bE12. [pmid: 16208143].
177 D'Elia L, De PD, Rossi G, et al. Not smoking is associated with lower risk of hypertension: results of the Olivetti Heart Study. Eur J Public Health. 2013. Mar. 28. KQ4aE7e, KQ4bE7e. [pmid: 23543678].
178 Dannenberg AL, Garrison RJ, Kannel WB. Incidence of hypertension in the Framingham Study. Am J Public Health. Jun. 1988;78(6):676-9. KQ4aE6, KQ4bE6. [pmid: 3259405].
179 Dauphinot V, Roche F, Kossovsky MP, et al. C-reactive protein implications in new-onset hypertension in a healthy population initially aged 65 years: the Proof study. J Hypertens. Apr. 2009;27(4):736-43. KQ4aE12, KQ4bE12. [pmid: 19516173].
180 Dauphinot V, Barthelemy JC, Pichot V, et al. Autonomic activation during sleep and new-onset ambulatory hypertension in the elderly. Int J Cardiol. Feb. 23. 2012;155(1):155-9. KQ4aE7e, KQ4bE7e. [pmid: 22078984].
181 Davidoff R, Schamroth CL, Goldman AP, et al. Postexercise blood pressure as a predictor of hypertension. Aviat Space Environ Med. Jun. 1982;53(6):591-4. KQ4aE9, KQ4bE9. [pmid: 7115246].
182 Davidson K, Jonas BS, Dixon KE, et al. Do depression symptoms predict early hypertension incidence in young adults in the CARDIA study? Coronary Artery Risk Development in Young Adults. Arch Intern Med. May. 22. 2000;160(10):1495-500. KQ4aE4b, KQ4bE4b. [pmid: 10826464].
183 Davidson RA, Hale WE, Moore MT, et al. Incidence of hypertension in an ambulatory elderly population. J Am Geriatr Soc. Sep. 1989;37(9):861-6. KQ4aE7e, KQ4bE7e. [pmid: 2760380].
184 Davies RJ, Jenkins NE, Stradling JR. Effect of measuring ambulatory blood pressure on sleep and on blood pressure during sleep. BMJ. 1994;308:820-3. KQ3aE3, KQ3bE3, KQ3cE3, KQ5E1. [pmid: 8167489].
185 Dawes MG, Coats AJ, Juszczak E. Daytime ambulatory systolic blood pressure is more effective at predicting mortality than clinic blood pressure. Blood Press Monit. Jun. 2006;11(3):111-8. KQ2aE3, KQ2bE3, KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 16702819].
186 de Gaudemaris R, Chau NP, Mallion JM. Home blood pressure: variability, comparison with office readings and proposal for reference values. Groupe de la Mesure, French Society of Hypertension. J Hypertens. Jul. 1994;12(7):831-8. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 7963513].
187 de la Sierra A, Banegas JR, Segura J, et al. Ambulatory blood pressure monitoring and development of cardiovascular events in high-risk patients included in the Spanish ABPM registry: the CARDIORISC Event study. J Hypertens. Apr. 2012;30(4):713-9. KQ3aE5, KQ3bE5, KQ3cE5. [pmid: 22306850].
188 de Marco M, de Simone G, Roman MJ, et al. Cardiovascular and metabolic predictors of progression of prehypertension into hypertension: the Strong Heart Study. Hypertension. Nov. 2009;54(5):974-80. KQ4aE7e, KQ4bE7e. [pmid: 19720957].
189 de Simone G, Devereux RB, Roman MJ, et al. Echocardiographic left ventricular mass and electrolyte intake predict arterial hypertension. Ann Intern Med. Feb. 1. 1991;114(3):202-9. KQ4aE7e, KQ4bE7e. [pmid: 1984744].
190 de Simone G, Devereux RB, Chinali M, et al. Risk factors for arterial hypertension in adults with initial optimal blood pressure: the Strong Heart Study. Hypertension. Feb. 2006;47(2):162-7. KQ4aE7e, KQ4bE7e. [pmid: 16380527].
191 de Simone G, Schillaci G, Chinali M, et al. Estimate of white-coat effect and arterial stiffness. J Hypertens. Apr. 2007;25(4):827-31. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17351375].
192 de Simone G, Devereux RB, Chinali M, et al. Left ventricular mass and incident hypertension in individuals with initial optimal blood pressure: the Strong Heart Study. J Hypertens. Sep. 2008;26(9):1868-74. KQ4aE7e, KQ4bE7e. [pmid: 18698223].
193 de Tuero GC, Boreu QF, Rodriguez-Poncelas A, et al. Assessment of self-monitoring of blood pressure in the diagnosis of isolated clinic hypertension. Blood Press. 2006;15(4):227-36. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 17078176].
194 de MC, Schroeter V, Butzer R, et al. Method specificity of non-invasive blood pressure measurement: oscillometry and finger pulse pressure vs acoustic methods. Br J Clin Pharmacol. Oct. 1995;40(4):291-7. KQ2aE4, KQ2bE3. [pmid: 8554929].
195 Dedier J, Stampfer MJ, Hankinson SE, et al. Nonnarcotic analgesic Use and the Risk of Hypertension in US Women. Hypertension. 2002;40(5):604-8. KQ4aE12, KQ4bE12. [pmid: 12411450].
196 Del Torre M, Mormino P, Roman E, et al. Comparison between office and ambulatory blood pressure in young and elderly subjects with isolated systolic hypertension. Blood Press Monit. Dec. 1996;1(6):457-62. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10226275].
197 Denolle T. Comparison and reproducibility of 4 methods of indirect blood pressure measurement in moderate hypertension. Arch Mal Coeur Vaiss. Aug. 1995;88(8):1165-70. KQ3aE8, KQ3bE8, KQ3cE8. [pmid: 8572866].
198 ders S, Schrader J, Berger J, et al. The PHARAO study: prevention of hypertension with the angiotensin-converting enzyme inhibitor ramipril in patients with high-normal blood pressure -- a prospective, randomized, controlled prevention trial of the German Hypertension League. J Hypertens. Jul. 2008;26(7):1487-96. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE7c, KQ4bE7c. [pmid: 18551027].
199 Dhingra R, Pencina MJ, Schrader P, et al. Relations of matrix remodeling biomarkers to blood pressure progression and incidence of hypertension in the community. Circulation. Mar 3. 2009;119(8):1101-7. KQ4aE7e, KQ4bE7e. [pmid: 19221217].
200 Di PP, Cannizzaro S, Paterna S. Does angiotensin-converting enzyme gene polymorphism affect blood pressure? Findings after 6 years of follow-up in healthy subjects. Eur J Heart Fail. Jan. 2004;6(1):11-6. KQ4aE7e, KQ4bE7e. [pmid: 15012913].
201 Di PP, Cannizzaro S, Scalzo S, et al. Cardiovascular effects of I/D angiotensin-converting enzyme gene polymorphism in healthy subjects. Findings after follow-up of six years. Acta Cardiol. Aug. 2005;60(4):427-35. KQ4aE7e, KQ4bE7e. [pmid: 16128377].
202 Diamond JA, Krakoff LR, Martin K, et al. Comparison of ambulatory blood pressure and amounts of left ventricular hypertrophy in men versus women with similar levels of hypertensive clinic blood pressures. Am J Cardiol. Feb. 15. 1997;79(4):505-8. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9052361].
203 Dieterle T, Schuurmans MM, Strobel W, et al. Moderate-to-severe blood pressure elevation at ED entry: hypertension or normotension?. Am J Emerg Med. Jul. 2005;23(4):474-9. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 16032614].
204 Diez Roux AV, Chambless L, Merkin SS, et al. Socioeconomic disadvantage and change in blood pressure associated with aging. Circulation. Aug. 6. 2002;106(6):703-10. KQ4aE12, KQ4bE12. [pmid: 12163431].
205 Dimsdale JE, von KR, Profant J, et al. Reliability of nocturnal blood pressure dipping. Blood Press Monit. Aug. 2000;5(4):217-21. KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 11035863].
206 Divison JA, Sanchis C, Artigao LM, et al. Home-based self-measurement of blood pressure: a proposal using new reference values (the PURAS study). Blood Press Monit. Aug. 2004;9(4):211-8. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 15311148].
207 Djousse L, Rudich T, Gaziano JM. Nut consumption and risk of hypertension in US male physicians. Clin Nutr. Feb. 2009;28(1):10-4. KQ4aE12, KQ4bE12. [pmid: 18834651].
208 Dolan E, Atkins N, McClory S, et al. Ambulatory blood pressure measurement as a predictor of outcome in an Irish population: methodology for ascertaining mortality outcome. Blood Press Monit. Aug. 2003;8(4):143-5. KQ3aE1, KQ3bE1, KQ3cE1. [pmid: 14517475].
209 Dolan E, Stanton A, Atkins N, et al. Determinants of white-coat hypertension. [Review] [16 refs]. Blood Press Monit. Dec. 2004;9(6):307-9. KQ3aE7b, KQ3bE7b, KQ3cE7b. [pmid: 15564985].
210 Dolan E, Stanton A, Thijs L, et al. Superiority of ambulatory over clinic blood pressure measurement in predicting mortality: the Dublin outcome study. Hypertension. Jul. 2005;46(1):156-61. KQ2aE3, KQ2bE3, KQ3bE4, KQ3cE4. [pmid: 15939805].
211 Dolan E, Staessen JA, O'Brien E. Data from the Dublin outcome study. Blood Press Monit. Dec. 2007;12(6):401-3. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 18277321].
212 Dolan E, Stanton AV, Thom S, et al. Ambulatory blood pressure monitoring predicts cardiovascular events in treated hypertensive patients--an Anglo-Scandinavian cardiac outcomes trial substudy. J Hypertens. Apr. 2009;27(4):876-85. KQ3aE5, KQ3bE5a, KQ3cE5a. [pmid: 19516185].
213 Donner-Banzhoff N, Chan Y, Szalai JP, et al. 'Home hypertension': exploring the inverse white coat response. Br J Gen Pract. Aug. 1998;48(433):1491-5. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10024708].
214 Dzielinska Z, Prejbisz A, Makowiecka-Ciesla M, et al. The 24-h blood pressure measurement may predict mortality and cardiovascular events in hypertensive patients with coronary artery disease. Blood Press Monit. Jun. 2009;14(3):99-102. KQ3aE5, KQ3bE5, KQ3cE5. [pmid: 19417635].
215 Dzien A, Pfeiffer K, Dzien-Bischinger C, et al. The correlation of office blood pressure and 24-hour ambulatory measurements in hypertensive patients - comparison between non-pharmacological treatment and antihypertensive medication. Eur J Med Res. Jun. 20. 2000;5(6):268-72. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10882643].
216 Eder MJ, Holzgreve H, Liebl ME, et al. Effect of clothing on sphygmomanometric and oscillometric blood pressure measurement in hypertensive subjects. Dtsch Med Wochenschr. 2008;133(24):1288-92. KQ2aE8, kQ2bE8. [pmid: 18528794].
217 Edick CM, Parnell D, Christensen ML, et al. Falsely elevated systolic blood pressure with patient-operated blood pressure measuring devices. J Am Pharm Assoc (Wash). Sep. 2000;40(5):670-2. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 11029849].
218 Edwards C, Hiremath S, Gupta A, et al. BpTRUth: do automated blood pressure monitors outperform mercury?. Journal of the American Society of Hypertension. Nov. 2013;7(6):448-53. KQ2aE5a, KQ2bE5a, KQ3aE5a, KQ3bE5a, KQ3cE5a. [pmid: 23969286].
219 Eguchi K, Yacoub M, Jhalani J, et al. Consistency of blood pressure differences between the left and right arms. Arch Intern Med. Feb. 26. 2007;167(4):388-93. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17325301].
220 Eguchi K, Pickering TG, Hoshide S, et al. Ambulatory blood pressure is a better marker than clinic blood pressure in predicting cardiovascular events in patients with/without type 2 diabetes. Am J Hypertens. Apr. 2008;21(4):443-50. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 18292756].
221 Eguchi K, Hoshide S, Hoshide Y, et al. Reproducibility of ambulatory blood pressure in treated and untreated hypertensive patients. J Hypertens. May. 2010;28(5):918-24. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 20216090].
222 Eguchi K, Kuruvilla S, Ishikawa J, et al. Correlations between different measures of clinic, home, and ambulatory blood pressure in hypertensive patients. Blood Press Monit. Jun. 2011;16(3):142-8. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 21562456].
223 Ejima Y, Hasegawa Y, Sanada S, et al. Characteristics of young-onset hypertension identified by targeted screening performed at a university health check-up. Hypertens Res. Apr. 2006;29(4):261-7. KQ1E4, KQ3aE4, KQ3bE10a, KQ3cE10a, KQ4aE10a, KQ4bE10a. [pmid: 16778333].
224 Ekerdt DJ, Sparrow D, Glynn RJ, et al. Change in blood pressure and total cholesterol with retirement. Am J Epidemiol. Jul. 1984;120(1):64-71. KQ4aE7e, KQ4bE7e. [pmid: 6741924].
225 Ekstrand K, Nilsson JA, Lilja B, et al. Markers for development of hypertension in commercial flight aviators. Aviat Space Environ Med. Oct. 1991;62(10):963-8. KQ4aE7e, KQ4bE7e. [pmid: 1764008].
226 Elijovich F, Laffer CL. Bayesian analysis supports use of ambulatory blood pressure monitors for screening. Hypertension. Feb. 1992;19(2 Suppl):II268-II272. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE7b, KQ3cE7b. [pmid: 1735591].
227 Elliott WJ, Young PE, DeVivo L, et al. A comparison of two sphygmomanometers that may replace the traditional mercury column in the healthcare workplace. Blood Press Monit. Feb. 2007;12(1):23-8. KQ2aE1, KQ2bE1, KQ3aE1, KQ3bE1, KQ3cE1. [pmid: 17303984].
228 Elmer PJ, Obarzanek E, Vollmer WM, et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. Apr. 4. 2006;144(7):485-95. KQ4aE7a, KQ4bE7a. [pmid: 16585662].
229 Emelianov D, Thijs L, Staessen JA, et al. Conventional and ambulatory measurements of blood pressure in old patients with isolated systolic hypertension: baseline observations in the Syst-Eur trial. Blood Press Monit. Jun. 1998;3(3):173-80. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10212350].
230 Engberink MF, Bakker SJ, Brink EJ, et al. Dietary acid load and risk of hypertension: the Rotterdam Study. Am J Clin Nutr. Jun. 2012;95(6):1438-44. KQ4aE12, KQ4bE12. [pmid: 22552032].
231 Engstrom G, Janzon L, Berglund G, et al. Blood pressure increase and incidence of hypertension in relation to inflammation-sensitive plasma proteins. Arterioscler Thromb Vasc Biol. Dec. 1. 2002;22(12):2054-8. KQ4aE12, KQ4bE12. [pmid: 12482834].
232 Engstrom G, Hedblad B, Berglund G, et al. Plasma levels of complement C3 is associated with development of hypertension: a longitudinal cohort study. J Hum Hypertens. Apr. 2007;21(4):276-82. KQ4aE12, KQ4bE12. [pmid: 17167524].
233 Engstrom S, Berne C, Gahnberg L, et al. Efficacy of screening for high blood pressure in dental health care. BMC Public Health. 2011;11:194. KQ1E1, KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 21450067].
234 Enstrom I, Thulin T, Lanke J, et al. Usefulness of self-measured blood pressure when diagnosing mild hypertension. J Hum Hypertens. Oct. 1992;6(5):375-9. KQ3aE4, KQ3bE7f, KQ3cE4. [pmid: 1464894].
235 Enstrom I, Lindholm LH. Blood pressure in middle-aged women: a comparison between office-, self-, and ambulatory recordings. Blood Press. Dec. 1992;1(4):240-6. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 1345221].
236 Enstrom I, Pennert K, Lindholm LH. Difference in blood pressure, but not in heart rate, between measurements performed at a health centre and at a hospital by one and the same physician. J Hum Hypertens. Jun. 2000;14(6):355-8. KQ2aE3, KQ2bE4. [pmid: 10878693].
237 Enstrom IE, Pennert KM. 24 h non-invasive ambulatory blood pressure monitoring: do the number of recordings per hour and/or ways of analyzing day and night matter?. Blood Press Monit. Oct. 2001;6(5):253-6. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 12055420].
238 Enström G I. Ambulatory blood pressure monitoring. A tool for more comprehensive assessment. Blood Press Suppl. 1992;5:1-27. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1345260].
239 Entonen AH, Suominen SB, Korkeila K, et al. Migraine predicts hypertension--a cohort study of the Finnish working-age population. Eur J Public Health. 2013. Sep. 23. KQ4aE4b, KQ4bE4b. [pmid: 24065369].
240 Erceg M, Ivicevic-Uhernik A, Kern J, et al. Plasma levels of complement C3 is associated with development of hypertension: a longitudinal cohort study. Coll Antropol. Jan. 2012;36:Suppl-7. PMID: None. KQ4aE10b, KQ4bE10b.
241 Erceg M, Ivicevic-Uhernik A, Kern J, et al. Is there any association between blood pressure and education level? The CroHort study. Coll Antropol. Jan. 2012;36(Suppl 1):125-9. KQ4aE4d, KQ4bE4d. [pmid: 22338760].
242 Eriksson C, Rosenlund M, Pershagen G, et al. Aircraft noise and incidence of hypertension. Epidemiology. Nov. 2007;18(6):716-21. KQ4aE12, KQ4bE12. [pmid: 17917607].
243 Ernst ME, Weber CA, Dawson JD, et al. How well does a shortened time interval characterize results of a full ambulatory blood pressure monitoring session?. J Clin Hypertens (Greenwich). Jun. 2008;10(6):431-5. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 18550932].
244 Ernst ME, Sezate GS, Lin W, et al. Indication-specific 6-h systolic blood pressure thresholds can approximate 24-h determination of blood pressure control. J Hum Hypertens. Apr. 2011;25(4):250-5. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 20574446].
245 Espinosa R, Spruill TM, Zawadzki MJ, et al. Can blood pressure measurements taken in the physician's office avoid the 'white coat' bias?. Blood Press Monit. Oct. 2011;16(5):231-7. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 21897208].
246 Everson SA, Goldberg DE, Kaplan GA, et al. Anger expression and incident hypertension. Psychosom Med. Nov. 1998;60(6):730-5. KQ4aE7e, KQ4bE7e. [pmid: 9847033].
247 Factor SH, Lo Y, Schoenbaum E, et al. Incident hypertension in older women and men with or at risk for HIV infection. HIV Med. Jul. 2013;14(6):337-46. KQ4aE7e, KQ4bE7e. [pmid: 23294666].
248 Fagard RH, Staessen JA, Thijs L, et al. Relationship between ambulatory blood pressure and follow-up clinic blood pressure in elderly patients with systolic hypertension. J Hypertens. Jan. 2004;22(1):81-7. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 15106798].
249 Fagard RH, van den Broeke C, de Cort P. Prognostic significance of blood pressure measured in the office, at home and during ambulatory monitoring in older patients in general practice. J Hum Hypertens. 2005;19(10):801-7. KQ2aE5b, KQ2bE5b, KQ3bE5b, KQ3cE5b. [pmid: 15959536].
250 Fagard RH, Thijs L, Staessen JA, et al. Prognostic significance of ambulatory blood pressure in hypertensive patients with history of cardiovascular disease. Blood Press Monit. Dec. 2008;13(6):325-32. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 18756173].
251 Fagard RH, Celis H, Thijs L, et al. Daytime and nighttime blood pressure as predictors of death and cause-specific cardiovascular events in hypertension. Hypertension. Jan. 2008;51(1):55-61. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 18039980].
252 Fagard RH, Thijs L, Staessen JA, et al. Night-day blood pressure ratio and dipping pattern as predictors of death and cardiovascular events in hypertension. J Hum Hypertens. Oct. 2009;23(10):645-53. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 19225527].
253 Fagot-Campagna A, Balkau B, Simon D, et al. High free fatty acid concentration: an independent risk factor for hypertension in the Paris Prospective Study. Int J Epidemiol. Oct. 1998;27(5):808-13. KQ4aE4d, KQ4bE4d. [pmid: 9839737].
254 Familoni OB, Olunuga TO. Comparison of the effects of arm position and support on blood pressure in hypertensive and normotensive subjects. Cardiovasc J S Afr. Mar. 2005;16(2):85-8. KQ2aE9, KQ2bE9. [pmid: 15915274].
255 Fan HQ, Li Y, Thijs L, et al. Prognostic value of isolated nocturnal hypertension on ambulatory measurement in 8711 individuals from 10 populations. J Hypertens. Oct. 2010;28(10):2036-45. KQ3aE6, KQ3bE5a, KQ3cE5a. [pmid: 20520575].
256 Fariello R, Boni E, Crippa M, et al. Ambulatory-determined 24-hour blood pressure in mild hypertensives and in normotensives. Angiology. Oct. 1996;47(10):957-62. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8873581].
257 Faselis C, Doumas M, Kokkinos JP, et al. Exercise capacity and progression from prehypertension to hypertension. Hypertension. Aug. 2012;60(2):333-8. KQ4aE12, KQ4bE12. [pmid: 22753224].
258 Fava C, Danese E, Montagnana M, et al. Serine/threonine kinase 39 is a candidate gene for primary hypertension especially in women: results from two cohort studies in Swedes. J Hypertens. Mar. 2011;29(3):484-91. KQ4aE12, KQ4bE12. [pmid: 21178783].
259 Fava C, Sjogren M, Montagnana M, et al. Prediction of blood pressure changes over time and incidence of hypertension by a genetic risk score in Swedes. Hypertension. Feb. 2013;61(2):319-26. KQ4aE12, KQ4bE12. [pmid: 23232644].
260 Feldman R. ACP Journal Club. Review: Home and clinic BP have limited accuracy compared with ambulatory BP for diagnosing hypertension. Ann Intern Med. Dec. 20. 2011;155(12):JC6-JC10. KQ2aE7, KQ2bE7, KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 22184711].
261 Felicio JS, Pacheco JT, Ferreira SR, et al. Reproducibility of ambulatory blood pressure monitoring in hypertensive patients with type 2 diabetes mellitus. Arq Bras Cardiol. 2007;88(2):206-11. KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 17384839].
262 Felix-Redondo FJ, Fernandez-Berges D, Espinosa-Garcia J, et al. Level of blood pressure control in a hypertensive population when measurements are performed outside the clinical setting. Cardiol J. 2009;16(1):57-67. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 19130417].
263 Ferguson JH, Shaar CJ. The effective diagnosis and treatment of hypertension by the primary care physician: impact of ambulatory blood pressure monitoring. [Erratum appears in J Am Board Fam Pract 1992 Nov-Dec;5(6):658]. J Am Board Fam Pract. Sep. 1992;5(5):457-65. KQ3aE4, KQ3bE4c, KQ3cE4. [pmid: 1414446].
264 Ferguson TS, Younger N, Tulloch-Reid MK, et al. Progression from prehypertension to hypertension in a Jamaican cohort: incident hypertension and its predictors. West Indian Med J. Oct. 2010;59(5):486-93. KQ4aE9, KQ4bE9. [pmid: 21473394].
265 Feskens EJ, Tuomilehto J, Stengard JH, et al. Hypertension and overweight associated with hyperinsulinaemia and glucose tolerance: a longitudinal study of the Finnish and Dutch cohorts of the Seven Countries Study. Diabetologia. Jul. 1995;38(7):839-47. KQ4aE7e, KQ4bE7e. [pmid: 7556987].
266 Fesler P, Ribstein J, du CG, et al. Determinants of cardiorenal damage progression in normotensive and never-treated hypertensive subjects. Kidney Int. May. 2005;67(5):1974-9. KQ4aE7e, KQ4bE7e. [pmid: 15840046].
267 Figueiredo D, Azevedo A, Pereira M, et al. Definition of hypertension: the impact of number of visits for blood pressure measurement. Rev Port Cardiol. Jul. 2009;28(7-8):775-83. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 19894656].
268 Fishman PA, Anderson ML, Cook AJ, et al. Accuracy of blood pressure measurements reported in an electronic medical record during routine primary care visits. J Clin Hypertens (Greenwich). Nov. 2011;13(11):821-8. KQ2aE3, KQ2bE5a. [pmid: 22051427].
269 Fleming J, Meredith C, Henry J. Detection of hypertension in the emergency department. Emerg Med J. Sep. 2005;22(9):636-40. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE10a, KQ3cE10a. [pmid: 16113183].
270 Flint AJ, Hu FB, Glynn RJ, et al. Whole grains and incident hypertension in men. Am J Clin Nutr. Sep. 2009;90(3):493-8. KQ4aE12, KQ4bE12. [pmid: 19571218].
271 Fogari R, Corradi L, Zoppi A, et al. Repeated office blood pressure controls reduce the prevalence of white-coat hypertension and detect a group of white-coat normotensive patients. Blood Press Monit. Feb. 1996;1(1):51-4. KQ2aE6, KQ2bE6, KQ3aE4, KQ3cE4. [pmid: 10226202].
272 Fogari R, Zoppi A, Lusardi P, et al. Fixed combination of benazepril and low-dose amlodipine in the treatment of mild to moderate essential hypertension: evaluation by 24-hour noninvasive ambulatory blood pressure monitoring. J Cardiovasc Pharmacol. 1997;30(2):176-81. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9269944].
273 Fogari R, Zoppi A, Mugellini A, et al. Efficacy and safety of two treatment combinations of hypertension in very elderly patients. Arch Gerontol Geriatr. 2009;48(3):401-5. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 18457886].
274 Foguet Q, Marti H, Elosua R, et al. Hypertension confirmation and blood pressure control rates in epidemiological surveys. Eur J Cardiovasc Prev Rehabil. Jun. 2008;15(3):263-9. KQ3aE4, KQ3bE3, KQ3cE3, KQ4aE5b, KQ4bE5b. [pmid: 18525380].
275 Folsom AR, Peacock JM, Nieto FJ, et al. Plasma fibrinogen and incident hypertension in the Atherosclerosis Risk in Communities (ARIC) Study. J Hypertens. Nov. 1998;16(11):1579-83. KQ4aE12, KQ4bE12. [pmid: 9856357].
276 Folsom AR, Parker ED, Harnack LJ. Degree of concordance with DASH diet guidelines and incidence of hypertension and fatal cardiovascular disease. Am J Hypertens. Mar. 2007;20(3):225-32. KQ4aE12, KQ4bE12. [pmid: 17324731].
277 Fonseca-Reyes S, de Alba-Garcia JG, Parra-Carrillo JZ, et al. Effect of standard cuff on blood pressure readings in patients with obese arms. How frequent are arms of a 'large circumference'?. Blood Press Monit. Jun. 2003;8(3):101-6. KQ2aE9, KQ2bE9. [pmid: 12900586].
278 Fonseca-Reyes S, Cervantes-Munguia R, de Alba-Garcia JG, et al. Evaluation and effects of the Omron 725 CIC device for measuring blood pressure in a hypertension clinic. Blood Press Monit. Oct. 2007;12(5):321-7. KQ2aE9, KQ2bE9. [pmid: 17890971].
279 Fonseca-Reyes S, Forsyth-MacQuarrie AM, Garcia de Alba-Garcia JE. Simultaneous blood pressure measurement in both arms in hypertensive and nonhypertensive adult patients. Blood Press Monit. Aug. 2012;17(4):149-54. KQ2aE9, KQ2bE9. [pmid: 22781632].
280 Ford ES, Cooper RS. Risk factors for hypertension in a national cohort study. Hypertension. Nov. 1991;18(5):598-606. KQ4aE12, KQ4bE12. [pmid: 1937662].
281 Forman JP, Bischoff-Ferrari HA, Willett WC, et al. Vitamin D intake and risk of incident hypertension: results from three large prospective cohort studies. Hypertension. Oct. 2005;46(4):676-82. KQ4aE12, KQ4bE12. [pmid: 16144983].
282 Forman JP, Rimm EB, Stampfer MJ, et al. Folate intake and the risk of incident hypertension among US women. JAMA. Jan. 19. 2005;293(3):320-9. KQ4aE12, KQ4bE12. [pmid: 15657325].
283 Forman JP, Choi H, Curhan GC. Plasma uric acid level and risk for incident hypertension among men. J Am Soc Nephrol. Jan. 2007;18(1):287-92. KQ4aE12, KQ4bE12. [pmid: 17167112].
284 Forman JP, Rimm EB, Curhan GC. Frequency of analgesic use and risk of hypertension among men. Arch Intern Med. Feb. 26. 2007;167(4):394-9. KQ4aE4b, KQ4bE4b. [pmid: 17325302].
285 Forman JP, Fisher ND, Schopick EL, et al. Higher levels of albuminuria within the normal range predict incident hypertension. J Am Soc Nephrol. Oct. 2008;19(10):1983-8. KQ4aE4b, KQ4bE4b. [pmid: 18579639].
286 Forman JP, Curhan GC, Schernhammer ES. Urinary melatonin and risk of incident hypertension among young women. J Hypertens. Mar. 2010;28(3):446-51. KQ4aE7e, KQ4bE7e. [pmid: 20090558].
287 Forman JP, Scheven L, de Jong PE, et al. Association between sodium intake and change in uric acid, urine albumin excretion, and the risk of developing hypertension. Circulation. Jun. 26. 2012;125(25):3108-16. KQ4aE12, KQ4bE12. [pmid: 22711274].
288 Forsvall A, Oscarsson M, Magalhaes LB, et al. An evaluation of the Rastreometro, a new device for populational screening for high blood pressure in developing countries. Arq Bras Cardiol. Oct. 2006;87(4):480-6. KQ2aE9, KQ2bE9. [pmid: 17128318].
289 Fotherby MD, Potter JF. Reproducibility of ambulatory and clinic blood pressure measurements in elderly hypertensive subjects. J Hypertens. May. 1993;11(5):573-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8390530].
290 Fox ER, Musani SK, Singh P, et al. Association of plasma B-type natriuretic peptide concentrations with longitudinal blood pressure tracking in African Americans: findings from the Jackson Heart Study. Hypertension. Jan. 2013;61(1):48-54. KQ4aE7e, KQ4bE7e. [pmid: 23184379].
291 Fragola PV, Romitelli S, Moretti A, et al. Precursors of established hypertension in borderline hypertensives. A two-year follow-up. Int J Cardiol. May. 1993;39(2):113-9. KQ4aE7e, KQ4bE7e. [pmid: 8314644].
292 Franks RM, Macintyre PA. Home blood pressure monitoring in an anaesthetic pre-admission clinic. Anaesthesia & Intensive Care. Sep. 2013;41(5):648-54. KQ3aE3, KQ3bE5, KQ3cE5. [pmid: 23977917].
293 Fravel MA, Ernst ME, Bergus GR. Psychological effect of ambulatory blood pressure monitoring. Am J Health Syst Pharm. Mar. 1. 2010;67(5):343. KQ5E7. [pmid: 20172981].
294 Freitag MH, Larson MG, Levy D, et al. Psychological effect of ambulatory blood pressure monitoring. Hypertension. Apr. 2003;41(4):978-83. KQ4aE4d, KQ4bE4d. [pmid: 12623868].
295 Friedman GD, Selby JV, Quesenberry CP Jr, et al. Precursors of essential hypertension: body weight, alcohol and salt use, and parental history of hypertension. Prev Med. Jul. 1988;17(4):387-402. KQ4aE12, KQ4bE12. [pmid: 3217372].
296 Friedman O, Logan AG. Nocturnal blood pressure profiles among normotensive, controlled hypertensive and refractory hypertensive subjects. Can J Cardiol. Sep. 2009;25(9):e312-e316. KQ5E1. [pmid: 19746250].
297 Fuchs FD, Chambless LE, Whelton PK, et al. Alcohol consumption and the incidence of hypertension: The Atherosclerosis Risk in Communities Study. Hypertension. May. 2001;37(5):1242-50. KQ4aE12, KQ4bE12. [pmid: 11358935].
298 Fung MM, Peters K, Redline S, et al. Decreased slow wave sleep increases risk of developing hypertension in elderly men. Hypertension. Oct. 2011;58(4):596-603. KQ4aE7e, KQ4bE7e. [pmid: 21876072].
299 Furugen M, Saitoh S, Ohnishi H, et al. Matsuda-DeFronzo insulin sensitivity index is a better predictor than HOMA-IR of hypertension in Japanese: the Tanno-Sobetsu study. J Hum Hypertens. May. 2012;26(5):325-33. KQ4aE7e, KQ4bE7e. [pmid: 21412265].
300 Gaffo AL, Jacobs DR Jr, Sijtsma F, et al. Serum urate association with hypertension in young adults: analysis from the Coronary Artery Risk Development in Young Adults cohort. Ann Rheum Dis. Aug. 2013;72(8):1321-7. KQ4aE4d, KQ4bE4d. [pmid: 22984170].
301 Galan P, Vergnaud AC, Tzoulaki I, et al. Low total and nonheme iron intakes are associated with a greater risk of hypertension. J Nutr. Jan. 2010;140(1):75-80. KQ4aE7c, KQ4bE7c. [pmid: 19923383].
302 Galletti F, D'Elia L, Barba G, et al. High-circulating leptin levels are associated with greater risk of hypertension in men independently of body mass and insulin resistance: results of an eight-year follow-up study. J Clin Endocrinol Metab. Oct. 2008;93(10):3922-6. KQ4aE7e, KQ4bE7e. [pmid: 18682500].
303 Gangwisch JE, Malaspina D, Posner K, et al. Insomnia and sleep duration as mediators of the relationship between depression and hypertension incidence. Am J Hypertens. Jan. 2010;23(1):62-9. KQ4aE4b, KQ4bE4b. [pmid: 19893498].
304 Garcia-Vera MP, Sanz J. How many self-measured blood pressure readings are needed to estimate hypertensive patients' "true" blood pressure?. J Behav Med. Feb. 1999;22(1):93-113. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 10196731].
305 Garcia-Vera MP, Labrador FJ, Sanz J. Comparison of clinic, home self-measured, and work self-measured blood pressures. Behav Med. 1999;25(1):13-22. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 10209694].
306 Garrison GM, Oberhelman S. Screening for hypertension annually compared with current practice. Ann Fam Med. Mar. 2013;11(2):116-21. KQ1E1, KQ2aE3, KQ2bE4, KQ3aE3, KQ3bE3, KQ3cE3, KQ4aE7e, KQ4bE7e. [pmid: 23508597].
307 Gasowski J, Li Y, Kuznetsova T, et al. Is "usual" blood pressure a proxy for 24-h ambulatory blood pressure in predicting cardiovascular outcomes?. Am J Hypertens. Sep. 2008;21(9):994-1000. KQ3bE4, KQ3cE4. [pmid: 18600212].
308 Gavish B, Gavish L. Blood pressure variation in response to changing arm cuff height cannot be explained solely by the hydrostatic effect. J Hypertens. Nov. 2011;29(11):2099-104. KQ2aE3, KQ2bE5a. [pmid: 21873886].
309 Gelber RP, Gaziano JM, Manson JE, et al. A prospective study of body mass index and the risk of developing hypertension in men. Am J Hypertens. Apr. 2007;20(4):370-7. KQ4aE12, KQ4bE12. [pmid: 17386342].
310 Georgiades A, de FU, Lemne C. Clinical prediction of normotension in borderline hypertensive men--a 10 year study. J Hypertens. Mar. 2004;22(3):471-8. KQ4aE7e, KQ4bE7e. [pmid: 15076151].
311 Gerber LM, Schwartz JE, Pickering TG. Albumin-to-creatinine ratio predicts change in ambulatory blood pressure in normotensive persons: a 7.5-year prospective study. Am J Hypertens. Feb. 2006;19(2):220-6. KQ4aE12, KQ4bE12. [pmid: 16448897].
312 Gerc V, Favrat B, Brunner HR, et al. Is nurse-measured blood pressure a valid substitute for ambulatory blood pressure monitoring?. Blood Press Monit. Aug. 2000;5(4):203-9. KQ3aE4, KQ3cE4. [pmid: 11035861].
313 Gerin W, Marion RM, Friedman R, et al. How should we measure blood pressure in the doctor's office?. Blood Press Monit. Oct. 2001;6(5):257-62. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 12055421].
314 Gerin W, Ogedegbe G, Schwartz JE, et al. Assessment of the white-coat effect. J Hypertens. Jan. 2006;24(1):67-74. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 16331103].
315 Gilbert-Ouimet M, Brisson C, Vezina M, et al. Repeated exposure to effort-reward imbalance, increased blood pressure, and hypertension incidence among white-collar workers: effort-reward imbalance and blood pressure. J Psychosom Res. Jan. 2012;72(1):26-32. KQ4aE4, KQ4bE4. [pmid: 22200519].
316 Gill G, Ala L, Gurgel R, et al. Accuracy of aneroid sphygmomanometer blood pressure recording compared with digital and mercury measurements in Brazil. Tropic Doct. Jan. 2004;34(1):26-7. KQ2aE9a, KQ2bE9a. [pmid: 14959969].
317 Gillum RF, Mussolino ME, Madans JH. Body fat distribution and hypertension incidence in women and men. The NHANES I Epidemiologic Follow-up Study. Int J Obes Relat Metab Disord. Feb. 1998;22(2):127-34. KQ4aE12, KQ4bE12. [pmid: 9504320].
318 Gillum RF, Mussolino ME, Madans JH. Fish consumption and hypertension incidence in African Americans and whites: the NHANES I Epidemiologic Follow-up Study. J Natl Med Assoc. Apr. 2001;93(4):124-8. KQ4aE12, KQ4bE12. [pmid: 12653399].
319 Gillum RF, Mussolino ME, Madans JH. Relation between region of residence in the United States and hypertension incidence--the NHANES I epidemiologic follow-up study. J Natl Med Assoc. May. 2004;96(5):625-34. KQ4aE12, KQ4bE12. [pmid: 15160977].
320 Ginty AT, Carroll D, Roseboom TJ, et al. Depression and anxiety are associated with a diagnosis of hypertension 5 years later in a cohort of late middle-aged men and women. J Hum Hypertens. Mar. 2013;27(3):187-90. KQ4aE5, KQ4bE5. [pmid: 22592133].
321 Godwin M, Birtwhistle R, Delva D, et al. Manual and automated office measurements in relation to awake ambulatory blood pressure monitoring. Fam Pract. Feb. 2011;28(1):110-7. KQ2aE5a, KQ2bE3, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 20720213].
322 Goff DC Jr, Zaccaro DJ, Haffner SM, et al. Insulin sensitivity and the risk of incident hypertension: insights from the Insulin Resistance Atherosclerosis Study. Diabetes Care. Mar. 2003;26(3):805-9. KQ4aE5a, KQ4bE5a. [pmid: 12610041].
323 Goldstein IB, Shapiro D, Guthrie D. A 5-year follow-up of ambulatory blood pressure in healthy older adults. Am J Hypertens. Aug. 2003;16(8):640-5. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE7e, KQ4bE7e. [pmid: 12878369].
324 Goldstein IB, Ancoli-Israel S, Shapiro D. Am J Hypertens. Sep. 2004;17(9):787-92. KQ4aE7e, KQ4bE7e. [pmid: 15363821].
325 Goodman M, Dembroski TM, Herbst JH. How many sphygmomanometric cuff inflations are necessary to obtain a hemodynamic baseline?. Biofeedback Self Regul. Sep. 1996;21(3):207-16. KQ2aE3, KQ2bE4. [pmid: 8894054].
326 Goonasekera CD, Dillon MJ. Random zero sphygmomanometer versus automatic oscillometric blood pressure monitor; is either the instrument of choice?. J Hum Hypertens. Nov. 1995;9(11):885-9. KQ2aE4, KQ2bE3. [pmid: 8583467].
327 Gorostidi M, Sobrino J, Segura J, et al. Ambulatory blood pressure monitoring in hypertensive patients with high cardiovascular risk: a cross-sectional analysis of a 20,000-patient database in Spain. J Hypertens. May. 2007;25(5):977-84. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 17414661].
328 Gosse P, Dauphinot V, Roche F, et al. Prevalence of clinical and ambulatory hypertension in a population of 65-year-olds: the PROOF study. J Clin Hypertens (Greenwich). Mar. 2010;12(3):160-5. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 20433528].
329 Gourlay SG, McNeil JJ, Marriner T, et al. Discordance of mercury sphygmomanometer and ambulatory blood pressure measurements for the detection of untreated hypertension in a population study. J Hum Hypertens. Oct. 1993;7(5):467-72. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 8263887].
330 Graves JW, Nash C, Burger K, et al. Clinical decision-making in hypertension using an automated (BpTRU) measurement device. J Hum Hypertens. Dec. 2003;17(12):823-7. KQ2aE5, KQ2bE5, KQ3aE4, KQ3bE5a, KQ3cE4. [pmid: 14704726].
331 Graves JW, Nash CA, Grill DE, et al. Limited (6-h) ambulatory blood pressure monitoring is a valid replacement for the office blood pressure by trained nurse clinician in the diagnosis of hypertension. Blood Press Monit. Aug. 2005;10(4):169-74. KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 16077261].
332 Graves JW, Grossardt BR. Discarding the first of three nurse-auscultatory or oscillometric blood pressure measurements does not improve the association of office blood pressure with ABPM. Blood Press Monit. Jun. 2010;15(3):146-51. KQ2aE4, KQ2bE4, KQ3aE4, KQ3cE4. [pmid: 20407368].
333 Greene SB, Aavedal MJ, Tyroler HA, et al. Smoking habits and blood pressure change: a seven year follow-up. J Chronic Dis. Jul. 1977;30(7):401-13. KQ4aE12, KQ4bE12. [pmid: 885983].
334 Greiver M, White D, Kaplan DM, et al. Where should automated blood pressure measurements be taken? Pilot RCT of BpTRU measurements taken in private or nonprivate areas of a primary care office. Blood Press Monit. Jun. 2012;17(3):137-8. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 22561736].
335 Griffin FC, Gadegbeku CA, Sowers MR. Vitamin D and subsequent systolic hypertension among women. Am J Hypertens. Mar. 2011;24(3):316-21. KQ4aE7e, KQ4bE7e. [pmid: 21088670].
336 Grimsrud A, Stein DJ, Seedat S, et al. The association between hypertension and depression and anxiety disorders: results from a nationally-representative sample of South African adults. PLoS One. 2009;4(5):e5552. KQ5E5a. [pmid: 19440241].
337 Grin JM, McCabe EJ, White WB. Management of hypertension after ambulatory blood pressure monitoring. Ann Intern Med. Jun 1. 1993;118(11):833-7. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 8480956].
338 Grobbee DE, van Hemert AM, Vandenbroucke JP, et al. Importance of body weight in determining rise and level of blood pressure in postmenopausal women. J Hypertens Suppl. Dec. 1988;6(4):S614-S616. KQ4aE12, KQ4bE12. [pmid: 3241266].
339 Grondal N, Sogaard R, Henneberg EW, et al. The Viborg Vascular (VIVA) screening trial of 65-74 year old men in the central region of Denmark: study protocol. Trials. 2010;11(67). KQ1E11, KQ4aE11, KQ4bE11. [pmid: 20507582].
340 Grossardt BR, Graves JW, Gullerud RE, et al. The occurrence of the alerting response is independent of the method of blood pressure measurement in hypertensive patients. Blood Press Monit. Dec. 2006;11(6):321-7. KQ2aE5, KQ2bE5, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17106316].
341 Grossman A, Prokupetz A, Gordon B, et al. Inter-arm blood pressure differences in young, healthy patients. J Clin Hypertens (Greenwich). Aug. 2013;15(8):575-8. KQ2aE3, KQ2bE4. [pmid: 23889720].
342 Grossman C, Shemesh J, Dovrish Z, et al. Coronary artery calcification is associated with the development of hypertension. Am J Hypertens. Jan. 2013;26(1):13-9. KQ4aE7e, KQ4bE7e. [pmid: 23382322].
343 Guagnano MT, Pace-Palitti V, Murri R, et al. The prevalence of hypertension in gynaecoid and android obese women. J Hum Hypertens. Sep. 1996;10(9):619-24. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 8953208].
344 Guagnano MT, Palitti VP, Murri R, et al. Many factors can affect the prevalence of hypertension in obese patients: role of cuff size and type of obesity. Panminerva Med. Mar. 1998;40(1):22-7. KQ2aE3, KQ2bE7. [pmid: 9573749].
345 Gudmundsdottir H, Strand AH, Kjeldsen SE, et al. Serum phosphate, blood pressure, and the metabolic syndrome--20-year follow-up of middle-aged men. J Clin Hypertens (Greenwich). Nov. 2008;10(11):814-21. KQ4aE7e, KQ4bE7e. [pmid: 19128269].
346 Gudmundsdottir H, Strand AH, Hoieggen A, et al. Do screening blood pressure and plasma catecholamines predict development of hypertension? Twenty-year follow-up of middle-aged men. Blood Press. 2008;17(2):94-103. KQ4aE7e, KQ4bE7e. [pmid: 18568698].
347 Gudmundsdottir H, Taarnhoj NC, Strand AH, et al. Blood pressure development and hypertensive retinopathy: 20-year follow-up of middle-aged normotensive and hypertensive men. J Hum Hypertens. Aug. 2010;24(8):505-13. KQ4aE7e, KQ4bE7e. [pmid: 20010619].
348 Gunes UY. Comparison of agreement between different measures of blood pressure in normotensive females. Appl Nurs Res. Aug. 2010;23(3):159-63. KQ2aE9, KQ2bE9. [pmid: 20643326].
349 Guo X, Zou L, Zhang X, et al. Prehypertension: a meta-analysis of the epidemiology, risk factors, and predictors of progression. [Review]. Tex Heart Inst J. 2011;38(6):643-52. KQ4aE7, KQ4bE7. [pmid: 22199424].
350 Gupta P, Mittal L, Rizzo RA, et al. In-use comparison of blood pressure measurements from an automated blood pressure instrument with those from a mercury sphygmomanometer. Biomed Instrum Technol. Mar. 2009;43(2):158-63. KQ3aE5, KQ3bE5, KQ3cE5. [pmid: 19480489].
351 Guss DA, Abdelnur D, Hemingway TJ. The impact of arm position on the measurement of orthostatic blood pressure. J Emerg Med. May. 2008;34(4):377-82. KQ2aE3, KQ2bE4c. [pmid: 18180133].
352 Gustavsen PH, Hoegholm A, Bang LE, et al. White coat hypertension is a cardiovascular risk factor: a 10-year follow-up study. J Hum Hypertens. Dec. 2003;17(12):811-7. KQ3aE4a. [pmid: 14704724].
353 Gutierrez-Misis A, Sanchez-Santos MT, Banegas JR, et al. Prevalence and incidence of hypertension in a population cohort of people aged 65 years or older in Spain. J Hypertens. Oct. 2011;29(10):1863-70. KQ4aE7e, KQ4bE7e. [pmid: 21841497].
354 Haffner SM, Ferrannini E, Hazuda HP, et al. Clustering of cardiovascular risk factors in confirmed prehypertensive individuals. Hypertension. Jul. 1992;20(1):38-45. KQ4aE12, KQ4bE12. [pmid: 1618551].
355 Haffner SM, Miettinen H, Gaskill SP, et al. Metabolic precursors of hypertension. The San Antonio Heart Study. Arch Intern Med. Sep. 23. 1996;156(17):1994-2001. KQ4aE12, KQ4bE12. [pmid: 8823152].
356 Hajjar I, Lackland DT, Cupples LA, et al. Association between concurrent and remote blood pressure and disability in older adults. Hypertension. Dec. 2007;50(6):1026-32. KQ4aE7e, KQ4bE7e. [pmid: 18025294].
357 Halanych JH, Safford MM, Kertesz SG, et al. Alcohol consumption in young adults and incident hypertension: 20-year follow-up from the Coronary Artery Risk Development in Young Adults Study. Am J Epidemiol. Mar. 1. 2010;171(5):532-9. KQ4aE4d, KQ4bE4d. [pmid: 20118194].
358 Hamer M, Batty GD, Stamatakis E, et al. Hypertension awareness and psychological distress. Hypertension. Sep. 2010;56(3):547-50. KQ5E7a. [pmid: 20625078].
359 Hamer M, Steptoe A. Cortisol responses to mental stress and incident hypertension in healthy men and women. J Clin Endocrinol Metab. Jan. 2012;97(1):E29-E34. KQ4aE7e, KQ4bE7e. [pmid: 22031509].
360 Handler J, Zhao Y, Egan BM. Impact of the number of blood pressure measurements on blood pressure classification in US adults: NHANES 1999-2008. J Clin Hypertens (Greenwich). Nov. 2012;14(11):751-9. KQ2aE3, KQ4aE4, KQ4bE4. [pmid: 23126346].
361 Hanninen MR, Niiranen TJ, Puukka PJ, et al. Comparison of home and ambulatory blood pressure measurement in the diagnosis of masked hypertension. J Hypertens. Apr. 2010;28(4):709-14. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 20061982].
362 Hanninen MR, Niiranen TJ, Puukka PJ, et al. Determinants of masked hypertension in the general population: the Finn-Home study. J Hypertens. Oct. 2011;29(10):1880-8. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 21841499].
363 Hanninen MR, Niiranen TJ, Puukka PJ, et al. Prognostic significance of masked and white-coat hypertension in the general population: the Finn-Home Study. J Hypertens. Apr. 2012;30(4):705-12. KQ3aE3, KQ3bE5a, KQ3cE5a. [pmid: 22278146].
364 Hanninen MR, Niiranen TJ, Puukka PJ, et al. Metabolic risk factors and masked hypertension in the general population: the Finn-Home study. J Hum Hypertens. 2014. Jan. 2. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 24384630].
365 Hansen TW, Jeppesen J, Rasmussen S, et al. Ambulatory blood pressure and mortality: a population-based study. Hypertension. Apr. 2005;45(4):499-504. KQ2aE3, KQ2bE3, KQ3bE4, KQ3cE4. [pmid: 15753229].
366 Hansen TW, Jeppesen J, Rasmussen S, et al. Ambulatory blood pressure monitoring and risk of cardiovascular disease: a population based study. Am J Hypertens. Mar. 2006;19(3):243-50. KQ3aE4a, KQ3bE5c, KQ3cE5c. [pmid: 16500508].
367 Hansen TW, Kikuya M, Thijs L, et al. Prognostic superiority of daytime ambulatory over conventional blood pressure in four populations: a meta-analysis of 7,030 individuals. J Hypertens. Aug. 2007;25(8):1554-64. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 17620947].
368 Hansen TW, Staessen JA, Zhang H, et al. Cardiovascular outcome in relation to progression to hypertension in the Copenhagen MONICA cohort. Am J Hypertens. May. 2007;20(5):483-91. KQ4aE12, KQ4bE12. [pmid: 17485007].
369 Harlan LC, Polk BF, Cooper S, et al. Effects of labeling and treatment of hypertension on perceived health. Am J Prev Med. Sep. 1986;2(5):256-61. KQ5E10b. [pmid: 3453188].
370 Harris DE, Hamel L, Aboueissa AM, et al. A cardiovascular disease risk factor screening program designed to reach rural residents of Maine, USA. Rural Remote Health. 2011;11(3):1-15. KQ1E4, KQ2aE3, KQ2bE3. [pmid: 21834601].
371 Hart CL, Hole DJ, Davey SG. Are two really better than one? Empirical examination of repeat blood pressure measurements and stroke risk in the Renfrew/Paisley and collaborative studies. Stroke. Nov. 2001;32(11):2697-9. KQ4aE4, KQ4bE4. [pmid: 11692037].
372 Hashimoto R, Adachi H, Nishida H, et al. Serum N-acetyl-beta-D-glucosaminidase activity in predicting the development of hypertension. Hypertension. Jun. 1995;25(6):1311-4. KQ4aE7e, KQ4bE7e. [pmid: 7768579].
373 Hayashi T, Boyko EJ, Leonetti DL, et al. Visceral adiposity is an independent predictor of incident hypertension in Japanese Americans. Ann Intern Med. Jun. 15. 2004;140(12):992-1000. KQ4aE7e, KQ4bE7e. [pmid: 15197016].
374 Hayes DK, Denny CH, Keenan NL, et al. Health-related quality of life and hypertension status, awareness, treatment, and control: National Health and Nutrition Examination Survey, 2001--2004. J Hypertens. Apr. 2008;26(4):641-7. KQ5E5a. [pmid: 18327071].
375 He J, Klag MJ, Appel LJ, et al. Seven-year incidence of hypertension in a cohort of middle-aged African Americans and whites. Hypertension. May. 1998;31(5):1130-5. KQ4aE7e, KQ4bE7e. [pmid: 9576125].
376 Head GA, Mihailidou AS, Duggan KA, et al. Definition of ambulatory blood pressure targets for diagnosis and treatment of hypertension in relation to clinic blood pressure: prospective cohort study. BMJ. 2010;340:c1104. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 20392760].
377 Hedstrand H, Aberg H. A 3-year follow-up of middle-aged men with borderline blood pressure. Acta Med Scand. Nov. 1975;198(5):389-95. KQ4aE7e, KQ4bE7e. [pmid: 1199815].
378 Helvaci MR, Seyhanli M. What a high prevalence of white coat hypertension in society!. Intern Med. 2006;45(10):671-4. KQ3aE9, KQ3bE9, KQ3cE9. [pmid: 16778338].
379 Henriksson KM, Lindblad U, Gullberg B, et al. Development of hypertension over 6 years in a birth cohort of young middle-aged men: the Cardiovascular Risk Factor Study in southern Sweden (CRISS). J Intern Med. Jul. 2002;252(1):21-6. KQ4aE7e, KQ4bE7e. [pmid: 12074734].
380 Heraclides A, Mishra GD, Hardy RJ, et al. Dairy intake, blood pressure and incident hypertension in a general British population: the 1946 birth cohort. Eur J Nutr. Aug. 2012;51(5):583-91. KQ4aE12, KQ4bE12. [pmid: 21877233].
381 Hergens MP, Lambe M, Pershagen G, et al. Risk of hypertension amongst Swedish male snuff users: a prospective study. J Intern Med. Aug. 2008;264(2):187-94. KQ4aE3, KQ4bE3. [pmid: 18393959].
382 Hermida RC. Ambulatory blood pressure monitoring in the prediction of cardiovascular events and effects of chronotherapy: rationale and design of the MAPEC study. Chronobiol Int. 2007;24(4):749-75. KQ3bE4, KQ3cE4. [pmid: 17701685].
383 Hermida RC, Ayala DE, Ýn A, et al. Decreasing sleep-time blood pressure determined by ambulatory monitoring reduces cardiovascular risk. J Am Coll Cardiol. Sep. 6. 2011;58(11):1165-73. KQ3bE4, KQ3cE4. [pmid: 21884956].
384 Hermida RC, Ayala DE, Mojon A, et al. Sleep-time blood pressure and the prognostic value of isolated-office and masked hypertension. Am J Hypertens. Mar. 2012;25(3):297-305. KQ3aE3, KQ3bE5a, KQ3cE5a. [pmid: 22089106].
385 Hermida RC, Ayala DE, Fernandez JR, et al. Sleep-time blood pressure: prognostic value and relevance as a therapeutic target for cardiovascular risk reduction. Chronobiol Int. Mar. 2013;30(1-2):68-86. KQ3aE4a, KQ3bE4, KQ3cE4. [pmid: 23181592].
386 Hermida RC, Ayala DE, Mojon A, et al. Differences between men and women in ambulatory blood pressure thresholds for diagnosis of hypertension based on cardiovascular outcomes. Chronobiol Int. Mar. 2013;30(1-2):221-32. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 23098170].
387 Hermida RC, Ayala DE, Mojon A, et al. Blunted sleep-time relative blood pressure decline increases cardiovascular risk independent of blood pressure level--the "normotensive non-dipper" paradox. Chronobiol Int. Mar. 2013;30(1-2):87-98. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 23039824].
388 Hermida RC, Ayala DE, Mojon A, et al. Ambulatory blood pressure thresholds for diagnosis of hypertension in patients with and without type 2 diabetes based on cardiovascular outcomes. Chronobiol Int. Mar. 2013;30(1-2):132-44. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 23181634].
389 Hermida RC, Ayala DE, Fontao MJ, et al. Ambulatory blood pressure monitoring: importance of sampling rate and duration--48 versus 24 hours--on the accurate assessment of cardiovascular risk. Chronobiol Int. Mar. 2013;30(1-2):55-67. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 23077972].
390 Hernelahti M, Kujala UM, Kaprio J, et al. Long-term vigorous training in young adulthood and later physical activity as predictors of hypertension in middle-aged and older men. Int J Sports Med. Apr. 2002;23(3):178-82. KQ4aE7e, KQ4bE7e. [pmid: 11914980].
391 Hernelahti M, Kujala U, Kaprio J. Stability and change of volume and intensity of physical activity as predictors of hypertension. Scand J Public Health. 2004;32(4):303-9. KQ4aE12, KQ4bE12. [pmid: 15370771].
392 Hietanen E, Wendelin-Saarenhovi M. Ambulatory blood pressure reproducibility and application of the method in a healthy Finnish cohort. SCAND J CLIN LAB INVEST. Aug. 1996;56(5):471-80. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8869670].
393 Hildrum B, Romild U, Holmen J. Anxiety and depression lowers blood pressure: 22-year follow-up of the population based HUNT study, Norway. BMC Public Health. 2011;11:601. KQ4aE12, KQ4bE12. [pmid: 21797992].
394 Hoegholm A, Kristensen KS, Madsen NH, et al. White coat hypertension diagnosed by 24-h ambulatory monitoring. Examination of 159 newly diagnosed hypertensive patients. Am J Hypertens. Feb. 1992;5(2):64-70. KQ3aE4. [pmid: 1550667].
395 Hoegholm A, Kristensen KS, Bang LE, et al. Left ventricular mass and geometry in patients with established hypertension and white coat hypertension. Am J Hypertens. Apr. 1993;6(4):282-6. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8507447].
396 Hoegholm A, Kristensen KS, Madsen NH, et al. The frequency of white coat hypertension among patients with newly diagnosed hypertension. Cardiovasc Rev Rep. 1994;15:55-61. PMID: None. KQ3aE4.
397 Hoegholm A, Kristensen KS, Bang LE, et al. White coat hypertension and target organ involvement: the impact of different cut-off levels on albuminuria and left ventricular mass and geometry. J Hum Hypertens. Jul. 1998;12(7):433-9. KQ3aE4, KQ3bE10b, KQ3cE4. [pmid: 9702928].
398 Hoeven NV, Lodestijn S, Nanninga S, et al. Simultaneous compared with sequential blood pressure measurement results in smaller inter-arm blood pressure differences. J Clin Hypertens. 2013;15:839-44. KQ2aE3, KQ2bE4. [pmid: 24102851].
399 Holleman DR Jr, Westman EC, McCrory DC, et al. The effect of sleeved arms on oscillometric blood pressure measurement. J Gen Intern Med. Jun. 1993;8(6):325-6. KQ2aE3, KQ2bE4. [pmid: 8320577].
400 Holmqvist L, Mortensen L, Kanckos C, et al. Exercise blood pressure and the risk of future hypertension. J Hum Hypertens. Dec. 2012;26(12):691-5. KQ4aE7e, KQ4bE7e. [pmid: 22129608].
401 Hond E, Celis H, Vandenhoven G, et al. Determinants of white-coat syndrome assessed by ambulatory blood pressure or self-measured home blood pressure. Blood Press Monit. 2003;8(1):37-40. KQ3aE4, KQ3cE4. [pmid: 12604935].
402 Hond ED, Celis H, Fagard R, et al. Self-measured versus ambulatory blood pressure in the diagnosis of hypertension. J Hypertens. Apr. 2003;21(4):717-22. KQ3aE4, KQ3cE4. [pmid: 12658017].
403 Howes LG, Reid C, Bendle R, et al. The prevalence of isolated systolic hypertension in patients 60 years of age and over attending Australian general practitioners. Blood Press. May. 1998;7(3):139-43. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9758082].
404 Hozawa A, Ohkubo T, Kikuya M, et al. Blood pressure control assessed by home, ambulatory and conventional blood pressure measurements in the Japanese general population: the Ohasama study. Hypertens Res. Jan. 2002;25(1):57-63. KQ3aE4. [pmid: 11924727].
405 Hozawa A, Jacobs DR Jr, Steffes MW, et al. Circulating carotenoid concentrations and incident hypertension: the Coronary Artery Risk Development in Young Adults (CARDIA) study. J Hypertens. Feb. 2009;27(2):237-42. KQ4aE12, KQ4bE12. [pmid: 19155781].
406 Hozawa A, Kuriyama S, Watanabe I, et al. Participation in health check-ups and mortality using propensity score matched cohort analyses. Prev Med. Nov. 2010;51(5):397-402. KQ1E1, KQ4aE4, KQ4bE4. [pmid: 20828583].
407 Hu FB, Willett WC, Colditz GA, et al. Prospective study of snoring and risk of hypertension in women. Am J Epidemiol. Oct. 15. 1999;150(8):806-16. KQ4aE12, KQ4bE12. [pmid: 10522651].
408 Huang CM, Wang KL, Cheng HM, et al. Central versus ambulatory blood pressure in the prediction of all-cause and cardiovascular mortalities. J Hypertens. Mar. 2011;29(3):454-9. KQ3aE9, KQ3bE9, KQ3cE9. [pmid: 21252703].
409 Huang YC, Morisky DE. Stability of blood pressure: is a sequential blood pressure reading protocol efficient for a large-scale community screening programme. J Hum Hypertens. Sep. 1999;13(9):637-42. KQ2aE5a, KQ2bE5a. [pmid: 10482974].
410 Huang Z, Willett WC, Manson JE, et al. Body weight, weight change, and risk for hypertension in women. Ann Intern Med. Jan. 15. 1998;128(2):81-8. KQ4aE12, KQ4bE12. [pmid: 9441586].
411 Hunt SC, Stephenson SH, Hopkins PN, et al. Body weight, weight change, and risk for hypertension in women. Hypertension. Jun. 1991;17(6:Pt 2):969-76. KQ4aE12, KQ4bE12. [pmid: 2045178].
412 Hwang ES, Choi KJ, Kang DH, et al. Prevalence, predictive factor, and clinical significance of white-coat hypertension and masked hypertension in Korean hypertensive patients. Korean J Intern Med. Dec. 2007;22(4):256-62. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 18309684].
413 Ikram MK, Witteman JC, Vingerling JR, et al. Retinal vessel diameters and risk of hypertension: the Rotterdam Study. Hypertension. Feb. 2006;47(2):189-94. KQ4aE12, KQ4bE12. [pmid: 16380526].
414 Imai Y, Nagai K, Sakuma M, et al. Ambulatory blood pressure of adults in Ohasama, Japan. Hypertension. Dec. 1993;22(6):900-12. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8244523].
415 Imai Y, Ohkubo T, Sakuma M, et al. Predictive power of screening blood pressure, ambulatory blood pressure and blood pressure measured at home for overall and cardiovascular mortality: a prospective observation in a cohort from Ohasama, northern Japan. Blood Press Monit. Jun. 1996;1(3):251-4. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10226238].
416 Imai Y, Tsuji I, Nagai K, et al. Ambulatory blood pressure monitoring in evaluating the prevalence of hypertension in adults in Ohasama, a rural Japanese community. Hypertens Res. Sep. 1996;19(3):207-12. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 8891750].
417 Imai Y, Ohkubo T, Tsuji I, et al. Relationships among blood pressures obtained using different measurement methods in the general population of Ohasama, Japan. Hypertens Res. Nov. 1999;22(4):261-72. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10580392].
418 Imai Y, Nishiyama A, Sekino M, et al. Characteristics of blood pressure measured at home in the morning and in the evening: the Ohasama study. J Hypertens. Jul. 1999;17(7):889-98. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10419061].
419 Imatoh T, Miyazaki M, Momose Y, et al. Adiponectin levels associated with the development of hypertension: a prospective study. Hypertens Res. Feb. 2008;31(2):229-33. KQ4aE7e, KQ4bE7e. [pmid: 18360041].
420 Imazu M, Yamamoto H, Toyofuku M, et al. Association of apolipoprotein E phenotype with hypertension in Japanese-Americans: data from the Hawaii-Los Angeles-Hiroshima Study. Hypertens Res. Sep. 2001;24(5):523-9. KQ4aE7e, KQ4bE7e. [pmid: 11675946].
421 Inden Y, Tsuda M, Hayashi H, et al. Relationship between Joint National Committee-VI classification of hypertension and ambulatory blood pressure in patients with hypertension diagnosed by casual blood pressure. Clin Cardiol. Nov. 1998;21(11):801-6. KQ3aE4. [pmid: 9825191].
422 Ingelsson E, Bjorklund-Bodegard K, Lind L, et al. Diurnal blood pressure pattern and risk of congestive heart failure. JAMA. 2006;295(24):2859-66. KQ3bE4, KQ3cE4. [pmid: 16804152].
423 Ingelsson E, Pencina MJ, Levy D, et al. Aortic root diameter and longitudinal blood pressure tracking. Hypertension. Sep. 2008;52(3):473-7. KQ4aE4d, KQ4bE4d. [pmid: 18663156].
424 Inoue R, Ohkubo T, Kikuya M, et al. Predicting stroke using 4 ambulatory blood pressure monitoring-derived blood pressure indices: the Ohasama Study. Hypertension. Nov. 2006;48(5):877-82. KQ3bE4, KQ3cE4. [pmid: 16982961].
425 Inoue R, Ohkubo T, Kikuya M, et al. Stroke risk in systolic and combined systolic and diastolic hypertension determined using ambulatory blood pressure. The Ohasama study. Am J Hypertens. Oct. 2007;20(10):1125-31. KQ3aE5a, KQ3bE4, KQ3cE4. [pmid: 17903698].
426 Inoue T, Iseki K, Iseki C, et al. Higher heart rate predicts the risk of developing hypertension in a normotensive screened cohort. Circ J. Nov. 2007;71(11):1755-60. KQ4bE4. [pmid: 17965497].
427 Ishikawa J, Shimizu M, Hoshide S, et al. Cardiovascular risks of dipping status and chronic kidney disease in elderly Japanese hypertensive patients. J Clin Hypertens (Greenwich). Oct. 2008;10(10):787-94. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 19090880].
428 Ishikawa J, Hoshide S, Eguchi K, et al. Masked hypertension defined by ambulatory blood pressure monitoring is associated with an increased serum glucose level and urinary albumin-creatinine ratio. J Clin Hypertens (Greenwich). Aug. 2010;12(8):578-87. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 20695934].
429 Ishikawa J, Hoshide S, Eguchi K, et al. Nighttime home blood pressure and the risk of hypertensive target organ damage. Hypertension. Oct. 2012;60(4):921-8. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22892810].
430 Iyriboz Y, Hearon CM, Edwards K. Agreement between large and small cuffs in sphygmomanometry: a quantitative assessment. J Clin Monit. Mar. 1994;10(2):127-33. KQ2aE3, KQ2bE4. [pmid: 8207453].
431 Jacobs DR Jr, Yatsuya H, Hearst MO, et al. Rate of decline of forced vital capacity predicts future arterial hypertension: the Coronary Artery Risk Development in Young Adults Study. Hypertension. Feb. 2012;59(2):219-25. KQ4aE12, KQ4bE12. [pmid: 22203738].
432 Jae SY, Heffernan KS, Yoon ES, et al. Temporal changes in cardiorespiratory fitness and the incidence of hypertension in initially normotensive subjects. Am J Hum Biol. Nov. 2012;24(6):763-7. KQ4aE4d, KQ4bE4d. [pmid: 22961862].
433 Jae SY, Kurl S, Laukkanen JA, et al. Higher blood hematocrit predicts hypertension in men. J Hypertens. Feb. 2014;32(2):245-50. KQ4aE4d, KQ4bE4d. [pmid: 24248088].
434 Jain A, Krakoff LR. Effect of recorded home blood pressure measurements on the staging of hypertensive patients. Blood Press Monit. Jun. 2002;7(3):157-61. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12131072].
435 Janzon E, Hedblad B, Berglund G, et al. Changes in blood pressure and body weight following smoking cessation in women. J Intern Med. Feb. 2004;255(2):266-72. KQ4aE12, KQ4bE12. [pmid: 14746564].
436 Jenkins P, Baker E, White B. Promoting good health in people aged over 75 in the community. Nurs Older People. Mar. 2009;21(2):34-9. KQ1E7, KQ4aE7, KQ4bE7. [pmid: 19284031].
437 Jhalani J, Goyal T, Clemow L, et al. Anxiety and outcome expectations predict the white-coat effect. Blood Press Monit. Dec. 2005;10(6):317-9. KQ5E1. [pmid: 16496447].
438 Johnston ME, Gibson ES, Terry CW, et al. Effects of labelling on income, work and social function among hypertensive employees. J Chronic Dis. 1984;37(6):417-23. KQ5E7. [pmid: 6725496].
439 Jonas BS, Franks P, Ingram DD. Are symptoms of anxiety and depression risk factors for hypertension? Longitudinal evidence from the National Health and Nutrition Examination Survey I Epidemiologic Follow-up Study. Arch Fam Med. Jan. 1997;6(1):43-9. KQ4aE12, KQ4bE12. [pmid: 9003169].
440 Jonas BS, Lando JF. Negative affect as a prospective risk factor for hypertension. Psychosom Med. Mar. 2000;62(2):188-96. KQ4aE12, KQ4bE12. [pmid: 10772396].
441 Jones D, Engelke MK, Brown ST, et al. A comparison of two noninvasive methods of blood pressure measurement in the triage area. J Emerg Nurs. Apr. 1996;22(2):111-5. KQ2aE4, KQ2bE3. [pmid: 8716299].
442 Jones S, Simpson H, Ahmed H. A comparison of two methods of blood pressure measurement. Br J Nurs. Sep. 28. 2006;15(17):948-51. KQ2aE3, KQ2bE4. [pmid: 17077789].
443 Joosten MM, Gansevoort RT, Mukamal KJ, et al. Urinary magnesium excretion and risk of hypertension: the prevention of renal and vascular end-stage disease study. Hypertension. Jun. 2013;61(6):1161-7. KQ4aE12, KQ4bE12. [pmid: 23608650].
444 Jorde R, Figenschau Y, Emaus N, et al. Serum 25-hydroxyvitamin D levels are strongly related to systolic blood pressure but do not predict future hypertension. Hypertension. Mar. 2010;55(3):792-8. KQ4aE12, KQ4bE12. [pmid: 20065152].
445 Jossa F, Farinaro E, Panico S, et al. Serum uric acid and hypertension: the Olivetti heart study. J Hum Hypertens. Sep. 1994;8(9):677-81. KQ4aE12, KQ4bE12. [pmid: 7807497].
446 Jousilahti P, Tuomilehto J, Vartiainen E, et al. Body mass index, blood pressure, diabetes and the risk of anti-hypertensive drug treatment: 12-year follow-up of middle-aged people in eastern Finland. J Hum Hypertens. Oct. 1995;9(10):847-54. KQ4aE12, KQ4bE12. [pmid: 8576902].
447 Jula A, Puukka P, Karanko H. Multiple clinic and home blood pressure measurements versus ambulatory blood pressure monitoring. Hypertension. Aug. 1999;34(2):261-6. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10454451].
448 Julius S, Nesbitt SD, Egan BM, et al. Feasibility of treating prehypertension with an angiotensin-receptor blocker. N Engl J Med. Apr. 20. 2006;354(16):1685-97. KQ4aE7c, KQ4bE7c. [pmid: 16537662].
449 Julliard K, Orvieto C, Win A, et al. Feasibility of referral of patients with elevated blood pressure from the Emergency Department. J Community Health. Feb. 2012;37(1):159-64. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 21706363].
450 Kabutoya T, Ishikawa J, Hoshide S, et al. Determinants of negative white-coat effect in treated hypertensive patients: the Jichi Morning Hypertension Research (J-MORE) study. Am J Hypertens. Jan. 2009;22(1):35-40. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 18927542].
451 Kaess BM, Rong J, Larson MG, et al. Aortic stiffness, blood pressure progression, and incident hypertension. JAMA. Sep. 5. 2012;308(9):875-81. KQ4aE12, KQ4bE12. [pmid: 22948697].
452 Kaetsu A, Kishimoto T, Osaki Y, et al. The lack of relationship between an endothelin-1 gene polymorphism (Ala288ser) and incidence of hypertension: a retrospective cohort study among Japanese workers. J Epidemiol. Jul. 2004;14(4):129-36. KQ4aE7e, KQ4bE7e. [pmid: 15369130].
453 Kahan E, Yaphe J, Knaani-Levinz H, et al. Comparison of blood pressure measurements on the bare arm, below a rolled-up sleeve, or over a sleeve. Fam Pract. Dec. 2003;20(6):730-2. KQ2aE3, KQ2bE4. [pmid: 14701900].
454 Kanda A, Hoshiyama Y, Kawaguchi T. Association of lifestyle parameters with the prevention of hypertension in elderly Japanese men and women: a four-year follow-up of normotensive subjects. Asia Pac J Public Health. 1999;11(2):77-81. KQ4aE7e, KQ4bE7e. [pmid: 11195162].
455 Kantola I, Vesalainen R, Kangassalo K, et al. Bell or diaphragm in the measurement of blood pressure?. J Hypertens. Mar. 2005;23(3):499-503. KQ2aE2, KQ2bE2, KQ3aE2, KQ3bE2, KQ3cE2. [pmid: 15716689].
456 Kario K, Shimada K, Schwartz JE, et al. Silent and clinically overt stroke in older Japanese subjects with white-coat and sustained hypertension. J Am Coll Cardiol. Jul. 2001;38(1):238-45. KQ3bE10b, KQ3cE10b. [pmid: 11451281].
457 Kario K, Ishikawa J, Eguchi K, et al. Sleep pulse pressure and awake mean pressure as independent predictors for stroke in older hypertensive patients. Am J Hypertens. May. 2004;17(5 Pt 1):439-45. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 15110904].
458 Kario K. Diagnosis of true uncontrolled hypertension using both home and ambulatory blood pressure monitoring. J Hum Hypertens. 2013. Aug. 8. KQ3aE4, KQ3cE4. [pmid: 23924872].
459 Karwalajtys T, Kaczorowski J, Hutchison B, et al. Blood pressure variability and prevalence of hypertension using automated readings from multiple visits to a pharmacy-based community-wide programme. J Hum Hypertens. Sep. 2009;23(9):585-9. KQ2aE3, KQ2bE5a. [pmid: 19158822].
460 Kasagi F, Akahoshi M, Shimaoka K. Relation between cold pressor test and development of hypertension based on 28-year follow-up. Hypertension. Jan. 1995;25(1):71-6. KQ4aE7e, KQ4bE7e. [pmid: 7843757].
461 Kasahara A, Adachi H, Hirai Y, et al. High level of plasma remnant-like particle cholesterol may predispose to development of hypertension in normotensive subjects. Am J Hypertens. Jun. 2013;26(6):793-8. KQ4aE7e, KQ4bE7e. [pmid: 23403840].
462 Kawabe H, Saito I, Saruta T. Status of home blood pressure measured in morning and evening: evaluation in normotensives and hypertensives in Japanese urban population. Hypertens Res. 2005;28(6):491-8. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 16231754].
463 Kawabe H, Saito I. Which measurement of home blood pressure should be used for clinical evaluation when multiple measurements are made?. J Hypertens. Jul. 2007;25(7):1369-74. KQ3aE4, KQ3bE5a, KQ3cE4. [pmid: 17563557].
464 Kawabe H, Saito I. Determinants of exaggerated difference in morning and evening home blood pressure in Japanese normotensives. Hypertens Res. Nov. 2009;32(11):1028-31. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 19730438].
465 Kawasaki T, Uezono K, Sanefuji M, et al. A 17-year follow-up study of hypertensive and normotensive male university students in Japan. Hypertens Res. Jun. 2003;26(6):445-52. KQ4aE10a, KQ4bE10a. [pmid: 12862200].
466 Kawecka-Jaszcz K, Kocemba J. Long-term study of borderline hypertension among male industrial workers. J Hum Hypertens. Aug. 1990;4(4):339-43. KQ4aE12, KQ4bE12. [pmid: 2258869].
467 Kershenbaum A, Sadetzki S, Chetrit A, et al. A new approach to blood pressure measurement in the primary care setting. Br J Gen Pract. Sep. 2000;50(458):725-6. KQ2aE5a, KQ2bE5a. [pmid: 11050789].
468 Khan AM, Sullivan L, McCabe E, et al. Lack of association between serum magnesium and the risks of hypertension and cardiovascular disease. Am Heart J. Oct. 2010;160(4):715-20. KQ4aE12, KQ4bE12. [pmid: 20934566].
469 Khattar RS, Swales JD, Banfield A, et al. Prediction of coronary and cerebrovascular morbidity and mortality by direct continuous ambulatory blood pressure monitoring in essential hypertension. Circulation. Sep. 7. 1999;100(10):1071-6. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 10477532].
470 Khattar RS, Senior R, Lahiri A. Prognostic value of direct, continuous ambulatory blood pressure monitoring in essential hypertension. J Clin Hypertens (Greenwich). Mar. 2001;3(2):90-8. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 11416690].
471 Khattar RS, Swales JD, Dore C, et al. Effect of aging on the prognostic significance of ambulatory systolic, diastolic, and pulse pressure in essential hypertension. Circulation. Aug. 14. 2001;104(7):783-9. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 11502703].
472 Khoury S, Yarows SA, O'Brien TK, et al. Ambulatory blood pressure monitoring in a nonacademic setting. Effects of age and sex. Am J Hypertens. Sep. 1992;5(9):616-23. KQ3aE4. [pmid: 1418850].
473 Kiefe CI, Williams OD, Bild DE, et al. Regional disparities in the incidence of elevated blood pressure among young adults: the CARDIA study. Circulation. Aug. 19. 1997;96(4):1082-8. KQ4aE4b, KQ4bE4b. [pmid: 9286933].
474 Kikuya M, Hozawa A, Ohokubo T, et al. Prognostic significance of blood pressure and heart rate variabilities: the Ohasama study. Hypertension. Nov. 2000;36(5):901-6. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 11082164].
475 Kikuya M, Ohkubo T, Asayama K, et al. Ambulatory blood pressure and 10-year risk of cardiovascular and noncardiovascular mortality: the Ohasama study. Hypertension. Feb. 2005;45(2):240-5. KQ3bE5a, KQ3cE5a. [pmid: 15596571].
476 Kikuya M, Hansen TW, Thijs L, et al. Diagnostic thresholds for ambulatory blood pressure monitoring based on 10-year cardiovascular risk. Circulation. Apr. 24. 2007;115(16):2145-52. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 17420350].
477 Kikuya M, Hansen TW, Thijs L, et al. Diagnostic thresholds for ambulatory blood pressure monitoring based on 10-year cardiovascular risk. Blood Press Monit. Dec. 2007;12(6):393-5. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 18277319].
478 Kim J, Yi H, Shin KR, et al. Snoring as an independent risk factor for hypertension in the nonobese population: the Korean Health and Genome Study. Am J Hypertens. Aug. 2007;20(8):819-24. KQ4aE4d, KQ4bE4d. [pmid: 17679026].
479 Kim JW, Bosworth HB, Voils CI, et al. How well do clinic-based blood pressure measurements agree with the mercury standard?. J Gen Intern Med. Jul. 2005;20(7):647-9. KQ2aE5, KQ2bE5. [pmid: 16050862].
480 Kim JW, Ko KP, Koo HJ, et al. Plasma calcium and risk of hypertension: propensity score analysis using data from the korean genome and epidemiology study. Osong Public Health & Research Perspectives. Sep. 2011;2(2):83-8. KQ4aE12, KQ4bE12. [pmid: 24159456].
481 Kim KB, Oh MK, Kim HG, et al. Inter-arm Differences in Simultaneous Blood Pressure Measurements in Ambulatory Patients without Cardiovascular Diseases. Korean J Fam Med. Mar. 2013;34(2):98-106. KQ2aE3, KQ2bE5a. [pmid: 23560208].
482 Kim MK, Baek KH, Song KH, et al. Increased serum ferritin predicts the development of hypertension among middle-aged men. Am J Hypertens. Apr. 2012;25(4):492-7. KQ4aE4d, KQ4bE4d. [pmid: 22278211].
483 Kim SJ, Lee J, Jee SH, et al. Cardiovascular risk factors for incident hypertension in the prehypertensive population. Epidemiol Health. 2010;32:e2010003. KQ4aE12, KQ4bE12. [pmid: 21191456].
484 Kim SJ, Lee SK, Kim SH, et al. Genetic association of short sleep duration with hypertension incidence: a 6-year follow-up in the Korean Genome and Epidemiology Study. Circ J. 2012;76(4):907-13. KQ4aE12, KQ4bE12. [pmid: 22322875].
485 Kimura A, Hashimoto J, Watabe D, et al. Patient characteristics and factors associated with inter-arm difference of blood pressure measurements in a general population in Ohasama, Japan. J Hypertens. Dec. 2004;22(12):2277-83. KQ2aE3, KQ2bE4. [pmid: 15614021].
486 Kirkendall WM, Feinleib M, Freis ED, et al. Recommendations for human blood pressure determination by sphygmomanometers. Subcommittee of the AHA Postgraduate Education Committee. Circulation. Nov. 1980;62(5):1146A-55A. KQ3aE4.
487 Kishimoto T, Suyama A, Igarashi A, et al. Angiotensinogen gene variation and hypertension in a cohort study in Japanese. J Epidemiol. May. 2001;11(3):115-9. KQ4aE12, KQ4bE12. [pmid: 11434422].
488 Kishimoto T, Misawa Y, Kaetu A, et al. eNOS Glu298Asp polymorphism and hypertension in a cohort study in Japanese. Prev Med. Nov. 2004;39(5):927-31. KQ4aE7e, KQ4bE7e. [pmid: 15475025].
489 Kivimaki M, Tabak AG, Batty GD, et al. Incremental predictive value of adding past blood pressure measurements to the Framingham hypertension risk equation: the Whitehall II Study. Hypertension. Apr. 2010;55(4):1058-62. KQ4aE4d, KQ4bE4d. [pmid: 20157053].
490 Klein R, Klein BE, Moss SE, et al. The relationship of retinopathy in persons without diabetes to the 15-year incidence of diabetes and hypertension: Beaver Dam Eye Study. Trans Am Ophthalmol Soc. 2006;104:98-107. KQ4aE4. [pmid: 17471330].
491 Koehler NR, Figueiredo CE, Ribeiro AC. Serial blood pressure measurements. Braz J Med Biol Res. May. 2002;35(5):555-9. KQ2aE4, KQ2bE4. [pmid: 12011940].
492 Kok RH, Beltman FW, Terpstra WF, et al. Home blood pressure measurement: reproducibility and relationship with left ventricular mass. Blood Press Monit. Apr. 1999;4(2):65-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10450121].
493 Kokubo Y, Kamide K, Okamura T, et al. Impact of high-normal blood pressure on the risk of cardiovascular disease in a Japanese urban cohort: the Suita study. Hypertension. Oct. 2008;52(4):652-9. KQ4aE4, KQ4bE4. [pmid: 18725580].
494 Korhonen PE, Kivela SL, Kautiainen H, et al. Health-related quality of life and awareness of hypertension. J Hypertens. Nov. 2011;29(11):2070-4. KQ5E1. [pmid: 21946696].
495 Kotseva K. Five year follow-up study of the incidence of arterial hypertension and coronary heart disease in vinyl chloride monomer and polyvinyl chloride production workers. Int Arch Occup Environ Health. 1996;68(6):377-9. KQ4aE7e, KQ4bE7e. [pmid: 8891770].
496 Kotsis V, Stabouli S, Bouldin M, et al. Impact of obesity on 24-hour ambulatory blood pressure and hypertension. Hypertension. Apr. 2005;45(4):602-7. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 15723966].
497 Kotsis V, Stabouli S, Toumanidis S, et al. Target organ damage in "white coat hypertension" and "masked hypertension". Am J Hypertens. Apr. 2008;21(4):393-9. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 18292757].
498 Kouame N, Cleroux J, Lefebvre J, et al. Incidence of overestimation and underestimation of hypertension in a large sample of Canadians with mild-to-moderate hypertension. Blood Press Monit. Oct. 1996;1(5):389-96. KQ3aE13, KQ3bE13, KQ3cE13. [pmid: 10226265].
499 Krishnan E, Kwoh CK, Schumacher HR, et al. Hyperuricemia and incidence of hypertension among men without metabolic syndrome. Hypertension. Feb. 2007;49(2):298-303. KQ4aE12, KQ4bE12. [pmid: 17190877].
500 Kristiansson K, Sigfusson N, Sigvaldason H, et al. Glucose tolerance and blood pressure in a population-based cohort study of males and females: the Reykjavik Study. J Hypertens. Jun. 1995;13(6):581-6. KQ4aE12, KQ4bE12. [pmid: 7594413].
501 Kristjansson K, Sigurdsson JA, Lissner L, et al. Blood pressure and pulse pressure development in a population sample of women with special reference to basal body mass and distribution of body fat and their changes during 24 years. Int J Obes Relat Metab Disord. Jan. 2003;27(1):128-33. KQ4aE12, KQ4bE12. [pmid: 12532164].
502 Kroke A, Fleischhauer W, Mieke S, et al. Blood pressure measurement in epidemiological studies: a comparative analysis of two methods. Data from the EPIC-Potsdam Study. European Prospective Investigation into Cancer and Nutrition. J Hypertens. Jun. 1998;16(6):739-46. KQ2bE3. [pmid: 9663913].
503 Kshirsagar AV, Chiu YL, Bomback AS, et al. A hypertension risk score for middle-aged and older adults. J Clin Hypertens (Greenwich). Oct. 2010;12(10):800-8. KQ4aE7, KQ4bE7. [pmid: 21029343].
504 Kugler J, Schmitz N, Seelbach H, et al. Rise in systolic blood pressure during sphygmomanometry depends on the maximum inflation pressure of the arm cuff. J Hypertens. Jul. 1994;12(7):825-9. KQ2aE3, KQ2bE6. [pmid: 7963512].
505 Kumagae S, Adachi H, Jacobs DR Jr, et al. High level of plasma endothelin-1 predicts development of hypertension in normotensive subjects. Am J Hypertens. Oct. 2010;23(10):1103-7. KQ4aE12, KQ4bE12. [pmid: 20559285].
506 Küppers HE, Jäger BA, Luszick JH, et al. Placebo-controlled comparison of the efficacy and tolerability of once-daily moxonidine and enalapril in mild-to-moderate essential hypertension. J Hypertens. 1997;15(1):93-7. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9050976].
507 La Batide-Alanore A, Chatellier G, Bobrie G, et al. Comparison of nurse- and physician-determined clinic blood pressure levels in patients referred to a hypertension clinic: implications for subsequent management. J Hypertens. Apr. 2000;18(4):391-8. KQ2aE3, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 10779088].
508 Laaksonen DE, Niskanen L, Nyyssonen K, et al. Dyslipidaemia as a predictor of hypertension in middle-aged men. Eur Heart J. Oct. 2008;29(20):2561-8. KQ4aE7e, KQ4bE7e. [pmid: 18308688].
509 Labaki G, Grès CS, Darné B, et al. Green study: quality of blood pressure measurement by general practitioners. Arch Mal Coeur Vaiss. 2002;95(7-8):713-7. KQ2aE8, KQ2bE8. [pmid: 12365085].
510 Lachouri M, Gourlet V, D'Athis P, et al. Changes in blood pressure in a large cohort of elderly individuals: Study 3C. Arch Cardiovasc Dis. Feb. 2009;102(2):127-34. KQ4aE4, KQ4bE4. [pmid: 19303580].
511 Lago RM, Pencina MJ, Wang TJ, et al. Interindividual variation in serum sodium and longitudinal blood pressure tracking in the Framingham Heart Study. J Hypertens. Nov. 2008;26(11):2121-5. KQ4aE4d, KQ4bE4d. [pmid: 18854750].
512 Lakoski SG, Herrington DM, Siscovick DM, et al. C-reactive protein concentration and incident hypertension in young adults: the CARDIA study. Arch Intern Med. Feb. 13. 2006;166(3):345-9. KQ4aE12, KQ4bE12. [pmid: 16476876].
513 Lamarre CM, Cheong NN, Larochelle P. Comparative assessment of four blood pressure measurement methods in hypertensives. The Canadian journal of cardiology. 2011;27:455-60. KQ2aE5a, KQ2bE4a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 21801977].
514 Landert M, Holm D, Steurer J, et al. Manipulation of blood pressure selfmeasurement protocols: A randomised controlled trial. Schweiz Rundsch Med Prax. 2003;92:1075-80. PMID: None. KQ3aE8, KQ3bE8, KQ3cE8.
515 Landgraf J, Wishner SH, Kloner RA. Comparison of automated oscillometric versus auscultatory blood pressure measurement. Am J Cardiol. Aug. 1. 2010;106(3):386-8. KQ2aE4, KQ2bE3. [pmid: 20643251].
516 Lane D, Beevers M, Barnes N, et al. Inter-arm differences in blood pressure: when are they clinically significant?. J Hypertens. Jun. 2002;20(6):1089-95. KQ2aE3, KQ2bE4. [pmid: 12023677].
517 Lang T, De GR, Chatellier G, et al. Prevalence and therapeutic control of hypertension in 30,000 subjects in the workplace. Hypertension. Sep. 2001;38(3):449-54. KQ2aE3, KQ2bE3, KQ3aE4, KQ3cE4, KQ4aE5, KQ4bE5. [pmid: 11566921].
518 Larkin KT, Schauss SL, Elnicki DM. Isolated clinic hypertension and normotension: false positives and false negatives in the assessment of hypertension. Blood Press Monit. 1998;3:247-54. PMID: None. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c.
519 Larkin KT, Schauss SL, Elnicki DM, et al. Detecting white coat and reverse white coat effects in clinic settings using measures of blood pressure habituation in the clinic and patient self-monitoring of blood pressure. J Hum Hypertens. Jul. 2007;21(7):516-24. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 17361194].
520 Lau K, Lorbeer R, Haring R, et al. The association between fatty liver disease and blood pressure in a population-based prospective longitudinal study. J Hypertens. Sep. 2010;28(9):1829-35. KQ4aE4, KQ4bE4. [pmid: 20577126].
521 Laurenzi M, Cirillo M, Panarelli W, et al. Baseline sodium-lithium countertransport and 6-year incidence of hypertension. The Gubbio Population Study. Circulation. Feb. 4. 1997;95(3):581-7. KQ4aE12, KQ4bE12. [pmid: 9024143].
522 Lazar J, Holman S, Minkoff HL, et al. Interarm blood pressure differences in the women's interagency HIV study. AIDS Res Hum Retroviruses. May. 2008;24(5):695-700. KQ2aE3, KQ2bE5a. [pmid: 18507529].
523 Leary AC, Murphy MB. Sleep disturbance during ambulatory blood pressure monitoring of hypertensive patients. Blood Press Monit. Feb. 1998;3(1):11-5. KQ5E7. [pmid: 10212326].
524 Lee DC, Sui X, Church TS, et al. Changes in fitness and fatness on the development of cardiovascular disease risk factors hypertension, metabolic syndrome, and hypercholesterolemia. J Am Coll Cardiol. Feb. 14. 2012;59(7):665-72. KQ4aE12, KQ4bE12. [pmid: 22322083].
525 Lee ET, Welty TK, Fabsitz R, et al. The Strong Heart Study. A study of cardiovascular disease in American Indians: design and methods. Am J Epidemiol. Dec. 1990;132(6):1141-55. KQ4aE10b, KQ4bE10b. [pmid: 2260546].
526 Lee SH, Kim YS, Sunwoo S, et al. A retrospective cohort study on obesity and hypertension risk among Korean adults. J Korean Med Sci. Apr. 2005;20(2):188-95. KQ4aE12, KQ4bE12. [pmid: 15831985].
527 Lee SK, Kim SH, Cho GY, et al. Obesity phenotype and incident hypertension: a prospective community-based cohort study. J Hypertens. Jan. 2013;31(1):145-51. KQ4aE7, KQ4bE7. [pmid: 23079679].
528 Lee SY, Kim MT, Jee SH, et al. Does long-term lactation protect premenopausal women against hypertension risk? A Korean women's cohort study. Prev Med. Aug. 2005;41(2):433-8. KQ4aE12, KQ4bE12. [pmid: 15917038].
529 Lee YJ, Kim MS, Cho S, et al. Association between simple renal cysts and development of hypertension in healthy middle-aged men. J Hypertens. Apr. 2012;30(4):700-4. KQ4aE12, KQ4bE12. [pmid: 22388228].
530 Leeman MJ, Lins RL, Sternon JE, et al. Effect of antihypertensive treatment on office and self-measured blood pressure: the Autodil study. J Hum Hypertens. Aug. 2000;14(8):525-9. KQ3aE4, KQ3bE10a, KQ3cE10a. [pmid: 10962521].
531 Lehman BJ, Taylor SE, Kiefe CI, et al. Relationship of early life stress and psychological functioning to blood pressure in the CARDIA study. Health Psychol. May. 2009;28(3):338-46. KQ4aE12, KQ4bE12. [pmid: 19450040].
532 Levitan EB, Kaciroti N, Oparil S, et al. Blood pressure measurement device, number and timing of visits, and intra-individual visit-to-visit variability of blood pressure. J Clin Hypertens (Greenwich). Nov. 2012;14(11):744-50. KQ2aE4, KQ2bE4, KQ4aE7c, KQ4bE7c. [pmid: 23126345].
533 Leynen F, De BG, Pelfrene E, et al. Increased absenteeism from work among aware and treated hypertensive and hypercholesterolaemic patients. Eur J Cardiovasc Prev Rehabil. Apr. 2006;13(2):261-7. KQ5E5a. [pmid: 16575282].
534 Li Y, Boggia J, Thijs L, et al. Is blood pressure during the night more predictive of cardiovascular outcome than during the day?. Blood Press Monit. Jun. 2008;13(3):145-7. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 18496289].
535 Liao D, Cai J, Barnes RW, et al. Association of cardiac autonomic function and the development of hypertension: the ARIC study. Am J Hypertens. Dec. 1996;9(12:Pt 1):1147-56. KQ4aE4d, KQ4bE4d. [pmid: 8972884].
536 Liao D, Arnett DK, Tyroler HA, et al. Arterial stiffness and the development of hypertension. The ARIC study. Hypertension. Aug. 1999;34(2):201-6. KQ4aE12, KQ4bE12. [pmid: 10454441].
537 Licitra R, Acconcia MC, Puddu PE, et al. Ambulatory blood pressure monitoring in prehypertensive subjects. Cardiovasc Hematol Disord Drug Targets. Sep. 2012;12(1):44-50. KQ3aE4, KQ3cE4, KQ4aE7e, KQ4bE7e. [pmid: 22524174].
538 Liebl M, Holzgreve H, Schulz M, et al. The effect of clothes on sphygmomanometric and oscillometric blood pressure measurement. Blood Press. 2004;13(5):279-82. KQ2aE4, KQ2bE4. [pmid: 15545150].
539 Liese AD, Mayer-Davis EJ, Chambless LE, et al. Elevated fasting insulin predicts incident hypertension: the ARIC study. Atherosclerosis Risk in Communities Study Investigators. J Hypertens. Aug. 1999;17(8):1169-77. KQ4aE12, KQ4bE12. [pmid: 10466473].
540 Lieu SJ, Curhan GC, Schernhammer ES, et al. Rotating night shift work and disparate hypertension risk in African-Americans. J Hypertens. Jan. 2012;30(1):61-6. KQ4aE12, KQ4bE12. [pmid: 22134389].
541 Liew G, Mitchell P, Wong TY, et al. Hypermetropia is not associated with hypertension: the Blue Mountains Eye Study. Am J Ophthalmol. Apr. 2006;141(4):746-8. KQ4aE4d, KQ4bE4d. [pmid: 16564816].
542 Lim NK, Son KH, Lee KS, et al. Predicting the risk of incident hypertension in a korean middle-aged population: Korean genome and epidemiology study. J Clin Hypertens (Greenwich). May. 2013;15(5):344-9. KQ4aE10b, KQ4bE10b. [pmid: 23614850].
543 Lim PO, Donnan PT, MacDonald TM. How well do office and exercise blood pressures predict sustained hypertension? A Dundee Step Test Study. J Hum Hypertens. Jul. 2000;14(7):429-33. KQ3aE4, KQ3bE7b, KQ3cE7b. [pmid: 10918547].
544 Lim YH, Choi SY, Oh KW, et al. Comparison Between an Automated Device and a Manual Mercury Sphygmomanometer in an Epidemiological Survey of Hypertension Prevalence. Am J Hypertens. 2013. Jun. 12. KQ2bE3. [pmid: 23764377].
545 Lima-Costa MF, Peixoto SV, Fuzikawa AK, et al. Apolipoprotein E and incident hypertension: the Bambui Health Aging Study. J Am Geriatr Soc. Nov. 2007;55(11):1895-7. KQ4aE9a, KQ4bE9b. [pmid: 17979915].
546 Lima-Costa M, Cesar C, Chor D, et al. Self-rated Health Compared With Objectively Measured Health Status as a Tool for Mortality Risk Screening in Older Adults: 10-Year Follow-up of the Bambu+­ Cohort Study of Aging. Am J Epidemiol. Feb. 2012;175(3):228-35. KQ5E7. [pmid: 22193172].
547 Lima SG, Albuquerque MF, Oliveira JR, et al. Exaggerated blood pressure response during the exercise treadmill test as a risk factor for hypertension. Braz J Med Biol Res. Apr. 2013;46(4):368-47. KQ4aE9a, KQ4bE9a. [pmid: 23598646].
548 Lindberg E, Janson C, Gislason T, et al. Snoring and hypertension: a 10 year follow-up. Eur Respir J. Apr. 1998;11(4):884-9. KQ4aE12, KQ4bE12. [pmid: 9623692].
549 Lissner L, Bengtsson C, Lapidus L, et al. Fasting insulin in relation to subsequent blood pressure changes and hypertension in women. Hypertension. Dec. 1992;20(6):797-801. KQ4aE7e, KQ4bE7e. [pmid: 1452295].
550 Little P, Barnett J, Barnsley L, et al. Comparison of agreement between different measures of blood pressure in primary care and daytime ambulatory blood pressure. BMJ. Aug. 3. 2002;325(7358):254. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12153923].
551 Loeb ED, Diamond JA, Krakoff LR, et al. Sex difference in response of blood pressure to calcium antagonism in the treatment of moderate-to-severe hypertension. Blood Press Monit. 1999;4(5):209-12. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10547639].
552 Logue JN, Hansen H. A case-control study of hypertensive women in a post-disaster community: Wyoming Valley, Pennsylvania. J Human Stress. 1980;6(2):28-34. KQ4aE7e, KQ4bE7e. [pmid: 7391558].
553 Lohmann FW, Eckert S, Verberk WJ. Interarm differences in blood pressure should be determined by measuring both arms simultaneously with an automatic oscillometric device. Blood Press Monit. Feb. 2011;16(1):37-42. KQ2aE3, KQ2bE5a. [pmid: 21284132].
554 Lopez-Garcia E, Faubel R, Guallar-Castillon P, et al. Fasting insulin in relation to subsequent blood pressure changes and hypertension in women. J Am Geriatr Soc. Apr. 2009;57(4):663-8. PMID: None. KQ4aE4b, KQ4bE4b. [pmid: 19392958].
555 Lu LC, Wei TM, Li S, et al. Differences in blood pressure readings between supine and sitting positions in hypertensive patients. Acta Cardiol. Dec. 2008;63(6):707-11. KQ2aE9, KQ2bE9. [pmid: 19157165].
556 Luders S, Gerdes M, Scholz M, et al. First results of a long-term study comparing office blood pressure measurement (OBP) vs. ambulatory blood pressure measurement (ABPM) in patients on ramipril therapy (PLUR-study. Nieren und Hochdruckkrankheiten. 1995;24:118-20. PMID: None. KQ3aE8, KQ3bE8, KQ3cE8.
557 Luepker RV, Arnett DK, Jacobs DR Jr, et al. Trends in blood pressure, hypertension control, and stroke mortality: the Minnesota Heart Survey. Am J Med. Jan. 2006;119(1):42-9. KQ2aE2, KQ2bE2, KQ3aE3, KQ3bE3, KQ3cE3, KQ4aE4, KQ4bE4. [pmid: 16431183].
558 Lurbe E, Thijs L, Torro MI, et al. Sexual dimorphism in the transition from masked to sustained hypertension in healthy youths. Hypertension. Aug. 2013;62(2):410-4. KQ4aE5, KQ4bE5. [pmid: 23734004].
559 Lusardi P, Vanasia A, Mugellini A, et al. Evaluation of nocturnal blood pressure by the Multi-P Analysis of 24-hour ambulatory monitoring. Z Kardiol. 1996;85(Suppl 3):121-3. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 8896314].
560 Lytsy P, Lind L, Sundstrom J. Endothelial function and risk of hypertension and blood pressure progression: the prospective investigation of the vasculature in Uppsala seniors. J Hypertens. May. 2013;31(5):936-9. KQ4aE7e, KQ4bE7e. [pmid: 23391984].
561 Ma G, Sabin N, Dawes M. A comparison of blood pressure measurement over a sleeved arm versus a bare arm. CMAJ. Feb. 26. 2008;178(5):585-9. KQ2aE4, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 18299548].
562 Ma SH, Park BY, Yang JJ, et al. Interaction of body mass index and diabetes as modifiers of cardiovascular mortality in a cohort study. J Prev MedPublic Health. Nov. 2012;45(6):394-401. KQ4aE12, KQ4bE12. [pmid: 23230470].
563 Ma Y, Temprosa M, Fowler S, et al. Evaluating the accuracy of an aneroid sphygmomanometer in a clinical trial setting. Am J Hypertens. Mar. 2009;22(3):263-6. KQ2aE4, KQ2bE3, KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 19057514].
564 Mackie A, Whincup P, McKinnon M. Does the Hawksley random zero sphygmomanometer underestimate blood pressure, and by how much?. J Hum Hypertens. May. 1995;9(5):337-43. KQ2aE3, KQ2bE3. [pmid: 7623370].
565 Madore F, Stampfer MJ, Rimm EB, et al. Nephrolithiasis and risk of hypertension. Am J Hypertens. Jan. 1998;11(1 Pt 1):46-53. KQ4aE12, KQ4bE12. [pmid: 9504449].
566 Mallion JM, De GR, Baguet JP, et al. Acceptability and tolerance of ambulatory blood pressure measurement in the hypertensive patient. Blood Press Monit. Jun. 1996;1(3):197-203. KQ5E5a. [pmid: 10226226].
567 Mallion JM, Mouret S, Baguet JP, et al. Ambulatory blood pressure variation in normotensive subjects in relation to the sitting or standing position. Blood Press Monit. Jun. 2000;5(3):169-73. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10915230].
568 Mallion JM, Genes N, Vaur L, et al. Detection of masked hypertension by home blood pressure measurement: is the number of measurements an important issue?. Blood Press Monit. Dec. 2004;9(6):301-5. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 15564984].
569 Mancia G, Bertinieri G, Grassi G, et al. Effects of blood-pressure measurement by the doctor on patient's blood pressure and heart rate. Lancet. Sep. 24. 1983;2(8352):695-8. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 6136837].
570 Mancia G, Ulian L, Parati G, et al. Increase in blood pressure reproducibility by repeated semi-automatic blood pressure measurements in the clinic environment. J Hypertens. Apr. 1994;12(4):469-73. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8064172].
571 Mancia G, Sega R, Bravi C, et al. Ambulatory blood pressure normality: results from the PAMELA study. J Hypertens. 1995;13(12 Pt 1):1377-90. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8866899].
572 Mancia G, Sega R, Milesi C, et al. Blood-pressure control in the hypertensive population. Lancet. 1997;349(9050):454-7. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9040574].
573 Mancia G, Omboni S, Parati G, et al. Twenty-four hour ambulatory blood pressure in the International Nifedipine GITS Study Intervention as a Goal in Hypertension Treatment (INSIGHT). J Hypertens. Mar. 2002;20(3):545-53. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 11875324].
574 Mancia G, Facchetti R, Bombelli M, et al. Long-term risk of mortality associated with selective and combined elevation in office, home, and ambulatory blood pressure. Hypertension. May. 2006;47(5):846-53. KQ3aE3, KQ3bE5c, KQ3cE5c. [pmid: 16567588].
575 Mancia G, Bombelli M, Facchetti R, et al. Long-term risk of sustained hypertension in white-coat or masked hypertension. Hypertension. Aug. 2009;54(2):226-32. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE12, KQ4bE12. [pmid: 19564548].
576 Mancia G. Defining blood pressure goals: is it enough to manage total cardiovascular risk?. J Hypertens Suppl. Jul. 2009;27(5):S3-S8. KQ3aE5c, KQ3bE5c, KQ3cE5c. [pmid: 19587552].
577 Mancia G, Bombelli M, Brambilla G, et al. Long-term prognostic value of white coat hypertension: an insight from diagnostic use of both ambulatory and home blood pressure measurements. Hypertension. Jul. 2013;62(1):168-74. KQ3aE4, KQ3bE5c, KQ3cE5c, KQ4aE12, KQ4bE12. [pmid: 23716584].
578 Mangum SA, Kraenow KR, Narducci WA. Identifying at-risk patients through community pharmacy-based hypertension and stroke prevention screening projects. J Am Pharm Assoc. Jan. 2003;43(1):50-5. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 23945804].
579 Manios ED, Koroboki EA, Tsivgoulis GK, et al. Factors influencing white-coat effect. Am J Hypertens. Feb. 2008;21(2):153-8. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 18174883].
580 Mann S. Inaccuracy of electronic sphygmomanometers. Clin Exp Pharmacol Physiol. May. 1992;19(5):304-6. KQ2aE4, KQ2bE3. [pmid: 1521362].
581 Manning G, Rushton L, Millar-Craig MW. Clinical implications of white coat hypertension: an ambulatory blood pressure monitoring study. J Hum Hypertens. Dec. 1999;13(12):817-22. KQ3aE4. [pmid: 10618670].
582 Manolio TA, Burke GL, Savage PJ, et al. Exercise blood pressure response and 5-year risk of elevated blood pressure in a cohort of young adults: the CARDIA study. Am J Hypertens. Mar. 1994;7(3):234-41. KQ4aE4d, KQ4bE4d. [pmid: 8003274].
583 Mansoor GA, McCabe EJ, White WB. Long-term reproducibility of ambulatory blood pressure. J Hypertens. Jun. 1994;12(6):703-8. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 7963496].
584 Mansoor GA, McCabe EJ, White WB. Determinants of the white-coat effect in hypertensive subjects. J Hum Hypertens. 1996;10(2):87-92. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 8867561].
585 Mansoor GA. Clinical use of ambulatory blood pressure monitoring in a Veteran's Medical Center. Blood Press Monit. Oct. 1997;2(5):217-21. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 10234120].
586 Mansoor GA, White WB. Self-measured home blood pressure in predicting ambulatory hypertension. Am J Hypertens. Nov. 2004;17(11:Pt 1):1017-22. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 15533727].
587 Mar J, Pastor R, Abasolo R, et al. Ambulatory blood pressure monitoring and diagnostic errors in hypertension: a Bayesian approach. Med Decis Making. Oct. 1998;18(4):429-35. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 10372586].
588 Margolis KL, Ray RM, Van HL, et al. Effect of calcium and vitamin D supplementation on blood pressure: the Women's Health Initiative Randomized Trial. Hypertension. Nov. 2008;52(5):847-55. KQ4aE12, KQ4bE12. [pmid: 18824662].
589 Margolis KL, Martin LW, Ray RM, et al. A prospective study of serum 25-hydroxyvitamin D levels, blood pressure, and incident hypertension in postmenopausal women. Am J Epidemiol. Jan. 1. 2012;175(1):22-32. KQ4aE12, KQ4bE12. [pmid: 22127681].
590 Marin JM, Agusti A, Villar I, et al. Association between treated and untreated obstructive sleep apnea and risk of hypertension. JAMA. May. 23. 2012;307(20):2169-76. KQ4aE3, KQ4bE3. [pmid: 22618924].
591 Markovitz JH, Matthews KA, Wing RR, et al. Psychological, biological and health behavior predictors of blood pressure changes in middle-aged women. J Hypertens. May. 1991;9(5):399-406. KQ4aE7e, KQ4bE7e. [pmid: 1649859].
592 Markovitz JH, Raczynski JM, Wallace D, et al. Cardiovascular reactivity to video game predicts subsequent blood pressure increases in young men: The CARDIA study. Psychosom Med. Mar. 1998;60(2):186-91. KQ4aE4d, KQ4bE4d. [pmid: 9560868].
593 Markovitz JH, Matthews KA, Whooley M, et al. Increases in job strain are associated with incident hypertension in the CARDIA Study. Ann Behav Med. Aug. 2004;28(1):4-9. KQ4aE12, KQ4bE12. [pmid: 15249254].
594 Markus MR, Stritzke J, Siewert U, et al. Variation in body composition determines long-term blood pressure changes in pre-hypertension: the MONICA/KORA (Monitoring Trends and Determinants on Cardiovascular Diseases/Cooperative Research in the Region of Augsburg) cohort study. J Am Coll Cardiol. Jun. 29. 2010;56(1):65-76. KQ4aE12, KQ4bE12. [pmid: 20620719].
595 Marshall T. Misleading measurements: modeling the effects of blood pressure misclassification in a United States population. Med Decis Making. Nov. 2006;26(6):624-32. KQ2aE7, KQ2bE7, KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 17099201].
596 Martinez-Lapiscina EH, Pimenta AM, Beunza JJ, et al. Nut consumption and incidence of hypertension: the SUN prospective cohort. Nutr Metab Cardiovasc Dis. Jun. 2010;20(5):359-65. KQ4aE4b, KQ4bE4b. [pmid: 19683907].
597 Martinez MA, Garcia-Puig J, Martin JC, et al. Frequency and determinants of white coat hypertension in mild to moderate hypertension: a primary care-based study. Monitorizacion Ambulatoria de la Presion Arterial (MAPA)-Area 5 Working Group. Am J Hypertens. Mar. 1999;12(3):251-9. KQ3aE4. [pmid: 10192226].
598 Maselli M, Giantin V, Franchin A, et al. Detection of blood pressure increments in active elderly individuals: The role of ambulatory blood pressure monitoring. Nutr Metab Cardiovasc Dis. 2014. Jan. 23. KQ3aE4, KQ3bE5a, KQ3cE5a, KQ4aE5, KQ4bE5. [pmid: 24548664].
599 Maslow AL, Sui X, Colabianchi N, et al. Muscular strength and incident hypertension in normotensive and prehypertensive men. Med Sci Sports Exerc. Feb. 2010;42(2):288-95. KQ4aE12, KQ4bE12. [pmid: 19927030].
600 Mason SM, Wright RJ, Hibert EN, et al. Intimate partner violence and incidence of hypertension in women. Ann Epidemiol. Aug. 2012;22(8):562-7. KQ4aE12, KQ4bE12. [pmid: 22717307].
601 Mattace-Raso FU, Verwoert GC, Hofman A, et al. Inflammation and incident-isolated systolic hypertension in older adults: the Rotterdam study. J Hypertens. May. 2010;28(5):892-5. KQ4aE12, KQ4bE12. [pmid: 20375909].
602 Matthews CE, Pate RR, Jackson KL, et al. Exaggerated blood pressure response to dynamic exercise and risk of future hypertension. J Clin Epidemiol. Jan. 1998;51(1):29-35. KQ4aE7, KQ4bE7. [pmid: 9467632].
603 Matthews KA, Kiefe CI, Lewis CE, et al. Socioeconomic trajectories and incident hypertension in a biracial cohort of young adults. Hypertension. Mar. 1. 2002;39(3):772-6. KQ4aE12, KQ4bE12. [pmid: 11897761].
604 Matthews KA, Katholi CR, McCreath H, et al. Blood pressure reactivity to psychological stress predicts hypertension in the CARDIA study. Circulation. Jul. 6. 2004;110(1):74-8. KQ4aE4d, KQ4bE4d. [pmid: 15210592].
605 Matthews KA, Chang Y, Kravitz HM, et al. Sleep and risk for high blood pressure and hypertension in midlife women: the SWAN (Study of Women's Health Across the Nation) Sleep Study. Sleep Medicine. Feb. 2014;15(2):203-8. KQ4aE7e, KQ4bE7e. [pmid: 24360982].
606 Matthys J, De MM, Mervielde I, et al. Influence of the presence of doctors-in-training on the blood pressure of patients: a randomised controlled trial in 22 teaching practices. J Hum Hypertens. Nov. 2004;18(11):769-73. KQ2aE3, KQ2bE5a. [pmid: 15141270].
607 Mauno V, Hannu K, Esko K. Proinflammation and hypertension: a population-based study. Mediators Inflamm. 2008;2008:619704. KQ4aE7e, KQ4bE7e. [pmid: 19125204].
608 McGowan N, Padfield PL. Self blood pressure monitoring: a worthy substitute for ambulatory blood pressure?. J Hum Hypertens. Dec. 2010;24(12):801-6. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 20164849].
609 McGreevy C, Mulrooney J, O'Keefe ST, et al. Do older people tolerate ambulatory blood pressure monitoring?. J Am Geriatr Soc. Oct. 2004;52(10):1780-1. KQ5E5. [pmid: 15450067].
610 McLarnon S. High blood pressure: when should employees be sent home from work?. AAOHN J. May. 2009;57(5):183. KQ5E7. [pmid: 19492754].
611 McLean DL. Nurses managing high blood pressure in patients with diabetes in community pharmacies. Can J Cardiovasc Nurs. 2007;17(2):17-21. KQ1E4. [pmid: 17585405].
612 McManus RJ, Mant J, Hull MR, et al. Does changing from mercury to electronic blood pressure measurement influence recorded blood pressure? An observational study. Br J Gen Pract. Dec. 2003;53(497):953-6. KQ2aE7, KQ2bE7, KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 14960220].
613 McManus RJ, Mant J, Roalfe A, et al. Targets and self monitoring in hypertension: randomised controlled trial and cost effectiveness analysis. BMJ. Sep. 3. 2005;331(7515):493-6. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16115830].
614 Mediavilla Garcia JD, Jaen AF, Fernandez TC, et al. Ambulatory blood pressure monitoring in the elderly. Int J Hypertens. 2012;2012:548286. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 22229085].
615 Meiland R, Geerlings SE, Stolk RP, et al. Escherichia coli bacteriuria in female adults is associated with the development of hypertension. Int J Infect Dis. Apr. 2010;14(4):e304-e307. KQ4aE7e, KQ4bE7e. [pmid: 19656709].
616 Melamed S, Froom P, Green MS. Hypertension and sickness absence: the role of perceived symptoms. J Behav Med. Oct. 1997;20(5):473-87. KQ5E7a. [pmid: 9415857].
617 Mellen PB, Bleyer AJ, Erlinger TP, et al. Serum uric acid predicts incident hypertension in a biethnic cohort: the atherosclerosis risk in communities study. Hypertension. Dec. 2006;48(6):1037-42. KQ4aE4d, KQ4bE4d. [pmid: 17060502].
618 Mena-Martin FJ, Martin-Escudero JC, Simal-Blanco F, et al. Health-related quality of life of subjects with known and unknown hypertension: results from the population-based Hortega study. J Hypertens. Jul. 2003;21(7):1283-9. KQ5E7a. [pmid: 12817174].
619 Mena LJ, Maestre GE, Hansen TW, et al. How Many Measurements Are Needed to Estimate Blood Pressure Variability Without Loss of Prognostic Information?. Am J Hypertens. 2013. Aug. 16. KQ3aE4, KQ3bE3, KQ3cE3, KQ4aE4, KQ4bE4. [pmid: 23955605].
620 Meneton P, Galan P, Bertrais S, et al. High plasma aldosterone and low renin predict blood pressure increase and hypertension in middle-aged Caucasian populations. J Hum Hypertens. Aug. 2008;22(8):550-8. KQ4aE7c, KQ4bE7c. [pmid: 18449201].
621 Mengden T, Schwartzkopff B, Strauer BE. What is the value of home (self) blood pressure monitoring in patients with hypertensive heart disease?. Am J Hypertens. Jul. 1998;11(7):813-9. KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 9683042].
622 Menkes MS, Matthews KA, Krantz DS, et al. Cardiovascular reactivity to the cold pressor test as a predictor of hypertension. Hypertension. Nov. 1989;14(5):524-30. KQ4aE7e, KQ4bE7e. [pmid: 2807514].
623 Mersich A, Jobbagy A. Identification of the cuff transfer function increases indirect blood pressure measurement accuracy. Physiol Meas. Mar. 2009;30(3):323-33. KQ2aE7, KQ2bE7. [pmid: 19234359].
624 Mesquita-Bastos J, Bertoquini S, Polonia J. Cardiovascular prognostic value of ambulatory blood pressure monitoring in a Portuguese hypertensive population followed up for 8.2 years. Blood Press Monit. 2010;15(5):240-6. KQ3bE4, KQ3cE4. [pmid: 20616705].
625 Metcalf P, Scragg R, Jackson R. Blood pressure changes over 7 years in a large workforce cohort in New Zealand. N Z Med J. 2006;119(1245):U2311. KQ4aE12, KQ4bE12. [pmid: 17146486].
626 Meyer JD, Mutambudzi M. Construction of life-course occupational trajectories: evidence for work as a mediator of racial disparities in hypertension. J Occup Environ Med. Oct. 2012;54(10):1201-7. KQ4aE4b, KQ4bE4b. [pmid: 22995805].
627 Michaelides AP, Liakos CI, Vyssoulis GP, et al. The interplay of exercise heart rate and blood pressure as a predictor of coronary artery disease and arterial hypertension. J Clin Hypertens (Greenwich). Mar. 2013;15(3):162-70. KQ4aE7e, KQ4bE7e. [pmid: 23458587].
628 Millar JA, Isles CG, Lever AF. Blood pressure, 'white-coat' pressor responses and cardiovascular risk in placebo-group patients of the MRC Mild Hypertension trial. J Hypertens. 1995;13(2):175-83. KQ4aE7c, KQ4bE7c. [pmid: 7615947].
629 Millar JA, Accioly JM. Measurement of blood pressure may be affected by an interaction between subject and observer based on gender. J Hum Hypertens. Jul. 1996;10(7):449-53. KQ2aE4, KQ2bE4. [pmid: 8880558].
630 Miller ST, Elam JT, Graney MJ, et al. Discrepancies in recording systolic blood pressure of elderly persons by ambulatory blood pressure monitor. Am J Hypertens. Jan. 1992;5(1):16-21. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1736929].
631 Minor DS, Butler KR Jr, Artman KL, et al. Evaluation of blood pressure measurement and agreement in an academic health sciences center. J Clin Hypertens (Greenwich). Apr. 2012;14(4):222-7. KQ2aE3, KQ2bE5a. [pmid: 22458743].
632 Miura K, Nakagawa H, Nakamura H, et al. Serum gamma-glutamyl transferase level in predicting hypertension among male drinkers. J Hum Hypertens. Jun. 1994;8(6):445-9. KQ4aE7e, KQ4bE7e. [pmid: 7916380].
633 Miura K, Nakagawa H, Nakamura H, et al. Serum creatinine level in predicting the development of hypertension. Ten-year follow-up of Japanese adults in a rural community. Am J Hypertens. May. 1994;7(5):390-5. KQ4aE7e, KQ4bE7e. [pmid: 8060570].
634 Miura K, Greenland P, Stamler J, et al. Relation of vegetable, fruit, and meat intake to 7-year blood pressure change in middle-aged men: the Chicago Western Electric Study. Am J Epidemiol. Mar. 15. 2004;159(6):572-80. KQ4aE4b, KQ4bE4b. [pmid: 15003961].
635 Miyai N, Arita M, Morioka I, et al. Exercise BP response in subjects with high-normal BP: exaggerated blood pressure response to exercise and risk of future hypertension in subjects with high-normal blood pressure. J Am Coll Cardiol. Nov. 1. 2000;36(5):1626-31. KQ4aE7e, KQ4bE7e. [pmid: 11079668].
636 Miyai N, Arita M, Miyashita K, et al. Blood pressure response to heart rate during exercise test and risk of future hypertension. Hypertension. Mar. 1. 2002;39(3):761-6. KQ4aE7e, KQ4bE7e. [pmid: 11897759].
637 Modesti PA, Pieri F, Cecioni I, et al. Comparison of ambulatory blood pressure monitoring and conventional office measurement in the workers of a chemical company. Int J Cardiol. Sep. 1994;46(2):151-7. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 7814164].
638 Moller DS, Dideriksen A, Sorensen S, et al. Accuracy of telemedical home blood pressure measurement in the diagnosis of hypertension. J Hum Hypertens. Aug. 2003;17(8):549-54. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 12874612].
639 Montgomery AA, Fahey T, Peters TJ. A factorial randomised controlled trial of decision analysis and an information video plus leaflet for newly diagnosed hypertensive patients. Br J Gen Pract. Jun. 2003;53(491):446-53. KQ5E3. [pmid: 12939889].
640 Moore CR, Krakoff LR, Phillips RA. Confirmation or exclusion of stage I hypertension by ambulatory blood pressure monitoring. Hypertension. May. 1997;29(5):1109-13. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9149674].
641 Mori H, Yamamoto H, Kuwashima M, et al. How does deep breathing affect office blood pressure and pulse rate?. Hypertens Res. Jun. 2005;28(6):499-504. KQ2aE3, KQ2bE4. [pmid: 16231755].
642 Morio M, Inoue M, Inoue K, et al. Impaired fasting glucose as an independent risk factor for hypertension among healthy middle-aged Japanese subjects with optimal blood pressure: the Yuport Medical Checkup Centre retrospective cohort study. Diabetology & metabolic syndrome. 2013;5(1):81. KQ4aE10a, KQ4bE10a. [pmid: 24360336].
643 Moseley JV, Linden W. Predicting blood pressure and heart rate change with cardiovascular reactivity and recovery: results from 3-year and 10-year follow up. Psychosom Med. Nov. 2006;68(6):833-43. KQ4aE7e, KQ4bE7e. [pmid: 17132835].
644 Mossey JM. Psychosocial consequences of labelling in hypertension. Clin Invest Med. 1981;4(3-4):201-7. KQ5E4. [pmid: 7337992].
645 Mourad A, Carney S, Gillies A, et al. Arm position and blood pressure: a risk factor for hypertension?. J Hum Hypertens. Jun. 2003;17(6):389-95. KQ2aE4, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 12764401].
646 Mourad JJ, Lopez-Sublet M, Aoun-Bahous S, et al. Impact of Miscuffing During Home Blood Pressure Measurement on the Prevalence of Masked Hypertension. Am J Hypertens. Jun. 1. 2013;26(10):1205-9. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 23727841].
647 Mozaffarian D, Shi P, Morris JS, et al. Mercury exposure and risk of hypertension in US men and women in 2 prospective cohorts. Hypertension. Sep. 2012;60(3):645-52. KQ4aE12, KQ4bE12. [pmid: 22868395].
648 Mueller UK, Wells M, Radevski II, et al. Repeated automated versus daytime ambulatory blood pressure measurement in mild, moderate and severe untreated black hypertensive patients. Blood Press Monit. Dec. 1997;2(1):21-5. KQ3aE2, KQ3bE2, KQ3cE2. [pmid: 10234086].
649 Mule G, Caimi G, Cottone S, et al. Value of home blood pressures as predictor of target organ damage in mild arterial hypertension. J Cardiovasc Risk. Apr. 2002;9(2):123-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 12006920].
650 Musso NR, Giacche M, Galbariggi G, et al. Blood pressure evaluation by noninvasive and traditional methods. Consistencies and discrepancies among photoplethysmomanometry, office sphygmomanometry, and ambulatory monitoring. Effects of blood pressure measurement. Am J Hypertens. Apr. 1996;9(4:Pt 1):293-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8722430].
651 Musso NR, Vergassola C, Barone C, et al. Ambulatory blood pressure monitoring: how reproducible is it?. Am J Hypertens. Aug. 1997;10(8):936-9. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 9270090].
652 Myers MG. The white-coat effect in treated hypertension. Blood Press Monit. Jun. 1996;1(3):247-9. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 10226237].
653 Myers MG, Valdivieso MA. Use of an automated blood pressure recording device, the BpTRU, to reduce the "white coat effect" in routine practice. Am J Hypertens. Jun. 2003;16(6):494-7. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12799100].
654 Myers MG, Valdivieso M, Kiss A. Optimum frequency of office blood pressure measurement using an automated sphygmomanometer. Blood Press Monit. Dec. 2008;13(6):333-8. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 19020423].
655 Myers MG, McInnis NH, Fodor GJ, et al. Comparison between an automated and manual sphygmomanometer in a population survey. Am J Hypertens. Mar. 2008;21(3):280-3. KQ2aE4c, KQ2bE3. [pmid: 18219304].
656 Myers MG, Valdivieso M, Kiss A. Use of automated office blood pressure measurement to reduce the white coat response. J Hypertens. Feb. 2009;27(2):280-6. KQ2aE3, KQ2bE3, KQ3aE4, KQ3cE4. [pmid: 19155785].
657 Myers MG, Valdivieso M, Kiss A. Consistent relationship between automated office blood pressure recorded in different settings. Blood Press Monit. Jun. 2009;14(3):108-11. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 19417634].
658 Myers MG. A proposed algorithm for diagnosing hypertension using automated office blood pressure measurement. J Hypertens. Apr. 2010;28(4):703-8. KQ2aE4c, KQ2bE3, KQ3aE4, KQ3cE4. [pmid: 20150823].
659 Myers MG, Godwin M, Dawes M, et al. The conventional versus automated measurement of blood pressure in the office (CAMBO) trial: masked hypertension sub-study. J Hypertens. Oct. 2012;30(10):1937-41. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22828087].
660 Myers MG, Valdivieso M. Evaluation of an automated sphygmomanometer for use in the office setting. Blood Press Monit. Jun. 2012;17(3):116-9. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22514038].
661 Myers MG, Godwin M, Dawes M, et al. Conventional versus automated measurement of blood pressure in the office (CAMBO) trial. Fam Pract. Aug. 2012;29(4):376-82. KQ2aE5a, KQ2bE3, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22117083].
662 Myers M, Godwin M, Dawes M, et al. Conventional versus automated measurement of blood pressure in primary care patients with systolic hypertension: randomised parallel design controlled trial. BMJ. Feb. 12. 2011;342(7793):372. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 21300709].
663 Nagai K, Imai Y, Tsuji I, et al. Prevalence of hypertension and rate of blood pressure control as assessed by home blood pressure measurements in a rural Japanese community, Ohasama. Clin Exp Hypertens. Jul. 1996;18(5):713-28. KQ3aE4, KQ3bE5, KQ3cE4. [pmid: 8781755].
664 Najjar SS, Scuteri A, Shetty V, et al. Pulse wave velocity is an independent predictor of the longitudinal increase in systolic blood pressure and of incident hypertension in the Baltimore Longitudinal Study of Aging. J Am Coll Cardiol. Apr. 8. 2008;51(14):1377-83. KQ4aE7e, KQ4bE7e. [pmid: 18387440].
665 Nakanishi N, Nakamura K, Ichikawa S, et al. Risk factors for the development of hypertension: a 6-year longitudinal study of middle-aged Japanese men. J Hypertens. Jun. 1998;16(6):753-9. KQ4aE12, KQ4bE12. [pmid: 9663915].
666 Nakanishi N, Nakamura K, Ichikawa S, et al. Lifestyle and the development of hypertension: a 3-year follow-up study of middle-aged Japanese male office workers. Occup Med (Lond). Feb. 1999;49(2):109-14. KQ4aE7e, KQ4bE7e. [pmid: 10436563].
667 Nakanishi N, Yoshida H, Nagano K, et al. Long working hours and risk for hypertension in Japanese male white collar workers. J Epidemiol Community Health. May. 2001;55(5):316-22. KQ4aE7e, KQ4bE7e. [pmid: 11297649].
668 Nakanishi N, Yoshida H, Okamoto M, et al. Hematocrit and risk for hypertension in middle-aged Japanese male office workers. Ind Health. Jan. 2001;39(1):17-20. KQ4aE7e, KQ4bE7e. [pmid: 11212285].
669 Nakanishi N, Yoshida H, Nakamura K, et al. Alcohol consumption and risk for hypertension in middle-aged Japanese men. J Hypertens. May. 2001;19(5):851-5. KQ4aE12, KQ4bE12. [pmid: 11393666].
670 Nakanishi N, Sato M, Shirai K, et al. White blood cell count as a risk factor for hypertension; a study of Japanese male office workers. J Hypertens. May. 2002;20(5):851-7. KQ4aE4d, KQ4bE4d. [pmid: 12011644].
671 Nakanishi N, Makino K, Nishina K, et al. Relationship of light to moderate alcohol consumption and risk of hypertension in Japanese male office workers. Alcohol Clin Exp Res. Jul. 2002;26(7):988-94. KQ4aE4d, KQ4bE4d. [pmid: 12170108].
672 Nakanishi N, Okamoto M, Yoshida H, et al. Serum uric acid and risk for development of hypertension and impaired fasting glucose or Type II diabetes in Japanese male office workers. Eur J Epidemiol. 2003;18(6):523-30. KQ4aE12, KQ4bE12. [pmid: 12908717].
673 Nakanishi N, Suzuki K. Daily life activity and the risk of developing hypertension in middle-aged Japanese men. Arch Intern Med. Jan. 24. 2005;165(2):214-20. KQ4aE12, KQ4bE12. [pmid: 15668369].
674 Narkiewicz K, Piccolo D, Borella P, et al. Response to orthostatic stress predicts office-daytime blood pressure difference, but not nocturnal blood pressure fall in mild essential hypertensives: results of the harvest trial. Clin Exp Pharmacol Physiol. Oct. 1995;22(10):743-7. KQ2aE5, KQ2bE5, KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 8575111].
675 Nascimento LR, Coelli AP, Cade NV, et al. Sensitivity and specificity in the diagnosis of hypertension with different methods. Rev Saude Publica. Oct. 2011;45(5):837-44. KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 21860912].
676 Nasothimiou EG, Tzamouranis D, Rarra V, et al. Diagnostic accuracy of home vs. ambulatory blood pressure monitoring in untreated and treated hypertension. Hypertens Res. Jul. 2012;35(7):750-5. KQ3aE4. [pmid: 22357523].
677 Nawrot TS, Staessen JA, Roels HA, et al. Diagnostic accuracy of home vs. ambulatory blood pressure monitoring in untreated and treated hypertension. Eur Heart J. Mar. 2007;28(5):628-33. KQ4aE7e, KQ4bE7e. [pmid: 17242009].
678 Nelson D, Kennedy B, Regnerus C, et al. Accuracy of automated blood pressure monitors. J Dent Hyg. 2008;82(4):35. KQ2aE4, KQ2bE3, KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 18755068].
679 Nelson MR, Quinn S, Bowers-Ingram L, et al. Cluster-randomized controlled trial of oscillometric vs. manual sphygmomanometer for blood pressure management in primary care (CRAB). Am J Hypertens. Jun. 2009;22(6):598-603. KQ2aE5a, KQ2bE3. [pmid: 19300424].
680 Nelson MR. Oscillometric devices are good in routine practice... conventional versus automated measurement of blood pressure in primary care patients with systolic hypertension: randomized parallel design controlled trial. BMJ: british medical journal. 2011;342:516. PMID: None. KQ2aE7, KQ2bE7.
681 Nemesure B, Wu SY, Hennis A, et al. The relationship of body mass index and waist-hip ratio on the 9-year incidence of diabetes and hypertension in a predominantly African-origin population. Ann Epidemiol. Aug. 2008;18(8):657-63. KQ4aE12, KQ4bE12. [pmid: 18652984].
682 Nesbitt SD, Amerena JV, Grant E, et al. Home blood pressure as a predictor of future blood pressure stability in borderline hypertension. The Tecumseh Study. Am J Hypertens. Nov. 1997;10(11):1270-80. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE7e, KQ4bE7e. [pmid: 9397247].
683 Neser WB, Thomas J, Semenya K, et al. Obesity and hypertension in a longitudinal study of black physicians: the Meharry Cohort Study. J Chronic Dis. 1986;39(2):105-13. KQ4aE7e, KQ4bE7e. [pmid: 3944222].
684 Netea RT, Smits P, Lenders JW, et al. Does it matter whether blood pressure measurements are taken with subjects sitting or supine?. J Hypertens. Mar. 1998;16(3):263-8. KQ2aE4, KQ2bE4. [pmid: 9557918].
685 Netea RT, Lenders JW, Smits P, et al. Arm position is important for blood pressure measurement. J Hum Hypertens. Feb. 1999;13(2):105-9. KQ2aE4, KQ2bE4. [pmid: 10100058].
686 Netea RT, Lenders JW, Smits P, et al. Both body and arm position significantly influence blood pressure measurement. J Hum Hypertens. Jul. 2003;17(7):459-62. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 12821952].
687 Ni H, Wu C, Prineas R, et al. Comparison of Dinamap PRO-100 and mercury sphygmomanometer blood pressure measurements in a population-based study. Am J Hypertens. Apr. 2006;19(4):353-60. KQ2aE5a, KQ2bE3, KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 16580569].
688 Niessen MA, van der Hoeven NV, van den Born BJ, et al. Home blood pressure measurement as a screening tool for hypertension in a web-based worksite health promotion programme. Eur J Public Health. 2013. Oct. 1. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 24088704].
689 Niiranen TJ, Jula AM, Kantola IM, et al. Comparison of agreement between clinic and home-measured blood pressure in the Finnish population: the Finn-HOME Study. J Hypertens. Aug. 2006;24(8):1549-55. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16877957].
690 Niiranen TJ, Hanninen MR, Johansson J, et al. Home-measured blood pressure is a stronger predictor of cardiovascular risk than office blood pressure: the Finn-Home study. Hypertension. Jun. 2010;55(6):1346-51. KQ2aE3, KQ2bE3, KQ3bE4, KQ3cE4. [pmid: 20385970].
691 Niiranen TJ, Johansson JK, Reunanen A, et al. Comparison of agreement between clinic and home-measured blood pressure in the Finnish population: the Finn-HOME Study. Hypertension. Jun. 2011;57(6):1081-6. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 21482956].
692 Niiranen TJ, Thijs L, Asayama K, et al. The International Database of HOme blood pressure in relation to Cardiovascular Outcome (IDHOCO): moving from baseline characteristics to research perspectives. Hypertens Res. Nov. 2012;35(11):1072-9. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 22763485].
693 Niiranen TJ, Asayama K, Thijs L, et al. Outcome-driven thresholds for home blood pressure measurement: international database of home blood pressure in relation to cardiovascular outcome. Hypertension. Jan. 2013;61(1):27-34. KQ3aE6, KQ3bE4, KQ3cE4. [pmid: 23129700].
694 Niiranen TJ, Rissanen H, Johansson JK, et al. Overall cardiovascular prognosis of isolated systolic hypertension, isolated diastolic hypertension and pulse pressure defined with home measurements: the Finn-home study. J Hypertens. Mar. 2014;32(3):518-24. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 24477096].
695 Nilsson PM, Lind L, Andersson PE, et al. On the use of ambulatory blood pressure recordings and insulin sensitivity measurements in support of the insulin-hypertension hypothesis. J Hypertens. Aug. 1994;12(8):965-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 7814857].
696 Niskanen L, Laaksonen DE, Nyyssonen K, et al. Inflammation, abdominal obesity, and smoking as predictors of hypertension. Hypertension. Dec. 2004;44(6):859-65. KQ4aE7e, KQ4bE7e. [pmid: 15492131].
697 Niyonsenga T, Vanasse A, Courteau J, et al. Impact of terminal digit preference by family physicians and sphygmomanometer calibration errors on blood pressure value: implication for hypertension screening. J Clin Hypertens (Greenwich). May. 2008;10(5):341-7. KQ2aE7, KQ2bE3. [pmid: 18453792].
698 Noguchi Y, Asayama K, Staessen JA, et al. Predictive power of home blood pressure and clinic blood pressure in hypertensive patients with impaired glucose metabolism and diabetes. J Hypertens. May. 13. 2013;31(8):1593-602. KQ3aE4a, KQ3bE4, KQ3cE4. [pmid: 23673350].
699 Nordmann A, Frach B, Walker T, et al. Comparison of self-reported home blood pressure measurements with automatically stored values and ambulatory blood pressure. Blood Press. 2000;9(4):200-5. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 11055472].
700 Nunez-Cordoba JM, Valencia-Serrano F, Toledo E, et al. The Mediterranean diet and incidence of hypertension: the Seguimiento Universidad de Navarra (SUN) Study. Am J Epidemiol. Feb. 1. 2009;169(3):339-46. KQ4aE4b, KQ4bE4b. [pmid: 19037007].
701 Nunez-Cordoba JM, Martinez-Gonzalez MA, Bes-Rastrollo M, et al. Inflammation, abdominal obesity, and smoking as predictors of hypertension. Rev Esp Cardiol. Jun. 2009;62(6):633-41. PMID: None. KQ4aE4b, KQ4bE4b. [pmid: 19480759].
702 O'Connor A. Decision aids reduced decisional conflict in patients with newly diagnosed hypertension. Evid Based Med. Jan. 2004;9(1):13. PMID: None. KQ5E7.
703 O'Connor GT, Caffo B, Newman AB, et al. Prospective study of sleep-disordered breathing and hypertension: the Sleep Heart Health Study. Am J Respir Crit Care Med. Jun. 15. 2009;179(12):1159-64. KQ4aE10b, KQ4bE10b. [pmid: 19264976].
704 O'Shea JC, Murphy MB. Ambulatory blood pressure monitoring: which arm?. J Hum Hypertens. Apr. 2000;14(4):227-30. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10805046].
705 Odahara T, Irokawa M, Karasawa H, et al. Detection of exaggerated blood pressure response using laboratory of physical science protocol and risk of future hypertension. J Occup Health. 2010;52(5):278-86. KQ4aE7e, KQ4bE7e. [pmid: 20697184].
706 Ogedegbe G, Pickering TG, Clemow L, et al. The misdiagnosis of hypertension: the role of patient anxiety. Arch Intern Med. Dec. 8. 2008;168(22):2459-65. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c, KQ5E4. [pmid: 19064830].
707 Ogedegbe G. Labeling and hypertension: it is time to intervene on its negative consequences. Hypertension. Sep. 2010;56(3):344-5. KQ5E7. [pmid: 20625073].
708 Ohkubo T, Imai Y, Tsuji I, et al. Prediction of mortality by ambulatory blood pressure monitoring versus screening blood pressure measurements: a pilot study in Ohasama. J Hypertens. Apr. 1997;15(4):357-64. KQ3bE4, KQ3cE4. [pmid: 9211170].
709 Ohkubo T, Imai Y, Tsuji I, et al. Reference values for 24-hour ambulatory blood pressure monitoring based on a prognostic criterion: the Ohasama Study. Hypertension. Aug. 1998;32(2):255-9. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 9719051].
710 Ohkubo T, Imai Y, Tsuji I, et al. Home blood pressure measurement has a stronger predictive power for mortality than does screening blood pressure measurement: a population-based observation in Ohasama, Japan. J Hypertens. Jul. 1998;16(7):971-5. KQ3bE4, KQ3cE4. [pmid: 9794737].
711 Ohkubo T, Hozawa A, Nagai K, et al. Prediction of stroke by ambulatory blood pressure monitoring versus screening blood pressure measurements in a general population: the Ohasama study. J Hypertens. Jul. 2000;18(7):847-54. KQ3bE4, KQ3cE4. [pmid: 10930181].
712 Ohkubo T, Hozawa A, Yamaguchi J, et al. Prognostic significance of the nocturnal decline in blood pressure in individuals with and without high 24-h blood pressure: the Ohasama study. J Hypertens. Nov. 2002;20(11):2183-9. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 12409956].
713 Ohkubo T, Asayama K, Kikuya M, et al. Prediction of ischaemic and haemorrhagic stroke by self-measured blood pressure at home: the Ohasama study. Blood Press Monit. Dec. 2004;9(6):315-20. KQ3bE4, KQ3cE4. [pmid: 15564987].
714 Ohkubo T, Asayama K, Kikuya M, et al. How many times should blood pressure be measured at home for better prediction of stroke risk? Ten-year follow-up results from the Ohasama study. J Hypertens. Jun. 2004;22(6):1099-104. KQ3bE4, KQ3cE4. [pmid: 15167443].
715 Ohkubo T, Kikuya M, Metoki H, et al. Prognosis of "masked" hypertension and "white-coat" hypertension detected by 24-h ambulatory blood pressure monitoring 10-year follow-up from the Ohasama study. J Am Coll Cardiol. Aug. 2. 2005;46(3):508-15. KQ3bE4, KQ3cE4, KQ4aE4, KQ4bE4. [pmid: 16053966].
716 Ohkubo T, Kikuya M, Asayama K, et al. Incorporating self-blood pressure measurements at home in the guideline from the Ohasama study. Blood Press Monit. Dec. 2007;12(6):407-9. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 18277323].
717 Ohmori S, Kiyohara Y, Kato I, et al. Alcohol intake and future incidence of hypertension in a general Japanese population: the Hisayama study. Alcohol Clin Exp Res. Jul. 2002;26(7):1010-6. KQ4aE12, KQ4bE12. [pmid: 12170111].
718 Okamura T, Kadowaki T, Hayakawa T, et al. What cause of mortality can we predict by cholesterol screening in the Japanese general population?. J Intern Med. Feb. 2003;253(2):169-80. KQ1E1, KQ4aE4, KQ4bE4. [pmid: 12542557].
719 Oksanen T, Kawachi I, Jokela M, et al. Workplace social capital and risk of chronic and severe hypertension: a cohort study. J Hypertens. Jun. 2012;30(6):1129-36. KQ4aE10b, KQ4bE10b. [pmid: 22525202].
720 Okumiya K, Matsubayashi K, Wada T, et al. A U-shaped association between home systolic blood pressure and four-year mortality in community-dwelling older men. J Am Geriatr Soc. Dec. 1999;47(12):1415-21. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 10591234].
721 Omvik P, Gerhardsen G. The Norwegian office-, home-, and ambulatory blood pressure study (NOHA). Blood Press. 2003;12(4):211-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 14596357].
722 Onat A, Can G, Hergenc G, et al. Serum apolipoprotein B predicts dyslipidemia, metabolic syndrome and, in women, hypertension and diabetes, independent of markers of central obesity and inflammation. Int J Obes (Lond). Jul. 2007;31(7):1119-25. KQ4aE9, KQ4bE9. [pmid: 17299378].
723 Onat A, Can G, Ornek E, et al. Serum -glutamyltransferase: independent predictor of risk of diabetes, hypertension, metabolic syndrome, and coronary disease. Obesity (Silver Spring). Apr. 2012;20(4):842-8. KQ4aE9, KQ4bE9. [pmid: 21633402].
724 Oren A, Vos LE, Uiterwaal CS, et al. What cause of mortality can we predict by cholesterol screening in the Japanese general population?. Eur J Epidemiol. 2003;18(7):715-27. KQ4aE5, KQ4bE5. [pmid: 12952149].
725 Orme S, Ralph SG, Birchall A, et al. The normal range for inter-arm differences in blood pressure. Age Ageing. Oct. 1999;28(6):537-42. KQ2aE3, KQ2bE4. [pmid: 10604505].
726 Ostchega Y, Nwankwo T, Sorlie PD, et al. Assessing the validity of the Omron HEM-907XL oscillometric blood pressure measurement device in a National Survey environment. J Clin Hypertens (Greenwich). Jan. 2010;12(1):22-8. KQ2bE3. [pmid: 20047626].
727 Ostchega Y, Prineas RJ, Nwankwo T, et al. Assessing blood pressure accuracy of an aneroid sphygmomanometer in a national survey environment. Am J Hypertens. Mar. 2011;24(3):322-7. KQ2aE3, KQ2bE3. [pmid: 21164495].
728 Otsuka K, Halberg F. Circadian profiles of blood pressure and heart rate of apparently healthy metropolitan Japanese. Front Med Biol Eng. 1994;6(2):149-55. KQ3aE4, KQ3bE10b, KQ3cE4. [pmid: 7993856].
729 Otsuka T, Kato K, Kachi Y, et al. Serum Cystatin C, Creatinine-Based Estimated Glomerular Filtration Rate, and the Risk of Incident Hypertension in Middle-Aged Men. Am J Hypertens. 2013. Sep. 5. KQ4aE7e, KQ4bE7e. [pmid: 24008123].
730 Otsuka T, Kato K, Ibuki C, et al. Does Subjective Evaluation of the Frequency of Salty Food Intake Predict the Risk of Incident Hypertension? A 4-year Follow-up Study in a Middle-aged Population. Intern Med J. Aug. 14. 2013;43(12):1316-21. KQ4aE7e, KQ4bE7e. [pmid: 23941129].
731 Ozdemir FN, Guz G, Sezer S, et al. Ambulatory blood pressure monitoring in potential renal transplant donors. Nephrol Dial Transplant. Jul. 2000;15(7):1038-40. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 10862644].
732 Paffenbarger RS Jr, Wing AL, Hyde RT, et al. Physical activity and incidence of hypertension in college alumni. Am J Epidemiol. Mar. 1983;117(3):245-57. KQ4aE12, KQ4bE12. [pmid: 6829553].
733 Paffenbarger RS Jr, Jung DL, Leung RW, et al. Physical activity and hypertension: an epidemiological view. Ann Med. Aug. 1991;23(3):319-27. KQ4aE12, KQ4bE12. [pmid: 1930924].
734 Pailleur C, Vacheron A, Landais P, et al. Talking effect and white coat phenomenon in hypertensive patients. Behav Med. 1996;22(3):114-22. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9116382].
735 Pailleur C, Helft G, Landais P, et al. The effects of talking, reading, and silence on the "white coat" phenomenon in hypertensive patients. Am J Hypertens. 1998;11(2):203-7. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9524049].
736 Palatini P, Pessina AC. A new approach to define the upper normal limits of ambulatory blood pressure. J Hypertens Suppl. Dec. 1990;8(6):S65-S70. KQ3aE4, KQ3bE10b, KQ3cE10b. [pmid: 2082000].
737 Palatini P, Graniero GR, Mormino P, et al. Relation between physical training and ambulatory blood pressure in stage I hypertensive subjects. Results of the HARVEST Trial. Hypertension and Ambulatory Recording Venetia Study. Circulation. Dec. 1994;90(6):2870-6. KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 7994832].
738 Palatini P, Julius S, Collatina S, et al. Optimizing the assessment of the elderly patient with borderline hypertension: the Hypertension and Ambulatory Recording in the OLD (HAROLD) study. Aging (Milano). Oct. 1997;9(5):365-71. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE4, KQ4bE4. [pmid: 9458997].
739 Palatini P, Winnicki M, Santonastaso M, et al. Prevalence and clinical significance of isolated ambulatory hypertension in young subjects screened for stage 1 hypertension. Hypertension. Aug. 2004;44(2):170-4. KQ3aE4, KQ3bE5, KQ3cE5, KQ4aE5b, KQ4bE5b. [pmid: 15210653].
740 Palatini P, Dorigatti F, Zaetta V, et al. Heart rate as a predictor of development of sustained hypertension in subjects screened for stage 1 hypertension: the HARVEST Study. J Hypertens. Sep. 2006;24(9):1873-80. KQ4aE5, KQ4bE5. [pmid: 16915038].
741 Palatini P, Longo D, Zaetta V, et al. Heart rate as a predictor of development of sustained hypertension in subjects screened for stage 1 hypertension: the HARVEST Study. J Hypertens. Jul. 2006;24(7):1375-81. KQ4aE7e, KQ4bE7e. [pmid: 16794487].
742 Palatini P, Ceolotto G, Ragazzo F, et al. Phosducin rs12402521 polymorphism predicts development of hypertension in young subjects with overweight or obesity. Nutr Metab Cardiovasc Dis. Apr. 2013;23(4):323-9. KQ4aE7e, KQ4bE7e. [pmid: 22365573].
743 Pannarale G, Bebb G, Clark S, et al. Bias and variability in blood pressure measurement with ambulatory recorders. Hypertension. Oct. 1993;22(4):591-8. KQ3aE3, KQ3bE3, KQ3cE3. [pmid: 8406665].
744 Pannarale G, Gaudio C, Mirabelli F, et al. Ambulatory monitoring predicts development of drug-treated hypertension in subjects with high normal blood pressure. Blood Press. 2004;13(4):247-51. KQ3aE4, KQ3bE5c, KQ3cE5c, KQ4aE12, KQ4bE12. [pmid: 15581340].
745 Pannarale G, Acconcia MC, Gianturco L, et al. Cigarette smoking and ambulatory blood pressure: a case-control study in normotensives. J Hum Hypertens. Feb. 2008;22(2):129-31. KQ4aE7, KQ4bE7. [pmid: 17597796].
746 Parati G, Mancia G. Assessing the white-coat effect: which blood pressure measurement should be considered?. J Hypertens. 2006;24(1):29-31. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 16331095].
747 Parikh NI, Pencina MJ, Wang TJ, et al. A risk score for predicting near-term incidence of hypertension: the Framingham Heart Study. Ann Intern Med. Jan. 15. 2008;148(2):102-10. KQ4aE4d, KQ4bE4d. [pmid: 18195335].
748 Park BW, Chung JW, Hyon MS, et al. Contact dermatitis caused by ambulatory blood pressure monitoring. Korean J Intern Med. Jan. 2013;28(1):120. KQ5E7. [pmid: 23346009].
749 Park SE, Rhee EJ, Park CY, et al. Impact of hyperinsulinemia on the development of hypertension in normotensive, nondiabetic adults: a 4-year follow-up study. Metabolism. Apr. 2013;62(4):532-8. KQ4aE4d, KQ4bE4d. [pmid: 23122695].
750 Park SK, Moon SY, Oh CM, et al. High Normal Urine Albumin-to-Creatinine Ratio Predicts Development of Hypertension in Korean Men. Circ J. 2013. Dec. 13. KQ4aE4d, KQ4bE4d. [pmid: 24334637].
751 Park SK, Jung JY, Choi WJ, et al. Elevated fasting serum insulin level predicts future development of hypertension. Int J Cardiol. 2014. Jan. 25. KQ4aE4d, KQ4bE4d. [pmid: 24491863].
752 Parker ED, Schmitz KH, Jacobs DR Jr, et al. Physical activity in young adults and incident hypertension over 15 years of follow-up: the CARDIA study. Am J Public Health. Apr. 2007;97(4):703-9. KQ4aE12, KQ4bE12. [pmid: 17329668].
753 Paschalis-Purtak K, Pucilowska B, Kabat M, et al. Clinical evaluation of 24 h ambulatory monitoring of blood pressure under various environmental conditions (home and work versus hospital). Blood Press Monit. Oct. 1998;3(5):289-94. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 10212368].
754 Patten SB, Beck CA, Kassam A, et al. Long-term medical conditions and major depression: strength of association for specific conditions in the general population. Can J Psychiatry. Mar. 2005;50(4):195-202. KQ5E1. [pmid: 15898458].
755 Pavan MV, Saura GE, Korkes HA, et al. Similarity between blood pressure values assessed by auscultatory method with mercury sphygmomanometer and automated oscillometric digital device. J Bras Nefrol. Mar. 2012;34(1):43-9. KQ2aE9a, KQ2bE9a, KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 22441181].
756 Pavek K, Taube A. Interchangeability of ambulatory and office blood pressure: limitations of reproducibility and agreement. Blood Press. 2000;9(4):192-9. KQ2aE4, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 11055471].
757 Pavlik VN, Hyman DJ, Toronjo C. Comparison of Automated and Mercury Column Blood Pressure Measurements in Health Care Settings. J Clin Hypertens (Greenwich). Mar. 2000;2(2):81-6. KQ2bE3. [pmid: 11416630].
758 Paynter NP, Cook NR, Everett BM, et al. Prediction of incident hypertension risk in women with currently normal blood pressure. Am J Med. May. 2009;122(5):464-71. KQ4aE12, KQ4bE12. [pmid: 19375556].
759 Paynter NP, Sesso HD, Conen D, et al. Lipoprotein subclass abnormalities and incident hypertension in initially healthy women. Clin Chem. Aug. 2011;57(8):1178-87. KQ4aE12, KQ4bE12. [pmid: 21700954].
760 Peacock JM, Folsom AR, Arnett DK, et al. Relationship of serum and dietary magnesium to incident hypertension: the Atherosclerosis Risk in Communities (ARIC) Study. Ann Epidemiol. Apr. 1999;9(3):159-65. KQ4aE12, KQ4bE12. [pmid: 10192647].
761 Pearce KA, Grimm RH Jr, Rao S, et al. Population-derived comparisons of ambulatory and office blood pressures. Implications for the determination of usual blood pressure and the concept of white coat hypertension. Arch Intern Med. Apr. 1992;152(4):750-6. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1558432].
762 Pearce KA, Evans GW, Summerson J, et al. Comparisons of ambulatory blood pressure monitoring and repeated office measurements in primary care. J Fam Pract. Nov. 1997;45(5):426-33. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9374969].
763 Pearson TA, Lacroix AZ, Mead LA, et al. The prediction of midlife coronary heart disease and hypertension in young adults: the Johns Hopkins multiple risk equations. Am J Prev Med. 1990;6(2 Suppl):23-8. KQ4aE12, KQ4bE12. [pmid: 2383409].
764 Pedersen OL, Mancia G, Pickering T, et al. Ambulatory blood pressure monitoring after 1 year on valsartan or amplodipine-based treatments: a VALUE substudy. J Hypertens. Mar. 2007;25(3):707-12. KQ3aE5, KQ3bE5a, KQ3cE5a. [pmid: 17278988].
765 Peralta CA, Adeney KL, Shlipak MG, et al. Structural and functional vascular alterations and incident hypertension in normotensive adults: the Multi-Ethnic Study of Atherosclerosis. Am J Epidemiol. Jan. 1. 2010;171(1):63-71. KQ4aE4d, KQ4bE4d. [pmid: 19951938].
766 Pereira M, Lunet N, Paulo C, et al. Incidence of hypertension in a prospective cohort study of adults from Porto, Portugal. BMC Cardiovasc Disord. 2012;12:114. KQ4aE7e, KQ4bE7e. [pmid: 23190867].
767 Pereira MA, Folsom AR, McGovern PG, et al. Physical activity and incident hypertension in black and white adults: the Atherosclerosis Risk in Communities Study. Prev Med. Mar. 1999;28(3):304-12. KQ4aE12, KQ4bE12. [pmid: 10072750].
768 Perini C, Muller FB, Buhler FR. Suppressed aggression accelerates early development of essential hypertension. J Hypertens. Jun. 1991;9(6):499-503. KQ4aE7e, KQ4bE7e. [pmid: 1653288].
769 Perloff D, Grim C, Flack J, et al. Human blood pressure determination by sphygmomanometry. Circulation. Nov. 1993;88(5 Pt 1):2460-70. KQ2aE7, KQ2bE7. [pmid: 8222141].
770 Perlstein TS, Gumieniak O, Williams GH, et al. Uric acid and the development of hypertension: the normative aging study. Hypertension. Dec. 2006;48(6):1031-6. KQ4aE12, KQ4bE12. [pmid: 17060508].
771 Pessanha P, Viana M, Ferreira P, et al. Diagnostic value and cost-benefit analysis of 24 hours ambulatory blood pressure monitoring in primary care in Portugal. BMC Cardiovascular Disorders. 2013;13:57. KQ3aE4. [pmid: 23937261].
772 Peters GL, Binder SK, Campbell NR. The effect of crossing legs on blood pressure: a randomized single-blind cross-over study. Blood Press Monit. Apr. 1999;4(2):97-101. KQ2aE3. [pmid: 10450120].
773 Peterson GM, Fitzmaurice KD, Kruup H, et al. Cardiovascular risk screening program in Australian community pharmacies. Pharm World Sci. Jun. 2010;32(3):373-80. KQ1E4. [pmid: 20217476].
774 Phillips B, Mannino DM. Do insomnia complaints cause hypertension or cardiovascular disease?. J Clin Sleep Med. Aug. 15. 2007;3(5):489-94. KQ4aE4d, KQ4bE4d. [pmid: 17803012].
775 Phillips B, Buzkova P, Enright P, et al. Insomnia did not predict incident hypertension in older adults in the cardiovascular health study. Sleep. Jan. 2009;32(1):65-72. KQ4aE12, KQ4bE12. [pmid: 19189780].
776 Pickering T, Schwartz J, Verdecchia P, et al. Prediction of strokes versus cardiac events by ambulatory monitoring of blood pressure: results from an international database. Blood Press Monit. Dec. 2007;12(6):397-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 18277320].
777 Pickering TG, James GD, Boddie C, et al. How common is white coat hypertension?. JAMA. Jan. 8. 1988;259(2):225-8. KQ3aE4, KQ3bE10b, KQ3cE10b. [pmid: 3336140].
778 Pickering TG. Now we are sick: labeling and hypertension. J Clin Hypertens (Greenwich). Jan. 2006;8(1):57-60. KQ5E4. [pmid: 16407691].
779 Pieper L, Wittchen HU, Glaesmer H, et al. Cardiovascular high-risk constellations in primary care. DETECT Study 2003. Bundesgesundheitsblatt, Gesundheitsforschung, Gesundheitsschutz. 2005;48(12):1374-82. KQ4aE8, KQ4bE8. [pmid: 16283123].
780 Pierdomenico SD, Mezzetti A, Lapenna D, et al. 'White-coat' hypertension in patients with newly diagnosed hypertension: evaluation of prevalence by ambulatory monitoring and impact on cost of health care. Eur Heart J. May. 1995;16(5):692-7. KQ3aE4. [pmid: 7588903].
781 Pierdomenico SD, Lapenna D, Bucci A, et al. Cardiovascular outcome in treated hypertensive patients with responder, masked, false resistant, and true resistant hypertension. Am J Hypertens. Nov. 2005;18(11):1422-8. KQ3bE5a, KQ3cE5a. [pmid: 16280275].
782 Pierdomenico SD, Lapenna D, Di MR, et al. Short- and long-term risk of cardiovascular events in white-coat hypertension. J Hum Hypertens. Jun. 2008;22(6):408-14. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 18288127].
783 Pierdomenico SD, Pannarale G, Rabbia F, et al. Prognostic relevance of masked hypertension in subjects with prehypertension. Am J Hypertens. Aug. 2008;21(8):879-83. KQ3aE4a, KQ3bE4, KQ3cE4. [pmid: 18464744].
784 Pierin AM, Alavarce DC, Gusmao JL, et al. Blood pressure measurement in obese patients: comparison between upper arm and forearm measurements. Blood Press Monit. Jun. 2004;9(3):101-5. KQ2aE9a, KQ2bE9a. [pmid: 15199302].
785 Pierin AM, Ignez EC, Jacob FW, et al. Blood pressure measurements taken by patients are similar to home and ambulatory blood pressure measurements. Clinics (Sao Paulo). Feb. 2008;63(1):43-50. KQ2aE9a, KQ2bE9a, KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 18297206].
786 Pimenta AM, Beunza JJ, Bes-Rastrollo M, et al. Work hours and incidence of hypertension among Spanish university graduates: the Seguimiento Universidad de Navarra prospective cohort. J Hypertens. Jan. 2009;27(1):34-40. KQ4aE4b, KQ4bE4b. [pmid: 19050449].
787 Pinar R, Ataalkin S, Watson R. The effect of clothes on sphygmomanometric blood pressure measurement in hypertensive patients. J Clin Nurs. Jul. 2010;19(13-14):1861-4. KQ2aE9, KQ2bE9. [pmid: 20920013].
788 Pincomb GA, Lovallo WR, McKey BS, et al. Acute blood pressure elevations with caffeine in men with borderline systemic hypertension. Am J Cardiol. 1996;77(4):270-4. KQ2aE3. [pmid: 8607407].
789 Pinto E, Bulpitt C, Beckett N, et al. Rationale and methodology of monitoring ambulatory blood pressure and arterial compliance in the Hypertension in the Very Elderly Trial. Blood Press Monit. Feb. 2006;11(1):3-8. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 16410734].
790 Pletcher MJ, Bibbins-Domingo K, Lewis CE, et al. Prehypertension during young adulthood and coronary calcium later in life. Ann Intern Med. Jul. 15. 2008;149(2):91-9. KQ4aE12, KQ4bE12. [pmid: 18626048].
791 Plichart M, Seux ML, Caillard L, et al. Home blood pressure measurement in elderly patients with cognitive impairment: comparison of agreement between relative-measured blood pressure and automated blood pressure measurement. Blood Press Monit. Aug. 2013;18(4):208-14. KQ3aE2, KQ3bE2, KQ3cE2. [pmid: 23797054].
792 Polk BF, Harlan LC, Cooper SP, et al. Disability days associated with detection and treatment in a hypertension control program. Am J Epidemiol. Jan. 1984;119(1):44-53. KQ5E10b. [pmid: 6691335].
793 Polonia JJ, Santos AR, Gama GM, et al. Follow-up clinic and ambulatory blood pressure in untreated white-coat hypertensive patients (evaluation after 2-5 years). Blood Press Monit. Dec. 1997;2(6):289-95. KQ4aE7e, KQ4bE7e. [pmid: 10388905].
794 Polonia JJ, Gama GM, Silva JA, et al. Sequential follow-up clinic and ambulatory blood pressure evaluation in a low risk population of white-coat hypertensive patients and in normotensives. Blood Press Monit. Apr. 2005;10(2):57-64. KQ3aE4, KQ3bE3, KQ3cE3, KQ4aE10a, KQ4bE10a. [pmid: 15812251].
795 Post WS, Larson MG, Levy D. Impact of left ventricular structure on the incidence of hypertension. The Framingham Heart Study. Circulation. Jul. 1994;90(1):179-85. KQ4aE4d, KQ4bE4d. [pmid: 8025994].
796 Post WS, Larson MG, Levy D. Hemodynamic predictors of incident hypertension. The Framingham Heart Study. Hypertension. 1994;24(5):585-90. KQ4aE6, KQ4bE6. [pmid: 7960017].
797 Powers BJ, Olsen MK, Smith VA, et al. Measuring blood pressure for decision making and quality reporting: where and how many measures?. Ann Intern Med. Jun. 21. 2011;154(12):781-8. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 21690592].
798 Prasad N, Wheeldon NM, MacDonald TM. Evaluating the use of a semiautomated cuff-oscillometric sphygmomanometer in the hypertension clinic. Br J Clin Pract. Nov. 1994;48(6):307-9. KQ2aE5a, KQ2bE5a. [pmid: 7848794].
799 Prasad N, Macfadyen RJ, Peebles L, et al. The white-coat response in ambulatory blood pressure monitoring: elimination and attenuation. Blood Press Monit. Dec. 1996;1(6):481-4. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 10226279].
800 Prisant LM, Resnick LM, Hollenberg SM. Assessment of sequential same arm agreement of blood pressure measurements by a CVProfilor DO-2020 versus a Baumanometer mercury sphygmomanometer. Blood Press Monit. Jun. 2001;6(3):149-52. KQ2aE4, KQ2bE3. [pmid: 11518838].
801 Qiao Q, Rajala U, Keinanen-Kiukaanniemi S. Hypertension, hyperinsulinaemia and obesity in middle-aged Finns with impaired glucose tolerance. J Hum Hypertens. Apr. 1998;12(4):265-9. KQ4aE7e, KQ4bE7e. [pmid: 9607697].
802 Quinones AR, Liang J, Ye W. Racial and ethnic differences in hypertension risk: new diagnoses after age 50. Ethn Dis. 2012;22(2):175-80. KQ4aE4b, KQ4bE4b. [pmid: 22764639].
803 Rabkin SW, Mathewson FA, Tate RB. Relationship of blood pressure in 20-39-year-old men to subsequent blood pressure and incidence of hypertension over a 30-year observation period. Circulation. Feb. 1982;65(2):291-300. KQ4aE10b, KQ4bE10b. [pmid: 7053886].
804 Radi S, Lang T, Lauwers-Cances V, et al. One-year hypertension incidence and its predictors in a working population: the IHPAF study. J Hum Hypertens. Jul. 2004;18(7):487-94. KQ3aE4, KQ3cE4. [pmid: 14961044].
805 Ragot S, Genes N, Vaur L, et al. Comparison of three blood pressure measurement methods for the evaluation of two antihypertensive drugs: feasibility, agreement, and reproducibility of blood pressure response. Am J Hypertens. Jun. 2000;13(6 Pt 1):632-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10912746].
806 Raikkonen K, Matthews KA, Kuller LH. Trajectory of psychological risk and incident hypertension in middle-aged women. Hypertension. Oct. 2001;38(4):798-802. KQ4aE7e, KQ4bE7e. [pmid: 11641289].
807 Rankinen T, Church TS, Rice T, et al. Cardiorespiratory fitness, BMI, and risk of hypertension: the HYPGENE study. Med Sci Sports Exerc. Oct. 2007;39(10):1687-92. KQ4aE12, KQ4bE12. [pmid: 17909393].
808 Rasmussen SL, Torp-Pedersen C, Borch-Johnsen K, et al. Normal values for ambulatory blood pressure and differences between casual blood pressure and ambulatory blood pressure: results from a Danish population survey. J Hypertens. Oct. 1998;16(10):1415-24. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9814611].
809 Rastam L, Ryden L. Work absenteeism and well-being in patients treated for hypertension. Eur Heart J. Sep. 1987;8(9):1024-31. KQ5E5a. [pmid: 3665953].
810 Reeves RA, Leenen FH, Joyner CD. Reproducibility of nurse-measured, exercise and ambulatory blood pressure and echocardiographic left ventricular mass in borderline hypertension. J Hypertens. Oct. 1992;10(10):1249-56. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1335008].
811 Reid CM, Ryan P, Miles H, et al. Who's really hypertensive?--Quality control issues in the assessment of blood pressure for randomized trials. Blood Press. 2005;14(3):133-8. KQ2aE3, KQ2bE3. [pmid: 16036492].
812 Reiff M, Schwartz S, Northridge M. Relationship of depressive symptoms to hypertension in a household survey in Harlem. Psychosom Med. Sep. 2001;63(5):711-21. KQ5E7a. [pmid: 11573017].
813 Reinprecht F, Elmstahl S, Janzon L, et al. Hypertension and changes of cognitive function in 81-year-old men: a 13-year follow-up of the population study "Men born in 1914", Sweden. J Hypertens. Jan. 2003;21(1):57-66. KQ4aE7e, KQ4bE7e. [pmid: 12544436].
814 Richey PA, Jones CL, Harshfield GA, et al. The AM5600 ambulatory blood pressure recording system. Blood Press Monit. Aug. 1997;2(4):193-5. KQ3aE13, KQ3bE13, KQ3cE13. [pmid: 10234116].
815 Ridderstrale W, Saluveer O, Johansson MC, et al. Consistency of blood pressure and impact on cardiovascular structure over 20 years in young men. J Intern Med. Mar. 2010;267(3):295-304. KQ4aE7e, KQ4bE7e. [pmid: 19572922].
816 Rihacek I, Frana P, Plachy M, et al. 24 hour ambulatory blood pressure values corresponding to office blood pressure value of 130/80 mm Hg. Kardiol Pol. 2013;71(7):675-80. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 23907899].
817 Rivas-Tumanyan S, Spiegelman D, Curhan GC, et al. Periodontal disease and incidence of hypertension in the health professionals follow-up study. Am J Hypertens. Jul. 2012;25(7):770-6. KQ4aE12, KQ4bE12. [pmid: 22476024].
818 Rogers MA, Buchan DA, Small D, et al. Telemedicine improves diagnosis of essential hypertension compared with usual care. J Telemed Telecare. 2002;8(6):344-9. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12537922].
819 Rosansky SJ, Menachery SJ, Johnson KL, et al. Nocturnal blood pressure measurement: can it be predicted by self-monitoring and is 24-hr BP monitoring clinically important in the treatment of hypertension. J S C Med Assoc. Jun. 1995;91(6):263-5. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 7630106].
820 Rose KM, Holme I, Light KC, et al. Association between the blood pressure response to a change in posture and the 6-year incidence of hypertension: prospective findings from the ARIC study. J Hum Hypertens. Nov. 2002;16(11):771-7. KQ4aE12, KQ4bE12. [pmid: 12444538].
821 Rosholm JU, Arnspang S, Matzen L, et al. Auscultatory versus oscillometric measurement of blood pressure in octogenarians. Blood Press. Oct. 2012;21(5):269-72. KQ2aE4, KQ2bE3. [pmid: 22545576].
822 Rotch AL, Dean JO, Kendrach MG, et al. Blood pressure monitoring with home monitors versus mercury sphygmomanometer. Ann Pharmacother. Jul. 2001;35(7-8):817-22. KQ2aE4, KQ2bE3, KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 11485126].
823 Roubsanthisuk W, Wongsurin U, Saravich S, et al. Blood pressure determination by traditionally trained personnel is less reliable and tends to underestimate the severity of moderate to severe hypertension. Blood Press Monit. Apr. 2007;12(2):61-8. KQ2aE9, KQ2bE9. [pmid: 17353647].
824 Rudd P, Price MG, Graham LE, et al. Consequences of worksite hypertension screening. Differential changes in psychosocial function. Am J Med. May. 1986;80(5):853-60. KQ5E10b. [pmid: 3706373].
825 Rutledge T, Linden W. Blood pressure determination by traditionally trained personnel is less reliable and tends to underestimate the severity of moderate to severe hypertension. J Hypertens. Feb. 2000;18(2):153-9. KQ4aE7e, KQ4bE7e. [pmid: 10694182].
826 Sabater-Hernandez D, de la Sierra A, Sanchez-Villegas P, et al. Agreement between community pharmacy and ambulatory and home blood pressure measurement methods to assess the effectiveness of antihypertensive treatment: the MEPAFAR study. J Clin Hypertens (Greenwich). Apr. 2012;14(4):236-44. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22458745].
827 Sackett DL, Haynes RB, Gibson ES, et al. Randomised clinical trial of strategies for improving medication compliance in primary hypertension. Lancet. May. 31. 1975;1(7918):1205-7. KQ5E4. [pmid: 48832].
828 Sagie A, Larson MG, Levy D. The natural history of borderline isolated systolic hypertension. N Engl J Med. Dec. 23. 1993;329(26):1912-7. KQ4aE12, KQ4bE12. [pmid: 8247055].
829 Saito I I, Murata K, Tsujioka M, et al. Long-term changes in clinic blood pressure in patients with white-coat hypertension. Blood Press Monit. Apr. 1998;3(2):97-100. KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 10212337].
830 Sakuma M, Imai Y, Nagai K, et al. Reproducibility of home blood pressure measurements over a 1-year period. Am J Hypertens. Jul. 1997;10(7 Pt 1):798-803. KQ3aE4, KQ3bE4, KQ3cE4, KQ4aE4, KQ4bE4. [pmid: 9234836].
831 Sakuma M, Imai Y, Tsuji I, et al. Predictive value of home blood pressure measurement in relation to stroke morbidity: a population-based pilot study in Ohasama, Japan. Hypertens Res. Sep. 1997;20(3):167-74. KQ3bE4, KQ3cE4. [pmid: 9328797].
832 Sala C, Santin E, Rescaldani M, et al. What is the accuracy of clinic blood pressure measurement?. Am J Hypertens. Feb. 2005;18(2 Pt 1):244-8. KQ2aE3, KQ2bE5a. [pmid: 15752953].
833 Sala C, Santin E, Rescaldani M, et al. How long shall the patient rest before clinic blood pressure measurement?. Am J Hypertens. Jul. 2006;19(7):713-7. KQ2aE3, KQ2bE5, KQ3aE4, KQ3bE4c, KQ3cE4. [pmid: 16814126].
834 Saladini F, Dorigatti F, Santonastaso M, et al. Natural history of hypertension subtypes in young and middle-age adults. Am J Hypertens. May. 2009;22(5):531-7. KQ3aE4, KQ3bE5, KQ3cE5, KQ4aE12, KQ4bE12. [pmid: 19229194].
835 Salles GF, Cardoso CR, Muxfeldt ES. Prognostic influence of office and ambulatory blood pressures in resistant hypertension. Arch Intern Med. Nov. 24. 2008;168(21):2340-6. KQ3aE5a, KQ3bE5a, KQ3cE5a. [pmid: 19029499].
836 Salomaa VV, Strandberg TE, Vanhanen H, et al. Glucose tolerance and blood pressure: long term follow up in middle aged men. BMJ. Mar. 2. 1991;302(6775):493-6. KQ4aE12, KQ4bE12. [pmid: 2012844].
837 Salonen JT, Lakka TA, Lakka HM, et al. Hyperinsulinemia is associated with the incidence of hypertension and dyslipidemia in middle-aged men. Diabetes. Feb. 1998;47(2):270-5. KQ4aE7e, KQ4bE7e. [pmid: 9519724].
838 Samsioe G, Lidfeldt J, Nerbrand C, et al. The women's health in the Lund area (WHILA) study--an overview. Maturitas. Jan. 2010;65(1):37-45. KQ4aE4, KQ4bE4. [pmid: 19962255].
839 Sandvik E, Steine S. White coat hypertension in a general practice. Prevalence, cardiovascular risk factors and clinical implications. Scand J Prim Health Care. Dec. 1998;16(4):222-6. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9932315].
840 Sapp B, Brown A, Kosseifi SG. Do no harm to the arm!: hypertension and unilateral hand rash. South Med J. Mar. 2007;100(3):335-6. KQ5E7. [pmid: 17402151].
841 Saremi A, Hanson RL, Tulloch-Reid M, et al. Alcohol consumption predicts hypertension but not diabetes. J Stud Alcohol. Mar. 2004;65(2):184-90. KQ4aE12, KQ4bE12. [pmid: 15151348].
842 Sarzynski MA, Rankinen T, Sternfeld B, et al. SNP-by-fitness and SNP-by-BMI interactions from seven candidate genes and incident hypertension after 20 years of follow-up: the CARDIA Fitness Study. J Hum Hypertens. Aug. 2011;25(8):509-18. KQ4aE12, KQ4bE12. [pmid: 20944660].
843 Sawada S, Tanaka H, Funakoshi M, et al. Five year prospective study on blood pressure and maximal oxygen uptake. Clin Exp Pharmacol Physiol. Jul. 1993;20(7-8):483-7. KQ4aE10b, KQ4bE10b. [pmid: 8403528].
844 Sbihi H, Davies HW, Demers PA. Hypertension in noise-exposed sawmill workers: a cohort study. Occup Environ Med. Sep. 2008;65(9):643-6. KQ4aE10b, KQ4bE10b. [pmid: 18178588].
845 Schell K, Bradley E, Bucher L, et al. Clinical comparison of automatic, noninvasive measurements of blood pressure in the forearm and upper arm. Am J Crit Care. May. 2005;14(3):232-41. KQ2aE6, KQ2bE6. [pmid: 15840897].
846 Scherpbier-de HN, van der Wel M, Schoenmakers G, et al. Thirty-minute compared to standardised office blood pressure measurement in general practice. Br J Gen Pract. Sep. 2011;61(590):e590-e597. KQ1E3, KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22152748].
847 Schillaci G, Verdecchia P, Zampi I, et al. Non-invasive ambulatory BP monitoring during the night: randomised comparison of different reading intervals. J Hum Hypertens. Jan. 1994;8(1):23-7. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8151602].
848 Schillaci G, Verdecchia P, Borgioni C, et al. Early cardiac changes after menopause. Hypertension. Oct. 1998;32(4):764-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 9774377].
849 Schroeder EB, Liao D, Chambless LE, et al. Hypertension, blood pressure, and heart rate variability: the Atherosclerosis Risk in Communities (ARIC) study. Hypertension. Dec. 2003;42(6):1106-11. KQ4aE12, KQ4bE12. [pmid: 14581296].
850 Schulze MB, Kroke A, Bergmann MM, et al. Differences of blood pressure estimates between consecutive measurements on one occasion: implications for inter-study comparability of epidemiologic studies. Eur J Epidemiol. 2000;16(10):891-8. KQ2aE3, KQ2bE4c. [pmid: 11338119].
851 Sebo P, Pechere-Bertschi A, Herrmann FR, et al. Blood pressure measurements are unreliable to diagnose hypertension in primary care. J Hypertens. Mar. 2014;32(3):509-17. KQ2aE3, KQ2bE10b. [pmid: 24299914].
852 Seccareccia F, Lanti M, Puddu PE, et al. Normotensive middle-aged men after 5-10 years: normal blood pressure or hypertension?. J Hypertens Suppl. Dec. 1988;6(4):S602-S604. KQ4aE7e, KQ4bE7e. [pmid: 3241261].
853 Sega R, Trocino G, Lanzarotti A, et al. Alterations of cardiac structure in patients with isolated office, ambulatory, or home hypertension: Data from the general population (Pressione Arteriose Monitorate E Loro Associazioni [PAMELA] Study). Circulation. Sep. 18. 2001;104(12):1385-92. KQ3aE4, KQ3bE5, KQ3cE5. [pmid: 11560854].
854 Sega R, Facchetti R, Bombelli M, et al. Prognostic value of ambulatory and home blood pressures compared with office blood pressure in the general population: follow-up results from the Pressioni Arteriose Monitorate e Loro Associazioni (PAMELA). Circulation. 2005;111(14):1777-83. KQ2aE4, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 15809377].
855 Segre CA, Ueno RK, Warde KR, et al. White-coat hypertension and normotension in the League of Hypertension of the Hospital das Clinicas, FMUSP: prevalence, clinical and demographic characteristics. Arq Bras Cardiol. Feb. 2003;80(2):117-26. KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 12640506].
856 Sehestedt T, Jeppesen J, Hansen TW, et al. Can ambulatory blood pressure measurements substitute assessment of subclinical cardiovascular damage?. J Hypertens. Mar. 2012;30(3):513-21. KQ3aE3, KQ3bE5c, KQ3cE5c. [pmid: 22241138].
857 Selassie A, Wagner CS, Laken ML, et al. Progression is accelerated from prehypertension to hypertension in blacks. Hypertension. Oct. 2011;58(4):579-87. KQ4aE5, KQ4bE5. [pmid: 21911708].
858 Selenta C, Hogan BE, Linden W. How often do office blood pressure measurements fail to identify true hypertension? An exploration of white-coat normotension. Arch Fam Med. Jun. 2000;9(6):533-40. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 10862216].
859 Sendra-Lillo J, Sabater-Hernandez D, Sendra-Ortola A, et al. Agreement between community pharmacy, physician's office, and home blood pressure measurement methods: the PALMERA Study. Am J Hypertens. Mar. 2012;25(3):290-6. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 22089107].
860 Sesso HD, Buring JE, Rifai N, et al. C-reactive protein and the risk of developing hypertension. JAMA. Dec. 10. 2003;290(22):2945-51. KQ4aE12, KQ4bE12. [pmid: 14665655].
861 Sesso HD, Buring JE, Chown MJ, et al. A prospective study of plasma lipid levels and hypertension in women. Arch Intern Med. Nov. 14. 2005;165(20):2420-7. KQ4aE12, KQ4bE12. [pmid: 16287773].
862 Sesso HD, Cook NR, Buring JE, et al. Alcohol consumption and the risk of hypertension in women and men. Hypertension. Apr. 2008;51(4):1080-7. KQ4aE12, KQ4bE12. [pmid: 18259032].
863 Seto S, Soda M, Nakashima E, et al. Longitudinal analysis of blood pressure trends and prognosis in isolated systolic hypertension in elderly individuals. Am J Hypertens. Feb. 2007;20(2):134-9. KQ4aE12, KQ4bE12. [pmid: 17261457].
864 Shahriari M, Rotenberg DK, Nielsen JK, et al. Measurement of arm blood pressure using different oscillometry manometers compared to auscultatory readings. Blood Press. 2003;12(3):155-9. KQ2aE4, KQ2bE3. [pmid: 12875477].
865 Shankar A, Klein BE, Klein R. Relationship between white blood cell count and incident hypertension. Am J Hypertens. Mar. 2004;17(3):233-9. KQ4aE12, KQ4bE12. [pmid: 15001197].
866 Shankar A, Klein R, Klein BE, et al. The association between serum uric acid level and long-term incidence of hypertension: Population-based cohort study. J Hum Hypertens. Dec. 2006;20(12):937-45. KQ4aE12, KQ4bE12. [pmid: 17024135].
867 Shankar A, Wang JJ, Rochtchina E, et al. Positive association between plasma fibrinogen level and incident hypertension among men: population-based cohort study. Hypertension. Dec. 2006;48(6):1043-9. KQ4aE7e, KQ4bE7e. [pmid: 17000922].
868 Shaw KC, McEniery CM, Wilkinson IB, et al. Unsafe health and safety: sphygmomanometer cuffs are not interchangeable. J Hum Hypertens. Jul. 2013;27(7):434-6. KQ2aE5a, KQ2bE5a. [pmid: 23172028].
869 Sheps SG, Bailey KR, Zachariah PK. Short-term (six hour), ambulatory blood pressure monitoring. J Hum Hypertens. Dec. 1994;8(12):873-8. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 7884784].
870 Shihab HM, Meoni LA, Chu AY, et al. Body mass index and risk of incident hypertension over the life course: the Johns Hopkins Precursors Study. Circulation. Dec. 18. 2012;126(25):2983-9. KQ4aE12, KQ4bE12. [pmid: 23151344].
871 Shimada K, Fujita T, Ito S, et al. The importance of home blood pressure measurement for preventing stroke and cardiovascular disease in hypertensive patients: a sub-analysis of the Japan Hypertension Evaluation with Angiotensin II Antagonist Losartan Therapy (J-HEALTH) study, a prospective nationwide observational study. Hypertens Res. Oct. 2008;31(10):1903-11. KQ3aE3, KQ3bE5a, KQ3cE5a. [pmid: 19015598].
872 Shimbo D, Kuruvilla S, Haas D, et al. Preventing misdiagnosis of ambulatory hypertension: algorithm using office and home blood pressures. J Hypertens. Sep. 2009;27(9):1775-83. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 19491703].
873 Shimbo D, Muntner P, Mann D, et al. Endothelial dysfunction and the risk of hypertension: the multi-ethnic study of atherosclerosis. Hypertension. May. 2010;55(5):1210-6. KQ3aE4, KQ3bE5c, KQ3cE5c, KQ4aE4d, KQ4bE4d. [pmid: 20308612].
874 Shimbo D, Newman JD, Schwartz JE. Masked hypertension and prehypertension: diagnostic overlap and interrelationships with left ventricular mass: the Masked Hypertension Study. Am J Hypertens. Jun. 2012;25(6):664-71. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 22378035].
875 Shinn EH, Poston WS, Kimball KT, et al. Blood pressure and symptoms of depression and anxiety: a prospective study. Am J Hypertens. Jul. 2001;14(7 Pt 1):660-4. KQ4aE7e, KQ4bE7e. [pmid: 11482304].
876 Shiue I. Knowing hypertension awareness and psychological distress in primary prevention. Hypertension. Dec. 2010;56(6):e173. KQ5E7. [pmid: 20956729].
877 Shono M, Kitano T, Futatsuka M. Risk estimation for hypertension based on follow-up health examination data in a small village in Kumamoto prefecture, Japan. Environ Health Prev Med. Jan. 1997;1(4):206-10. KQ4aE7e, KQ4bE7e. [pmid: 21432476].
878 Shook RP, Lee DC, Sui X, et al. Cardiorespiratory fitness reduces the risk of incident hypertension associated with a parental history of hypertension. Hypertension. Jun. 2012;59(6):1220-4. KQ4bE4d. [pmid: 22585947].
879 Shuger SL, Sui X, Church TS, et al. Body mass index as a predictor of hypertension incidence among initially healthy normotensive women. Am J Hypertens. Jun. 2008;21(6):613-9. KQ4aE12, KQ4bE12. [pmid: 18437123].
880 Silagy CA, McNeil JJ, Farish S, et al. Components of blood pressure variability in the elderly and effects on sample size calculations for clinical trials. Am J Hypertens. Jul. 1992;5(7):449-58. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1637517].
881 Silagy CA, McNeil JJ, Farish S, et al. Comparison of repeated measurement of ambulatory and clinic blood pressure readings in isolated systolic hypertension. Clin Exp Hypertens. Sep. 1993;15(5):895-909. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8401420].
882 Singer AJ, Hollander JE. Blood pressure. Assessment of interarm differences. Arch Intern Med. Sep. 23. 1996;156(17):2005-8. KQ2aE3, KQ2bE4. [pmid: 8823153].
883 Singh JP, Larson MG, Manolio TA, et al. Blood pressure response during treadmill testing as a risk factor for new-onset hypertension. The Framingham heart study. Circulation. Apr. 13. 1999;99(14):1831-6. KQ4aE12, KQ4bE12. [pmid: 10199879].
884 Skarfors ET, Lithell HO, Selinus I. Risk factors for the development of hypertension: a 10-year longitudinal study in middle-aged men. J Hypertens. Mar. 1991;9(3):217-23. KQ4aE12, KQ4bE12. [pmid: 1851784].
885 Slaby A, Josifko M. Does sequential automated measurement improve the estimate of resting blood pressure?. J Hum Hypertens. Feb. 1992;6(1):31-4. KQ2aE3, KQ2bE4. [pmid: 1583628].
886 Smith PM, Mustard CA, Lu H, et al. Comparing the risk associated with psychosocial work conditions and health behaviours on incident hypertension over a nine-year period in Ontario, Canada. Can J Public Health. Jan. 2013;104(1):e82-e86. KQ4aE12, KQ4bE12. [pmid: 23618123].
887 Smith W, Wang JJ, Wong TY, et al. Retinal arteriolar narrowing is associated with 5-year incident severe hypertension: the Blue Mountains Eye Study. Hypertension. Oct. 2004;44(4):442-7. KQ4aE10b, KQ4bE10b. [pmid: 15302843].
888 Smulders YM, Godfried MH, van Montfrans GA. Frequency of spontaneous fist clenching during routine blood pressure measurements and its effect on measurement accuracy. Blood Press Monit. Jun. 2002;7(3):145-7. KQ2aE3, KQ2bE4. [pmid: 12131070].
889 Snapir A, Heinonen P, Tuomainen TP, et al. G-protein beta3 subunit C825T polymorphism: no association with risk for hypertension and obesity. J Hypertens. Dec. 2001;19(12):2149-55. KQ4aE7e, KQ4bE7e. [pmid: 11725157].
890 Song HS, Jun TG, Choi EJ, et al. Accuracy comparison of blood pressure among the direct measurement method and two automatic indirect measurement methods in the patients with various blood pressure. J Korean Acad Fundam Nurs. 2001;8(3):366-78. PMID: None. KQ2aE8, KQ2bE8, KQ3aE8, KQ3bE8, KQ3cE8.
891 Song Y, Sesso HD, Manson JE, et al. Dietary magnesium intake and risk of incident hypertension among middle-aged and older US women in a 10-year follow-up study. Am J Cardiol. Dec. 15. 2006;98(12):1616-21. KQ4aE12, KQ4bE12. [pmid: 17145221].
892 Sossai P, Amenta F, Porcellati C. Observational study of hypertension in Matelica, Italy (Matelica hypertension study). Clin Exp Hypertens. Nov. 2007;29(8):531-7. KQ2aE3, KQ2bE3. [pmid: 18058478].
893 Souza WK, Jardim PC, Porto LB, et al. Comparison and correlation between self-measured blood pressure, casual blood pressure measurement and ambulatory blood pressure monitoring. Arq Bras Cardiol. Aug. 2011;97(2):148-55. KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 21691677].
894 Sparrow D, Thomas HE Jr, Rosner B, et al. The relationship of the baseline ECG to blood pressure change. JAMA. Sep. 9. 1983;250(10):1285-8. KQ4aE12, KQ4bE12. [pmid: 6224026].
895 Sparrow D, Tifft CP, Dibbs E, et al. The relationship of various indices of heart size on chest x-ray to the 10-year incidence of hypertension. The Normative Aging Study. Am J Epidemiol. Nov. 1985;122(5):782-8. KQ4aE7e, KQ4bE7e. [pmid: 2931974].
896 Sparrow D, Rosner B, Vokonas PS, et al. Relation of blood pressure measured in several positions to the subsequent development of systemic hypertension. The Normative Aging Study. Am J Cardiol. Feb. 1. 1986;57(4):218-21. KQ4aE12, KQ4bE12. [pmid: 3946211].
897 Sparrow D, Weiss ST, Vokonas PS, et al. Forced vital capacity and the risk of hypertension. The Normative Aging Study. Am J Epidemiol. Apr. 1988;127(4):734-41. KQ4aE12, KQ4bE12. [pmid: 3354540].
898 Spiro A III, Aldwin CM, Ward KD, et al. Personality and the incidence of hypertension among older men: longitudinal findings from the Normative Aging Study. Health Psychol. Nov. 1995;14(6):563-9. KQ4aE7e, KQ4bE7e. [pmid: 8565931].
899 Spruill TM, Gerber LM, Schwartz JE, et al. Race differences in the physical and psychological impact of hypertension labeling. Am J Hypertens. Apr. 2012;25(4):458-63. KQ5E7a. [pmid: 22258335].
900 Spruill TM, Feltheimer SD, Harlapur M, et al. Are there consequences of labeling patients with prehypertension? An experimental study of effects on blood pressure and quality of life. J Psychosom Res. May. 2013;74(5):433-8. KQ4aE7e, KQ4bE7e. [pmid: 23597332].
901 Staessen DE, Kuznetsova T. Comparing conventional with ambulatory blood pressure measurement for hypertension management. Cardiology Review. 1998;15:53-5. PMID: None. KQ3aE13, KQ3bE13, KQ3cE13.
902 Staessen JA, O'Brien ET, Atkins N, et al. Short report: ambulatory blood pressure in normotensive compared with hypertensive subjects. The Ad-Hoc Working Group. J Hypertens. Nov. 1993;11(11):1289-97. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 8301112].
903 Staessen JA, Thijs L, Clement D, et al. Ambulatory pressure decreases on long-term placebo treatment in older patients with isolated systolic hypertension. Syst-Eur Investigators. J Hypertens. 1994;12(9):1035-9. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 7852746].
904 Staessen JA, O'Brien ET, Amery AK, et al. Ambulatory blood pressure in normotensive and hypertensive subjects: results from an international database. J Hypertens Suppl. 1994;12(7):S1-12. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 7769499].
905 Staessen JA, O'Brien ET, Atkins N, et al. A consistent reference frame for ambulatory blood pressure monitoring is found in different populations. J Hum Hypertens. Jun. 1994;8(6):423-31. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8089827].
906 Staessen JA, Bieniaszewski L, O'Brien ET, et al. An epidemiological approach to ambulatory blood pressure monitoring:the Belgian Population Study. Blood Press Monit. Feb. 1996;1(1):13-26. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10226197].
907 Staessen JA, Fagard R, Thijs L, et al. Randomised double-blind comparison of placebo and active treatment for older patients with isolated systolic hypertension. The Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. Lancet. Sep. 13. 1997;350(9080):757-64. KQ3bE4, KQ3cE4. [pmid: 9297994].
908 Staessen JA, Thijs L, Fagard R, et al. Predicting cardiovascular risk using conventional vs ambulatory blood pressure in older patients with systolic hypertension. Systolic Hypertension in Europe Trial Investigators. JAMA. Aug. 11. 1999;282(6):539-46. KQ3bE4, KQ3cE4. [pmid: 10450715].
909 Staessen JA, Wang JG, Brand E, et al. Effects of three candidate genes on prevalence and incidence of hypertension in a Caucasian population. J Hypertens. Aug. 2001;19(8):1349-58. KQ4aE10b, KQ4bE10b. [pmid: 11518842].
910 Staessen JA, Celis H, Hond ED, et al. Comparison of conventional and automated blood pressure measurements: interim analysis of the THOP trial. Treatment of Hypertension According to Home or Office Blood Pressure. Blood Press Monit. Feb. 2002;7(1):61-2. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12040246].
911 Staessen JA, Thijs L, O'Brien ET, et al. Ambulatory pulse pressure as predictor of outcome in older patients with systolic hypertension. Am J Hypertens. Oct. 2002;15(10 Pt 1):835-43. KQ3bE4, KQ3cE4. [pmid: 12372669].
912 Staessen JA, Den HE, Celis H, et al. Antihypertensive treatment based on blood pressure measurement at home or in the physician's office: a randomized controlled trial. JAMA. Feb. 25. 2004;291(8):955-64. KQ3aE4, KQ3cE4. [pmid: 14982911].
913 Stahl CH, Novak M, Lappas G, et al. High-normal blood pressure and long-term risk of type 2 diabetes: 35-year prospective population based cohort study of men. BMC Cardiovasc Disord. 2012;12:89. KQ4aE4, KQ4bE4. [pmid: 23067205].
914 Stang A, Moebus S, Mohlenkamp S, et al. Algorithms for converting random-zero to automated oscillometric blood pressure values, and vice versa. [Erratum appears in Am J Epidemiol. 2007 Apr 1;165(7):848]. Am J Epidemiol. Jul. 1. 2006;164(1):85-94. KQ2aE6, KQ2bE3. [pmid: 16675536].
915 Starr JM, Inch S, Cross S, et al. Seven-year follow-up of blood pressure in the Healthy Old People in Edinburgh (HOPE) cohort. J Hum Hypertens. Dec. 2000;14(12):773-8. KQ4aE7e, KQ4bE7e. [pmid: 11114692].
916 Steffens AA, Moreira LB, Fuchs SC, et al. Incidence of hypertension by alcohol consumption: is it modified by race?. J Hypertens. Aug. 2006;24(8):1489-92. KQ4aE9a, KQ4bE9a. [pmid: 16877949].
917 Stein DJ, Aguilar-Gaxiola S, Alonso J, et al. Associations between mental disorders and subsequent onset of hypertension. Gen Hosp Psychiatry. 2013. Nov. 14. KQ4aE4b, KQ4bE4b. [pmid: 24342112].
918 Stenehjem AE, Os I. Incidence of hypertension by alcohol consumption: is it modified by race?. Blood Press. 2004;13(4):214-24. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 15581335].
919 Stepien M, Stepien A, Matusewicz W. Comparative analysis of ambulatory self-measurement of blood pressure and automatic ambulatory blood pressure monitoring. Acta Cardiol. Feb. 2002;57(1):74-5. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 11918165].
920 Stergiou GS, Malakos JS, Voutsa AV, et al. Home monitoring of blood pressure: limited value in general practice. J Hum Hypertens. Apr. 1996;10(4):219-23. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 8736452].
921 Stergiou GS, Voutsa AV, Achimastos AD, et al. Home self-monitoring of blood pressure: is fully automated oscillometric technique as good as conventional stethoscopic technique?. Am J Hypertens. Apr. 1997;10(4 Pt 1):428-33. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9128209].
922 Stergiou GS, Zourbaki AS, Skeva II, et al. White coat effect detected using self-monitoring of blood pressure at home: comparison with ambulatory blood pressure. Am J Hypertens. Jul. 1998;11(7):820-7. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 9683043].
923 Stergiou GS, Thomopoulou GC, Skeva II, et al. Home blood pressure normalcy: the Didima study. Am J Hypertens. Jun. 2000;13(6 Pt 1):678-85. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10912753].
924 Stergiou GS, Skeva II, Baibas NM, et al. Diagnosis of hypertension using home or ambulatory blood pressure monitoring: comparison with the conventional strategy based on repeated clinic blood pressure measurements. J Hypertens. Dec. 2000;18(12):1745-51. KQ2aE3, KQ2bE3, KQ3aE4. [pmid: 11132597].
925 Stergiou GS, Baibas NM, Gantzarou AP, et al. Reproducibility of home, ambulatory, and clinic blood pressure: implications for the design of trials for the assessment of antihypertensive drug efficacy. Am J Hypertens. Feb. 2002;15(2 Pt 1):101-4. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 11863243].
926 Stergiou GS, Efstathiou SP, Argyraki CK, et al. Clinic, home and ambulatory pulse pressure: comparison and reproducibility. J Hypertens. Oct. 2002;20(10):1987-93. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 12359977].
927 Stergiou GS, Efstathiou SP, Argyraki CK, et al. White coat effect in treated versus untreated hypertensive individuals: a case-control study using ambulatory and home blood pressure monitoring. Am J Hypertens. Feb. 2004;17(2):124-8. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 14751653].
928 Stergiou GS, Alamara CV, Skeva II, et al. Diagnostic value of strategy for the detection of white coat hypertension based on ambulatory and home blood pressure monitoring. J Hum Hypertens. Feb. 2004;18(2):85-9. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 14730322].
929 Stergiou GS, Salgami EV, Tzamouranis DG, et al. Masked hypertension assessed by ambulatory blood pressure versus home blood pressure monitoring: is it the same phenomenon?. Am J Hypertens. Jun. 2005;18(6):772-8. KQ3aE4, KQ3bE10b, KQ3cE10b. [pmid: 15925734].
930 Stergiou GS, Baibas NM, Kalogeropoulos PG. Cardiovascular risk prediction based on home blood pressure measurement: the Didima study. J Hypertens. Aug. 2007;25(8):1590-6. KQ2aE3, KQ2bE3, KQ3aE4a, KQ3bE5c, KQ3cE5c. [pmid: 17620954].
931 Stergiou GS, Lourida P, Tzamouranis D, et al. Unreliable oscillometric blood pressure measurement: prevalence, repeatability and characteristics of the phenomenon. J Hum Hypertens. Dec. 2009;23(12):794-800. KQ2aE5a, KQ2bE3. [pmid: 19322203].
932 Stergiou GS, Nasothimiou EG, Kalogeropoulos PG, et al. The optimal home blood pressure monitoring schedule based on the Didima outcome study. J Hum Hypertens. Mar. 2010;24(3):158-64. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 19587701].
933 Stergiou GS, Lourida P, Tzamouranis D. Replacing the mercury manometer with an oscillometric device in a hypertension clinic: implications for clinical decision making. J Hum Hypertens. Nov. 2011;25(11):692-8. KQ2aE5a, KQ2bE3, KQ3aE4, KQ3bE5a, KQ3cE4. [pmid: 21107434].
934 Stergiou GS, Nasothimiou EG, Destounis A, et al. Assessment of the diurnal blood pressure profile and detection of non-dippers based on home or ambulatory monitoring. Am J Hypertens. Sep. 2012;25(9):974-8. KQ3aE4, KQ3bE5, KQ3cE5, KQ5E5. [pmid: 22695508].
935 Stern SL, Dhanda R, Hazuda HP. Helplessness predicts the development of hypertension in older Mexican and European Americans. J Psychosom Res. Oct. 2009;67(4):333-7. KQ4aE7e, KQ4bE7e. [pmid: 19773026].
936 Stewart JC, France CR, Sheffield D. Hypertension awareness and pain reports: data from the NHANES III. Ann Behav Med. Aug. 2003;26(1):8-14. KQ5E7a. [pmid: 12867349].
937 Stolarz-Skrzypek K, Kuznetsova T, Thijs L, et al. Fatal and nonfatal outcomes, incidence of hypertension, and blood pressure changes in relation to urinary sodium excretion. JAMA. May. 4. 2011;305(17):1777-85. KQ4aE12, KQ4bE12. [pmid: 21540421].
938 Stolt M, Sjonell G, Astrom H, et al. Improved accuracy of indirect blood pressure measurement in patients with obese arms. Am J Hypertens. Jan. 1993;6(1):66-71. KQ2aE3, KQ2bE6. [pmid: 8427664].
939 Stolt M, Sjonell G, Astrom H, et al. Factors affecting the validity of the standard blood pressure cuff. Clin Physiol. Nov. 1993;13(6):611-20. KQ2aE5a, KQ2bE3. [pmid: 8119055].
940 Strand A, Gudmundsdottir H, Hoieggen A, et al. Increased hematocrit before blood pressure in men who develop hypertension over 20 years. J Am Soc Hypertens. Nov. 2007;1(6):400-6. KQ4aE7e, KQ4bE7e. [pmid: 20409872].
941 Strandberg TE, Salomaa V. White coat effect, blood pressure and mortality in men: prospective cohort study. Eur Heart J. Oct. 2000;21(20):1714-8. KQ2aE3, KQ2bE10b, KQ4aE7c, KQ4bE7c. [pmid: 11032699].
942 Stranges S, Trevisan M, Dorn JM, et al. Body fat distribution, liver enzymes, and risk of hypertension: evidence from the Western New York Study. Hypertension. Nov. 2005;46(5):1186-93. KQ4aE12, KQ4bE12. [pmid: 16203871].
943 Strazzullo P, Siani A, Cappuccio FP, et al. Red blood cell sodium-lithium countertransport and risk of future hypertension: the Olivetti Prospective Heart Study. Hypertension. Jun. 1998;31(6):1284-9. KQ4aE7e, KQ4bE7e. [pmid: 9622143].
944 Strazzullo P, Barba G, Vuotto P, et al. Past history of nephrolithiasis and incidence of hypertension in men: a reappraisal based on the results of the Olivetti Prospective Heart Study. Nephrol Dial Transplant. Nov. 2001;16(11):2232-5. KQ4aE7e, KQ4bE7e. [pmid: 11682673].
945 Stryker T, Wilson M, Wilson TW. Accuracy of home blood pressure readings: monitors and operators. Blood Press Monit. Jun. 2004;9(3):143-7. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 15199308].
946 Suka M, Yoshida K, Sugimori H. Persistent insomnia is a predictor of hypertension in Japanese male workers. J Occup Health. Nov. 2003;45(6):344-50. KQ4aE5, KQ4bE5. [pmid: 14676413].
947 Sundstrom J, Sullivan L, D'Agostino RB, et al. Plasma homocysteine, hypertension incidence, and blood pressure tracking: the Framingham Heart Study. Hypertension. Dec. 2003;42(6):1100-5. KQ4aE4d, KQ4bE4d. [pmid: 14597642].
948 Sundstrom J, Sullivan L, D'Agostino RB, et al. Relations of serum uric acid to longitudinal blood pressure tracking and hypertension incidence. Hypertension. Jan. 2005;45(1):28-33. KQ4aE4d, KQ4bE4d. [pmid: 15569852].
949 Svardsudd K, Wilhelmsen L. Change of blood pressure in relation to other variables and to development of hypertensive disease indices in a longitudinal population study. The study of men born in 1913. Eur Heart J. Oct. 1980;1(5):355-9. KQ4aE7e, KQ4bE7e. [pmid: 7274248].
950 Svardsudd K, Tibblin G. A longitudinal blood pressure study. Change of blood pressure during 10 yr in relation to initial values. The study of men born in 1913. J Chronic Dis. 1980;33(10):627-36. KQ4aE7e, KQ4bE7e. [pmid: 7410522].
951 Takahashi O, Glasziou PP, Perera R, et al. Blood pressure re-screening for healthy adults: what is the best measure and interval?. J Hum Hypertens. Sep. 2012;26(9):540-6. KQ4aE10a, KQ4bE10a. [pmid: 21814284].
952 Taleyarkhan PR, Geddes LA, Kemeny AE, et al. Loose cuff hypertension. Cardiovasc Eng. Sep. 2009;9(3):113-8. KQ2aE3, KQ2bE4. [pmid: 19662531].
953 Talleruphuus U, Bang LE, Wiinberg N, et al. Isolated systolic hypertension in an elderly Danish population. Prevalence and daytime ambulatory blood pressure. Blood Press. 2006;15(6):347-53. KQ2aE6, KQ2bE6, KQ3aE4, KQ3cE4. [pmid: 17472025].
954 Tamaki S, Nakamura Y, Yoshino T, et al. The association between morning hypertension and metabolic syndrome in hypertensive patients. Hypertens Res. Oct. 2006;29(10):783-8. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 17283865].
955 Tanabe P, Persell SD, Adams JG, et al. Increased blood pressure in the emergency department: pain, anxiety, or undiagnosed hypertension?. Ann Emerg Med. Mar. 2008;51(3):221-9. KQ3aE4, KQ5E7a. [pmid: 18207606].
956 Tanabe Y, Kawasaki R, Wang JJ, et al. Retinal arteriolar narrowing predicts 5-year risk of hypertension in Japanese people: the Funagata study. Microcirculation. Feb. 2010;17(2):94-102. KQ4aE7e, KQ4bE7e. [pmid: 20163536].
957 Tate RB, Manfreda J, Krahn AD, et al. Tracking of blood pressure over a 40-year period in the University of Manitoba Follow-up Study, 1948-1988. Am J Epidemiol. Nov. 1. 1995;142(9):946-54. KQ4aE4, KQ4bE4. [pmid: 7572975].
958 Taylor A, Thompson C. Decision aids reduced decisional conflict in patients with newly diagnosed hypertension. Evid Based Nurs. 2004;7(1):17. KQ5E7. [pmid: 14994690].
959 Taylor EN, Curhan GC, Forman JP. Parathyroid hormone and the risk of incident hypertension. J Hypertens. Jul. 2008;26(7):1390-4. KQ4aE7e, KQ4bE7e. [pmid: 18551015].
960 Terent A, Breig-Asberg E. Parathyroid hormone and the risk of incident hypertension. Blood Press. May. 1994;3(3):156-63. KQ2aE3, KQ2bE4. [pmid: 8069403].
961 Thadhani R, Camargo CA Jr, Stampfer MJ, et al. Prospective study of moderate alcohol consumption and risk of hypertension in young women. Arch Intern Med. Mar. 11. 2002;162(5):569-74. KQ4aE12, KQ4bE12. [pmid: 11871925].
962 Thalenberg JM, Povoa RM, Bombig MT, et al. Slow breathing test increases the suspicion of white-coat hypertension in the office. Arq Bras Cardiol. 2008;91(4):243-9. KQ2aE9a, KQ2bE9a, KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 19009177].
963 Thalenberg JM, Luna FB, Bombig MT, et al. Is there a need to redo many of the diagnoses of hypertension?. Sao Paulo Med J. 2012;130(3):173-8. KQ2aE9a, KQ2bE9a, KQ3aE9a, KQ3bE9a, KQ3cE9a. [pmid: 22790550].
964 Theodorou M, Kaitelidou D, Galanis P, et al. Quality of life measurement in patients with hypertension in Cyprus. Hellenic J Cardiol. Sep. 2011;52(5):407-15. KQ5E1. [pmid: 21940288].
965 Thijs L, Amery A, Clement D, et al. Ambulatory blood pressure monitoring in elderly patients with isolated systolic hypertension. J Hypertens. Jul. 1992;10(7):693-9. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1321198].
966 Thijs L, Staessen J, Fagard R, et al. Number of measurements required for the analysis of diurnal blood pressure profile. J Hum Hypertens. Apr. 1994;8(4):239-44. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 8021903].
967 Thijs L, Celis H, Clement D, et al. Conventional and ambulatory blood pressure measurement in older patients with isolated systolic hypertension:second progress report on the ambulatory blood pressure monitoring project in the Syst-Eur trial. Blood Press Monit. Apr. 1996;1(2):95-103. KQ3aE4, KQ3bE10b, KQ3cE10b. [pmid: 10226209].
968 Thijs L, Staessen JA, Celis H, et al. Reference values for self-recorded blood pressure: a meta-analysis of summary data. Arch Intern Med. Mar. 9. 1998;158(5):481-8. KQ3aE4, KQ3bE7, KQ3cE7. [pmid: 9508226].
969 Thijs L, Staessen JA, Celis H, et al. The international database of self-recorded blood pressures in normotensive and untreated hypertensive subjects. Blood Press Monit. Apr. 1999;4(2):77-86. KQ3aE4, KQ3bE5c, KQ3cE5c, KQ4aE4, KQ4bE4. [pmid: 10450117].
970 Thijs L, Hansen TW, Kikuya M, et al. The International Database of Ambulatory blood pressure in relation to Cardiovascular Outcome (IDACO): protocol and research perspectives. Blood Press Monit. Aug. 2007;12(4):255-62. KQ3aE6, KQ3bE5a, KQ3cE5a, KQ4aE4, KQ4bE4. [pmid: 17760218].
971 Thomas CB, Duszynski KR. Blood pressure levels in young adulthood as predictors of hypertension and the fate of the cold pressor test. Johns Hopkins Med J. Sep. 1982;151(3):93-100. KQ4aE4b, KQ4bE4b. [pmid: 7109420].
972 Thomas J, Semenya KA, Neser WB, et al. Risk factors and the incidence of hypertension in black physicians: the Meharry Cohort Study. Am Heart J. Sep. 1985;110(3):637-45. KQ4aE7e, KQ4bE7e. [pmid: 4036789].
973 Thomas J, Neser WB, Knuckles B, et al. Failure of the cold pressor test to predict hypertension in black physicians: the Meharry Cohort Study. J Natl Med Assoc. Nov. 1988;80(11):1185-8. KQ4aE7e, KQ4bE7e. [pmid: 3249323].
974 Thomas J, Semenya K, Neser WB, et al. Parental hypertension as a predictor of hypertension in black physicians: the Meharry Cohort Study. J Natl Med Assoc. Jun. 1990;82(6):409-12. KQ4aE7e, KQ4bE7e. [pmid: 2362297].
975 Thomas RJ, Liu K, Jacobs DR Jr, et al. Positional change in blood pressure and 8-year risk of hypertension: the CARDIA Study. Mayo Clin Proc. Aug. 2003;78(8):951-8. KQ4aE4d, KQ4bE4d. [pmid: 12911043].
976 Thomopoulos C, Tsioufis C, Makris T, et al. Free leptin predicts incident (clinic) hypertension in a Danish cohort. Am J Hypertens. Aug. 2010;23(8):814. KQ4aE7, KQ4bE7. [pmid: 20644526].
977 Tielemans SM, Geleijnse JM, van Baak MA, et al. Twenty-four hour urinary urea excretion and 9-year risk of hypertension: the PREVEND study. J Hypertens. Aug. 2013;31(8):1564-9. KQ4aE12, KQ4bE12. [pmid: 23751964].
978 Tobias DK, Hu FB, Forman JP, et al. Increased risk of hypertension after gestational diabetes mellitus: findings from a large prospective cohort study. Diabetes Care. Jul. 2011;34(7):1582-4. KQ4aE12, KQ4bE12. [pmid: 21593289].
979 Toledo E, Beunza JJ, Nunez-Cordoba JM, et al. Metabolic risk factors in a cohort of young adults and their association with a body-mass index between 22 and 25 kg/m2. Med Clin (Barc). May. 9. 2009;132(17):654-60. KQ4aE4b, KQ4bE4b. [pmid: 19395040].
980 Toledo E, de AC-T, Alonso A, et al. Hypothesis-oriented food patterns and incidence of hypertension: 6-year follow-up of the SUN (Seguimiento Universidad de Navarra) prospective cohort. Public Health Nutr. Mar. 2010;13(3):338-49. KQ4aE4b, KQ4bE4b. [pmid: 19656442].
981 Tomiyama H, Matsumoto C, Yamada J, et al. Predictors of progression from prehypertension to hypertension in Japanese men. Am J Hypertens. Jun. 2009;22(6):630-6. KQ4aE7e, KQ4bE7e. [pmid: 19265783].
982 Toyama H, Hasegawa Y, Ejima Y, et al. Characteristics of young-onset white coat hypertension identified by targeted screening for hypertension at a university health check-up. Hypertens Res. Jun. 2008;31(6):1063-8. KQ3aE4, KQ3cE4, KQ4aE4, KQ4bE4. [pmid: 18716352].
983 Trembath CR, Hickner JM, Bishop SW. Incidental blood pressure elevations: a MIRNET project. J Fam Pract. Apr. 1991;32(4):378-81. KQ3aE4, KQ3bE10b, KQ3cE10b, KQ4aE5, KQ4bE5. [pmid: 2010735].
984 Trudel X, Brisson C, Larocque B, et al. Masked hypertension: different blood pressure measurement methodology and risk factors in a working population. J Hypertens. Aug. 2009;27(8):1560-7. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 19444141].
985 Tsai PS. Determinants of the white-coat effect in normotensives and never-treated mild hypertensives. Clin Exp Hypertens. Oct. 2003;25(7):443-54. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 14596368].
986 Tsuji I, Imai Y, Nagai K, et al. Proposal of reference values for home blood pressure measurement: prognostic criteria based on a prospective observation of the general population in Ohasama, Japan. Am J Hypertens. Apr. 1997;10(4 Pt 1):409-18. KQ3bE4, KQ3cE4. [pmid: 9128207].
987 Tsumura K, Hayashi T, Hamada C, et al. Blood pressure response after two-step exercise as a powerful predictor of hypertension: the Osaka Health Survey. J Hypertens. Aug. 2002;20(8):1507-12. KQ4aE12, KQ4bE12. [pmid: 12172311].
988 Tsuruta M, Hashimoto R, Adachi H, et al. Hyperinsulinaemia as a predictor of hypertension: an 11-year follow-up study in Japan. J Hypertens. Apr. 1996;14(4):483-8. KQ4aE7e, KQ4bE7e. [pmid: 8761898].
989 Tsuruta M, Adachi H, Hirai Y, et al. Association between alcohol intake and development of hypertension in Japanese normotensive men: 12-year follow-up study. Am J Hypertens. May. 2000;13(5 Pt 1):482-7. KQ4aE7e, KQ4bE7e. [pmid: 10826398].
990 Tu K, Chen Z, Lipscombe LL, et al. Prevalence and incidence of hypertension from 1995 to 2005: a population-based study. CMAJ. May. 20. 2008;178(11):1429-35. KQ4aE4b, KQ4bE4b. [pmid: 18490638].
991 Turner MJ, Irwig L, Bune AJ, et al. Lack of sphygmomanometer calibration causes over- and under-detection of hypertension: a computer simulation study. J Hypertens. Oct. 2006;24(10):1931-8. KQ2aE3, KQ2bE7, KQ3aE4, KQ3bE7, KQ3cE7. [pmid: 16957551].
992 Ugajin T, Hozawa A, Ohkubo T, et al. White-coat hypertension as a risk factor for the development of home hypertension: the Ohasama study. Arch Intern Med. Jul. 11. 2005;165(13):1541-6. KQ3aE4, KQ3bE5c, KQ3cE5c, KQ4aE12, KQ4bE12. [pmid: 16009871].
993 Uhernik AI, Vuletic S, Kern J, et al. The Croatian Adult Health Cohort Study (CroHort) --background, methodology & perspectives. Coll Antropol. Jan. Suppl 1. 2012;36:3-7. KQ4aE10b, KQ4bE10b. [pmid: 22338740].
994 Uhernik AI, Erceg M, Milanovic SM. Association of hypertension with long-term overweight status and weight gain: the CroHort study. Coll Antropol. Jan. 2012;36(Suppl 1):131-4. KQ4aE4d, KQ4bE4d. [pmid: 22338761].
995 Uiterwaal CS, Verschuren WM, Bueno-de-Mesquita HB, et al. Coffee intake and incidence of hypertension. Am J Clin Nutr. Mar. 2007;85(3):718-23. KQ4aE12, KQ4bE12. [pmid: 17344492].
996 Umscheid CA, Maguire MG, Pines JM, et al. Untreated hypertension and the emergency department: a chance to intervene?. Acad Emerg Med. Jun. 2008;15(6):529-36. KQ1E7, KQ2aE7, KQ2bE7. [pmid: 18616438].
997 Ungar A, Pepe G, Monami M, et al. Isolated ambulatory hypertension is common in outpatients referred to a hypertension centre. J Hum Hypertens. Dec. 2004;18(12):897-903. KQ2aE3, KQ2bE3, KQ3aE4, KQ3cE4. [pmid: 15241442].
998 Vaccaro O, Imperatore G, Iovino V, et al. Does impaired glucose tolerance predict hypertension? A prospective analysis. Diabetologia. Jan. 1996;39(1):70-6. KQ4aE7e, KQ4bE7e. [pmid: 8720605].
999 Vaillant GE, Gerber PD. Natural history of male psychological health, XIII: Who develops high blood pressure and who responds to treatment. Am J Psychiatry. Jul. 1996;153(7 Suppl):24-9. KQ4aE7e, KQ4bE7e. [pmid: 8659638].
1000 Van Beresteijn EC, Riedstra M, van der Wel A, et al. Habitual dietary calcium intake and blood pressure change around the menopause: a longitudinal study. Int J Epidemiol. Aug. 1992;21(4):683-9. KQ4aE7e, KQ4bE7e. [pmid: 1521971].
1001 van Boxtel MP, Gaillard C, van Es PN, et al. Repeated automatic versus ambulatory blood pressure measurement: the effects of age and sex in a normal ageing population. J Hypertens. Jan. 1996;14(1):31-40. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12013492].
1002 van de Weijgert EJ, Braun JJ. Experience with noninvasive ambulatory 24-hour blood pressure recording in a community hospital. Neth J Med. Apr. 1992;40(3-4):175-82. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 1603208].
1003 van der Steen MS, Lenders JW, Graafsma SJ, et al. Reproducibility of ambulatory blood pressure monitoring in daily practice. J Hum Hypertens. May. 1999;13(5):303-8. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10376847].
1004 van der Steen MS, Pleijers AM, Lenders JW, et al. Influence of different supine body positions on blood pressure: consequences for night blood pressure/dipper-status. J Hypertens. Dec. 2000;18(12):1731-6. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 11132595].
1005 van der Wel MC, Buunk IE, van WC, et al. A novel approach to office blood pressure measurement: 30-minute office blood pressure vs daytime ambulatory blood pressure. Ann Fam Med. Mar. 2011;9(2):128-35. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 21403139].
1006 van Popele NM, Bos WJ, de Beer NA, et al. Arterial stiffness as underlying mechanism of disagreement between an oscillometric blood pressure monitor and a sphygmomanometer. Hypertension. Oct. 2000;36(4):484-8. KQ2aE4, KQ2bE3. [pmid: 11040223].
1007 Vasan RS, Evans JC, Larson MG, et al. Serum aldosterone and the incidence of hypertension in nonhypertensive persons. N Engl J Med. Jul. 1. 2004;351(1):33-41. KQ4aE4d, KQ4bE4d. [pmid: 15229305].
1008 Vazquez-Rodriguez B, Pita-Fernandez S, Regueiro-Lopez M, et al. Concordance between automatic and manual recording of blood pressure depending on the absence or presence of atrial fibrillation. Am J Hypertens. Oct. 2010;23(10):1089-94. KQ2aE2, KQ2bE2. [pmid: 20596036].
1009 Veerman DP, van Montfrans GA. Nurse-measured or ambulatory blood pressure in routine hypertension care. J Hypertens. Mar. 1993;11(3):287-92. KQ2aE3, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 8387086].
1010 Vera-Cala LM, Orostegui M, Valencia-Angel LI, et al. Accuracy of the Omron HEM-705 CP for blood pressure measurement in large epidemiologic studies. Arq Bras Cardiol. May. 2011;96(5):393-8. KQ2aE9, KQ2bE9. [pmid: 21468531].
1011 Verberk WJ, Kroon AA, Kessels AGH, et al. The optimal scheme of self blood pressure measurement as determined from ambulatory blood pressure recordings. J Hypertens. Aug. 2006;24(8):1541-8. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 16877956].
1012 Verdecchia P, Schillaci G, Boldrini F, et al. Variability between current definitions of 'normal' ambulatory blood pressure. Implications in the assessment of white coat hypertension. Hypertension. Oct. 1992;20(4):555-62. KQ3aE4. [pmid: 1398890].
1013 Verdecchia P, Schillaci G, Borgioni C, et al. White coat hypertension and white coat effect. Similarities and differences. Am J Hypertens. Aug. 1995;8(8):790-8. KQ3aE4. [pmid: 7576395].
1014 Verdecchia P, Schillaci G, Borgioni C, et al. Identification of subjects with white-coat hypertension and persistently normal ambulatory blood pressure. Blood Press Monit. Jun. 1996;1(3):217-22. KQ3aE4, KQ3bE3, KQ3cE3, KQ4aE7e, KQ4bE7e. [pmid: 10226230].
1015 Verdecchia P, Schillaci G, Borgioni C, et al. Prognostic significance of the white coat effect. Hypertension. Jun. 1997;29(6):1218-24. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 9180621].
1016 Verdecchia P, Palatini P, Schillaci G, et al. Independent predictors of isolated clinic ('white-coat') hypertension. J Hypertens. Jun. 2001;19(6):1015-20. KQ3aE4, KQ3bE6, KQ3cE6. [pmid: 11403348].
1017 Verdecchia P, Schillaci G, Reboldi G, et al. Different prognostic impact of 24-hour mean blood pressure and pulse pressure on stroke and coronary artery disease in essential hypertension. Circulation. May. 29. 2001;103(21):2579-84. KQ3bE4, KQ3cE4. [pmid: 11382727].
1018 Verdecchia P, Schillaci G, Reboldi G, et al. Ambulatory monitoring for prediction of cardiac and cerebral events. Blood Press Monit. Aug. 2001;6(4):211-5. KQ3aE10b, KQ3bE4, KQ3cE4. [pmid: 11805472].
1019 Verdecchia P, Reboldi G, Porcellati C, et al. Risk of cardiovascular disease in relation to achieved office and ambulatory blood pressure control in treated hypertensive subjects. J Am Coll Cardiol. Mar. 6. 2002;39(5):878-85. KQ3aE4a, KQ3bE4, KQ3cE4. [pmid: 11869856].
1020 Verdecchia P, Reboldi GP, Angeli F, et al. Short- and long-term incidence of stroke in white-coat hypertension. Hypertension. Feb. 2005;45(2):203-8. KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 15596572].
1021 Verdecchia P, Angeli F, Gattobigio R, et al. Regression of left ventricular hypertrophy and prevention of stroke in hypertensive subjects. Am J Hypertens. May. 2006;19(5):493-9. KQ3aE3, KQ3bE4d, KQ3cE4. [pmid: 16647622].
1022 Verdecchia P, Angeli F, Borgioni C, et al. Ambulatory blood pressure and cardiovascular outcome in relation to perceived sleep deprivation. Hypertension. Apr. 2007;49(4):777-83. KQ3aE3, KQ3bE4, KQ3cE4. [pmid: 17261645].
1023 Verdecchia P, Angeli F, Borgioni C, et al. Prognostic value of circadian blood pressure changes in relation to differing measures of day and night. J Am Soc Hypertens. Mar. 2008;2(2):88-96. KQ3aE3, KQ3bE5a, KQ3cE5a. [pmid: 20409890].
1024 Viera AJ, Hinderliter AL, Kshirsagar AV, et al. Reproducibility of masked hypertension in adults with untreated borderline office blood pressure: comparison of ambulatory and home monitoring. Am J Hypertens. Nov. 2010;23(11):1190-7. KQ3aE4, KQ3bE7f, KQ3cE7f. [pmid: 20671718].
1025 Vijayaraghavan M, Kushel MB, Vittinghoff E, et al. Housing instability and incident hypertension in the CARDIA cohort. J Urban Health. Jun. 2013;90(3):427-41. KQ4aE12, KQ4bE12. [pmid: 22752301].
1026 Vinyoles E, Blancafort X, Lopez-Quinones C, et al. Blood pressure measurement in an ambulatory setting: concordance between physician and patient self-measurement. J Hum Hypertens. Jan. 2003;17(1):45-50. KQ2aE5a, KQ2bE5a, KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 12571616].
1027 Vinyoles E, Felip A, Pujol E, et al. Clinical characteristics of isolated clinic hypertension. J Hypertens. Mar. 2008;26(3):438-45. KQ3aE4, KQ3bE10b, KQ3cE10b. [pmid: 18300853].
1028 Vinyoles E, Rodriguez-Blanco T, de la Sierra A, et al. Isolated clinic hypertension: diagnostic criteria based on 24-h blood pressure definition. J Hypertens. Dec. 2010;28(12):2407-13. KQ2aE3, KQ2bE3, KQ3aE4, KQ3bE10b, KQ3cE4. [pmid: 20852448].
1029 Vollmer WM, Appel LJ, Svetkey LP, et al. Comparing office-based and ambulatory blood pressure monitoring in clinical trials. J Hum Hypertens. Jan. 2005;19(1):77-82. KQ3aE1, KQ3bE1, KQ3cE1. [pmid: 15361888].
1030 Volzke H, Ittermann T, Schmidt CO, et al. Subclinical hyperthyroidism and blood pressure in a population-based prospective cohort study. Eur J Endocrinol. Oct. 2009;161(4):615-21. KQ4aE4d, KQ4bE4d. [pmid: 19581285].
1031 Vreugdenhil G, Schrey G, de Leeuw PW. Comparison of office and serial automatic blood pressure readings in renovascular and essential hypertension. J Hum Hypertens. Jun. 1992;6(3):189-91. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1629887].
1032 Wagenknecht LE, Mayer EJ, Rewers M, et al. The insulin resistance atherosclerosis study (IRAS) objectives, design, and recruitment results. Ann Epidemiol. Nov. 1995;5(6):464-72. KQ4aE5a, KQ4bE5a. [pmid: 8680609].
1033 Waitzman NJ, Smith KR. The effects of occupational class transitions on hypertension: racial disparities among working-age men. Am J Public Health. Jun. 1994;84(6):945-50. KQ4aE12, KQ4bE12. [pmid: 8203691].
1034 Walsh CR, Larson MG, Vasan RS, et al. Serum potassium is not associated with blood pressure tracking in the Framingham Heart Study. Am J Hypertens. Feb. 2002;15(2 Pt 1):136. KQ4aE4d, KQ4bE4d. [pmid: 11863248].
1035 Walworth CC, Charman RC. Industrial hypertension program in a rural state. Efficacy and cost effectiveness. JAMA. May. 2. 1977;237(18):1942-5. KQ4aE7e, KQ4bE7e. [pmid: 403306].
1036 Wang L, Manson JE, Buring JE, et al. Dietary intake of dairy products, calcium, and vitamin D and the risk of hypertension in middle-aged and older women. Hypertension. Apr. 2008;51(4):1073-9. KQ4aE12, KQ4bE12. [pmid: 18259007].
1037 Wang L, Szklo M, Folsom AR, et al. Endogenous sex hormones, blood pressure change, and risk of hypertnesion in postmenopausal women: the Multi-Ethnic Study of Atherosclerosis. Atherosclerosis. Sep. 2012;224(1):228-34. KQ4aE7e, KQ4bE7e. [pmid: 22862963].
1038 Wang TJ, Evans JC, Meigs JB, et al. Low-grade albuminuria and the risks of hypertension and blood pressure progression. Circulation. Mar. 22. 2005;111(11):1370-6. KQ4aE4d, KQ4bE4d. [pmid: 15738353].
1039 Wang TJ, Gona P, Larson MG, et al. Multiple biomarkers and the risk of incident hypertension. Hypertension. Mar. 2007;49(3):432-8. KQ4aE4d, KQ4bE4d. [pmid: 17242302].
1040 Wang W, Lee ET, Fabsitz RR, et al. A longitudinal study of hypertension risk factors and their relation to cardiovascular disease: the Strong Heart Study. Hypertension. Mar. 2006;47(3):403-9. KQ4aE10b, KQ4bE10b. [pmid: 16432042].
1041 Wang X, Poole JC, Treiber FA, et al. Ethnic and gender differences in ambulatory blood pressure trajectories: results from a 15-year longitudinal study in youth and young adults. Circulation. Dec. 19. 2006;114(25):2780-7. KQ4aE4, KQ4bE4. [pmid: 17130344].
1042 Warren RE, Marshall T, Padfield PL, et al. Variability of office, 24-hour ambulatory, and self-monitored blood pressure measurements. Br J Gen Pract. Sep. 2010;60(578):675-80. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 20849695].
1043 Watanabe Y, Metoki H, Ohkubo T, et al. Accumulation of common polymorphisms is associated with development of hypertension: a 12-year follow-up from the Ohasama study. Hypertens Res. Feb. 2010;33(2):129-34. KQ4aE7e, KQ4bE7e. [pmid: 19927152].
1044 Weber MA, Neutel JM, Smith DH, et al. Diagnosis of mild hypertension by ambulatory blood pressure monitoring. Circulation. Nov. 1994;90(5):2291-8. KQ3aE4, KQ3bE10b, KQ3cE4. [pmid: 7955186].
1045 Weel C, Bakx C, Hoogen H, et al. Long-term outcome of cardiovascular prevention: A Nijmegen Academic Family Practices Network study. J Am Board Fam Med. 2006;19(1):62-8. KQ4aE12, KQ4bE12. [pmid: 16492007].
1046 Weiner RB, Wang F, Isaacs SK, et al. Blood pressure and left ventricular hypertrophy during american-style football participation. Circulation. Jul. 30. 2013;128(5):524-31. KQ4aE7e, KQ4bE7e. [pmid: 23897848].
1047 Weisser B, Grune S, Burger R, et al. The Dubendorf Study: a population-based investigation on normal values of blood pressure self-measurement. J Hum Hypertens. Apr. 1994;8(4):227-31. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 8021901].
1048 Wendelin-Saarenhovi M, Isoaho R, Hartiala J, et al. Long-term reproducibility of ambulatory blood pressure in unselected elderly subjects. Clin Physiol. May. 2001;21(3):316-22. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 11380531].
1049 Wessel SE, van der Hoeven NV, Cammenga M, et al. 'Diagnostic mode' improves adherence to the home blood pressure measurement schedule. Blood Press Monit. Oct. 2012;17(5):214-9. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 22850440].
1050 Westhoff TH, Straub-Hohenbleicher H, Schmidt S, et al. Convenience of ambulatory blood pressure monitoring: comparison of different devices. Blood Press Monit. Oct. 2005;10(5):239-42. KQ5E5. [pmid: 16205441].
1051 Whincup PH, Bruce NG, Cook DG, et al. The Dinamap 1846SX automated blood pressure recorder: comparison with the Hawksley random zero sphygmomanometer under field conditions. J Epidemiol Community Health. Apr. 1992;46(2):164-9. KQ2aE4, KQ2bE3. [pmid: 1583434].
1052 Widener J, Yang C, Costello P, et al. Modifications to standard guidelines and changes in blood pressure readings: use of an automatic blood pressure device. AAOHN J. Mar. 1999;47(3):107-13. KQ2aE3, KQ2bE4. [pmid: 10347396].
1053 Wiinberg N, Raymond IE, Bang LE, et al. A comparison between the oscillometric and the auscultatory method for ambulatory 24 h blood pressure monitoring. Blood Press Monit. Jun. 1996;1(3):187-91. KQ2aE6, KQ2bE6, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 10226224].
1054 Wildman RP, Sutton-Tyrrell K, Newman AB, et al. Lipoprotein levels are associated with incident hypertension in older adults. J Am Geriatr Soc. Jun. 2004;52(6):916-21. KQ4aE7e, KQ4bE7e. [pmid: 15161455].
1055 Williams PT. Vigorous exercise, fitness and incident hypertension, high cholesterol, and diabetes. Med Sci Sports Exerc. Jun. 2008;40(6):998-1006. KQ4aE12, KQ4bE12. [pmid: 18461008].
1056 Williams PT. Increases in weight and body size increase the odds for hypertension during 7 years of follow-up. Obesity (Silver Spring). Nov. 2008;16(11):2541-8. KQ4aE12, KQ4bE12. [pmid: 18756262].
1057 Williams PT. A cohort study of incident hypertension in relation to changes in vigorous physical activity in men and women. J Hypertens. Jun. 2008;26(6):1085-93. KQ4aE12, KQ4bE12. [pmid: 18475145].
1058 Williams PT, Thompson PD. Walking versus running for hypertension, cholesterol, and diabetes mellitus risk reduction. Arterioscler Thromb Vasc Biol. May. 2013;33(5):1085-91. KQ4aE12, KQ4bE12. [pmid: 23559628].
1059 Winegarden CR. From "prehypertension" to hypertension? Additional evidence. Ann Epidemiol. Oct. 2005;15(9):720-5. KQ4aE12, KQ4bE12. [pmid: 15921930].
1060 Wingfield D, Grodzicki T, Palmer AJ, et al. Transiently elevated diastolic blood pressure is associated with a gender-dependent effect on cardiovascular risk. J Hum Hypertens. May. 2005;19(5):347-54. KQ4aE12, KQ4bE12. [pmid: 15744334].
1061 Winkelmayer WC, Stampfer MJ, Willett WC, et al. Habitual caffeine intake and the risk of hypertension in women. JAMA. Nov. 9. 2005;294(18):2330-5. KQ4aE12, KQ4bE12. [pmid: 16278361].
1062 Winnicki M, Somers VK, Dorigatti F, et al. Lifestyle, family history and progression of hypertension. J Hypertens. Aug. 2006;24(8):1479-87. KQ4aE5b, KQ4bE5b. [pmid: 16877948].
1063 Witmer JM, Hensel MR, Holck PS, et al. Heart disease prevention for Alaska Native women: a review of pilot study findings. J Womens Health (Larchmt). 2004;13(5):569-78. KQ4aE4, KQ4bE4. [pmid: 15257848].
1064 Witteman JC, Willett WC, Stampfer MJ, et al. Relation of moderate alcohol consumption and risk of systemic hypertension in women. Am J Cardiol. Mar. 1. 1990;65(9):633-7. KQ4aE4b, KQ4bE4b. [pmid: 2309634].
1065 Wittenberg C, Zabludowski JR, Rosenfeld JB. Overdiagnosis of hypertension in the elderly. J Hum Hypertens. Oct. 1992;6(5):349-51. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 1464890].
1066 Wittenberg C, Erman A, Sulkes J, et al. Which cuff size is preferable for blood pressure monitoring in most hypertensive patients?. J Hum Hypertens. Nov. 1994;8(11):819-22. KQ2aE3, KQ2bE4, KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 7853324].
1067 Wolak T, Wilk L, Paran E, et al. Is it possible to shorten ambulatory blood pressure monitoring?. J Clin Hypertens (Greenwich). Aug. 2013;15(8):570-4. KQ3aE4, KQ3bE3, KQ3cE3. [pmid: 23889719].
1068 Wong RC, Yeo TC. 'Office-hour' ambulatory blood pressure monitoring is sufficient for blood pressure diagnosis. J Hum Hypertens. Jun. 2006;20(6):440-3. KQ3aE4, KQ3bE4, KQ3cE4, KQ5E5. [pmid: 16598289].
1069 Wong TY, Klein R, Sharrett AR, et al. Retinal arteriolar diameter and risk for hypertension. Ann Intern Med. Feb. 17. 2004;140(4):248-55. KQ4aE4d, KQ4bE4d. [pmid: 14970147].
1070 Wong TY, Shankar A, Klein R, et al. Prospective cohort study of retinal vessel diameters and risk of hypertension. BMJ. Jul. 10. 2004;329(7457):79. KQ4aE12, KQ4bE12. [pmid: 15175230].
1071 Wood S, Martin U, Gill P, et al. Blood pressure in different ethnic groups (BP-Eth): a mixed methods study. BMJ Open. 2012;2(6):2012. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 23129572].
1072 Wright JC, Looney SW. Prevalence of positive Osler's manoeuver in 3387 persons screened for the Systolic Hypertension in the Elderly Program (SHEP). J Hum Hypertens. May. 1997;11(5):285-9. KQ2aE3, KQ2bE4. [pmid: 9205934].
1073 Xun P, Hou N, Daviglus M, et al. Fish oil, selenium and mercury in relation to incidence of hypertension: a 20-year follow-up study. J Intern Med. Aug. 2011;270(2):175-86. KQ4aE12, KQ4bE12. [pmid: 21205024].
1074 Xun P, Liu K, Loria CM, et al. Folate intake and incidence of hypertension among American young adults: a 20-y follow-up study. Am J Clin Nutr. May. 2012;95(5):1023-30. KQ4aE12, KQ4bE12. [pmid: 22492371].
1075 Xun P, Liu K, Cao W, et al. Fasting insulin level is positively associated with incidence of hypertension among American young adults: a 20-year follow-up study. Diabetes Care. Jul. 2012;35(7):1532-7. KQ4aE12, KQ4bE12. [pmid: 22511258].
1076 Yamasue K, Hayashi T, Ohshige K, et al. Masked hypertension in elderly managerial employees and retirees. Clin Exp Hypertens. Apr. 2008;30(3):203-11. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 18425700].
1077 Yan LL, Liu K, Matthews KA, et al. Psychosocial factors and risk of hypertension: the Coronary Artery Risk Development in Young Adults (CARDIA) study. JAMA. Oct. 22. 2003;290(16):2138-48. KQ4aE12, KQ4bE12. [pmid: 14570949].
1078 Yarows SA, Patel K, Brook R. Rapid oscillometric blood pressure measurement compared to conventional oscillometric measurement. Blood Press Monit. Jun. 2001;6(3):145-7. KQ2aE3, KQ2bE4. [pmid: 11518837].
1079 Yasui D, Asayama K, Takada N, et al. Evaluating home blood pressure in treated hypertensives in comparison with the referential value of casual screening of blood pressure: the Ohasama study. Blood Press Monit. Jun. 2012;17(3):89-95. KQ3aE4, KQ3bE5c, KQ3cE5c. [pmid: 22425704].
1080 Yavuz BB, Yavuz B, Tayfur O, et al. White coat effect and its clinical implications in the elderly. Clin Exp Hypertens. Jun. 2009;31(4):306-15. KQ3aE9, KQ3bE9, KQ3cE9. [pmid: 19811359].
1081 Ye S, Claire WY, Shimbo D, et al. Effect of change in systolic blood pressure between clinic visits on estimated 10-year cardiovascular disease risk. J Am Soc Hypertens. 2013. Dec. 19. KQ3aE4, KQ3bE4, KQ3cE4. [pmid: 24462238].
1082 Yoon HJ, Ahn Y, Park JB, et al. Are metabolic risk factors and target organ damage more frequent in masked hypertension than in white coat hypertension?. Clin Exp Hypertens. 2010;32(7):480-5. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 21029014].
1083 Youde JH, Manktelow B, Ward-Close S, et al. Measuring postural changes in blood pressure in the healthy elderly. Blood Press Monit. Feb. 1999;4(1):1-5. KQ2aE3, KQ2bE4. [pmid: 10362884].
1084 Yucha CB, Yang MC, Tsai PS, et al. Comparison of blood pressure measurement consistency using tonometric and automated oscillometric instruments. J Nurs Meas. 2003;11(1):73-86. KQ3aE4, KQ3bE5a, KQ3cE5a. [pmid: 15132013].
1085 Zabludowski JR, Rosenfeld JB. Evaluation of clinic blood pressure measurements: assessment by daytime ambulatory blood pressure monitoring. Isr J Med Sci. Jun. 1992;28(6):345-8. KQ2aE3, KQ2bE3, KQ3aE4. [pmid: 1607269].
1086 Zawadzka A, Bird R, Casadei B, et al. Audit of ambulatory blood pressure monitoring in the diagnosis and management of hypertension in practice. J Hum Hypertens. Apr. 1998;12(4):249-52. KQ3aE4, KQ3cE4. [pmid: 9607694].
1087 Zdrojewski T, Kozicka-Kakol K, Chwojnicki K, et al. Arm circumference in adults in Poland as an important factor influencing the accuracy of blood pressure readings. Blood Press Monit. Apr. 2005;10(2):73-7. KQ2aE7, KQ2bE7, KQ3aE7, KQ3bE7, KQ3cE7. [pmid: 15812254].
1088 Zhang H, Thijs L, Kuznetsova T, et al. Progression to hypertension in the non-hypertensive participants in the Flemish Study on Environment, Genes and Health Outcomes. J Hypertens. Sep. 2006;24(9):1719-27. KQ4aE10b, KQ4bE10b. [pmid: 16915020].
1089 Zhang J, Niaura R, Todaro JF, et al. Suppressed hostility predicted hypertension incidence among middle-aged men: the normative aging study. J Behav Med. Oct. 2005;28(5):443-54. KQ4aE7e, KQ4bE7e. [pmid: 16179978].
1090 Zhang L, Curhan GC, Forman JP. Diet-dependent net acid load and risk of incident hypertension in United States women. Hypertension. Oct. 2009;54(4):751-5. KQ4aE12, KQ4bE12. [pmid: 19667248].
1091 Zhang L, Curhan GC, Forman JP. Plasma resistin levels associate with risk for hypertension among nondiabetic women. J Am Soc Nephrol. Jul. 2010;21(7):1185-91. KQ4aE7e, KQ4bE7e. [pmid: 20378819].
1092 Zhang L, Curhan GC, Forman JP. Plasma prolactin level and risk of incident hypertension in postmenopausal women. J Hypertens. Jul. 2010;28(7):1400-5. KQ4aE7e, KQ4bE7e. [pmid: 20453663].
1093 Zhang L, Curhan GC, Forman JP. Plasma insulin-like growth factor-1 level and risk of incident hypertension in nondiabetic women. J Hypertens. Feb. 2011;29(2):229-35. KQ4aE4b, KQ4bE4b. [pmid: 21045735].
1094 Zhang Y, Tuomilehto J, Jousilahti P, et al. Lifestyle factors and antihypertensive treatment on the risks of ischemic and hemorrhagic stroke. Hypertension. Oct. 2012;60(4):906-12. KQ4aE4, KQ4bE4. [pmid: 22868396].
1095 Zheng D, Amoore JN, Mieke S, et al. How important is the recommended slow cuff pressure deflation rate for blood pressure measurement?. Ann Biomed Eng. Oct. 2011;39(10):2584-91. KQ2aE3, KQ2bE4. [pmid: 21735319].
1096 Zheng Y, Yu B, Alexander D, et al. Metabolomics and incident hypertension among blacks: the atherosclerosis risk in communities study. Hypertension. Aug. 2013;62(2):398-403. KQ4aE7e, KQ4bE7e. [pmid: 23774226].
1097 Zheng ZJ, Folsom AR, Ma J, et al. Plasma fatty acid composition and 6-year incidence of hypertension in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Am J Epidemiol. Sep. 1. 1999;150(5):492-500. KQ4aE12, KQ4bE12. [pmid: 10472949].
1098 Zhu N, Bu M, Chen D, et al. A study of the white-coat phenomenon in patients with primary hypertension. Hypertens Res. Jan. 2008;31(1):37-41. KQ2aE9, KQ2bE9, KQ3aE9, KQ3bE9, KQ3cE9. [pmid: 18360016].
1099 Ziemens B, Wallaschofski H, Volzke H, et al. Positive association between testosterone, blood pressure, and hypertension in women: longitudinal findings from the Study of Health in Pomerania. J Hypertens. Jun. 2013;31(6):1106-13. KQ4aE4d, KQ4bE4d. [pmid: 23636018].