# Detailed Methods

## Search Strategies

### Systematic Reviews Literature Search Strategy

#### Cochrane Database of Systematic Reviews

#1 (hypertensi*:ti,ab,kw or "blood pressure":ti,ab,kw) near/5 (screen*:ti,ab,kw or monitor*:ti,ab,kw or determin*:ti,ab,kw or diagnos*:ti,ab,kw or measur*:ti,ab,kw) from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#2 [mh ^hypertension/DI] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#3 [mh ^Sphygmomanometers] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#4 [mh ^"Blood Pressure Monitors"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#5 [mh ^"Blood Pressure Monitoring, Ambulatory"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#6 [mh ^"Blood Pressure Determination"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#7 [mh ^"White Coat Hypertension"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#8 [mh ^"Masked Hypertension"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#9 [mh ^Prehypertension/DI] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#10 or #1-#9 from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#11 [mh ^hypertension] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#12 [mh ^"blood pressure"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#13 [mh ^"arterial pressure"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#14 or #11-#13 from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#15 [mh ^"mass screening"] from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#16 #14 and #15 from 2005 to 2013, in Cochrane Reviews (Reviews and Protocols)
#17 #10 or #16

#### DARE

1. (hypertensi* NEAR5 determin*) OR (determin* NEAR5 hypertensi*) OR (hypertensi* NEAR5 diagnos*) OR (diagnos* NEAR5 hypertensi*) IN DARE FROM 2005 TO 2013
2. (hypertensi* NEAR5 screen*) OR (screen* NEAR5 hypertensi*) OR (hypertensi* NEAR5 monitor*) OR (monitor* NEAR5 hypertensi*) IN DARE FROM 2005 TO 2013
3. (hypertensi* NEAR5 measur*) OR (measur* NEAR5 hypertensi*) OR (blood pressure NEAR5 screen*) OR (screen* NEAR5 blood pressure) IN DARE FROM 2005 TO 2013
4. (blood pressure NEAR5 monitor*) OR (monitor* NEAR5 blood pressure) OR (blood pressure NEAR5 determin*) OR (determin* NEAR5 blood pressure) IN DARE FROM 2005 TO 2013
5. (blood pressure NEAR5 diagnos*) OR (diagnos* NEAR5 blood pressure) OR (blood pressure NEAR5 measur*) OR (measur* NEAR5 blood pressure) IN DARE FROM 2005 TO 2013
6. #1 OR #2 OR #3 OR #4 OR #5
7. (Sphygmomanometer*) IN DARE FROM 2005 TO 2013
8. #6 OR #7

#### HTA

1. (hypertensi* NEAR5 determin*) OR (determin* NEAR5 hypertensi*) OR (hypertensi* NEAR5 diagnos*) OR (diagnos* NEAR5 hypertensi*) IN HTA FROM 2005 TO 2013
2. (hypertensi* NEAR5 screen*) OR (screen* NEAR5 hypertensi*) OR (hypertensi* NEAR5 monitor*) OR (monitor* NEAR5 hypertensi*) IN HTA FROM 2005 TO 2013
3. (hypertensi* NEAR5 measur*) OR (measur* NEAR5 hypertensi*) OR (blood pressure NEAR5 screen*) OR (screen* NEAR5 blood pressure) IN HTA FROM 2005 TO 2013
4. (blood pressure NEAR5 monitor*) OR (monitor* NEAR5 blood pressure) OR (blood pressure NEAR5 determin*) OR (determin* NEAR5 blood pressure) IN HTA FROM 2005 TO 2013
5. (blood pressure NEAR5 diagnos*) OR (diagnos* NEAR5 blood pressure) OR (blood pressure NEAR5 measur*) OR (measur* NEAR5 blood pressure) IN HTA FROM 2005 TO 2013
6. (Sphygmomanometer*) IN HTA FROM 2005 TO 2013
7. #1 OR #2 OR #3 OR #4 OR #5 OR #6

#### MEDLINE

1. *Sphygmomanometers/
2. *Blood Pressure Monitors/
3. *Blood Pressure Monitoring, Ambulatory/
4. *Blood Pressure Determination/
5. *Hypertension/di [Diagnosis]
6. *White Coat Hypertension/
7. *Masked Hypertension/
8. *Prehypertension/di [Diagnosis]
9. *Blood Pressure/
10. *Arterial Pressure/ or *hypertension/ or *Prehypertension/
11. 9 or 10
12. Mass Screening/
13. (screen$ or monitor$ or determin$ or diagnos$ or measur$).ti.
14. 12 or 13
15. 11 and 14
16. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 15
17. limit 16 to systematic reviews
18. limit 17 to "all adult (19 plus years)"
19. limit 17 to "all child (0 to 18 years)"
20. 19 not 18
21. 17 not 20
22. limit 21 to english language
23. limit 22 to yr="2005 -Current"
24. ((hypertensi$ or blood pressure) adj5 (screen$ or monitor$ or determin$ or diagnos$ or measur$)).ti,ab.
25. limit 24 to systematic reviews
26. limit 25 to ("in data review" or in process or "pubmed not medline")
27. limit 26 to english language
28. limit 27 to yr="2005 -Current"
29. 23 or 28

#### PubMed

#1 (hypertensi*[ti] OR blood pressure[ti]) AND (screen*[tiab] OR monitor*[tiab] OR determin*[tiab] OR diagnos*[tiab] OR measur*[tiab])
#2 #1 AND systematic[sb]
#3 #2 AND publisher[sb] Filters: Publication date from 2005/01/01; English

### Key Questions 1 and 5 Search Strategies

#### PubMed

#6 Search #5 AND publisher[sb] Filters: Publication date from 2003/01/01; English
#5 Search #3 and #4
#4 Search random*[tiab] OR trial*[tiab]
#3 Search #1 AND #2
#2 Search screen[tiab] OR screens[tiab] OR screening[tiab] OR screened[tiab] OR diagnos*[tiab] OR measur*[tiab] OR monitor*[tiab] OR determin*[tiab]
#1 Search hypertension[ti] OR hypertensive[ti] OR prehypertension[ti] OR prehypertensive[ti] OR "Arterial Pressure"[ti] OR "blood pressure"[ti]

#### MEDLINE

1. Hypertension/ ()
2. Masked Hypertension/ ()
3. White Coat Hypertension/ ()
4. Prehypertension/ ()
5. Blood Pressure/ ()
6. Arterial Pressure/ ()
7. hypertensi$.ti. ()
8. prehypertensi$.ti. ()
9. Arterial Pressure.ti. ()
10. (systolic pressure or diastolic pressure).ti,ab. ()
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 ()
12. Mass Screening/ ()
13. screen$.ti,ab. ()
14. 12 or 13 ()
15. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ ()
16. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
17. random$.ti,ab. ()
18. Meta-Analysis as Topic/ ()
19. control groups/ or double-blind method/ or single-blind method/ ()
20. clinical trial$.ti,ab. ()
21. controlled trial$.ti,ab. ()
22. 15 or 16 or 17 or 18 or 19 or 20 or 21 ()
23. 11 and 14 and 22 ()
24. limit 23 to english language ()
25. limit 24 to yr="2003-Current" ()
26. limit 25 to "all adult (19 plus years)" ()
27. limit 25 to "all child (0 to 18 years)" ()
28. 27 not 26 ()
29. 25 not 28 ()
30. hypertensi$.ti,ab. ()
31. prehypertensi$.ti,ab. ()
32. Arterial Pressure.ti,ab. ()
33. blood pressure.ti,ab. ()
34. (systolic pressure or diastolic pressure).ti,ab. ()
35. 30 or 31 or 32 or 33 or 34 ()
36. screen$.ti,ab. ()
37. random$.ti,ab. ()
38. clinical trial$.ti,ab. ()
39. controlled trial$.ti,ab. ()
40. 37 or 38 or 39 ()
41. 35 and 36 and 40 ()
42. limit 41 to ("in data review" or in process or "pubmed not medline") ()
43. limit 42 to english language ()
44. limit 43 to yr="2003 -Current" ()
45. 29 or 44 ()
46. remove duplicates from 45 ()

1. Hypertension/di ()
2. Prehypertension/di ()
3. 1 or 2 ()
4. Hypertension/ ()
5. Masked hypertension/ ()
6. White coat hypertension/ ()
7. Prehypertension/ ()
8. Blood Pressure/ ()
9. Arterial Pressure/ ()
10. hypertensi$.ti. ()
11. prehypertensi$.ti. ()
12. arterial pressure.ti. ()
13. blood pressure.ti. ()
14. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 ()
15. Mass screening/ ()
16. screen$.ti,ab. ()
17. diagnos$.ti. ()
18. Awareness/ ()
19. 15 or 16 or 17 or 18 ()
20. 14 and 19 ()
21. (aware$ adj5 (hypertensi$ or prehypertensi$ or "blood pressure" or "arterial pressure")).ti,ab. ()
22. known hypertension.ti,ab. ()
23. 3 or 20 or 21 or 22 ()
24. ae.fs. ()
25. Quality of life/ ()
26. Absenteeism/ ()
27. Sick leave/ ()
28. Sick role/ ()
29. Illness behavior/ ()
30. Anxiety/ ()
31. Depression/ ()
32. quality of life.ti,ab. ()
33. self rated health.ti,ab. ()
34. (psychological adj (distress or effect$ or impact)).ti,ab. ()
35. anxiety.ti,ab. ()
36. (depression or depressed or depressive).ti,ab. ()
37. absenteeism.ti,ab. ()
38. ((disability or sick) adj3 day$).ti,ab. ()
39. 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 ()
40. 23 and 39 ()
41. (label$ adj5 (hypertensi$ or prehypertensi$ or "blood pressure" or "arterial pressure")).ti,ab. ()
42. 40 or 41 ()
43. limit 42 to (english language and yr="2003 -Current") ()
44. remove duplicates from 43 ()

#### CENTRAL

#1 hypertens*:ti,ab,kw from 2003 to 2014, in Trials
#2 prehypertens*:ti,ab,kw from 2003 to 2014, in Trials
#3 "masked hypertension":ti,ab,kw from 2003 to 2014, in Trials
#4 "white coat hypertension":ti,ab,kw from 2003 to 2014, in Trials
#5 "blood pressure":ti,ab,kw from 2003 to 2014, in Trials
#6 "arterial pressure":ti,ab,kw from 2003 to 2014, in Trials
#7 "systolic pressure":ti,ab,kw from 2003 to 2014, in Trials
#8 "diastolic pressure":ti,ab,kw from 2003 to 2014, in Trials
#9 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8
#10 screen*:ti,ab,kw from 2003 to 2014, in Trials
#11 #9 and #10 from 2003 to 2014, in Trials

#### CINAHL

S8 S5 AND S6 Limiters - Published Date from: 20030101-20131231; Language: English
S7 S5 AND S6
S6 (MH "Meta Analysis") OR (MH "Control Group") OR (MH "Single-Blind Studies") OR (MH "Double-Blind Studies") OR (MH "Triple-Blind Studies") OR (MH "Randomized Controlled Trials") OR (MH "Clinical Trials") OR (MH "Random Assignment") OR (AB clinical n1 trial*) OR (AB controlled n1 trial*) OR (TI clinical n1 trial*) OR (TI controlled n1 trial*) OR (PT Clinical trial) OR (PT randomized controlled trial)
S5 S3 OR S4
S4 (TI hypertensi* N3 determin*) OR (AB hypertensi* N3 determin*) OR (TI hypertensi* N3 diagnos*) OR (AB hypertensi* N3 diagnos*) OR (TI hypertensi* N3 measur*) OR (AB hypertensi* N3 measur*) OR (TI hypertension N3 monitor*) OR (AB hypertension N3 monitor*) OR (TI blood pressure N3 measur*) OR (AB blood pressure N3 measur*) OR (TI blood pressure N3 monitor*) OR (AB blood pressure N3 monitor*) OR (TI blood pressure N3 determin*) OR (AB blood pressure N3 determin*) OR (TI blood pressure N3 diagnos*) OR (AB blood pressure N3 diagnos*)
S3 S1 AND S2
S2 TI "screen*" OR AB "screen*"
S1 MH "Hypertension" OR MH "Hypertension, White Coat" OR MH "Masked Hypertension" OR MH "Prehypertension" OR MH "Blood Pressure" OR MH "Arterial Pressure" OR MH "Systolic Pressure" OR MH "Diastolic Pressure" OR TI ("blood pressure" OR hypertens* OR prehypertens* OR "arterial pressure" OR "systolic pressure" OR "diastolic pressure") OR AB ("blood pressure" OR hypertens* OR prehypertens* OR "arterial pressure" OR "systolic pressure" OR "diastolic pressure")

S29 S28 Limiters - Published Date from: 20030101-20131231; Language: English
S28 S26 OR S27
S27 TI ((labelled or labeled or labeling or labelling) N5 (hypertens* or prehypertensi* or "blood pressure" or "arterial pressure")) OR AB ((labelled or labeled or labeling or labelling) N5 (hypertens* or prehypertensi* or "blood pressure" or "arterial pressure"))
S26 S8 AND S25 512
S25 S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24
S24 TI ((disability or sick) N3 day*) OR AB ((disability or sick) N3 day*)
S23 TI absenteeism OR AB absenteeism
S22 TI anxiety OR AB anxiety
S21 TI (depression or depressed or depressive) OR AB (depression or depressed or depressive)
S20 TI (psychological N1 (distress or effect* OR impact)) OR AB (psychological N1 (distress or effect* OR impact))
S19 TI "self rated health" OR AB "self rated health"
S18 TI "quality of life" OR AB "quality of life"
S17 MW adverse effects
S16 (MH "Depression")
S15 (MH "Anxiety")
S14 (MH "Attitude to Illness")
S13 (MH "Sick Role")
S12 (MH "Sick Leave")
S11 (MH "Absenteeism")
S10 (MH "Quality of Life")
S9 (MH "Adverse Health Care Event")
S8 S5 OR S6 OR S7
S7 TI "known hypertension" OR AB "known hypertension"
S6 TI (aware* N5 (hypertensi* or prehypertens* OR "blood pressure" or "arterial pressure")) OR AB (aware* N5 (hypertensi* OR prehypertensi* OR "blood pressure" or "arterial pressure"))
S5 S3 OR S4
S4 MH Hypertension/DI
S3 S1 AND S2
S2 TI "screen*" OR AB "screen*" OR TI diagnos*
S1 MH "Hypertension" OR MH "Hypertension, White Coat" OR MH "Masked Hypertension" OR MH "Prehypertension" OR MH "Blood Pressure" OR MH "Arterial Pressure" OR MH "Systolic Pressure" OR MH "Diastolic Pressure" OR TI ("blood pressure" OR hypertens* OR prehypertens* OR "arterial pressure" OR "systolic pressure" OR "diastolic pressure") OR AB ("blood pressure" OR hypertens* OR prehypertens* OR "arterial pressure" OR "systolic pressure" OR "diastolic pressure")

### Key Questions 2 and 3 Search Strategies

#### PubMed

#5 #4 AND publisher[sb] Filters: Publication date from 1992/01/01; English
#4 #3 NOT ((child*[ti] OR adolescen*[ti]))
#3 #1 AND #2
#2 (screen[tiab] OR screens[tiab] OR screening[tiab] OR screened[tiab] OR diagnos*[tiab] OR measur*[tiab] OR monitor*[tiab] OR determin*[tiab])
#1 (hypertensi*[ti] OR blood pressure[ti])

#### MEDLINE

1. Hypertension/di ()
2. Blood pressure determination/ ()
3. Blood pressure monitoring, Ambulatory/ ()
4. Blood pressure monitors/ ()
5. Sphygmomanometers/ ()
6. 1 or 2 or 3 or 4 or 5 ()
7. (("blood pressure$" or BP) adj1 (monitor$ or measure$)).ti,ab. ()
8. ((office or clinic) adj3 ("blood pressure$" or BP)).ti,ab. ()
9. ((self$ or home or ambulatory) adj3 ("blood pressure$" or BP)).ti,ab. ()
10. ((manual$ or automated) adj3 ("blood pressure$" or BP)).ti,ab. ()
11. AOBP.ti,ab. ()
12. MOBP.ti,ab. ()
13. ABPM.ti,ab. ()
14. sphygmomanometer$.ti,ab. ()
15. 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 ()
16. limit 15 to ("in data review" or in process or "pubmed not medline") ()
17. (hypertens$ and screen$ and instrument$).ti,ab. ()
18. 6 or 16 or 17 ()
19. "Sensitivity and Specificity"/ ()
20. "Predictive Value of Tests"/ ()
21. ROC Curve/ ()
22. False Negative Reactions/ ()
23. False Positive Reactions/ ()
24. Diagnostic Errors/ ()
25. "Reproducibility of Results"/ ()
26. Reference Values/ ()
27. Reference Standards/ ()
28. Observer Variation/ ()
29. Prevalence/ ()
30. Receiver operat$.ti,ab. ()
31. ROC curve$.ti,ab. ()
32. sensitivit$.ti,ab. ()
33. specificit$.ti,ab. ()
34. predictive value.ti,ab. ()
35. accuracy.ti,ab. ()
36. false positive$.ti,ab. ()
37. false negative$.ti,ab. ()
38. miss rate$.ti,ab. ()
39. error rate$.ti,ab. ()
40. prevalence.ti,ab. ()
41. 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 ()
42. 18 and 41 ()
43. Blood Pressure Determination/mt, st ()
44. ((BP or "blood pressure$" or hypertens$) adj3 confirm$).ti,ab. ()
45. (clinic or office).ti. ()
46. (home or self$ or ambulatory).ti. ()
47. ("blood pressure$" or hypertens$).ti. ()
48. 45 and 46 and 47 ()
49. 42 or 43 or 44 or 48 ()
50. ((cardiovascular or CV) adj3 (risk or predict$ or stratif$ or event$ or morbidit$ or prognos$ or outcome$)).ti,ab. ()
51. 18 and 50 ()
52. 49 or 51 ()
53. limit 52 to "all adult (19 plus years)" ()
54. limit 52 to "all child (0 to 18 years)" ()
55. 54 not 53 ()
56. 52 not 55 ()
57. (child$ or adolescen$).ti. ()
58. 56 not 57 ()
59. limit 58 to humans ()
60. limit 58 to animals ()
61. 60 not 59 ()
62. 58 not 61 ()
63. limit 62 to (case reports or comment or editorial or letter or news) ()
64. 62 not 63 ()
65. limit 64 to english language ()
66. limit 65 to yr="1992 -Current" ()

#### CENTRAL

#1 (prehypertens*:ti or hypertensi*:ti or "blood pressure":ti or sphygmomanometer*:ti) from 1992 to 2014, in Trials
#2 (hypertensi*:ti,ab,kw or "blood pressure":ti,ab,kw) near/5 (screen*:ti,ab,kw or monitor*:ti,ab,kw or determin*:ti,ab,kw or diagnos*:ti,ab,kw or measur*:ti,ab,kw or confirm*:ti,ab,kw) from 1992 to 2014, in Trials
#3 #1 and #2 from 1992 to 2014, in Trials
#4 (sensitivity:ti,ab,kw or specificity:ti,ab,kw or accuracy:ti,ab,kw or "predictive value":ti,ab,kw) from 1992 to 2014, in Trials
#5 #1 and #4 from 1992 to 2014, in Trials
#6 (cardiovascular:ti,ab,kw or CV:ti,ab,kw) near/5 (risk:ti,ab,kw or predict*:ti,ab,kw or stratif*:ti,ab,kw or event*:ti,ab,kw or morbidit*:ti,ab,kw or prognos*:ti,ab,kw or outcome*:ti,ab,kw) from 1992 to 2014, in Trials
#7 #1 and #6 from 1992 to 2014, in Trials
#8 #3 or #5 or #7 from 1992 to 2014, in Trials
#9 (child*:ti or adolescen*:ti) from 1992 to 2014, in Trials
#10 #8 not #9 from 1992 to 2014, in Trials

### Key Question 4 Search Strategies

#### PubMed

#8 #7 AND publisher[sb] Filters: Publication date from 1966/01/01; English
#7 #6 NOT ((child*[ti] OR adolescen*[ti]))
#6 #4 AND #5
#5 cohort*[tiab] OR longitudinal[tiab] OR follow up[tiab] OR followup[tiab] OR retrospective[tiab] OR prospective[tiab]
#4 #1 AND (#2 OR #3)
#3 incident hypertension[tiab]
#2 change*[tiab] OR progress*[tiab] OR develop[tiab] OR develops[tiab] OR developed[tiab] OR development[tiab] OR predict*[tiab] OR re-screen*[tiab] OR re-measure*[tiab] OR rescreen*[tiab] OR re measure*[tiab]
#1 blood pressure[ti] OR BP[ti] OR arterial pressure[ti] OR hypertensi*[ti]

#### MEDLINE

1. *Hypertension/ ()
2. *Blood pressure/ ()
3. *Arterial pressure/ ()
4. *Blood pressure determination/ ()
5. *Blood pressure monitoring, Ambulatory/ ()
6. *Prehypertension/ ()
7. 1 or 2 or 3 or 4 or 5 or 6 ()
8. (inciden$ adj3 hypertens$).ti,ab. ()
9. ((progress$ or develop$ or predict$) adj5 (hypertens$ or prehypertens$ or pre hypertens$)).ti,ab. ()
10. (change$ adj5 (blood pressure or BP or arterial pressure)).ti,ab. ()
11. (rescreen$ or re-screen$ or remeasure$ or re-measure$).ti,ab. ()
12. (previous$ adj1 (screen$ or measur$ or monitor$)).ti,ab. ()
13. 8 or 9 or 10 or 11 or 12 ()
14. epidemiologic studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/ ()
15. 7 and 13 and 14 ()
16. limit 15 to (english language and yr="1966 -Current") ()
17. (blood pressure or BP or hypertens$ or arterial pressure).ti. ()
18. (11 or 12) and 17 ()
19. 8 or 9 or 10 or 18 ()
20. cohort.ti,ab. ()
21. longitudinal.ti,ab. ()
22. incidence stud$.ti,ab. ()
23. retrospective.ti,ab. ()
24. (follow-up or followup).ti,ab. ()
25. prospective.ti,ab. ()
26. 20 or 21 or 22 or 23 or 24 or 25 ()
27. 19 and 26 ()
28. limit 27 to ("in data review" or in process or "pubmed not medline") ()
29. limit 28 to (english language and yr="1966 -Current") ()
30. 16 or 29 ()
31. limit 30 to "all adult (19 plus years)" ()
32. limit 30 to "all child (0 to 18 years)" ()
33. 32 not 31 ()
34. 30 not 33 ()
35. (child$ or adolesc$).ti. ()
36. 34 not 35 ()
37. remove duplicates from 36 ()

## Selection Criteria

Appendix A Figure 1 Literature Flow Diagram

Appendix Figure 1 is a flow chart that summarizes the search and selection of articles. There were 28,816 citations identified through literature databases. An additional 94 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 19,309 unique citations were screened at the title/abstract stage. The full-text of 1,171 citations were examined for inclusion for one or more of the five Key Questions.

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Inclusion | Exclusion
Aim | KQs 1, 2, 4, 5: Screening for high blood pressure in a primary care setting (alone or as part of a clinical examination) KQ 3: Measuring blood pressure to confirm diagnosis of hypertension | Measurement of short-term diet-, exercise-, or drug-induced blood pressure changes; measurement of blood pressure as part of a disease management program for heart failure or weight loss; mathematical transformation of BP results (e.g., pulse pressure, variability, morning surge, dipping) for use as additional diagnostic criteria and/or predicting risk
Population | KQs 1, 2, 5: Adults age 18 years or older KQ 3: Adults age 18 years or older with at least one elevated blood pressure measurement (as defined by study) identified by clinic-based screening KQ 4: Adults age 18 years or older whose previous clinic-based blood pressure screening was normal or not in the treatable range, or for whom an initial diagnosis of hypertension was not confirmed | Pregnant women, children (age <18 years), inpatients, institutionalized persons, patients with underlying causes of high blood pressure, and highly selected groups of patients (e.g., patients with diabetes, chronic kidney disease, or renal transplant) who do not represent a primary screening population KQs 1, 2, 3b, 3c, 4, 5:; - Patients treated for hypertension with medication (if study is among hypertensives, assume all treated if no details about current treatment are available); - Studies that include more than 20% of the above excluded populations and in which the data are not stratified; KQ 4: Patients with treatable high blood pressure within the current treatment guidelines
Intervention | KQs 1, 2, 4, 5: Clinic-based, noninvasive blood pressure measurement using any commonly used device or screening protocol during a single encounter; blood pressure measurements conducted as part of a multicomponent cardiovascular risk assessment in which blood pressure elevation is the initial and sole factor that determines whether a patient proceeds to additional assessment KQ 3: Any clinic-based blood pressure measurement confirmed by another clinic-based, home, or ambulatory blood pressure measurement (with any device or measurement protocol). For all ambulatory devices, average 24- or 48-hour, daytime, and nighttime blood pressure measurements are acceptable | Wrist and finger monitors, forearm cuffing, ankle and toe measures; any method not commonly used in routine BP screening (e.g., invasive methods, non-invasive method of central blood pressure measurement); Osler’s maneuver
Comparator | KQs 1, 5: No blood pressure screening KQ 2: A noninvasive blood pressure measurement method that differs either by device or protocol (e.g., manual vs. automated; clinic-based using one protocol vs. clinic-based using a different protocol) KQ 3: Any clinic-based blood pressure measurement confirmed by another clinic-based, home, or ambulatory blood pressure measurement (with any device or protocol) KQ 4: Time interval for rescreening using the same method | KQs 2, 3: Within-class comparative effectiveness of devices (e.g., automated vs. automated; random zero vs. standard sphygmomanometer) with identical screening protocols; validation and accuracy studies of devices compared to standards or using specific protocols (e.g., British Hypertension Society protocol, Association for the Advancement of Medical Instrumentation)
Outcomes | KQ 1:; - Mortality (all-cause and cardiovascular-related); - Cardiovascular disease, as defined by fatal and nonfatal cardiovascular events, including: myocardial infarction, sudden cardiac death, stroke, heart failure, atrial fibrillation, transient ischemic attack; composite measures are eligible if they do not contain excluded outcomes; - End-stage kidney disease (i.e., doubling of serum creatinine, halving of glomerular filtration rate, or transition to dialysis/transplant); KQs 2, 3b, 3c: Sensitivity, specificity, positive and negative predictive value (or comparable statistics or data that allow calculation of such), concordance for hypertension diagnosis (e.g., Kappa statistics for categories of diagnosis) KQ 3a: Measures of association of blood pressure and fatal or nonfatal cardiovascular events (as listed above), such as risk ratio or hazard ratio KQ 4: Change in blood pressure classification (i.e., normal to diagnosis of hypertension) when rescreened at different time intervals (e.g., 1 year, 5 years) as identified through BP measurements or physician diagnosis (e.g., medical chart review) KQ 5:; - Psychological effects of labeling; - Absenteeism; - Quality of life | KQs 1, 3: Cardiovascular symptoms (e.g., palpitations), angina pectoris (chest pain), revascularization, carotid intima-media thickness, left ventricular hypertrophy, patient satisfaction, quality of life KQs 2, 3b: Studies that do not provide enough data to create 2×2 tables or calculate sensitivity and specificity; studies that are designed to assess devices versus blood pressure measurement standards. Mean differences in blood pressure or other correlations based on numeric BP values will not be included at full-text stage (e.g., r, r^2^, p-value for comparison of or difference of means). Lack of directionality with a reported change in diagnosis KQ 3a: Studies that do not define composite cardiovascular disease outcomes; composite cardiovascular outcomes that contain excluded outcomes (as listed above, excepting patient satisfaction, quality of life) KQ 4: Studies that report only average change in blood pressure for the entire population; studies that report incident antihypertensive drug use only or studies that utilize self-reported measures (BP, medication use or physician diagnosis) but do not report change in classification from measured BP or change in physician diagnosis
Timing of outcome assessment | No restrictions for KQs 1, 2, 3, and 5. KQ4: Less than 6 years | No restrictions for KQs 1, 2, 3, and 5. KQ4: Greater than or equal to 6 years
Setting | KQs 1, 2, 4, 5: Eligible primary care settings must have personnel trained in blood pressure measurement, established blood pressure measurement protocols, and ongoing documentation procedures for each (e.g., internal medicine, family practice, obstetrics/gynecology, school- and military-based health clinics, pharmacies, retail and mobile clinics, dental offices) KQ 3: Primary care settings (see above for definition), home | Health care or nonhealth care settings (e.g., worksites, school) that do not have personnel trained in blood pressure measurement, do not have established blood pressure measurement protocols, or do not have ongoing documentation procedures for each; inpatient/residential facilities, correctional facilities
Study design | KQ 1: Randomized, controlled trials (RCTs) or controlled clinical trials (CCTs) KQ 2: Diagnostic accuracy studies, RCTs, CCTs, cohort studies KQ 3: Diagnostic accuracy studies, RCTs, CCTs, cohort studies, case-control studies KQ 4: Longitudinal cohort studies KQ 5: RCTs, CCTs, cohort studies | All KQs: Before-after studies, time series, case series, case reports; studies enrolling treated hypertension patients with less than a 2-week washout period; comparison of diagnostic accuracy of devices in different populations within the same study, case-control studies; simulation studies KQ3b, 3c: Study size of untreated hypertensives <100 KQ 4: Use of the untreated placebo group from treatment trials as a cohort; use of individuals from other intervention trials as a cohort study (e.g., SU.VI.MAX); study size <1,000 individuals KQ 5: Cross-sectional studies
Country | Studies in countries rated as “very high” on the 2013 Human Development Index: Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Seychelles, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States | Studies in countries rated below “very high” on the 2013 Human Development Index
Literature search dates | KQs 1, 5: January 2002 to present (which includes carrying forward any previously included studies in the previous USPSTF systematic review) KQs 2, 3: January 1992 to present. The rationale is based on that of Verberk and colleagues;81 1992 was chosen because the first protocol with guidelines for validation of blood pressure monitoring devices was published in 1990, and a lag time of 2 years was added to allow the guidelines to be fully implemented. KQ 4: January 1965 to present. The rationale is that this is a new KQ that has never been addressed in a USPSTF systematic review
Language | English | Other languages than English
Study quality | Fair or good | Poor, according to design-specific USPSTF criteria

Abbreviations: BP = blood pressure; CCT = controlled clinical trial; KQ = Key Question; RCT = randomized controlled trial; USPSTF = U.S. Preventive Services Task Force.

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the USPSTF methods97 | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)100 | - Was the cohort systematically selected to avoid bias?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid and reliable?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) II instrument98 | - Risk of Bias: Could the selection of patients have introduced bias?; ○ Signaling Question 1: Was a consecutive or random sample of patients enrolled; ○ Signaling Question 2: Was a case-control design avoided?; ○ Signaling Question 3: Did the study avoid inappropriate exclusions?; - Risk of Bias: Could the conduct or interpretation of the index test have introduced bias?; ○ Signaling Question 1: Were the tests evaluated independently and were assessors blinded to results?; ○ Signaling Question 2: If a threshold was use, was it prespecified?; - Risk of Bias: Could the patient flow have introduced bias?; ○ Signaling Question 1: Was there an appropriate interval between the tests and was it applied consistently?; ○ Signaling Question 2: Did all patients receive the same tests?; ○ Signaling Question 3: Were all patients included in the analysis?; ○ Was the handling of missing data appropriate?; ○ Was the order of tests randomized among patients?; - Other quality considerations:; ○ Was the device calibration and/or maintenance reported?; ○ Were the devices validated?; ○ Was the training of interventionists reported?; ○ Was there intervention fidelity?; ○ Was there adequate adherence to the intervention?
Prognostic studies, adapted from the Quality in Prognosis Studies (QUIPS) tool99 | - Does the study sample adequately represent the population of interest?; ○ Was there a description of source population or population of interest (i.e., was there a generalizable population)?; ○ Was there adequate participation in the study by eligible persons?; ○ Was there an adequate description of the inclusion and exclusion criteria?; ○ Was there an adequate description of the sampling frame, recruitment period and place?; ○ Was there a description of the baseline study sample?; ○ Were subject with the outcome of interest at baseline excluded or handled in the analysis?; - Does the study data available adequately represent the study sample?; ○ Was there acceptable followup?; ○ Were the attempts to collect information on participants who dropped out described and were those lost to followup similar to those who remained?; ○ Were the reasons for loss to followup provided?; - Was the prognostic factor measure in a similar way for all participants?; ○ Was the prognostic factor clear defined?; ○ Was the method of prognostic factor measurement valid and reliable (i.e., equal and similar for all participants)?; ○ Was there an adequate proportion of the study sample who had complete data for the prognostic factor?; ○ Were the methods and settings of the measurement of the prognostic factor the same across all participants and across all timepoints?; - Was the outcome of interest measured in a similar way for all participants?; ○ Was there a clear definition of the outcome?; ○ Was the method and setting of outcome measurement the same for all participants (i.e., valid and reliable)?; - Were important confounding factors appropriately accounted for in the study design and analysis?; - Was the statistical analysis appropriate?; ○ Was there evidence of selective reporting of outcomes?