# References

1 Ellis EM, Thal DJ. (2008). Early language delay and risk for language impairment. Perspectives Lang Learn Educat.
2 Girolametto L, Wiigs M, Smyth R, et al. (2001). Children with a history of expressive vocabulary delay: outcomes at 5 years of age. Am J Speech Lang Pathol.
3 Rescorla L. (2011). Late talkers: do good predictors of outcome exist?. Dev Disabil Res Rev.
4 Rice ML, Taylor CL, Zubrick SR. (2008). Language outcomes of 7-year old children with or without a history of late language emergence at 24 months. J Speech Lang Hear Res.
5 National Dissemination Center for Children with Disabilities. Speech and Language Impairments.
6 Chawarska K, Paul R, Klin A, et al. (2007). Parental recognition of developmental problems in toddlers with autism spectrum disorders. J Autism Dev Disord.
7 Guinchat V, Chamak B, Bonniau B, et al. (2012). Very early signs of autism reported by parents include many concerns not specific to autism criteria. Res Autism Spectr Disord.
8 American Speech-Language-Hearing Association. (1993). Definitions of Communication Disorders and Variations [paper].
9 Rowe ML, Goldin-Meadow S. (2009). Early gesture selectively predicts later language learning. Dev Sci.
10 Crais ER, Watson LR, Baranek GT. (2009). Use of gesture development in profiling children’s prelinguistic communication skills. Am J Speech Lang Pathol.
11 Thal DJ, Tobias S. (1992). Communicative gestures in children with delayed onset of oral expressive vocabulary. J Speech Hear Res.
12 Whitehurst GJ, Smith M, Fischel JE, et al. (1991). The continuity of babble and speech in children with specific expressive language delay. J Speech Hear Res.
13 Law J, Boyle J, Harris F, et al. (2000). Prevalence and natural history of primary speech and language delay: findings from a systematic review of the literature. Int J Lang Commun Disord.
14 Pinborough-Zimmerman J, Satterfield R, Miller J, et al. (2007). Communication disorders: prevalence and comorbid intellectual disability, autism, and emotional/behavioral disorders. Am J Speech Lang Pathol.
15 Hannus S, Kauppila T, Launonen K. (2009). Increasing prevalence of specific language impairment (SLI) in primary healthcare of a Finnish town, 1989–99. Int J Lang Commun Disord.
16 McLeod S, Harrison LJ. (2009). Epidemiology of speech and language impairment in a nationally representative sample of 4- to 5-year-old children. J Speech Lang Hear Res.
17 U.S. Department of Education, Office of Special Education and Rehabilitative Serivces, Office of Special Education Programs. (2009). 31st Annual Report to Congress on the Implementation of the Individuals with Disabilities Education Act.
18 American Speech-Language-Hearing Association. (2011). The Speech-Language Pathology Medical Review Guidelines.
19 Felsenfeld S, Broen PA, McGue M. (1994). A 28-year follow-up of adults with a history of moderate phonological disorder: educational and occupational results. J Speech Hear Res.
20 Ruben RJ. (2000). Redefining the survival of the fittest: communication disorders in the 21st century. Laryngoscope.
21 Conti-Ramsden G, Falcaro M, Simkin Z, et al. (2007). Familial loading in specific language impairment: patterns of differences across proband characteristics, gender and relative types. Genes Brain Behav.
22 Newbury DF, Monaco AP. (2010). Genetic advances in the study of speech and language disorders. Neuron.
23 Rice ML, Smith SD, Gayan J. (2009). Convergent genetic linkage and associations to language, speech and reading measures in families of probands with Specific Language Impairment. J Neurodev Disord.
24 DeThorne LS, Hart SA, Petrill SA, et al. (2006). Children’s history of speech-language difficulties: genetic influences and associations with reading-related measures. J Speech Lang Hear Res.
25 Kovas Y, Hayiou-Thomas ME, Oliver B, et al. (2005). Genetic influences in different aspects of language development: the etiology of language skills in 4.5-year-old twins. Child Dev.
26 Oliver BR, Plomin R. (2007). Twins’ Early Development Study (TEDS): a multivariate, longitudinal genetic investigation of language, cognition and behavior problems from childhood through adolescence. Twin Res Hum Genet.
27 Viding E, Spinath FM, Price TS, et al. (2004). Genetic and environmental influence on language impairment in 4-year-old same-sex and opposite-sex twins. J Child Psychol Psychiatry.
28 Kang C, Drayna D. (2011). Genetics of speech and language disorders. Annu Rev Genomics Hum Genet.
29 Grigorenko EL. (2009). Speaking genes or genes for speaking? Deciphering the genetics of speech and language. J Child Psychol Psychiatry.
30 Bashir AS, Scavuzzo A. (1992). Children with language disorders: natural history and academic success. J Learn Disabil.
31 Raitano NA, Pennington BF, Tunick RA, et al. (2004). Pre-literacy skills of subgroups of children with speech sound disorders. J Child Psychol Psychiatry.
32 Peterson RL, Pennington BF, Shriberg LD, et al. (2009). What influences literacy outcome in children with speech sound disorder?. J Speech Lang Hear Res.
33 Catts HW, Fey ME, Tomblin JB, et al. (2002). A longitudinal investigation of reading outcomes in children with language impairments. J Speech Lang Hear Res.
34 Scarborough HS, Dobrich W. (1990). Development of children with early language delay. J Speech Hear Res.
35 Richman N, Stevenson J, Graham PJ. (1982). Pre-school to school: a behavioural study. Behavioural Development: A Series of Monographs.
36 Silva PA, Williams S, McGee R. (1987). A longitudinal study of children with developmental language delay at age three: later intelligence, reading and behaviour problems. Dev Med Child Neurol.
37 Bishop DV, Clarkson B. (2003). Written language as a window into residual language deficits: a study of children with persistent and residual speech and language impairments. Cortex.
38 Stern LM, Connell TM, Lee M, et al. (1995). The Adelaide preschool language unit: results of follow-up. J Paediatr Child Health.
39 Silva PA, McGee R, Williams SM. (1983). Developmental language delay from three to seven years and its significance for low intelligence and reading difficulties at age seven. Dev Med Child Neurol.
40 Young AR, Beitchman JH, Johnson C, et al. (2002). Young adult academic outcomes in a longitudinal sample of early identified language impaired and control children. J Child Psychol Psychiatry.
41 Catts H, Fey M, Zhang X, et al. (2001). Estimating the risk of future reading difficulties in kindergarten children: a research-based model and its clinical implementation. Lang Speech Hear Serv Sch.
42 Tomblin JB, Zhang X, Buckwalter P, et al. (2000). The association of reading disability, behavioral disorders, and language impairment among second-grade children. J Child Psychol Psychiatry.
43 Glogowska M, Roulstone S, Peters TJ, et al. (2006). Early speech- and language-impaired children: linguistic, literacy, and social outcomes. Dev Med Child Neurol.
44 Snowling MJ, Bishop DV, Stothard SE, et al. (2006). Psychosocial outcomes at 15 years of children with a preschool history of speech-language impairment. J Child Psychol Psychiatry.
45 Delgado CEF. (2009). Fourth grade outcomes of children with a preschool history of developmental disability. Educat Train Dev Dis.
46 Law J, Rush R, Schoon I, et al. (2009). Modeling developmental language difficulties from school entry into adulthood: literacy, mental health, and employment outcomes. J Speech Lang Hear Res.
47 Cohen NJ, Barwick MA, Horodezky NB, et al. (1998). Language, achievement, and cognitive processing in psychiatrically disturbed children with previously identified and unsuspected language impairments. J Child Psychol Psychiatry.
48 Cohen NJ, Menna R, Vallance DD, et al. (1998). Language, social cognitive processing, and behavioral characteristics of psychiatrically disturbed children with previously identified and unsuspected language impairments. J Child Psychol Psychiatry.
49 Council on Children with Disabilities. (2006). Identifying infants and young children with developmental disorders in the medical home: an algorithm for developmental surveillance and screening. Pediatrics.
50 American Academy of Pediatrics. (1990). Bright Futures.
51 Glascoe FP, Shouse H, Woods SK, et al. (2013). Parents’ Evaluation of Developmental Status (PEDS).
52 Frankenburg WK, Dodds J, Archer P, et al. (1992). The Denver II: a major revision and restandardization of the Denver Developmental Screening Test. Pediatrics.
53 Squires J, Bricker D. (2009). Ages & Stages Questionnaires (ASQ-3).
54 Rescorla L. (1989). The Language Development Survey: a screening tool for delayed language in toddlers. J Speech Hear Disord.
55 Fenson L, Marchman VA, Thal DJ, et al. (2006). The MacArthur-Bates Communicative Development Inventories User’s Guide and Technical Manual.
56 American Speech-Language-Hearing Association. American Speech-Language-Hearing Association; 1997–2013.
57 Baker E, McLeod S. (2011). Evidence-based practice for children with speech sound disorders: part 2 application to clinical practice. Lang Speech Hear Serv Sch.
58 (2005). Kamhi AG, Pollock KE, editors. Phonological Disorders in Children: Clinical Decision Making in Assessment and Intervention.
59 Pickstone C, Goldbart J, Marshall J, et al. (2009). A systematic review of environmental interventions to improve child language outcomes for children with or at risk of primary language impairment. J Res Spec Educat Needs.
60 Snowling MJ, Hulme C. (2012). Interventions for children’s language and literacy difficulties. Int J Lang Commun Disord.
61 Boyle J, McCartney E, O’Hare A, et al. (2010). Intervention for mixed receptive-expressive language impairment: a review. Dev Med Child Neurol.
62 Burne B, Knafelc V, Melonis M, et al. (2011). The use and application of assistive technology to promote literacy in early childhood: a systematic review. Disabil Rehabil Assist Technol.
63 Desch LW, Gaebler-Spira D. (2008). Prescribing assistive-technology systems: focus on children with impaired communication. Pediatrics.
64 Nelson HD, Nygren P, Walker M, et al. (2006). Screening for speech and language delay in preschool children: systematic evidence review for the US Preventive Services Task Force. Pediatrics.
65 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
66 Clark JG, Jorgensen SK, Blondeau R. (1995). Investigating the validity of the Clinical Linguistic Auditory Milestone Scale. Int J Pediatr Otorhinolaryngol.
67 Levett L, Muir J. (1983). Which three year olds need speech therapy? Uses of the Levett-Muir language screening test. Health Visit.
68 Sherman T, Shulman BB, Trimm RF, et al. (1996). PLASTER: predicting communication impairments in a NICU follow-up population—Pediatric Language Acquisition Screening Tool for Early Referral. Infant Toddler Interv Transdisciplinary J.
69 Rescorla L, Hadicke-Wiley M, Escarce E. (1993). Epidemiological investigation of expressive language delay at age two. First Lang.
70 De Koning HJ, de Ridr-Sluiter JG, van Agt HME, et al. (2004). A cluster-randomised trial of screening for language disorders in toddlers. J Med Screen.
71 Van Agt HM, van der Stege HA, de Ridder-Sluiter H, et al. (2007). A cluster-randomized trial of screening for language delay in toddlers: effects on school performance and language development at age 8. Pediatrics.
72 Frisk V, Montgomery L, Boychyn E, et al. (2009). Why screening Canadian preschoolers for language delays is more difficult than it should be. Infants Young Child.
73 Guiberson M, Rodriguez BL. (2010). Measurement properties and classification accuracy of two Spanish parent surveys of language development for preschool-age children. Am J Speech Lang Pathol.
74 Guiberson M, Rodriguez BL, Dale PS. (2011). Classification accuracy of brief parent report measures of language development in Spanish-speaking toddlers. Lang Speech Hear Serv Sch.
75 Heilmann J, Weismer SE, Evans J, et al. (2005). Utility of the MacArthur-Bates Communicative Development Inventory in identifying language abilities of late-talking and typically developing toddlers. Am J Speech Lang Pathol.
76 Sachse S, Von Suchodoletz W. (2008). Early identification of language delay by direct language assessment or parent report?. J Dev Behav Pediatr.
77 Sachse S, Von Suchodoletz W. (2009). J Dev Behav Pediatr.
78 Westerlund M, Berglund E, Eriksson M. (2006). Can severely language delayed 3-year-olds be identified at 18 months? Evaluation of a screening version of the MacArthur-Bates Communicative Development Inventories. J Speech Lang Hear Res.
79 Elbaum B, Gattamorta KA, Penfield RD. (2010). Evaluation of the Battelle Developmental Inventory, 2nd Edition, Screening Test for use in states’ child outcomes measurement systems under the Individuals with Disabilities Education Act. J Early Interv.
80 Skarakis-Doyle E, Campbell W, Dempsey L. (2009). Identification of children with language impairment: investigating the classification accuracy of the MacArthur-Bates Communicative Development Inventories, Level III. Am J Speech Lang Pathol.
81 Henrichs J, Rescorla L, Schenk JJ, et al. (2011). Examining continuity of early expressive vocabulary development: the generation R study. J Speech Lang Hear Res.
82 Heo KH, Squires J, Yovanoff P. (2008). Cross-cultural adaptation of a pre-school screening instrument: comparison of Korean and US populations. J Intellect Disabil Res.
83 Mossabeb R, Wade KC, Finnegan K, et al. (2012). Language development survey provides a useful screening tool for language delay in preterm infants. Clin Pediatr (Phila).
84 Sices L, Stancin T, Kirchner HL, et al. (2009). PEDS and ASQ developmental screening tests may not identify the same children. Pediatrics.
85 Van Agt HM, van der Stege HA, de Ridder-Sluiter JG, et al. (2007). Detecting language problems: accuracy of five language screening instruments in preschool children. Dev Med Child Neurol.
86 Rigby MJ, Chesham I. (1981). A trial speech screening test for school entrants. Br Med J (Clin Res Ed).
87 Coulter L, Gallagher C. (2001). Piloting new ways of working: evaluation of the WILSTAAR Programme. Int J Lang Commun Disord.
88 Wetherby AM, Goldstein H, Clearly J, et al. (2003). Early identification of children with communication disorders: concurrent and predictive validity of the CSBS Developmental Profile. Infants Young Child.
89 Law J, Boyle J, Harris F, et al. (1998). Screening for speech and language delay: a systematic review of the literature. Health Technol Assess.
90 Nelson HD, Nygren P, Walker M, et al. (2006). Screening for Speech and Language Delay in Preschool Children.
91 Alberts FM, Davis BL, Prentice L. (1995). Validity of an observation screening instrument in a multicultural population. J Early Interv.
92 Allen DV, Bliss LS. (1987). Concurrent validity of two language screening tests. J Commun Disord.
93 Bliss LS, Allen DV. (1984). Screening Kit of Language Development: a preschool language screening instrument. J Commun Disord.
94 Borowitz KC, Glascoe FP. (1986). Sensitivity of the Denver Developmental Screening Test in speech and language screening. Pediatrics.
95 Burden V, Stott CM, Forge J, et al. (1996). The Cambridge Language and Speech Project (CLASP). I. Detection of language difficulties at 36 to 39 months. Dev Med Child Neurol.
96 Dixon J, Kot A, Law J. (1988). Early language screening in City and Hackney: work in progress. Child Care Health Dev.
97 Drumwright A, Van Natta P, Camp B, et al. (1973). The Denver articulation screening exam. J Speech Hear Disord.
98 Klee T, Carson DK, Gavin WJ, et al. (1998). Concurrent and predictive validity of an early language screening program. J Speech Lang Hear Res.
99 Laing GJ, Law J, Levin A, et al. (2002). Evaluation of a structured test and a parent led method for screening for speech and language problems: prospective population based study. BMJ.
100 Law J. (1994). Early language screening in City and Hackney: the concurrent validity of a measure designed for use with 2 1/2-year-olds. Child Care Health Dev.
101 McGinty C. (2000). An investigation into aspects of the Mayo early language screening test. Child Care Health Dev.
102 Rescorla L, Alley A. (2001). Validation of the Language Development Survey (LDS): a parent report tool for identifying language delay in toddlers. J Speech Lang Hear Res.
103 Stokes SF. (1997). Secondary prevention of paediatric language disability: a comparison of parents and nurses as screening agents. Eur J Disord Commun.
104 Stott CM, Merricks MJ, Bolton PF, et al. (2002). Screening for speech and language disorders: the reliability, validity and accuracy of the General Language Screen. Int J Lang Commun Disord.
105 Sturner RA, Heller JH, Funk SG, et al. (1993). The Fluharty Preschool Speech and Language Screening Test: a population-based validation study using sample-independent decision rules. J Speech Hear Res.
106 Sturner RA, Funk SG, Green JA. (1996). Preschool speech and language screening: further validation of the sentence repetition screening test. J Dev Behav Pediatr.
107 Walker D, Gugenheim S, Downs MP, et al. (1989). Early Language Milestone Scale and language screening of young children. Pediatrics.
108 Ward S. (1984). Detecting abnormal auditory behaviours in infancy: the relationship between such behaviours and linguistic development. Br J Disord Commun.
109 Oakenfull S, McGregor T, Ramtin F, et al. (2001). Re: WILSTAAR. Int J Lang Commun Disord.
110 Merrell AW, Plante E. (1997). Norm-referenced test interpretation in the diagnostic process. Lang Speech Hear Ser Schools.
111 Black MM, Gerson LF, Freeland CA, et al. (1988). Language screening for infants prone to otitis media. J Pediatr Psychol.
112 Blaxley L, Clinker M, Warr-Leeper GA. (1983). Two language screening tests compared with developmental sentence scoring. Lang Speech Hear Ser Schools.
113 Chaffee CA, Cunningham CE, Secord-Gilbert M, et al. (1990). Screening effectiveness of the Minnesota Child Development Inventory Expressive and Receptive Language Scales: sensitivity, specificity, and predictive value. Psychol Assess.
114 Dodge GR. (1980). A comparison of language screening methods. Lang Speech Hear Ser Schools.
115 Glascoe FP. (1991). Can clinical judgment detect children with speech-language problems?. Pediatrics.
116 Plante E, Vance R. (1995). Diagnostic accuracy of two tests of preschool language. Am J Speech Lang Pathol.
117 Scherer NJ, D’Antonio LL. (1995). Parent questionnaire for screening early language development in children with cleft palate. Cleft Palate Craniofac J.
118 Wilcox LD, Anderson RT. (1998). Distinguishing between phonological difference and disorder in children who speak African-American vernacular English: an experimental testing instrument. J Commun Disord.
119 Feeney J, Bernthal J. (1996). The efficiency of the revised Denver Developmental Screening Test as a language screening tool. Lang Speech Hear Ser Schools.
120 German ML, Williams E, Herzfeld J, et al. (1982). Utility of the Revised Denver Developmental Screening Test and the Developmental Profile II in identifying preschool children with cognitive, language, and motor problems. Educ Train Mental Retard.
121 Rescorla L, Achenbach TM. (2002). Use of the Language Development Survey (LDS) in a national probability sample of children 18 to 35 months old. J Speech Lang Hear Res.
122 Klee T, Pearce K, Carson DK. (2000). Improving the positive predictive value of screening for developmental language disorder. J Speech Lang Hear Res.
123 Hamm RM. (2004). Clinical Decision Making Calculators.
124 Ebell M, Barry H. (2008). Likelihood Ratios Part 1: Introduction.
125 Fricke S, Bowyer-Crane C, Haley AJ, et al. (2013). Efficacy of language intervention in the early years. J Child Psychol Psychiatry.
126 Jones M, Onslow M, Packman A, et al. (2005). Randomised controlled trial of the Lidcombe programme of early stuttering intervention. BMJ.
127 Lewis C, Packman A, Onslow M, et al. (2008). A phase II trial of telehealth delivery of the Lidcombe Program of Early Stuttering Intervention. Am J Speech Lang Pathol.
128 Wake M, Tobin S, Girolametto L, et al. (2011). Outcomes of population based language promotion for slow to talk toddlers at ages 2 and 3 years: Let’s Learn Language cluster randomised controlled trial. BMJ.
129 Yoder P, Camarata M, Gardner E. (2005). Treatment effects on speech intelligibility and length of utterance in children with specific language and intelligibility impairments. J Early Interv.
130 Wake M, Tobin S, Levickis P, et al. (2013). Randomized trial of a population-based, home-delivered intervention for preschool language delay. Pediatrics.
131 Morgan AT, Vogel AP. (2009). A Cochrane review of treatment for childhood apraxia of speech. Eur J Phys Rehabil Med.
132 Denne M, Langdown N, Pring T, et al. (2005). Treating children with expressive phonological disorders: does phonological awareness therapy work in the clinic?. Int J Lang Commun Disord.
133 Grogan-Johnson S, Alvares R, Rowan L, et al. (2010). A pilot study comparing the effectiveness of speech language therapy provided by telemedicine with conventional on-site therapy. J Telemed Telecare.
134 Almost D, Rosenbaum P. (1998). Effectiveness of speech intervention for phonological disorders: a randomized controlled trial. Dev Med Child Neurol.
135 Glogowska M, Roulstone S, Enderby P, et al. (2000). Randomised controlled trial of community based speech and language therapy in preschool children. BMJ.
136 Gibbard D. (1994). Parental-based intervention with pre-school language-delayed children. Eur J Disord Commun.
137 Girolametto L, Pearce PS, Weitzman E. (1996). Interactive focused stimulation for toddlers with expressive vocabulary delays. J Speech Hear Res.
138 Girolametto L, Pearce PS, Weitzman E. (1997). Effects of lexical intervention on the phonology of late talkers. J Speech Lang Hear Res.
139 Robertson SB, Ellis Weismer S. (1999). Effects of treatment on linguistic and social skills in toddlers with delayed language development. J Speech Lang Hear Res.
140 Robertson SB, Ellis Weismer S. (1997). The influence of peer models on the play scripts of children with specific language impairment. J Speech Lang Hear Res.
141 Shelton RL, Johnson AF, Ruscello DM, et al. (1978). Assessment of parent-administered listening training for preschool children with articulation deficits. J Speech Hear Disord.
142 Barratt J, Littlejohns P, Thompson J. (1992). Trial of intensive compared with weekly speech therapy in preschool children. Arch Dis Child.
143 Cole KN, Dale PS. (1986). Direct language instruction and interactive language instruction with language delayed preschool children: a comparison study. J Speech Hear Res.
144 Courtright JA, Courtright IC. (1979). Imitative modeling as a language intervention strategy: the effects of two mediating variables. J Speech Hear Res.
145 Rvachew S, Nowak M. (2001). The effect of target-selection strategy on phonological learning. J Speech Lang Hear Res.
146 Wilcox MJ, Kouri TA, Caswell SB. (1991). Early language intervention: a comparison of classroom and individual treatment. Am J Speech-Lang Path.
147 Law J, Kot A, Barnett G. (1999). A Comparison of Two Methods for Providing Intervention to Three Year Old Children With Expressive/Receptive Language Impairment.
148 Manolson HA, Ward B, Doddington N. (1995). You Make the Difference in Helping Your Child Learn.
149 Bowyer-Crane C, Snowling MJ, Duff FJ, et al. (2008). Improving early language and literacy skills: differential effects of an oral language versus a phonology with reading intervention. J Child Psychol Psychiatry.
150 Boyle J, McCartney E, Forbes J, et al. (2007). A randomised controlled trial and economic evaluation of direct versus indirect and individual versus group modes of speech and language therapy for children with primary language impairment. Health Technol Assess.
151 Zimmerman I, Steiner B, Pond R. (1992). Preschool Language Scale.
152 Fudala J, Reynolds W. (1986). Arizona Articulation Proficiency Scale.
153 Lee LL. (1971). Northwestern Syntax Screening Test.
154 Bird J, Bishop DV, Freeman NH. (1995). Phonological awareness and literacy development in children with expressive phonological impairments. J Speech Hear Res.
155 Catts HW. (1993). The relationship between speech-language impairments and reading disabilities. J Speech Hear Res.
156 Pagel Paden E, Novak MA, Beiter AL. (1987). Predictors of phonologic inadequacy in young children prone to otitis media. J Speech Hear Disord.
157 Hodson B, Pagels Paden E. (1991). Targeting Intelligible Speech: A Phonological Approach to Remediation.
158 Hodson B. (1986). The Assessment of Phonological Processes-Revised.
159 Goldman H, Fristoe M. (1969). Goldman-Fristoe Test of Articulation.
160 (2003). Onslow M, Packman A, Harrison E, editors. The Lidcombe Program of Early Stuttering Intervention: A Clinician’s Guide.
161 Cohen J. (1988). Statistical Power Analysis for the Behavioral Sciences.
162 Ferguson CJ. (2009). An effect size primer: a guide for clinicians and researchers. Prof Psychol.
163 Macias MM. (2006). Developmental Screening Tools, D-PIP Training Workshop.
164 Sturner RA, Kunze L, Funk SG, et al. (1993). Elicited imitation: its effectiveness for speech and language screening. Dev Med Child Neurol.
165 Alston E, St James-Roberts I. (2005). Home environments of 10-month-old infants selected by the WILSTAAR screen for pre-language difficulties. Int J Lang Commun Disord.
166 Pruitt SL, Garrity AW, Oetting JB. (2010). Family history of speech and language impairment in African American children: implications for assessment. Topics Lang Disord.
167 Tomblin JB, Hardy JC, Hein HA. (1991). Predicting poor-communication status in preschool children using risk factors present at birth. J Speech Hear Res.
168 Tomblin JB, Smith E, Zhang X. (1997). Epidemiology of specific language impairment: prenatal and perinatal risk factors. J Commun Disord.
169 Whitehurst GJ, Arnold DS, Smith M, et al. (1991). Family history in developmental expressive language delay. J Speech Hear Res.
170 Weindrich D, Jennen-Steinmetz C, Laucht M, et al. (2000). Epidemiology and prognosis of specific disorders of language and scholastic skills. Eur Child Adolesc Psychiatry.
171 Desmarais C, Sylvestre A, Meyer F, et al. (2008). Systematic review of the literature on characteristics of late-talking toddlers. Int J Lang Commun Disord.
172 Law J, Rush R, Anandan C, et al. (2012). Predicting language change between 3 and 5 years and its implications for early identification. Pediatrics.
173 Campbell TF, Dollaghan CA, Rockette HE, et al. (2003). Risk factors for speech delay of unknown origin in 3-year-old children. Child Dev.
174 Hammer CS, Farkas G, Maczuga S. (2010). The language and literacy development of Head Start children: a study using the Family and Child Experiences Survey Database. Lang Speech Hear Ser Schools.
175 Choudhury N, Benasich AA. (2003). A family aggregation study: the influence of family history and other risk factors on language development. J Speech Lang Hear Res.
176 Zubrick SR, Taylor CL, Rice ML, et al. (2007). Late language emergence at 24 months: an epidemiological study of prevalence, predictors, and covariates. J Speech Lang Hear Res.
177 Reilly S, Onslow M, Packman A, et al. (2009). Predicting stuttering onset by the age of 3 years: a prospective, community cohort study. Pediatrics.
178 Reilly S, Wake M, Bavin EL, et al. (2007). Predicting language at 2 years of age: a prospective community study. Pediatrics.
179 Harrison LJ, McLeod S. (2010). Risk and protective factors associated with speech and language impairment in a nationally representative sample of 4- to 5-year-old children. J Speech Lang Hear Res.
180 Adams-Chapman I, Bann CM, Vaucher YE, et al. (2013). Association between feeding difficulties and language delay in preterm infants using Bayley Scales of Infant Development-Third Edition. J Pediatr.
181 Reilly S, Onslow M, Packman A, et al. (2013). Natural history of stuttering to 4 years of age: a prospective community-based study. Pediatrics.
182 Tallal P, Ross R, Curtiss S. (1989). Familial aggregation in specific language impairment. J Speech Hear Disord.
183 Pena ED, Gillam RB, Bedore LM, et al. (2011). Risk for poor performance on a language screening measure for bilingual preschoolers and kindergarteners. Am J Speech Lang Pathol.
184 Singer LT, Siegel AC, Lewis B, et al. (2001). Preschool language outcomes of children with history of bronchopulmonary dysplasia and very low birth weight. J Dev Behav Pediatr.
185 Foster-Cohen SH, Friesen MD, Champion PR, et al. (2010). High prevalence/low severity language delay in preschool children born very preterm. J Dev Behav Pediatr.
186 Kerstjens JM, Bos AF, ten Vergert EMJ, et al. (2009). Support for the global feasibility of the Ages and Stages Questionnaire as developmental screener. Early Hum Dev.
187 Zambrana IM, Pons F, Eadie P, et al. (2014). Trajectories of language delay from age 3 to 5: persistence, recovery and late onset. Int J Lang Commun Disord.
188 Fox AV, Dodd B, Howard D. (2002). Risk factors for speech disorders in children. Int J Lang Commun Disord.
189 Kerstjens JM, de Winter AF, Bocca-Tjeertes IF, et al. (2011). Developmental delay in moderately preterm-born children at school entry. J Pediatr.
190 Kerstjens JM, de Winter AF, Bocca-Tjeertes IF, et al. (2012). Risk of developmental delay increases exponentially as gestational age of preterm infants decreases: a cohort study at age 4 years. Dev Med Child Neurol.
191 Potijk MR, Kerstjens JM, Bos AF, et al. (2013). Developmental delay in moderately preterm-born children with low socioeconomic status: risks multiply. J Pediatr.
192 Schjolberg S, Eadie P, Zachrisson HD, et al. (2011). Predicting language development at age 18 months: data from the Norwegian Mother and Child Cohort Study. J Dev Behav Pediatr.
193 Van Lierde KM, Roeyers H, Boerjan S, et al. (2009). Expressive and receptive language characteristics in three-year-old preterm children with extremely low birth weight. Folia Phoniatrica et Logopaedica.
194 Williams C. (2006). Teacher judgements of the language skills of children in the early years of schooling. Child Lang Teach Ther.
195 Whitehouse AJ, Robinson M, Zubrick SR. (2011). Late talking and the risk for psychosocial problems during childhood and adolescence. Pediatrics.
196 Conti-Ramsden G. (2003). Processing and linguistic markers in young children with specific language impairment (SLI). J Speech Lang Hear Res.
197 Coplan J, Gleason JR, Ryan R, et al. (1982). Validation of an early language milestone scale in a high-risk population. Pediatrics.
198 Glascoe FP, Byrne KE. (1993). The accuracy of three developmental screening tests. J Early Interv.
199 Leppert ML, Shank TP, Shapiro BK, et al. (1998). The capute scales: CAT/CLAMS-A pediatric assessment tool for the early detection of mental retardation and communicative disorders. Ment Retard Dev Disabil Res Rev.
200 Macias MM, Saylor CF, Greer MK, et al. (1998). Infant screening: the usefulness of the Bayley Infant Neurodevelopmental Screener and the Clinical Adaptive Test/Clinical Linguistic Auditory Milestone Scale. J Dev Behav Pediatr.
201 Law J, Garrett Z, Nye C. (2003). Speech and language therapy interventions for children with primary speech and language delay or disorder. Cochrane Database Syst Rev.
202 Alvik A, Groholt B. (2011). Examination of the cut-off scores determined by the Ages and Stages Questionnaire in a population-based sample of 6 month-old Norwegian infants. BMC Pediatr.
203 Dionne C, Squires J, Leclerc D, et al. (2006). Cross-cultural comparison of a French Canadian and U.S. developmental screening test. Dev Disabil Bull.
204 Fenson L, Marchman VA, Thal DJ, et al. (2007). MacArthur-Bates Communicative Development Inventories: Users Guide and Technical Manual.
205 Fluharty NB. (1974). The design and standardization of a speech and language screening test for use with preschool children. J Speech Hear Disord.
206 Jackson-Maldonado D, Marchman VA, Fernald LCH. (2013). Short-form versions of the Spanish MacArthur–Bates Communicative Development Inventories. Appl Psycholinguist.
207 Rescorla L, Ratner NB, Jusczyk P, et al. (2005). Concurrent validity of the language development survey: associations with the MacArthur-Bates communicative development inventories: words and sentences. Am J Speech Lang Pathol.
208 Squires J, Potter L, Bricker D. (1999). Ages and Stages Questionnaire User’s Guide.
209 Sturner RS, Layton TL, Evans AW, et al. (1994). Preschool speech and language screening: a review of currently available tests. Am J Speech Lang Pathol.
210 Vach W, Bleses D, Jorgensen R. (2010). Construction of a Danish CDI short form for language screening at the age of 36 months: methodological considerations and results. Clin Linguist Phon.
211 Westerlund M, Eriksson M, Berglund E. (2004). A short-term follow-up of children with poor word production at the age of 18 months. Acta Paediatr.
212 Wetherby AM, Allen L, Cleary J, et al. (2002). Validity and reliability of the Communication and Symbolic Behavior Scales Developmental Profile with very young children. J Speech Lang Hear Res.
213 Brookhouser PE, Hixson PK, Matkin ND. (1979). Early childhood language delay: the otolaryngologist’s perspective. Laryngoscope.
214 Cantwell DP, Baker L. (1985). Psychiatric and learning disorders in children with speech and language disorders: a descriptive analysis. Adv Learning Behav Disabilities.
215 Everitt A, Hannaford P, Conti-Ramsden G. (2013). Markers for persistent specific expressive language delay in 3–4-year-olds. Int J Lang Commun Disord.
216 Glascoe FP, Leew S. (2010). Parenting behaviors, perceptions, and psychosocial risk: impacts on young children’s development. Pediatrics.
217 Klein PS, Tzuriel D. (1986). Preschoolers type of temperament as predictor of potential difficulties in cognitive functioning. Isr J Psychiatry Relat Sci.
218 Kloth S, Janssen P, Kraaimaat F, et al. (1995). Communicative behavior of mothers of stuttering and nonstuttering high-risk children prior to the onset of stuttering. J Fluency Disord.
219 Lyytinen H, Ahonen T, Eklund K, et al. (2001). Developmental pathways of children with and without familial risk for dyslexia during the first years of life. Dev Neuropsychol.
220 O’Leary C, Zubrick SR, Taylor CL, et al. (2009). Prenatal alcohol exposure and language delay in 2-year-old children: the importance of dose and timing on risk. Pediatrics.
221 Peters SA, Grievink EH, van Bon WH, et al. (1997). The contribution of risk factors to the effect of early otitis media with effusion on later language, reading, and spelling. Dev Med Child Neurol.
222 Roth C, Magnus P, Schjolberg S, et al. (2011). Folic acid supplements in pregnancy and severe language delay in children. JAMA.
223 Van Batenburg-Eddes T, Henrichs J, Schenk JJ, et al. (2013). Early infant neuromotor assessment is associated with language and nonverbal cognitive function in toddlers: the Generation R Study. J Dev Behav Pediatr.
224 Yliherva A, Olsen P, Maki-Torkko E, et al. (2001). Linguistic and motor abilities of low-birthweight children as assessed by parents and teachers at 8 years of age. Acta Paediatr.
225 Fey ME, Cleave PL, Long SH, et al. (1993). Two approaches to the facilitation of grammar in children with language impairment: an experimental evaluation. J Speech Hear Res.
226 Fey ME, Cleave PL, Ravida AI, et al. (1994). Effects of grammar facilitation on the phonological performance of children with speech and language impairments. J Speech Hear Res.
227 Fey ME, Cleave PL, Long SH. (1997). Two models of grammar facilitation in children with language impairments: phase 2. J Speech Lang Hear Res.
228 Girolametto L, Pearce PS, Weitzman E. (1996). The effects of focused stimulation for promoting vocabulary in young children with delays: a pilot study. J Child Commun Dev.
229 Glogowska M, Campbell R, Peters TJ, et al. (2002). A multimethod approach to the evaluation of community preschool speech and language therapy provision. Child Care Health Dev.
230 Mulac A, Tomlinson CN. (1977). Generalization of an operant remediation program for syntax with language delayed children. J Commun Disord.
231 Schwartz RG, Chapman K, Terrell BY, et al. (1985). Facilitating word combination in language-impaired children through discourse structure. J Speech Hear Disord.