# 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope, KQs, and analytic framework (Figure 1) that guided the literature search and review. The KQs are listed below.

Figure 1 Analytic Framework

a Excluding children with diagnosed disorders including autism, mental retardation, Fragile X, hearing loss, degenerative and other neurologic conditions.

b School performance, behavioral competence, socioemotional development, quality of life, and others.

This figure is an analytic framework depicting the key questions (KQs) relevant to screening and interventions for speech and language delays in children age 5 years or younger. The figure illustrates the relationship between screening, surveillance, referral, diagnosis, and interventions for speech and language delays. KQ1 concerns the relationship between screening and the ultimate outcomes of interest: improved speech and language or improved nonspeech and language outcomes. The population (children age 5 years or younger) is shown as either screening positive or negative. For children who screen negative, the path leads to surveillance at nonscreening visits and cycles back to a screening evaluation. For children who screen positive, the path leads to referral to a diagnostic evaluation (KQ2). Based on the diagnostic evaluation, the framework depicts a path to the endpoint of other diagnostic concerns, no delay or disorder detected, or to an intervention. Interventions for speech and language delays or disorders result in outcomes concerning whether there is improved speech and language (KQ5) and improved nonspeech and language skills and abilities (KQ6). Adverse effects of screening (KQ3) and adverse effects of interventions (KQ7) are also shown.

### Key Questions

1. Does screening for speech and language delays or disorders lead to improved speech and language outcomes as well as improved outcomes in domains other than speech and language?
2. Do screening evaluations in the primary care setting accurately identify children for diagnostic evaluations and interventions?
  a. What is the accuracy of these screening techniques, and does it vary by age, cultural/linguistic background, whether the screening is conducted in a child’s native language, or how the screening is administered (i.e., parent report, parent interview, or direct assessment of child by professional)?
  b. What are the optimal ages and frequency for screening?
  c. Is selective screening based on risk factors more effective than unselected, general-population screening?
  d. Does the accuracy of selective screening vary based on risk factors? Is the accuracy of screening different for children with an inherent language disorder compared with children whose language delay is due to environmental factors?
3. What are the adverse effects of screening for speech and language delays or disorders?
4. Does surveillance (active monitoring) by primary care clinicians play a role in accurately identifying children for diagnostic evaluations and interventions?
5. Do interventions for speech and language delays or disorders improve speech and language outcomes?
6. Do interventions for speech and language delays or disorders improve other outcomes, such as academic achievement, behavioral competence, socioemotional development, or health outcomes, such as quality of life?
7. What are the adverse effects of interventions for speech and language delays or disorders (e.g., time, stress, and stigma)?

### Contextual Questions

We included three contextual questions to help inform the report. We do not show these questions in the analytic framework because they were not analyzed using the same rigorous systematic review methodology as the studies that met the report’s inclusion criteria. At the title and abstract and full-text article review stages, reviewers categorized studies not included to answer KQs that related to the specific contextual questions.

We addressed techniques of screening, risk factors for speech and language delays or disorders, and the role of primary care providers if screening is conducted in other venues via the following contextual questions:

1. What are the techniques for screening for speech and language delays or disorders, and do they differ by the child’s age or cultural background?
2. What risk factors are associated with speech and language delays or disorders?
3. What is the role of primary care providers in screening children age 5 years or younger that is performed in other venues (such as Head Start or preschool)?

### Search Strategies

We searched PubMed/MEDLINE^®^, the Cochrane Library, PsycInfo^®^, and CINAHL for English-language articles published from January 1, 2004 through July 20, 2014. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, screening tests, interventions, outcomes, and study designs. Appendix A describes the complete search strategies. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles.

## Study Selection

We selected studies on the basis of inclusion and exclusion criteria developed for each KQ based on the PICOTS approach for identifying populations, interventions, comparators, outcomes, timing, settings, and study designs (Appendix A). Appendix B lists the excluded studies. We imported all citations identified through searches and other sources into EndNote X7. Two investigators independently reviewed titles and abstracts. We dually and independently reviewed the full text of abstracts marked for potential inclusion by either reviewer. Two experienced team members then resolved disagreements.

### Population

We included studies that focused on screening in children age 5 years or younger. Also, all children who scored positive on a screening had to receive diagnostic assessments for speech or language delays or disorders by age 6 years. Treatment studies had to focus on the treatment of children who were screened or diagnosed according to our age criteria. If studies included a mix of ages and only some children met our age requirements, the studies were included only if evidence was available for subgroups of children who met our inclusion criteria.

### Interventions

For KQs 1 through 3, we searched for studies that examined screening instruments specific to speech and language conditions, as well as more general developmental screening tools with speech and language modules, that clinicians could use to identify speech and language delays and disorders. All tools needed to be feasible for primary care settings (i.e., could be administered or interpreted by primary care providers). For KQ 4, we searched for studies that examined processes of monitoring speech and language rather than use of formal screening instruments. For KQs 5 through 7, we searched for studies that examined treatment interventions for children diagnosed with specific speech and language delays or disorders. We searched for interventions designed to improve speech or language in children, as long as diagnosis occurred at age 6 years or younger.

### Comparators

For KQs 1 and 3, we included studies that compared screened with unscreened groups. For KQ 2, we included studies that compared screening outcomes with those of a reference standard. For subparts of KQ 2, we included studies that compared screening accuracy in different subpopulations, and for KQ 4, we included studies examining surveillance versus other approaches to referral for diagnosis. For KQs 5 through 7, we included studies that compared an intervention with no intervention, delayed treatment, or watchful waiting.

### Outcomes and Timing

We searched for studies on improvements in all aspects of speech and language functioning as well as improvements in other types of functioning, such as emergent academic skills, academic achievement (e.g., reading, writing, spelling, arithmetic), behavior competence, socioemotional functioning, quality of life, and parental satisfaction. Additionally, we excluded any screening study that did not provide test accuracy because it would prevent us from calculating sensitivity and specificity of the screening instruments.

### Settings

Screening studies had to be conducted within a primary care setting or screening instruments had to be interpretable in a primary care setting (KQs 1 through 4). Treatment studies were not limited by location and could be conducted in speech and language clinics, schools, or homes (KQs 5 through 7). For all KQs, we limited our search to studies conducted in the United States or in countries with a high Human Development Index.

## Study Designs

For KQs 1 through 4, we included randomized, controlled trials (RCTs); cohort studies; and systematic reviews. For KQs 5 through 7, we included RCTs and systematic reviews of RCTs. We systematically searched for studies for all KQs from 2004 forward, and we hand-searched the references from included systematic reviews. Studies identified from the hand search could have been published at any time.

### Studies in the 2006 Review

We applied the inclusion and exclusion criteria dually and independently to all studies included in the 2006 review.64 We resolved disagreements by discussion and consensus; if necessary, we sought adjudication of conflicts from other experienced team members. We also conducted a check of the quality rating to ensure that studies met our current quality rating criteria. If the reviewer did not agree with this earlier assessment, we re-rated the quality of the study through dual review. Among included studies from the 2006 report, one reviewer checked for errors in previously generated abstraction tables and updated them as needed.

### Newly Identified Studies

We abstracted pertinent information from each newly included study; details include methods and patient characteristics. A second investigator checked all data abstractions for completeness and accuracy. Using predefined criteria developed by the USPSTF and others, two investigators independently assessed the quality of each study as good, fair, or poor. Appendix C describes the quality rating criteria.65 Disagreements were resolved by discussion and consensus. Studies with fatal flaws were rated as poor quality. For KQ 2, fatal flaws that could result in poor-quality ratings included use of an inappropriate reference standard (i.e., a reference standard not typically used by speech-language pathologists for diagnosis of speech and language disorders), improper administration of the screening test, biased ascertainment of the reference standard, very small sample size, or a very narrowly selected spectrum of patients. For KQs 5 and 6, fatal flaws that could result in poor-quality ratings included assembly of groups that were not initially comparable or maintained throughout the study, use of unreliable or invalid measurement instruments or instruments that were not applied equally across groups (including not masking outcome assessment), lack of intention-to-treat analysis, a very high rate of loss to followup, or important differential loss to followup.

## Data Synthesis and Analysis

In the Results, we first summarize the newly identified studies that met inclusion criteria. We then describe the previously identified studies that continue to meet current inclusion and quality criteria. Finally, we present a qualitative synthesis of previous and current findings. The Discussion summarizes conclusions from the previous review, the 2006 USPSTF recommendation statement, and the implications of the new synthesis for previous conclusions. In addition, we assess the overall summary of the body of evidence for each KQ, using methods developed by the USPSTF, based on the number, quality, and size of studies; consistency of results among studies (similar magnitude and direction of effect); and applicability of the results to the population of interest.

## Expert Review and Public Comment

A draft report was reviewed by outside content experts, USPSTF members, and AHRQ Medical Officers and was posted for public comment on the USPSTF Web site from November 18 to December 15, 2014. In response to public comments, the EPC authors added three additional comments to the Discussion section of the report. The first is a reminder to the reader that the findings apply to children without developmental disabilities and that the review does not address speech and language screening in children with intellectual disabilities, sensory or motor impairments, or structural abnormalities of the head or neck. The second concerns factors that may be associated with the effectiveness of treatment. We note that we are unable to comment on the minimum amount of intensity required for a treatment to likely be effective, and that intensity alone cannot account for either positive or null findings among treatment trials. Third, we specifically acknowledge the need for studies of children who are non-English speakers. Lastly, while we agree that consideration of risk factors may improve screening accuracy, we found no relevant studies.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.