# 1 Introduction

## Overview and Objective

This systematic review provides evidence to be used to update U.S. Preventive Services Task Force (USPSTF) recommendations released in 2006 concerning screening preschool children (i.e., children age 5 years or younger) for language delays and disorders in primary care settings. The 2006 USPSTF recommendation and conclusions, which are described below, provide the context and rationale for the current update. The rest of the Introduction includes a description of speech and language delays and disorders in children age 5 years or younger; an overview of the epidemiology of the condition; a description of screening, intervention, and current clinical practice; and a discussion and justification of the changes in scope of the current review. The Methods section describes the Key Questions (KQs), contextual questions, and analytic framework that guided this update review, as well as the search strategy, study selection, data abstraction, quality rating, and data analyses. The Results section presents findings organized by KQ. The Discussion section summarizes the findings and presents information on the applicability and context of the findings; any limitations, gaps, and future research needs; and conclusions.

## Previous USPSTF Recommendation and Conclusions

In 2006, the USPSTF concluded that the evidence was insufficient to recommend for or against routine use of brief, formal screening instruments in primary care to detect speech and language delays in children age 5 years or younger (I recommendation).

### Importance

The USPSTF noted that speech and language delays affect up to 8 percent of preschool-age children and, if untreated, often persist into the school years. Such delays may be associated with diminished school achievement and behavioral problems.

### Detection

The USPSTF concluded that there was insufficient evidence that brief instruments suitable for use in primary care can accurately identify speech and language delays in preschool-age children. Although there is extensive literature evaluating the reliability and validity of many instruments, the optimal method of screening for speech and language delays or disorders has not been identified.

### Benefits of Detection and Early Intervention

Although the USPSTF did not find evidence that screening for speech and language delays is beneficial for identifying children who would profit from further assessment and intervention, it found fair evidence that speech and language interventions can improve outcomes in the short term. However, the USPSTF noted that no studies evaluated whether brief screening yields any benefits beyond those that are found by addressing clinical or parent concerns.

### Harms of Detection and Early Treatment

The USPSTF indicated that no studies addressed the harms of either screening or intervention for speech and language delays. Thus, it was unable to determine the benefit-harm ratio of using brief, formal screening instruments to screen for these delays in the primary care setting.

### Risk Factors and Prevalence Rates

The USPSTF was unable to develop a list of specific risk factors to guide primary care providers in selective screening. The most consistently reported risk factors included a family history of speech and language delays, male sex, and perinatal factors, such as prematurity and low birth weight. In studies that evaluated speech and language delays in preschool children ages 2 to 4.5 years, the prevalence of speech and language delays ranged from 5 to 8 percent, while studies of only language delays reported rates of 2.3 to 19 percent.

## Condition Definition

A speech or language delay implies that the child is developing speech or language in the correct sequence but at a slower rate than expected, while a speech or language disorder suggests that the child’s speech or language ability is qualitatively different from typical development.

The distinction between the two is complicated because screening instruments are unable to distinguish between a child who has a delay (i.e., a child with late-emerging language during the first 2 years of life) that subsequently resolves and one who will go on to display a speech and language disorder (i.e., a child who will later receive a formal diagnosis of specific language impairment). Some researchers report that many children with language delays, particularly in expressive language, score in the normal range by age 4 or 5 years, but that their performance is often weaker than that of children without delays.1–4 Because children with delays often test in the normal range by school age, the ability of screening instruments to make long-term predictions based solely on preschool screening findings is limited.1

Other terms used to describe speech and language delays or disorders are speech and language “disabilities” and “impairment.” In the remainder of the report, we use the terms “speech and language delay,” “speech and language disorder,” “speech and language impairment,” and “speech and language disability” interchangeably.

The Individuals with Disabilities Education Act (IDEA) defines a speech and language disability as “a communication disorder, such as stuttering, impaired articulation, a language impairment, or a voice impairment, that adversely affects a child’s educational performance.”5 Children with speech and language disorders function well below the norm for their age in one or more aspects of speech or language.

A defining feature of these disorders is whether the impairment is considered primary or secondary. In some cases, children have other developmental, sensory, or physical problems that “explain” their speech and language difficulties, such as intellectual disabilities, autism spectrum disorders, hearing loss, structural abnormalities (such as cleft lip or palate), an impairment of motor function (such as cerebral palsy), or some combination of these factors; such children are categorized as having a secondary speech and language disorder. In other cases, no specific explanation for the speech and language delay or disorder is ever identified; these children are diagnosed as having a primary language disorder. Another term for primary language disorder is specific language impairment (SLI).

Although it is likely to be useful to distinguish between primary and secondary language disorders in determining appropriate treatment, in the context of screening, it may not be possible. Early screening may flag symptoms of speech and language disorders later determined to be associated with another developmental disorder in which speech and language delays are prominent. At the time of the screening, the primary care provider will be blind to the eventual diagnostic outcome. For example, the most common early concern reported by parents prior to their children’s eventual diagnosis of autism spectrum disorder is related to speech and language development.6,7

Another way of thinking about speech and language disorders is to consider their etiology. Speech and language disorders may be acquired or developmental. In acquired cases, the language disorder is the result of an injury that occurred sometime after birth (e.g., focal lesion; acquired aphasia secondary to a seizure disorder; brain damage after tumors, infections, or radiation; and traumatic brain injury). Developmental language disorders become apparent as development unfolds but are thought to be present at birth, and often for no apparent reason. When no other condition exists that explains the language difficulty, it is labeled a primary speech or language disorder.

The focus of this review is on primary speech or language disorders whose etiology is developmental and is limited to children who have not been previously identified with another disorder or disability, not those with acquired, focal causes of speech and language delay, and with the understanding that some of the children identified will receive a primary diagnosis for a disorder such as autism or mental retardation subsequent to the screening. This may be considered an additional outcome of screening.

Other classifications of speech and language disorders consider symptoms. For example, the International Classification of Diseases (ICD), 10th edition, lists specific speech and language developmental disorders, including specific speech expressive disorder, expressive language disorder (difficulty getting a message across to others), and receptive language disorder (difficulty in understanding messages from others). The use of the modifier “specific” in the ICD-10 indicates that the disorder is not a symptom of another disorder, such as intellectual disability, hearing loss, or autism spectrum disorder. The American Speech-Language-Hearing Association (ASHA) guidelines8 describe a speech disorder as an impairment of the articulation of speech sounds, fluency, or voice, and a language disorder as impaired comprehension or use of spoken, written, or other symbol systems. ASHA further states that the disorder may involve the form of language (phonology, morphology, syntax), the content of language (semantics), and the function of language in communication (pragmatics) in any combination. Prelinguistic communication behaviors (e.g., gestures, babbling, joint attention) are important precursors of language ability; they have been found to predict language development in typically developing children9 as well as subsequent language delays.10–12 For these reasons, this review considers screening for both verbal and preverbal communication skills.

## Prevalence

Speech and language delays and disorders are common problems in pediatric populations. A systematic review conducted by Law et al13 estimated the prevalence of speech and/or language delays in children ages 2 to 5 years to be between 5 and 12 percent, with a median of 6 percent.13 This estimate was based on data from six studies on either speech or language delays among children in the United Kingdom. More specifically, the prevalence of primary language delays (not including speech) has been estimated to be between 3 and 16 percent, with a median prevalence of 7 percent. This estimate was based on eight studies of preschoolers in the United Kingdom, Canada, New Zealand, the United States, and Hong Kong.

Other studies of single populations provide similar prevalence estimates. In a population-based study in Utah of children age 8 years, the prevalence of communication disorders (speech or language), based on special education or ICD-9 classifications, was 63.4 cases per 1,000 children.14 Removing all cases identified with communication disorders that also met diagnostic criteria for autism spectrum disorder or intellectual disability, the prevalence dropped to 59.1 cases per 1,000 children. This was the only prevalence study conducted in the United States; no U.S. prevalence studies of preschool children have been conducted.

A population study in a large town in Finland reported a prevalence of 10 cases per 1,000 children for SLI (not a component of another primary diagnosis) in children age 6 years or younger.15 In a nationally representative sample of children ages 4 and 5 years in Australia, 13 percent of parents reported being “a little concerned” and 12 percent reported being “concerned” about some aspect of how their child talked and made speech sounds, and 5 percent were “a little concerned” and 4 percent were “concerned” about how their child understood language.16

Approximately 2.6 percent of children ages 3 to 5 years (298,274 children) were served under IDEA in 2007 for speech and language disabilities in the United States.17

The usefulness of language screening in the primary care setting is best measured by how well it identifies children who are not already flagged as having potential speech or language delays. Therefore, specific groups of children who would have been identified as at higher than average risk, such as children diagnosed with hearing deficits, intellectual disability, or craniofacial abnormalities, would not be considered in determining the value of screening.

## Burden

ASHA18 estimates that speech sound disorders affect 10 percent of children, the prevalence of language difficulty in preschool children is between 2 and 19 percent, and specific language impairment affects 7 percent of children. As adults, children who had speech and language disorders, especially when language is affected, may hold lower-skilled jobs and are more likely to be unemployed than unaffected children.19 According to one study detailing the economic impact of communication disorders,20 the rate of unemployment among individuals with communication impairments is 43 percent. Further, these researchers found that 44 percent of individuals whose speech makes it difficult for them to be understood are in the lowest income strata compared with 17 percent of those free of disabilities. Finally, they estimated that in 1999 dollars, the total economic impact of communication disorders, including costs of unemployment, underemployment, rehabilitation, and special education services, was approximately $154 billion, about 2.5 percent of total gross domestic product.

## Course, Comorbidity, and Sequelae

### Etiology and Natural History

In contrast to acquired speech and language disorders, developmental speech and language disorders, which are not secondary to another condition, are often of unknown origin. Still, many speech and language disorders originating in childhood are known to cluster in families.21–23 Recent studies of twins have shown a strong concordance for language impairment in monozygotic twins.24–27 The Twins Early Development Study26,27 found that concordance increases at the more extreme ends of the language impairment distribution, with genetic influences being similar for males and females. Moreover, genetic linkage studies have identified a number of candidate genes associated with stuttering, speech sound disorders, and other SLIs.22,23,28,29 Although only a small proportion of childhood speech and language disorders can be explained by genetic findings to date, the increasing sophistication of genetic approaches is likely to yield a better understanding of the role of genetics in these disorders in the near future.22,23,28,29

### Sequelae

Childhood speech and language disorders include a broad set of disorders with heterogeneous outcomes. Evidence from studies of children identified with these disorders who are followed into early school years, adolescence, and adulthood is accumulating to provide outcomes for this population. Although few of these studies account for participants’ treatment histories, it is unlikely that most individuals were completely untreated for their speech and language disorders. Thus, a true picture of the natural history of language delays and disorders is limited. Followup studies report that when young children have speech and language delays, they are at increased risk for learning disabilities once they reach school age,30 and children with both speech sound disorders and language impairment are at greatest risk for language-based learning disabilities.31,32 These children may have difficulty reading in elementary school33–36 and may have difficulty with written language.37 These issues may lead to overall academic underachievement38 and, in some cases, lower IQ scores39 that may persist into adulthood.40 Estimates of the increased risk for poor reading outcomes in second and fourth grades, according to the findings of one research group, are 7 to 8 times greater for children with nonspecific language impairment (i.e., language impairment accompanied by low IQ) and about 5 times greater for children with a SLI.33,41,42 These estimates are in line with the findings from a study of children referred as preschoolers for speech and language assessments who were subsequently prioritized for an intervention based on the assessment results; they were significantly more likely to exhibit language and literacy impairments in elementary school than children never referred for speech and language assessments.43

The risk for poor outcomes is greater for children whose disorders persist past the early childhood years and for those who have both lower IQ scores and language impairments rather than only speech impairments.44 Estimates of the proportion of children with early speech and language delays whose disorders persist into the school years vary and may depend to some extent on the inclusion criteria for children based on their early characteristics. In one large study using a database of children who received preschool services in Florida under IDEA part B, Delgado45 found that 54 percent of 2,045 children classified as having a speech or language delay for preschool service eligibility were classified as having an educational disability when they were in the fourth grade.45 A study in England43 followed up with 196 of 350 children ages 7 to 9 years who were initially referred to community clinics for speech and language concerns prior to age 3.5 years. The researchers found that 36 percent of the group of children prioritized for intervention after their early assessment showed significant language and literacy impairments (at least 2 standard deviations below the mean on one or more assessments) at followup compared with 16 percent of the referred nonprioritized group and 8 percent of the control group. In addition to persisting speech- and language-related underachievement (verbal, reading, spelling), language-delayed children have also shown more behavior problems and impaired psychosocial adjustment, and the psychosocial problems can persist into adulthood.46–48

## Current Clinical Practice in the United States

### Identification of Speech and Language Delays and Disorders in Primary Care Settings

Screening for speech and language disorders has been defined as using standardized tools to detect the risk of a delay, which can be corroborated by a full-scale diagnostic evaluation. Screening for speech and language disorders in clinical practice most often occurs in pediatric outpatient clinics in the context of routine developmental surveillance and screening. By surveillance we mean the informal checks about developmental progress that occur during routine well-child visits; surveillance is also known as monitoring.

In 2006, the American Academy of Pediatrics published clinical guidelines for developmental screening and surveillance in the primary care setting.49 These guidelines recommend that pediatric health care providers perform surveillance at every well-child visit for children younger than age 36 months, and if any concerns arise, to screen using standardized developmental tools. Irrespective of concerns, the guidelines identify 9, 18, and 30 (or 24) months as the specific ages when developmental screening should be done. The American Academy of Pediatrics also developed the Bright Futures Guidelines for Health Supervision of Infants, Children, and Adolescents,50 which offer primary care providers a set of processes and tools for surveillance; documentation of findings; and talking with parents about health, global development, and concerns. Bright Futures Guidelines recommend screening for developmental concerns, including speech and language, at regular intervals as part of well-child visits. Irrespective of the procedures used, when a child screens positive, the primary care provider should make a referral for further evaluation and treatment.

A variety of tools have been used to screen for speech and language delays; many are part of a broader screening for developmental delays. Some screening tools are designed to be administered to the child; others are checklists that are designed to be completed by a parent or teacher. Often primary care providers use broad-band instruments that screen for a variety of developmental issues. One such instrument is the Parents’ Evaluation of Developmental Status questionnaire;51 it asks parents about concerns they may have about their child’s development using one question on each of several different developmental domains, including expressive and receptive language. The results indicate the need for further screening or referral. Alternatively, other broad-band instruments such as the Denver II52 and the Ages and Stages Questionnaire (ASQ)53 have separate scales that probe for more detailed information about the different developmental domains (e.g., language, motor, adaptive, social-emotional skills). While the Denver II directly assesses the child, the ASQ asks parents about their child’s development. In contrast to broad-band instruments, narrow-band instruments are designed to screen only for speech and language skills. Some narrow-band screening instruments for speech and language include the Language Development Survey (LDS)54 and the MacArthur-Bates Communicative Development Inventory (CDI);55 parents complete these screening instruments, but they can be scored by a primary care provider.

The rationale for identifying speech and language problems during the years prior to formal schooling is that early intervention services may be initiated before these problems interfere with school learning. However, individual clinicians lack specific pediatric organizational or governmental policy recommendations concerning the effectiveness of speech and language screening outside of more global developmental screening recommendations. Additionally, because a variety of screening instruments are available, practitioners may be confused about which tools are best at which times. Screening may be considered a low priority because administering the instruments is time consuming and the reimbursement level may be considered low. Further complicating the motivation for speech and language screening is the lack of a universal system for referral and management once abnormalities are detected through screening.

### Interventions/Treatment

Once a child is diagnosed with a speech-language disorder, he or she is typically referred for therapy. Therapies and treatment plans for childhood speech and language disorders are highly variable and are commonly individualized to the patterns of symptoms exhibited by a particular child.56 Treatments are designed to adapt to the child’s interests, personality, and learning style, and to address the priorities of the child, parents, or teachers based on the functional impact of the child’s disorder in different settings.

The content of therapy sessions depends on the child’s identified needs. For example, for a child with an articulation disorder, the speech-language pathologist may model the production of problematic sounds, cue the child on placement of the articulators, and provide multiple opportunities for practice. When speech sound disorders are determined to follow rule-based error patterns (phonological disorders), the therapy addresses the disorder using systematic presentation of speech sound stimuli to help the child learn the phonological rules of the language.57,58 Similarly, for children with language disorders, therapy is designed to address the symptoms, guided by knowledge of what is developmentally appropriate and by assessment information identifying the child’s specific weaknesses in expressive or receptive language related to vocabulary, syntax, pragmatics, or some combination of these. Strategies include environmental adaptations and a rich exposure of the child to vocabulary, language structures, and varied language interactions or a more focused program of modeling, prompting, and practicing specific language targets that are appropriate next steps based on the child’s current developmental level.59–61

For children who have severe communication impairments that include limited or no ability to speak intelligibly, an augmentative and alternative communication system might be designed in conjunction with the speech-language therapy. These systems are sometimes built around “high tech” speech-generating devices; in other cases, the systems are “low tech” and involve the use of picture communication boards or books, sometimes combined with gestures. Many assistive technology options are now available to support individuals with speech and language disorders in their daily functioning.62,63

Therapy may take place in various settings, such as speech and language specialty clinics, home, schools, or classrooms. Therapy may be administered to an individual or group. Therapists may be speech-language pathologists, parents, or teachers. Therapy may be child-centered or include peer and family components. The duration and intensity of the intervention varies depending on the severity of the speech or language disorder and the child’s progress in meeting therapy goals.

## Rationale for Changes to Scope Since 2006 Review

The USPSTF used this report to update its 2006 recommendations on brief, formal screening for speech and language delays and disorders in children age 5 years or younger in primary care settings.

This review summarizes the evidence to date for the benefits and harms of screening and the accuracy of screening tests in children age 5 years or younger, and the benefits and harms of treating speech and language delays and disorders using accepted techniques among children who were identified by age 6 years.

The updated review generally adheres to the scope of the previous review, with rigorous attention to including only studies of children who were not previously identified with hearing impairments; developmental disorders such as Down syndrome, fragile X syndrome, or autism; craniofacial anomalies; or neurological/neurogenetic impairments. Studies including these populations of children, some of which were included in the previous review, are not useful because they include children who have already been diagnosed with conditions that are marked by deficits in speech and language. The updated review also does not include studies of screening in children older than age 5 years if separate data are not available for preschool-age children; some of these studies were included in the previous review. Although the previous review included some studies in which screening occurred in school settings, the current review does not address questions concerning the effectiveness of screening in settings such as preschools or kindergartens and the role of primary care providers vis-à-vis these other screening programs. We have included this as a contextual question.