# Appendix G Ongoing Trials

Principal Investigators | Location | Population | Approximate Size | Investigations | Outcomes | Status as of 2014
Magalie Demilly and Gabriela Certad, MD, PhD | France | Children, ages 28 to 32 months, born preterm | 140 | Parent-implemented language intervention | Language score of the developmental neuropsychological assessment (NEPSY) | Not yet recruiting
Alan L. Mendelsohn, MD | US | Infant-mother dyads receiving care at Bellevue Hospital Center | 675 | Parenting programs to promote language development and school readiness for at-risk children | Language development Parenting Literacy development School readiness | Data collection anticipated to be completed June 2017
Holly Storkel | US | Children with specific language impairment, ages 5 to 6 years, normal intelligence | 104 | Use of interactive book reading to optimize word learning | Naming Ability to define words | Recruiting, anticipated to be completed September 2018
Shuvo Ghosh, MD | Canada | Children ages 24 to 42 months with diagnosed language impairment | 30 | Use of omega-3 supplementation to improve fast-mapping language skills | Change in learning assessed by a fast-mapping task | Recruiting, completion date unknown
Ann Kaiser | US | Children ages 24 to 42 months with language delay | 120 | RCT of Enhanced Milieu teaching with parents (language support services to improve their children’s language skills) | Expressive language at 4 months Number of words and average sentence length | Final data collection completion anticipated to be September 2015
Anke Buschmann, MA | Germany | Children ages 24 to 27 months with receptive or expressive language delays | 150 | RCT of highly-structured parent-based language intervention | Parent report through screening instruments | Start date 2003, completion date unknown
Aravind Namasivayam, PhD | Canada | Children ages 3 to 10 years, moderate to severe speech sound disorder | 44 | RCT of Prompts for Restructuring Oral Muscular Phonetic Targets (PROMPT) approach | Change in speech motor control Change in speech articulation Change in word-level speech intelligibility Change in phonological processes | Recruiting, anticipated completion December 2015
Mark Onslow, MD | Australia | Children ages 3 to 7 years who have completed Lidcombe program on stuttering | 180 | RCT of short message service reminders | Percentage of syllables stuttered | Estimated completion December 2011, actual completion unknown
Mark Onslow, MD | Australia | Children ages 3 to 6 years with early stuttering | 120 | RCT of Lidcombe method, varying the time between clinic visits during the first stage of the program | Number of clinic visits needed to achieve various stages of reduction in stuttering | Estimated completion December 2009, actual completion unknown

Abbreviations: RCT = randomized, controlled trial; US = United States.