# Appendix F External Validity

Appendix F Table 1 External Validity of Screening Studies

Author, Year | Screening/Treatment Interventions and Comparators | Study Design | Is the Study Population Broadly Applicable? | Comments | Is the Intervention/Screening Broadly Applicable? | Comments
Sachse and Von Suchodoletz, 2008^76^ Sachse and Von Suchodoletz, 2009^77^ | German version of the CDI Toddler form (ELFRA-2) | Prospective followup of screened group | Yes | Population appears to be representative of 2-year-olds in one community in Germany; 71% response rate to screening | Yes | German version of CDI
Westerlund et al, 2006^78^ | G1: Swedish Communication Screening at age 18 months (SCS-18) (derived from CDI) G2: Traditional 18-month assessment (child’s use of at least 8 words and understanding of more) | RCT cluster | Yes | Population is representative of 18-month-olds in Sweden | Yes | Swedish version of CDI
Heilmann et al, 2005^75^ | Communicative Development Inventory Words and Sentences | Other | Yes | NA | Yes | NA
Guiberson et al, 2011^74^ | Spanish version of Ages and Stages Questionnaire; Spanish version of CDI-short form (Inventarios del desarrolo de habilidades comunicativas: palabras y enuciados [INV-II]); mean of three longest reported utterances; demographic and developmental questionnaire | 0 | Yes | Spanish-speaking population from Head Start and early intervention programs; probably representative of lower-income Spanish-speaking families | Yes | Screening information is applicable for Spanish-speaking toddlers
Guiberson and Rodriguez, 2010^73^ | Spanish Ages and Stages Questionnaire Communication Domain; Spanish version of CDI-III (Pilot Inventario-III) | Prospective followup of screened group | Yes | Applicable to Spanish-speaking preschool children in Head Start | Yes | Applicable to Spanish-speaking children
Frisk et al, 2009^72^ | Ages and Stages Questionnaire; Battelle Developmental Inventory Screening Test; Brigance Preschool Screen; Early Screening Profile | Prospective followup of screened group | No | Very high risk group in which the majority has evidence of one or more risk factors and 42% displaying less than average intelligence | Yes | NA
Rigby and Chesham, 1981^86^ | Trial speech screening test | 0 | Cannot be determined | No information other than participants were the total population of children (somewhere in the United Kingdom) who came for school entry medical examination who were being seen by a speech therapist. | Cannot be determined | NA
Wetherby et al, 2003^88^ | Infant-Child Checklist, a 5- to 10-minute checklist completed by parents | Other | Yes | Racially/ethnically diverse, though fewer with low socioeconomic status; sample was weighted with more children who screened positive | Yes | NA

Author, Year | Is the Comparator Broadly Applicable? | Comments | Are Outcomes Broadly Applicable? | Comments | External Validity Assessment | Comment
Sachse and Von Suchodoletz, 2008^76^ Sachse and Von Suchodoletz, 2009^77^ | NA | NA | NA | NA | Fair | German health care system may be different
Westerlund et al, 2006^78^ | Yes | Comparison screening is single question | NA | NA | Fair | Swedish health care system may be different
Heilmann et al, 2005^75^ | NA | NA | NA | NA | Good | Study was conducted in United States and includes children who are broadly representative of those who are late talkers with typical language development, although not quite as demographically and racially diverse as would be desired
Guiberson et al, 2011^74^ | NA | NA | NA | NA | Fair | Small sample of lower-income families (Spanish-speaking)
Guiberson and Rodriguez, 2010^73^ | NA | NA | NA | NA | Fair | Small sample of lower-income families
Frisk et al, 2009^72^ | NA | NA | NA | NA | Poor | While the study may have applicability for an at risk population, the findings may not apply to a U.S. primary care population
Rigby and Chesham, 1981^86^ | NA | NA | NA | NA | Fair | The screening instrument was used in primary care settings in the United Kingdom, so presumably it could be done in the United States, but little is known about other aspects of the population of children or the settings
Wetherby et al, 2003^88^ | NA | NA | NA | NA | Fair | Fewer low socioeconomic status children and greater weighting of children who screened positive

Abbreviations: CDI = MacArthur Bates Communicative Development Inventory; ELFRA-2 = Elternfragebogen fur die Fruberkennung von Riskokindern; NA = not applicable; RCT = randomized, controlled trial; SCS-18 = Swedish Communication Screening at 18 months of age.

Appendix F Table 2 External Validity of Intervention Studies

Author, Year | Screening/Treatment Interventions and Comparators | Study Design | Is the Study Population Broadly Applicable? | Comments | Is the Intervention/ Screening Broadly Applicable? | Comments
Fricke et al, 2013^125^ | G1: Oral language intervention; 30-week program to improve vocabulary, narrative skills, listening, and speaking G2: Wait-list control group | RCT parallel | Yes | NA | No | School-based study implemented in the United Kingdom with children in Nursery (ages 3 to 4 years) and Reception (age 5 years) classrooms; intervention spanned both classrooms. Dissimilarites with U.S. early education system constrain applicability.
Jones et al, 2005^126^ | G2: Lidcombe Programme of Early Stuttering | RCT parallel | Yes | NA | No | Lidcombe program not widely available in United States; training in Lidcombe program not widely available and currently costs ~$500
Lewis et al, 2008^127^ | G3: None | RCT parallel | Yes | NA | No | Lidcombe program not widely available in United States; training in Lidcombe program not widely available and currently costs ~$500
Wake et al, 2011^128^ | G1: Modified “You Make a Difference” (Hanen parent training program) G2: Control group | RCT cluster | Yes | NA | No | Study implemented in Australia; use of Hanen requires certification; many certified providers of Hanen parent training programs in United States, especially in private practice; current cost of 3-day certification workshop is ~$850
Gibbard, 1994^136^ Study 1 | G1: Parent group-training sessions 60–75 minutes every other week for 6 months focusing on language activities to use with children G2: Wait-list control group | RCT parallel | No | Excluded children with medical conditions associated with speech and language delays, including otitis media, which occurs frequently in this age group | Yes | Study was implemented in the United Kingdom but seems feasible in U.S. context
Girolametto et al, 1996^137^ Girolametto et al, 1997^138^ | G1: Hanen parent training program, comprising eight 2.5-hour parent group sessions and three home visits to teach parents focused stimulation of children’s language G2: Wait-list control | RCT parallel | Yes | NA | No | Study implemented in Canada; use of Hanen requires certification; many certified providers of Hanen parent training programs in United States, especially in private practice; current cost of 3-day certification workshop is ~$850
Robertson and Weismer, 1999^139^ | G1: Speech-language pathologist–directed small group therapy 150 minutes per week for 12 weeks G2: Wait-list control | RCT parallel | Yes | NA | No | Study in a U.S. center-based birth-to-3-years program; current public IDEA part C programs are primarily home-based
Robertson and Weismer, 1997^140^ | G1: At least four 15- to 20-minute unstructured play sessions in “house” area with normal peers over 3 weeks G2: No play sessions with normal peers | RCT parallel | Yes | NA | Yes | NA
Almost and Rosenbaum, 1998^134^ | G1: Speech-language therapy for phonology using a cycles approach, two 30-minute sessions per week for 4 months G2: Wait-list control | RCT parallel | Yes | NA | Yes | Study conducted through a secondary care facility in Canada, but the approach is widely used in the United States across varied settings
Shelton et al, 1978^141^ | G1: Parent-directed speech sound listening/ discrimination activities for 5 minutes per day G2: 15 minutes per day of parent-child storybook interaction (reading and talking group) for 57 days G3: Control group | RCT parallel | Yes | NA | No | Use of parents to provide explicit treatment of articulation (G1) is not currently a common practice in the United States; group that used storybook interactions would be applicable
Glogowska et al, 2000^135^ | G1: Clinician-directed individual intervention routinely offered by the therapist for 12 months (mean of 6.2 total hours of therapy) G2: Watchful waiting control group | RCT parallel | Yes | NA | Yes | Study conducted in the United Kingdom but level of service is feasible within the U.S. system of care
Yoder et al, 2005^129^ | G1: Broad target recasts intervention G2: No intervention control; “free to participate in community-based treatments” | RCT parallel | Yes | NA | Cannot be determined | Study did not limit community-based services and so replication of comparison would be difficult
Wake et al, 2013^130^ | G1: 18 in-home sessions by “language assistant” over 1 year G2: Parents contacted and given information on local speech pathology services | RCT | Yes | NA | Yes | Manualized intervention that can be delivered by nonspecialist staff

Author, Year | Is the Comparator Broadly Applicable? | Comments | Are the Outcomes Broadly Applicable? | Comments | External Validity Assessment
Fricke et al, 2013^10^ | No | Comparator (wait-list control) involved children enrolled in Nursery and Reception classrooms in the United Kingdom who did not receive the experimental program | Yes | NA | Fair
Jones et al, 2005^126^ | Yes | NA | Yes | NA | Fair
Lewis et al, 2008^127^ | Yes | NA | Yes | NA | Fair
Wake et al, 2011^128^ | Yes | NA | Yes | NA | Fair
Gibbard, 1994^136^ Study 1 | Yes | NA | Yes | NA | Fair
Girolametto et al, 1996^137^ Girolametto et al, 1997^138^ | Yes | NA | Yes | NA | Fair
Robertson and Weismer, 1999^139^ | No | Wait list for same intervention | Yes | NA | Fair
Robertson and Weismer, 1997^140^ | Yes | NA | No | Outcomes are tied closely to the context of the intervention; they were maintained across time, but evidence of generalization to broader gains in language was not provided | Fair
Almost and Rosenbaum, 1998^134^ | Yes | NA | Yes | NA | Good
Shelton et al, 1978^141^ | Yes | NA | Yes | NA | Fair
Glogowska et al, 2000^135^ | Yes | NA | Yes | NA | Good
Yoder et al, 2005^129^ | Cannot be determined | Study did not limit community-based services and so replication of comparison would be difficult | Yes | NA | Fair
Wake et al, 2013^130^ | Yes | NA | Yes | NA | Good

Abbreviations: G = group; RCT = randomized controlled trial.