# Appendix E Formulas for Accuracy

Formula for calculating 95% confidence interval for sensitivity:

95% confidence interval = sensitivity +/− 1.96 (SE _sensitivity_)

Where SE _sensitivity_ = square root [sensitivity – (1-sensitivity)]/n _sensitivity_)

Formula for calculating 95% confidence interval for specificity:

95% confidence interval = specificity +/− 1.96 (SE _specificity_)

Where SE _specificity_ = square root [specificity – (1-specificity)]/n _specificity_)

From Robert M. Hamm, PhD; http://www.fammed.ouhsc.edu/robhamm/cdmcalc.htm

Derivation of formula for any proportion or probability:

pi*n =(p/n)*n (1-pi)*n = (q/n)*n

The normal approximation is not trustable as pi nears 0 or nears 1.

From Ott L. (1988). An Introduction to Statistical Methods and Data Analysis. .

Confidence interval = best estimate +/− (z for desired (1-alpha)) times (standard error of pi)

Best estimate is pi

Pi z for 95% CI, 2 tailed is 1.96

standard error of pi is square root of (pq/nnn) pq/nnn or sqrt(pi*(1-pi)/n)

Confidence interval = Pi+/−1.96*pq/nnn

From Ebell E, Barry H. Evidence-Based Medicine Course. East Lansing, MI: Michigan State University; 2008. http://omerad.msu.edu/ebm/index.html

## Likelihood Ratios Part 1: Introduction

When we decide to order a diagnostic test, we want to know which test (or tests) will best help us rule-in or rule-out disease in our patient. In the language of clinical epidemiology, we take our initial assessment of the likelihood of disease (“pre-test probability”), do a test to help us shift our suspicion one way or the other, and then determine a final assessment of the likelihood of disease (“post-test probability”). Take a look at the diagram below, which graphically illustrates this process of “revising the probability of disease.”

threshold

Likelihood ratios tell us how much we should shift our suspicion for a particular test result. Because tests can be positive or negative, there are at least two likelihood ratios for each test. The “positive likelihood ratio” (LR+) tells us how much to increase the probability of disease if the test is positive, while the “negative likelihood ratio” (LR−) tells us how much to decrease it if the test is negative. The formula for calculating the likelihood ratio is:

probability of an individual with the condition having the test result LR = probability of an individual without the condition having the test result

Thus, the positive likelihood ratio is:

probability of an individual with the condition having a positive test LR+ = probability of an individual without the condition having a positive test

Similarly, the negative likelihood ratio is:

probability of an individual with the condition having a negative test LR− = probability of an individual without the condition having a negative test

You can also define the LR+ and LR− in terms of sensitivity and specificity:

LR+ = sensitivity 1-specificity

LR− = 1-sensitivity specificity

(Of course, if you’re using sensitivity and specificity on a scale of 0 to 100 instead of 0 to 1, the equations would be sensitivity / (100-specificity) and (100-sensitivity)/specificity, respectively).

Let’s consider an example. In a study of the ability of rapid antigen tests to diagnose strep pharyngitis, 90% of patients with strep pharyngitis have a positive rapid antigen test, while only 5% of those without strep pharyngitis have a positive test. The LR+ for the ability of rapid antigen tests to diagnose strep pharyngitis is (select one):

- LR+ = 90% / 5% = 18 (http://omerad.msu.edu/ebm/Diagnosis/strepanswer18.html)
- LR+ = 95% / 10% = 9.5 (http://omerad.msu.edu/ebm/Diagnosis/strepanswer9.html)
- LR+ = 90% / 95% = 0.95 (http://omerad.msu.edu/ebm/Diagnosis/strepanswer95.html)

## Interpreting Likelihood Ratios: General Guidelines

The first thing to realize about LR’s is that an LR > 1 indicates an increased probability that the target disorder is present, and an LR < 1 indicates a decreased probability that the target disorder is present. Correspondingly, an LR = 1 means that the test result does not change the probability of disease at all! The following are general guidelines, which must be correlated with the clinical scenario:

LR | Interpretation
> 10 | Large and often conclusive increase in the likelihood of disease
5 – 10 | Moderate increase in the likelihood of disease
2 – 5 | Small increase in the likelihood of disease
1 – 2 | Minimal increase in the likelihood of disease
1 | No change in the likelihood of disease
0.5 – 1.0 | Minimal decrease in the likelihood of disease
0.2 – 0.5 | Small decrease in the likelihood of disease
0.1 – 0.2 | Moderate decrease in the likelihood of disease
< 0.1 | Large and often conclusive decrease in the likelihood of disease

The decision to order a test is also based on our initial assessment of the likelihood of the target disorder, and how important it is to rule-in or rule-out disease. For example, a chest x-ray might have a good likelihood ratio for pneumonia. But if you believe a patient has a simple cold, this test, no matter how good the LR, probably shouldn’t be ordered. It is sometimes helpful to be able to calculate the exact probability of disease given a positive or negative test. We saw that this is next to impossible using sensitivity and specificity at the bedside (unless you can do Bayes’ Theorem in your head).