# Appendix D Evidence Tables

Appendix D Table 1 Evidence Tables for Screening for Speech and Language Delays in Children: KQ 2 Outcomes

Appendix D Table 2 Evidence Tables for Interventions From 2006 USPSTF Review

Appendix D Table 3 Evidence Tables for Interventions for Speech and Language Delays in Children Age 5 Years or Younger: KQ 5 Outcomes