# Appendix C Quality Assessment Tables

Appendix C Table 1 Quality Ratings of Studies of Screening Outcomes for Speech and Language Delays in Children Age 5 Years and Younger (KQ 1)

Author, Year | Screening or Treatment Interventions and Comparators | Study Design | Selection Criteria Clearly Described? | Inclusion/Exclusion Criteria Measured Using Valid and Reliable Measures, Implemented Across All Study Participants? | Subject’s Status Determined Using Valid and Reliable Methods? | Method of Randomization Adequate? | Allocation Concealment Adequate?
Van Agt et al, 2007^71^ | G1: Screening G2: No screening (usual care) | RCT cluster | Yes | Yes | Sometimes | Yes | NA

Author, Year | Recruitment Strategy Differ Across Study Groups? | Baseline Characteristics Similar Between Groups? | Outcome Assessors Blind to Intervention Status of Participants? | Intervention Fidelity Adequate? | Study Protocol Variation Compromise Conclusions of the Study? | Overall Attrition? | High Attrition Raise Concern for Bias? | Intention-to-Treat Analysis? | Cross-Overs or Contamination Raise Concern for Bias?
Van Agt et al, 2007^71^ | No | Not among those reported | Yes | No | No | Approximately 50% or more based on outcome | Yes | Yes, but attrition was very high and approach was not described | No

Author, Year | Outcomes Prespecified/Defined and Adequately Described? | Outcome Measures Valid and Reliable? | Duration of Followup Adequate to Assess the Outcome? | Appropriate Method Used to Handle Missing Data? | Acceptable Statistical Methods Used ? | Quality Rating | Comments
Van Agt et al, 2007^71^ | Yes | Some | Yes | Unknown, but believe not | Yes | Poor | This study had a very high attrition rate, so we could not be confident that the results were comparing a comparable group of children screened to those not screened

Appendix C Table 2 Quality Ratings of Studies of Screening Accuracy for Speech and Language Delays in Children Age 5 Years and Younger (KQ 2a)^a^

Author, Year | Screening Test Adequately Described? | Selection Criteria Clearly Described? | Credible Reference Standard Used? | Time Period Between Screening Test and the Comparator Short Enough? | Whole or a Random Selection of the Sample Received Screening Test?
Alberts et al, 1995^91^ | Yes | Yes | Yes | NR | Yes
Allen and Bliss, 1987^92^ | Yes | No | Yes | Yes | Yes
Bliss and Allen, 1984^93^ | Yes | No | Yes | NR | Yes
Borowitz and Glascoe, 1986^94^ | Yes | Yes | Yes | Yes | Yes
Burden et al, 1996^95^ | Yes | Yes | Yes | Yes | Yes
Clark et al, 1995^66^ | Yes | No | Yes | Yes | Yes
Coulter and Gallagher, 2001^87^ | Yes | Yes | Unclear | Unclear | Yes
Dixon et al, 1988^96^ | Yes | No | Yes | Yes | Yes
Drumwright et al, 1973^97^ | Yes | No | Yes | Yes | Yes
Elbaum et al, 2010^79^ | Yes | Yes | Yes | Yes | Yes
Frisk et al, 2009^72^ | Yes | Yes | Yes | Yes | Yes
Guiberson and Rodriguez, 2010^73^ | Yes | Yes | Yes | Yes | Yes
Guiberson et al, 2011^74^ | Yes | Yes | Yes | Yes | Yes
Heilmann et al, 2005^75^ | Yes | Yes | Yes | Yes | Yes
Henrichs et al, 2011^81^ | Yes | Yes | No | No | Yes
Heo et al, 2008^82^ | Yes | Yes | No | Yes | Yes
Klee et al, 1998^98^ | Yes | No | Yes | Yes | Yes
Klee et al, 2000^122^ | Yes | No | Yes | Yes | Yes
Laing et al, 2002^99^ | Yes | Yes | Yes | Yes | Yes
Law, 1994^100^ | Yes | Yes | Yes | Yes | Yes
Levett and Muir, 1983^67^ | Yes | Yes | Yes | Yes | Yes
McGinty, 2000^101^ | No | Yes | Yes | Yes | Yes
Mossabeb et al, 2012^83^ | Yes | Yes | No | Unclear | Unclear
Rescorla, 1989^54^ | Yes | Unclear | Yes | Yes | Yes
Rescorla et al, 1993^69^ | Yes | Yes | No | Yes | Yes
Rescorla and Alley, 2001^102^
Study 1 | Yes | No | No | Yes | Yes
Study 2 | Yes | No | Yes | Yes | Yes
Rigby and Chesham, 1981^86^ | Yes | Yes | Yes | Unclear | Yes
Sachse and Von Suchodoletz, 2008^76^ Sachse and Von Suchodoletz, 2009^77^ | Yes | Yes | Yes | Yes | Yes
Sherman et al, 1995^65^ | Yes | Yes | Yes | Yes | Yes
Sices et al, 2009^84^ | Yes | Yes | No | Yes | Yes
Skarakis-Doyle and Campbell, 2009^80^ | Yes | Yes | No | No | Yes
Stokes, 1997^103^ | Yes | Yes | Yes | Yes | Yes
Stott et al, 2002^104^ | Yes | No | Yes | Yes | Yes
Sturner et al, 1993^105^
Study 1 | Yes | No | Yes | Yes | Yes
Study 2 | Yes | No | Yes | Yes | Yes
Sturner et al, 1996^106^ | Yes | No | Yes | Yes | Yes
Van Agt et al, 2007^71^ | Yes | Yes | No | Unclear | Yes
Walker et al, 1989^107^ | Yes | Yes | Yes | Yes | Yes
Ward, 1984^108^ | Yes | Yes | Yes | Yes | Yes
Westerlund et al, 2006^78^ | Yes | Yes | Yes | No | Yes
Wetherby et al, 2003^88^ | Yes | Yes | Yes | Yes | Yes

Author, Year | Patients Receive the Same Reference Test Regardless of Results? | Reference Standard Independent of Screening Test? | Sample Size Adequate? | Quality Rating | Comments
Alberts et al, 1995^91^ | Yes | Yes | Yes 59 | Fair | Sample size is adequate but not good. Reference test is a combination of measures, including a cognitive measure. No information about the length of time between the two tests.
Allen and Bliss, 1987^92^ | Yes | Unclear | Yes 182 | Fair | No description of eligibility or exclusionary criteria other than the children were in Head Start. It was not explicitly stated that the reference test and screening test were independently administered.
Bliss and Allen, 1984^93^ | Yes | Yes | Yes 602 | Fair | No description of eligibility or exclusionary criteria other than the children were in Head Start. No indication of the the length of time between screening and reference standard.
Borowitz and Glascoe, 1986^94^ | Yes | Yes | Yes 71 | Fair | Sample size is adequate but not good.
Burden et al, 1996^95^ | Yes | Yes | Yes 425 | Good | This is a large epidemiological sample that is well described. All criteria for a good rating were met.
Clark et al, 1995^66^ | Yes | Unclear | Yes 99 | Poor | Eligibility and exclusionary criteria not described other than age. May not be independent assessment and screening.
Coulter and Gallagher, 2001^87^ | Unclear | Unclear | Yes 1,174 | Poor | No information is provided on the reference standard, nor is there any information about the screening instrument, though there are references.
Dixon, 1988^96^ | Yes | Yes | No 40 | Poor | It is unclear what the eligibility criteria were. Two separate samples were combined, and the sample size is small.
Drumwright et al, 1983^97^ | Yes | Yes | Yes 150 | Fair | Little information regarding the sample other than age and that participants were economically disadvantaged.
Elbaum et al, 2010^79^ | Yes | No | Yes 100 | Poor | Screening test, which is a subset of the full instrument, was validated against the full instrument; that is, the subset of items was extracted from the larger data set from the whole test—no separate administration.
Frisk et al, 2009^72^ | Yes | Yes | Yes 112 | Fair | Somewhat restricted sample; 41% of sample were cognitively below average and 8% had global cognitive delay. Also, screening tests were not administered as separate instruments but were intermingled.
Guiberson and Rodriguez, 2010^73^ | Yes | Yes | No 48 | Fair | Meets all criteria except sample size.
Guiberson et al, 2011^74^ | Yes | Yes | No 45 | Fair | Meets all criteria except sample size.
Heilmann et al, 2005^75^ Study 2 | Yes | Yes | Yes 100 | Fair | Meets all criteria: uses appropriate diagnostic procedure, interprets diagnosis separate from screening procedure, sample is 100 late talking toddlers and typical language toddlers.
Henrichs et al, 2011^81^ | Yes | Yes | Yes 3,759 | Poor | Uses another screening instrument as a reference test. The length of time between the screening test and the reference test is 1 year, which is too long for children this age.
Heo et al, 2008^82^ | No | Yes | Yes 404 (in validity analysis) | Poor | Reference test is screening instrument, not diagnostic assessment.
Klee et al, 1998^98^ Klee et al, 2000^122^ | Yes | Yes | Yes 64 | Fair | Sample size is adequate but not good.
Laing et al, 2002^99^ | Yes | Yes | Yes 458 | Good | This is a large epidemiological sample that is well described. All criteria for a good rating were met.
Law, 1994^100^ | Yes | Yes | Yes 189 | Good | This is a large epidemiological sample that is well described. All criteria for a good rating were met.
Levett and Muir, 1983^67^ | Yes | Yes | No 14 | Poor | Sample size for sensitivity and specificity evaluation is too small.
McGinty, 2000^101^ | Yes | Yes | Yes 200 | Poor | Limited information is given about screening test.
Mossabeb et al, 2012^83^ | Yes | Yes | Yes 178 | Poor | It is not clear when the children were screened in relation to receiving the reference test. Reference test is a measure of cognitive development and not a reasonable reference measure.
Rescorla, 1989^54^ | Yes | Yes | Yes 81 | Fair | Little information regarding exclusionary criteria. Sample size is adequate but not good.
Rescorla et al, 1993^69^ | Yes | Yes | Yes 108 and 92 | Poor | The reference test is insufficient to determine language delay.
Rescorla and Alley, 2001^102^ Study 1 | Yes | Unclear | Yes 422 | Poor | Reference test is individual items from two measures of cognitive development. No information was provided about eligibility or exclusionary criteria other than age.
Rescorla and Alley, 2001^102^ Study 2 | Yes | Unclear | Yes 66 | Fair | Unlike Study 1, a credible reference standard is used. No information was provided about eligibility or exclusionary criteria other than the sample was comprised of 2-year-olds who screened positive in study 1 or screened negative and were matched with an at-risk child.
Rigby and Chesham, 1981^86^ | Yes | No | Yes 438 | Fair | This is a large epidemiological sample that is generally well carried out with some limitations. No indication of the time span between the screening and diagnostic test. All children received two of the diagnostic instruments; the third, an articulation test, was only given if SLP felt it was necessary.
Sachse and Von Suchodoletz, 2008^76^ Sachse and Von Suchodoletz, 2009^77^ | Yes | Yes | Yes 117 | Good | All criteria for a good rating are met.
Sherman et al, 1996^65^ | Yes | No | Yes 173 | Poor | The reference standard was not independent of the screening test because the same individual administered both during the same session.
Sices et al, 2009^84^ | Yes | No | Yes 60 | Poor | The reference standard is only the provider’s rating of a concern, not a diagnostic assessment, and the providers were present when the screening test was completed.
Skarakis-Doyle and Campbell, 2009^80^ | No | No | Yes 58 | Poor | No independent reference test is provided, only classification status as LI/TLD prior to screening.
Stokes, 1997^103^ | Yes | Yes | Yes 398 | Fair | This is a large epidemiological sample that is well described. All criteria for a good rating were met.
Stott et al, 2002^104^ | Yes | Yes | Yes 254 | Fair | The sample is only described in terms of age and how they were recruited, no exclusionary criteria provided.
Sturner et al, 1993^105^ Study 1 | Yes | Yes | Yes 51 | Fair | The sample is only described in terms of age and how they were recruited, no exclusionary criteria provided. The sample size is adequate but not large.
Sturner et al, 1993^105^ Study 2 | Yes | Yes | Yes 147 | Fair | The sample is only described in terms of age and how they were recruited, no exclusionary criteria provided.
Sturner et al, 1996^106^ | Yes | Yes | Yes 76 | Fair | The sample is only described in terms of age and how they were recruited, no exclusionary criteria provided. The sample size is adequate but not large.
van Agt et al, 2007^71^ | No | No | Yes 317 | Poor | Inappropriate reference test: two procedures used for validation used for positive and negative screens—a parent response to a question or a specialist report for children who were seen for suspected language problems. The reference test was not independent of the screening test. Also, there isno information regarding the timing between the screening and the reference test.
Walker et al, 1989^107^ | Yes | No | Yes 77 | Poor | The same individuals who administered the screening instrument administered the reference standard.
Ward, 1984^108^ | Yes | Unclear | Yes 1,070 | Fair | The report indicates that the author visited those who screened positive and 10% of those who screened negative. The report does not say that they were blinded as to group membership.
Westerlund et al, 2006^78^ | Yes | Yes | Yes 891 | Fair | 18 months between screening and reference test is long for an initial evaluation of the sensitivity and specificity of the instrument because of changes in development, but the authors state that no children received speech and language services.
Wetherby et al, 2003^88^ | Yes | Unclear | Yes 232 | Fair | Not specified whether the two procedures were completely independent; a random selection of those who were screened had the behavior sampling, but the sample size was sufficient.

a All studies in previous review and newly found studies were rated for quality.

Abbreviations: KQ = key question; LI/TLD = language impaired/typical language development; NR = not reported; SL = speech language; SLP = speech-language pathologist.

Appendix C Table 3 Quality Ratings of Included Randomized, Controlled Trials Examining Interventions for Speech and Language Delays or Disorders

Author, Year | Screening or Treatment Interventions and Comparators | Study Design | Eligibility Criteria Described Clearly? | Inclusion/Exclusion Criteria Measured Using Valid and Reliable Measures, Implemented Across All Study Participants? | Subject’s Status Determined Using Valid and Reliable Methods? | Method of Randomization Adequate? | Allocation Concealment Adequate?
Denne et al, 2005^132^ | G1: Phonological awareness therapy G2: No treatment | RCT | Yes | Yes | Yes | NR | NR
Fricke et al, 2013^125^ | G1: Oral language skills, phonological awareness, literacy skill intervention G2: Wait-list control group | RCT cluster | Yes | Yes | Yes | NR | NR
Grogan-Johnson et al, 2010^133^ | G1: Teletherapy G2: Conventional therapy | RCT cross-over | Yes | No | Yes | NR | NR
Jones et al, 2005^126^ | G1: Lidcombe program for stuttering G2: No treatment | Dynamically balanced randomization with stratification | Yes | Yes | Yes | Yes | Yes
Lewis et al, 2008^127^ | G1: Telehealth of Lidcombe stuttering intervention G2: No Treatment | RCT | Yes | NR | Yes | NR | Yes
Wake et al, 2011^128^ | G1: Parent-based languge program G2: Usual care | Block randomization | Yes | Yes | Yes | Yes | Yes
Wake et al, 2013^130^ | G1: 18 in-home sessions by language assistant over 1 year G2: Parents contacted and given information on local speech-pathology services | RCT | Yes | NR | Yes | Yes | Yes
Yoder et al, 2005^129^ | G1: Broad target recasts | Two-arm RCT | Yes | Yes | Yes | Yes | No

Author, Year | Recruitment Strategy Differ Across Study Groups? | Baseline Characteristics Similar Between Groups? | Outcome Assessors Blind to Intervention Status of Participants? | Intervention Fidelity Adequate? | Study Protocol Variation Compromise Study Conclusions? | Overall Attrition? | High Attrition Raise Concern for Bias? | Intention-to-Treat Analysis? | Cross-Overs or Contamination Raise Concern for Bias? | Outcomes Prespecified/Defined and Adequately Described?
Denne et al, 2005^132^ | No | Yes, but no demographic information was included, only pretest information | NR | Yes | No | 0.05 | No | No | No | Yes
Fricke et al, 2013^125^ | No | Yes | NR | Yes | No | 0.09 | No | NR | No | Yes
Grogan-Johnson et al, 2010^133^ | No | Not reported | NR | Yes | No | 0.16 | NR | NR | No | Yes
Jones et al, 2005^126^ | No | Yes | Yes | Yes | No | 0.13 | No | Yes | No | Yes
Lewis et al, 2008^127^ | No | No/Yes for baseline stuttering | NR | Yes | No | 0.18 | No | Yes | No | Yes
Wake et al, 2011^128^ | No | Yes | Yes | Yes | No | 5% at 2 years; 11% at 3 years | No | Yes | No | Yes
Wake et al, 2013^130^ | No | Yes | Yes | NR | NR | 8% for intervention; 13% for control | No | Yes | NR | Yes
Yoder et al, 2005^129^ | No | Yes | Yes | Yes | No | 0 | No | NR | No | Yes

Author, Year | Outcome Measures Valid and Reliable? | Duration of Followup Adequate to Assess Outcome? | Appropriate Method Used to Handle Missing Data? | Acceptable Statistical Methods Used? | Quality Rating | Comments
Denne et al, 2005^132^ | Yes | Yes: End of treatment | NR | Yes | Poor | No discussion of how the group was randomized or whether they used any procedures for missing data. No baseline data other than pretest scores were presented. Intention-to-treat is not addressed other than to say one intervention participant had to be excluded because s/he was unable to attend several therapy sessions.
Fricke et al, 2013^125^ | Yes | Yes: 6 months | Yes | Yes | Fair | No discussion of how groups were randomized or whether analysis was conducted on an intention-to-treat basis. However, they did use appropriate techniques for missing data.
Grogan-Johnson et al, 2010^133^ | Yes | Yes: Every 3 months | NR | No | Poor | There is no mention of how the children were assigned. No baseline characteristics provided. Data for many variables are combined across conditions. Therapists who provided treatment rated children’s progress; no independent measure of outcome.
Jones et al, 2005^126^ | Yes | Yes: 9 months post-randomization | Yes | Yes | Fair | Differential attrition (13%) is close to the limit, with somewhat more in the control group. No data were available after randomization for these participants. Five protocol violations occurred: four children in the control group received some Lidcombe treatment and one child in treatment group had only 3 weeks of treatment.
Lewis et al, 2008^127^ | Yes | Yes: 9 months post-randomization and 12 months after stage 1 (treatment group) and 18 months after randomization (control group) | NR | Yes | Fair | No information on how missing data was handled. Atrittion is at the lower end of acceptable. Some differences in baseline characteristics.
Wake et al, 2011^128^ | Yes | Yes: 3 and 15 months post-program | Yes | Yes | Good | Meets all criteria.
Wake et al, 2013^130^ | Yes | Yes: 1 year | NR | NR | Fair | Intention-to-treat principles were used (outcomes were compared based on randomization without regard for adherence to protocol), but no information was provided about how missing outcome data were handled. No information was provided about handling missing data in general. Although there was training and ongoing consultation to help maintain fidelity of implementation, no fidelity measures were reported. No information is given on whether children in the experimental groups received other therapy, or what kind of therapy children in the control group may have received. These factors represent potential confounders that were not addressed in the analyses.
Yoder et al, 2005^129^ | Yes | Yes; 6 and 14 months | NR | Yes | Fair | This study does not appear to have any fatal flaws. However, the extent to which there was any loss through attrition is unclear, and if it occurred, how it was handled.

Abbreviations: G = group; NR = not reported; RCT = randomized, controlled trial.

Appendix C Table 4 Quality Ratings of Randomized, Controlled Trials From the 2006 USPSTF Review Examining Interventions for Speech and Language Delays or Disorders

Study | Randomization | Blinding of Assessors | Similarities at Baseline | Explanation of Withdrawals | Discounting in Analysis of Missing Values | Degree of Attrition | Intention-to-Treat Analysis | Power | Description of Eligibility Criteria | USPSTF Quality Rating
Almost et al, 1998^134^ | A | A | A | A | A (last known scores used) | C (0.15) | A (intention-to-treat) | A | A | Fair
Fey et al, 1993^225^ | B | A | C (mother’s education) | A | C | A (0.03) | B | B | A | Poor
Fey et al, 1994^226^ | B | C | A | A | A (none) | A (none) | B | B | A | Poor
Fey et al, 1997^227^ | B | A | A | A | C | A (0.06) | B | B | A | Poor
Gibbard, 1994^136^ Study 2 | B | B | A | A (none) | A (none) | A (none) | B | B | A | Poor
Gibbard, 1994^136^ Study 1 | B | B | A | A (none) | A (none) | A (none) | B | B | A | Fair
Girolametto et al, 1996^137^ | B | A | A | A (none) | A (none) | A (none) | B | B | A | Fair
Girolametto et al, 1996^228^ | B | A | C (behavior) | A (none) | A (none) | A (none) | B | B | A | Poor
Girolametto et al, 1997^138^ | B | A | A | A (none) | A (none) | A (none) | B | B | A | Fair
Glogowska et al, 2000^135^ | A | A | A | A | C | A (0.03) | A (intention-to-treat) | C | A | Good
Glogowska et al, 2002^229^ | A | B | B | C | B | B | B | B | C | Poor
Mulac and Tomlinson, 1977^230^ | B | A | B | B | B | B | B | B | B | Poor
Robertson and Ellis Weismer, 1997^140^ | A | B | A | A | B | A (none) | B | B | A | Fair
Robertson and Ellis Weismer, 1999^139^ | B | B | A | A | C | C (0.13) | B | B | A | Fair
Rvachew and Nowak, 1994^145^ | B | A | A | B | C | C (0.13) | B | B | A | Poor
Schwartz et al, 1985^231^ | B | C | B | B | B | B | B | B | A | Poor
Shelton et al, 1978^141^ | B | B | A | A | C | A (0.08) | B | B | A | Fair