# Appendix B Excluded Studies

X1 | Not original research (nonsystematic review articles, commentaries, opinions, commentaries, editorials/letters to the editor and other publications with no primary data)
X2 | Wrong language (study not published in English)
X3 | Wrong age range, probable reason for delay or disorder identified prior to speech and language diagnostic procedure, or wrong population of interest (i.e., wrong condition).
X4 | Wrong comparator (Comparison of screening or diagnostic instruments; treatment comparisons; single group designs with no comparator)
X5 | Wrong study design based on key questions (e.g., case study, case series, cross-sectional study)
X6 | Screening or diagnosis does not focus on speech and language or the instrument does not include a speech and language component
X7 | Wrong geographic setting (countries without a high human development index)
X8 | No accuracy information provided
X9 | Full text article irretrievable

1 (2006). Screening for speech and language delay in preschool children: recommendation statement. Am Fam Physician.
2 (2011). Narrative Ability of Children With Speech Sound Disorders and the Prediction of Later Literacy Skills. Lang Speech Hear Ser Schools.
3 (2013). Real-Word and Nonword Repetition in Italian-Speaking Children With Specific Language Impairment: A Study of Diagnostic Accuracy. J Speech Lang Hear Res.
4 (2013). Tense Marking and Spontaneous Speech Measures in Spanish Specific Language Impairment: A Discriminant Function Analysis. J Speech Lang Hear Res.
5 Aarnoudse-Moens CS, Weisglas-Kuperus N, van Goudoever JB, et al. (2009). Meta-analysis of neurobehavioral outcomes in very preterm and/or very low birth weight children. Pediatrics.
6 Adams C, Lockton E, Freed J, et al. (2012). The Social Communication Intervention Project: a randomized controlled trial of the effectiveness of speech and language therapy for school-age children who have pragmatic and social communication problems with or without autism spectrum disorder. Int J Lang Commun Disord.
7 Adams C, Lockton E, Gaile J, et al. (2012). Implementation of a manualized communication intervention for school-aged children with pragmatic and social communication needs in a randomized controlled trial: the Social Communication Intervention Project. Int J Lang Commun Disord.
8 Adams-Chapman I. (2009). Insults to the developing brain and impact on neurodevelopmental outcome. J Commun Disord.
9 Allen CW, Silove N, Williams K, et al. (2007). Validity of the Social Communication Questionnaire in assessing risk of autism in preschool children with developmental problems. J Autism Dev Disord.
10 American Speech-Language-Hearing Association. (1997). Guidelines for Audiological Screening [Guidelines].
11 Amess P, Young T, Burley H, et al. (2010). Developmental outcome of very preterm babies using an assessment tool deliverable by health visitors. Eur J Paediatr Neurol.
12 Andersson L. (2005). Determining the Adequacy of Tests of Children’s Language. Commun Disord Q.
13 Anthony JL, Aghara RG, Dunkelberger MJ, et al. (2011). What factors place children with speech sound disorders at risk for reading problems?. Am J Speech Lang Pathol.
14 Anthony JL, Aghara RG, Dunkelberger MJ, et al. (2011). What Factors Place Children With Speech Sound Disorders at Risk for Reading Problems?. Am J Speech Lang Pathol.
15 Antoniazzi D, Snow P, Dickson-Swift V. (2010). Teacher identification of children at risk for language impairment in the first year of school. Int J Speech Lang Pathol.
16 Antonio MCS, Fenick AM, Shabanova V, et al. (2014). Developmental screening using the Ages and Stages Questionnaire: Standardized versus-real-world conditions. Infants Young Child.
17 Archibald LM, Joanisse MF. (2009). On the sensitivity and specificity of nonword repetition and sentence recall to language and memory impairments in children. J Speech Lang Hear Res.
18 Baatenburg de Jong RJ. (2011). Early Intervention in Very Preterm Children.
19 Bahr RH. (2005). Differential diagnosis of severe speech disorders using speech gestures. Topics Lang Disord.
20 Bailet LL, Repper KK, Piasta SB, et al. (2009). Emergent literacy intervention for prekindergarteners at risk for reading failure. J Learn Disabil.
21 Baker E, McLeod S. (2011). Evidence-based practice for children with speech sound disorders: part 2 application to clinical practice. Lang Speech Hear Serv Sch.
22 Ballantyne AO, Spilkin AM, Trauner DA. (2007). The revision decision: is change always good? A comparison of CELF--R and CELF--3 test scores in children with language impairment, focal brain damage, and typical development. Lang Speech Hear Ser Schools.
23 Barbaro J, Dissanayake C. (2010). Prospective identification of autism spectrum disorders in infancy and toddlerhood using developmental surveillance: the social attention and communication study. J Dev Behav Pediatr.
24 Barratt J, Littlejohns P, Thompson J. (1992). Trial of intensive compared with weekly speech therapy in preschool children. Arch Dis Child.
25 Barrett S, Prior M, Manjiviona J. (2004). Children on the borderlands of autism: differential characteristics in social, imaginative, communicative and repetitive behaviour domains. Autism.
26 Becker DB, Grames LM, Pilgram T, et al. (2004). The effect of timing of surgery for velopharyngeal dysfunction on speech. J Craniofac Surg.
27 Beitchman JH, Jiang H, Koyama E, et al. (2008). Models and determinants of vocabulary growth from kindergarten to adulthood. J Child Psychol Psychiatry.
28 Berkoff MC, Leslie LK, Stahmer AC. (2006). Accuracy of caregiver identification of developmental delays among young children involved with child welfare. J Dev Behav Pediatr.
29 Bernard JY, De Agostini M, Forhan A, et al. (2013). The dietary n6:n3 fatty acid ratio during pregnancy is inversely associated with child neurodevelopment in the EDEN mother-child cohort. J Nutr.
30 Bernhardt B, Major E. (2005). Speech, language and literacy skills 3 years later: A follow-up study of early phonological and metaphonological intervention. Int J Lang Commun Disord.
31 Beverly BL, McGuinness TM, Blanton DJ. (2008). Communication and academic challenges in early adolescence for children who have been adopted from the former Soviet Union. Lang Speech Hear Serv Sch.
32 Bharti B, Bharti S. (2010). Parent-based language intervention for 2-year old children with specific expressive language delay: a randomised controlled trial with erroneous confidence (intervals). Arch Dis Child.
33 Bierman KL, Nix RL, Greenberg MT, et al. (2008). Executive functions and school readiness intervention: impact, moderation, and mediation in the Head Start REDI program. Dev Psychopathol.
34 Bingham GE, Hall-Kenyon KM, Culatta B. (2010). Systematic and engaging early literacy: Examining the effects of paraeducator implemented early literacy instruction. Commun Disord Q.
35 Bishop DV, Baird G. (2001). Parent and teacher report of pragmatic aspects of communication: use of the children’s communication checklist in a clinical setting. Dev Med Child Neurol.
36 Bishop DV, Hayiou-Thomas ME. (2008). Heritability of specific language impairment depends on diagnostic criteria. Genes Brain Behav.
37 Bishop DVM, Baird G. (2005). ‘Parent and teacher report of pragmatic aspects of communication: Use of the Children’s Communication Checklist in a clinical setting’: Erratum. Dev Med Child Neurol.
38 Black MM, Gerson LF, Freeland CA, et al. (1988). Language screening for infants prone to otitis media. J Pediatr Psychol.
39 Blaxley L, Clinker M, Warr-Leeper GA. (1983). Two language screening tests compared with developmental sentence scoring. Lang Speech Hear Ser Schools.
40 Bleses D, Vach W, Jorgensen RN, et al. (2010). The internal validity and acceptability of the Danish SI-3: a language-screening instrument for 3-year-olds. J Speech Lang Hear Res.
41 Boets B, Vandermosten M, Poelmans H, et al. (2011). Preschool impairments in auditory processing and speech perception uniquely predict future reading problems. Res Dev Disabil.
42 Bölte S, Westerwald E, Holtmann M, et al. (2011). Autistic traits and autism spectrum disorders: The clinical validity of two measures presuming a continuum of social communication skills. J Autism Dev Disord.
43 Bolton PF, Golding J, Emond A, et al. (2012). Autism spectrum disorder and autistic traits in the Avon Longitudinal Study of Parents and Children: precursors and early signs. J Am Acad Child Adolesc Psychiatry.
44 Boris NW. (2010). Minding the transition to school. J Am Acad Child Adolesc Psychiatry.
45 Bornman J, Sevcik RA, Romski M, et al. (2010). Successfully translating language and culture when adapting assessment measures. J Pol Pract Intell Disabil.
46 Bortolini U, Arfe B, Caselli CM, et al. (2006). Clinical markers for specific language impairment in Italian: The contribution of clitics and non-word repetition. Int J Lang Commun Disord.
47 Bothe AK, Davidow JH, Bramlett RE, et al. (2006). Stuttering treatment research 1970–2005: I. Systematic review incorporating trial quality assessment of behavioral, cognitive, and related approaches. Am J Speech Lang Pathol.
48 Boudreau D. (2005). Use of a parent questionnaire in emergent and early literacy assessment of preschool children. Lang Speech Hear Ser Schools.
49 Bowyer-Crane C, Snowling MJ, Duff FJ, et al. (2008). Improving early language and literacy skills: differential effects of an oral language versus a phonology with reading intervention. J Child Psychol Psychiatry.
50 Boyle J, McCartney E, O’Hare A, et al. (2010). Intervention for mixed receptive-expressive language impairment: a review. Dev Med Child Neurol.
51 Bozaykut A, Aksoy HU, Sezer RG, et al. (2014). Evaluation of Clinical Course and Neurocognition in Children With Self-Limited Infantile Epilepsy in a Turkish Cohort Study. J Child Neurol.
52 Braaten EB, Norman D. (2006). Intelligence (IQ) testing. Pediatr Rev.
53 Brackenbury T, Pye C. (2005). Semantic deficits in children with language impairments: issues for clinical assessment. Lang Speech Hear Serv Sch.
54 Brancalioni AR, Magnago KF, Keske-Soares M. (2012). Proposal for classifying the severity of speech disorder using a fuzzy model in accordance with the implicational model of feature complexity. Clin Linguist Phon.
55 Briggs RD, Stettler EM, Silver EJ, et al. (2012). Social-emotional screening for infants and toddlers in primary care. Pediatrics.
56 Brookhouser PE, Hixson PK, Matkin ND. (1979). Early childhood language delay: the otolaryngologist’s perspective. Laryngoscope.
57 Broomfield J, Dodd B. (2004). The nature of referred subtypes of primary speech disability. Child Lang Teach Ther.
58 Brownlie EB, Beitchman JH, Escobar M, et al. (2004). Early language impairment and young adult delinquent and aggressive behavior. J Abnorm Child Psychol.
59 Burne B, Knafelc V, Melonis M, et al. (2011). The use and application of assistive technology to promote literacy in early childhood: a systematic review. Disabil Rehabil Assist Technol.
60 Busari JO, Weggelaar NM. (2004). How to investigate and manage the child who is slow to speak. BMJ.
61 Buschmann A, Jooss B, Rupp A, et al. (2008). Children with developmental language delay at 24 months of age: results of a diagnostic work-up. Dev Med Child Neurol.
62 Buschmann A, Jooss B, Rupp A, et al. (2009). Parent based language intervention for 2-year-old children with specific expressive language delay: a randomised controlled trial. Arch Dis Child.
63 Butterworth B, Kovas Y. (2013). Understanding neurocognitive developmental disorders can improve education for all. Science.
64 Cabell SQ, Justice LM, Zucker TA, et al. (2009). Validity of teacher report for assessing the emergent literacy skills of at-risk preschoolers. Lang Speech Hear Serv Sch.
65 Camilleri B, Botting N. (2013). Beyond static assessment of children’s receptive vocabulary: the dynamic assessment of word learning (DAWL). Int J Lang Commun Disord.
66 Camilleri B, Law J. (2007). Assessing children referred to speech and language therapy: static and dynamic assessment of receptive vocabulary. Adv Speech Lang Pathol.
67 Campisi L, Serbin LA, Stack DM, et al. (2009). Precursors of language ability and academic performance: an inter-generational, longitudinal study of at-risk children. Infant Child Develop.
68 Cantwell DP, Baker L. (1985). Psychiatric and learning disorders in children with speech and language disorders: a descriptive analysis. Adv in Learning & Behav Disabilities.
69 Cappiello MM, Gahagan S. (2009). Early child development and developmental delay in indigenous communities. Pediatr Clin North Am.
70 Capute AJ, Palmer FB, Shapiro BK, et al. (1986). Clinical linguistic and auditory milestone scale: prediction of cognition in infancy. Dev Med Child Neurol.
71 Carr Swift M, O’Brian S, Hewat S, et al. (2011). Investigating parent delivery of the Lidcombe Program. Int J Speech Lang Pathol.
72 Carter AS, Messinger DS, Stone WL, et al. (2011). A randomized controlled trial of Hanen’s ‘More Than Words’ in toddlers with early autism symptoms. J Child Psychol Psychiatry.
73 Caskey M, Vohr B. (2013). Assessing language and language environment of high-risk infants and children: a new approach. Acta Paediatr.
74 Cattani A, Bonifacio S, Fertz M, et al. (2010). Communicative and linguistic development in preterm children: A longitudinal study from 12 to 24 months. Int J Lang Commun Disord.
75 Catts HW, Petscher Y, Schatschneider C, et al. (2009). Floor effects associated with universal screening and their impact on the early identification of reading disabilities. J Learn Disabil.
76 Chaffee CA, Cunningham CE, Secord-Gilbert M, et al. (1990). Screening effectiveness of the Minnesota Child Development Inventory Expressive and Receptive Language Scales: sensitivity, specificity, and predictive value. Psychol Assess.
77 Champion TB, Rosa-Lugo LI, Rivers KO, et al. (2010). A preliminary investigation of second- and fourth-grade African American students’ performance on the Gray Oral Reading Test—Fourth Edition. Topics Lang Disord.
78 Chang SE, Zhu DC. (2013). Neural network connectivity differences in children who stutter. Brain.
79 Chen CW, Li CY, Wang JK. (2004). Growth and development of children with congenital heart disease. J Adv Nurs.
80 Chiat S, Roy P. (2007). The preschool repetition test: an evaluation of performance in typically developing and clinically referred children. J Speech Lang Hear Res.
81 Chiu S, DiMarco MA. (2010). A pilot study comparing two developmental screening tools for use with homeless children. Journal of Pediatric Healthcare.
82 Choudhury N, Benasich AA. (2011). Maturation of auditory evoked potentials from 6 to 48 months: prediction to 3 and 4 year language and cognitive abilities. Clin Neurophysiol.
83 Christensen RV, Hansson K, Oetting J, et al. (2012). The Use and Productivity of Past Tense Morphology in Specific Language Impairment: An Examination of Danish. J Speech Lang Hear Res.
84 Ciccia AH, Whitford B, Krumm M, et al. (2011). Improving the access of young urban children to speech, language and hearing screening via telehealth. J Telemed Telecare.
85 Ciccone N, Hennessey N, Stokes SF. (2012). Community-based early intervention for language delay: A preliminary investigation. Int J Lang Commun Disord.
86 Ciolli L, Seymour HN. (2004). Dialect identification versus evaluation of risk in language screening. Semin Speech Lang.
87 Clegg J, Ansorge L, Stackhouse J, et al. (2012). Developmental communication impairments in adults: Outcomes and life experiences of adults and their parents. Language, Speech, and Hearing Services in Schools.
88 Cole KN, Dale PS. (1986). Direct language instruction and interactive language instruction with language delayed preschool children: a comparison study. J Speech Hear Res.
89 Conti-Ramsden G. (2003). Processing and linguistic markers in young children with specific language impairment (SLI). J Speech Lang Hear Res.
90 Coplan J, Gleason JR, Ryan R, et al. (1982). Validation of an early language milestone scale in a high-risk population. Pediatrics.
91 Core C, Hoff E, Rumiche R, et al. (2013). Total and conceptual vocabulary in Spanish-English bilinguals from 22 to 30 months: implications for assessment. J Speech Lang Hear Res.
92 Council on Children with Disabilities. (2006). Identifying infants and young children with developmental disorders in the medical home: an algorithm for developmental surveillance and screening. Pediatrics.
93 Courtright JA, Courtright IC. (1979). Imitative modeling as a language intervention strategy: the effects of two mediating variables. J Speech Hear Res.
94 Crais ER. (2011). Testing and beyond: strategies and tools for evaluating and assessing infants and toddlers. Lang Speech Hear Serv Sch.
95 Cummings AE, Barlow JA. (2011). A comparison of word lexicality in the treatment of speech sound disorders. Clin Linguist Phon.
96 de Lourdes Drachler M, de Castro Aerts DG, de Souza RM, et al. (2005). Social inequalities in maternal opinion of child development in southern Brazil. Acta Paediatr.
97 de Ridder H, van derStege H. (2004). Early detection of developmental language disorders. Verhoeven L, van Balkom H, editors. Classification of developmental language disorders: Theoretical issues and clinical implications.
98 Deave T, Heron J, Evans J, et al. (2008). The impact of maternal depression in pregnancy on early child development. BJOG.
99 Deevy P, Weil LW, Leonard LB, et al. (2010). Extending use of the NRT to preschool-age children with and without specific language impairment. Lang Speech Hear Serv Sch.
100 Delgado CE, Vagi SJ, Scott KG. (2006). Tracking preschool children with developmental delay: third grade outcomes. Am J Ment Retard.
101 Dereu M, Roeyers H, Raymaekers R, et al. (2012). How useful are screening instruments for toddlers to predict outcome at age 4? General development, language skills, and symptom severity in children with a false positive screen for autism spectrum disorder. Eur Child Adolesc Psychiatry.
102 Desch LW, Gaebler-Spira D. (2008). Prescribing assistive-technology systems: focus on children with impaired communication. Pediatrics.
103 Dethorne LS, Johnson BW, Loeb JW. (2005). A closer look at MLU: what does it really measure?. Clin Linguist Phon.
104 Devescovi A, Caselli MC. (2007). Sentence repetition as a measure of early grammatical development in Italian. Int J Lang Commun Disord.
105 Diepeveen FB, De Kroon ML, Dusseldorp E, et al. (2013). Among perinatal factors, only the Apgar score is associated with specific language impairment. Dev Med Child Neurol.
106 Dietz C, Swinkels S, van Daalen E, et al. (2006). Screening for autistic spectrum disorder in children aged 14–15 months. II: population screening with the Early Screening of Autistic Traits Questionnaire (ESAT). Design and general findings. J Autism Dev Disord.
107 Dockrell JE, Stuart M, King D. (2010). Supporting early oral language skills for English language learners in inner city preschool provision. Br J Educ Psychol.
108 Dodge GR. (1980). A comparison of language screening methods. Lang Speech Hear Ser Schools.
109 D’Odorico L, Majorano M, Fasolo M, et al. (2011). Characteristics of phonological development as a risk factor for language development in Italian-speaking pre-term children: A longitudinal study. Clin Linguist Phon.
110 Dohmen A, Vogt S. (2006). Late talker -- early intervention for children being at risk of language disorder. Forum Logopadie.
111 Dollaghan CA, Horner EA. (2011). Bilingual language assessment: a meta-analysis of diagnostic accuracy. J Speech Lang Hear Res.
112 Duffner PK, Granger C, Lyon N, et al. (2012). Developmental and functional outcomes in children with a positive newborn screen for Krabbe disease: A pilot study of a phone-based interview surveillance technique. J Pediatr.
113 Eadie PA, Ukoumunne O, Skeat J, et al. (2010). Assessing early communication behaviours: structure and validity of the Communication and Symbolic Behaviour Scales-Developmental Profile (CSBS-DP) in 12-month-old infants. Int J Lang Commun Disord.
114 Earls MF, Andrews JE, Hay SS. (2009). A longitudinal study of developmental and behavioral screening and referral in North Carolina’s Assuring Better Child Health and Development participating practices. Clin Pediatr (Phila).
115 Ebbels SH, van der Lely HK, Dockrell JE. (2007). Intervention for verb argument structure in children with persistent SLI: a randomized control trial. J Speech Lang Hear Res.
116 Edwards J, Beckman ME. (2008). Methodological questions in studying consonant acquisition. Clin Linguist Phon.
117 Einarsdottir J, Ingham R. (2009). Accuracy of parent identification of stuttering occurrence. Int J Lang Commun Disord.
118 Einarsdottir J, Ingham RJ. (2005). Have disfluency-type measures contributed to the understanding and treatment of developmental stuttering?. Am J Speech Lang Pathol.
119 Eisenberg S. (2005). Clinical focus. When conversation is not enough: assessing infinitival complements through elicitation. Am J Speech Lang Pathol.
120 Eisenberga SL, Ling-Yu G. (2013). Differentiating Children With and Without Language Impairment Based on Grammaticality. Lang Speech Hear Ser Schools.
121 Ek U, Norrelgen F, Westerlund J, et al. (2012). Teenage outcomes after speech and language impairment at preschool age. Neuropsychiatr Dis Treat.
122 Elbro C, Dalby M, Maarbjerg S. (2011). Language-learning impairments: a 30-year follow-up of language-impaired children with and without psychiatric, neurological and cognitive difficulties. Int J Lang Commun Disord.
123 Ellis JM, Tan HK, Gilbert RE, et al. (2008). Supplementation with antioxidants and folinic acid for children with Down’s syndrome: randomised controlled trial. BMJ.
124 Emanuel R, Chiat S, Roy P. (2007). Evaluation of the clinical decisions made for 2-year-olds referred for speech and language therapy: a follow-up study. Int J Lang Commun Disord.
125 Engel S, Tronhjem KM, Hellgren LI, et al. (2013). Docosahexaenoic acid status at 9 months is inversely associated with communicative skills in 3-year-old girls. Matern Child Nutr.
126 Eom S, Fisher B, Dezort C, et al. (2014). Routine developmental, autism, behavioral, and psychological screening in epilepsy care settings. Dev Med Child Neurol.
127 Erford BT, Luce CL. (2005). Reliability and validity of scores on the Slosson Auditory Perception Skills Screener. Percept Mot Skills.
128 Eriksson M, Westerlund M, Miniscalco C. (2010). Problems and limitations in studies on screening for language delay. Res Dev Disabil.
129 Farkas C. (2011). Inventario del Desarrollo de Habilidades Comunicativas McArthur-Bates (CDI): Propuesta de una versión abreviada. Universitas Psychologica.
130 Farmer M, Oliver A. (2005). Assessment of pragmatic difficulties and socioemotional adjustment in practice. Int J Lang Commun Disord.
131 Farver JM, Nakamoto J, Lonigan CJ. (2007). Assessing preschoolers’ emergent literacy skills in English and Spanish with the Get Ready to Read! screening tool. Ann Dyslexia.
132 Feeney J, Bernthal J. (1996). The efficiency of the revised Denver Developmental Screening Test as a language screening tool. Lang Speech Hear Ser Schools.
133 Feldman HM. (2005). Evaluation and management of language and speech disorders in preschool children. Pediatr Rev.
134 Felsenfeld S, van Beijsterveldt CE, Boomsma DI. (2010). Attentional regulation in young twins with probable stuttering, high nonfluency, and typical fluency. J Speech Lang Hear Res.
135 Fernald LCH, Kariger P, Hidrobo M, et al. (2012). Socioeconomic gradients in child development in very young children: Evidence from India, Indonesia, Peru, and Senegal. PNAS Proceedings of the National Academy of Sciences of the United States of America.
136 Fernell E, Hedvall A, Westerlund J, et al. (2011). Early intervention in 208 Swedish preschoolers with autism spectrum disorder. A prospective naturalistic study. Res Dev Disabil.
137 Flax JF, Realpe-Bonilla T, Roesler C, et al. (2009). Using early standardized language measures to predict later language and early reading outcomes in children at high risk for language-learning impairments. J Learn Disabil.
138 Flipsen P, Hammer JB, Yost KM. (2005). Measuring severity of involvement in speech delay: segmental and whole-word measures. Am J Speech Lang Pathol.
139 Franken MC, Kielstra-Van der Schalk CJ, Boelens H. (2005). Experimental treatment of early stuttering: a preliminary study. J Fluency Disord.
140 Fulks MA, Harris SR. (2005). Predictive accuracy of the Miller assessment for preschoolers in children with prenatal drug exposure. Phys Occup Ther Pediatr.
141 Gallardo G, Guàrdia J, Villaseñor T, et al. (2011). Psychometric data for the Revised Token Test in normally developing Mexican children ages 4–12 years. Arch Clin Neuropsychol.
142 Gamliel I, Yirmiya N, Jaffe DH, et al. (2009). Developmental trajectories in siblings of children with autism: cognition and language from 4 months to 7 years. J Autism Dev Disord.
143 Gardner H, Froud K, McClellan A, et al. (2006). Development of the Grammar and Phonology Screening (GAPS) test to assess key markers of specific language and literacy difficulties in young children. Int J Lang Commun Disord.
144 Gatt D, Grech H, Dodd B. (2013). Early lexical expression in typically developing Maltese children: implications for the identification of language delay. Clin Linguist Phon.
145 Gejao MG, Ferreira AT, Silva GK, et al. (2009). Communicative and psycholinguistic abilities in children with phenylketonuria and congenital hypothyroidism. J Appl Oral Sci.
146 Gerber S, Brice A, Capone N, et al. (2012). Language use in social interactions of school-age children with language impairments: an evidence-based systematic review of treatment. Lang Speech Hear Serv Sch.
147 German ML, Williams E, Herzfeld J, et al. (1982). Utility of the Revised Denver Developmental Screening Test and the Developmental Profile II in identifying preschool children with cognitive, language, and motor problems. Educ Train Mental Retard.
148 Gernand KL Moran MJ Phonological awareness abilities of 6-year-old children with mild to moderate phonological impairments Commun Disord Q 2007 28 4 206 15 2008-04464-002First Author & Affiliation: Gernand, Keri Leigh. Exclusion Code: X3
149 Gerrits E, de Bree E. (2009). Early language development of children at familial risk of dyslexia: Speech perception and production. J Commun Disord.
150 Geurts H, Embrechts M. (2010). Pragmatics in pre-schoolers with language impairments. Int J Lang Commun Disord.
151 Ghassabian A, Rescorla L, Henrichs J, et al. (2014). Early lexical development and risk of verbal and nonverbal cognitive delay at school age. Acta Paediatr.
152 Gibson J, Adams C, Lockton E, et al. (2013). Social communication disorder outside autism? A diagnostic classification approach to delineating pragmatic language impairment, high functioning autism and specific language impairment. Journal of Child Psychology and Psychiatry.
153 Gildersleeve-Neumann CE, Kester ES, Davis BL, et al. (2008). English speech sound development in preschool-aged children from bilingual English-Spanish environments. Lang Speech Hear Serv Sch.
154 Gillam RB, Loeb DF, Hoffman LM, et al. (2008). The efficacy of Fast ForWord Language intervention in school-age children with language impairment: a randomized controlled trial. J Speech Lang Hear Res.
155 Gillon GT. (2006). Phonological Awareness Intervention: A Preventive Framework for Preschool Children with Specific Speech and Language Impairments. McCauley RJ, Fey ME, editors. Treatment of language disorders in children.
156 Gillon GT, Moran CA, Hamilton E, et al. (2007). Phonological awareness treatment effects for children from low socioeconomic backgrounds. Asia Pacific Journal of Speech, Language, and Hearing.
157 Girolametto L, Weitzman E, Greenberg J. (2012). Facilitating emergent literacy: efficacy of a model that partners speech-language pathologists and educators. Am J Speech Lang Pathol.
158 Glascoe FP. (1991). Can clinical judgment detect children with speech-language problems?. Pediatrics.
159 Glascoe FP, Byrne KE. (1993). The accuracy of three developmental screening tests. J Early Interv.
160 Glaspey A, Stoel-Gammon C. (2007). A dynamic approach to phonological assessment. Adv Speech Lang Pathol.
161 Glaspey AM, Stoel-Gammon C. (2005). Dynamic assessment in phonological disorders: the Scaffolding Scale of Stimulability. Topics Lang Disord.
162 Glennen SL. (2007). Predicting language outcomes for internationally adopted children. J Speech Lang Hear Res.
163 Glogowska M, Roulstone S, Peters TJ, et al. (2006). Early speech- and language-impaired children: linguistic, literacy, and social outcomes. Dev Med Child Neurol.
164 Goldberg CS, Lu M, Sleeper LA, et al. (2014). Factors Associated with Neurodevelopment for Children with Single Ventricle Lesions. J Pediatr.
165 Goldstein B, Kohnert K. (2005). Speech, language, and hearing in developing bilingual children: current findings and future directions. Lang Speech Hear Serv Sch.
166 Gollenberg AL, Lynch CD, Jackson LW, et al. (2010). Concurrent validity of the parent-completed Ages and Stages Questionnaires, 2nd Ed. with the Bayley Scales of Infant Development II in a low-risk sample. Child Care Health Dev.
167 Gordon K, Pasco G, McElduff F, et al. (2011). A communication-based intervention for nonverbal children with autism: what changes? Who benefits?. J Consult Clin Psychol.
168 Gorman BK. (2009). Cross-linguistic universals in reading acquisition with applications to English-language learners with reading disabilities. Semin Speech Lang.
169 Gray S. (2003). Diagnostic accuracy and test-retest reliability of nonword repetition and digit span tasks administered to preschool children with specific language impairment. J Commun Disord.
170 Greenslade KJ, Plante E, Vance R. (2009). The diagnostic accuracy and construct validity of the structured photographic expressive language test--preschool: second edition. Lang Speech Hear Serv Sch.
171 Grizzle KL, Simms MD. (2005). Early language development and language learning disabilities. Pediatr Rev.
172 Guadarrama-Celaya F, Otero-Ojeda GA, Bernardo Pliego-Rivero F, et al. (2012). Screening of neurodevelopmental delays in four communities of Mexico and Cuba. Public Health Nurs.
173 Guiberson M, Rodriguez BL. (2013). Classification accuracy of nonword repetition when used with preschool-age Spanish-speaking children. Lang Speech Hear Serv Sch.
174 Gutierrez-Clellen V, Simon-Cereijido G, Sweet M. (2012). Predictors of second language acquisition in Latino children with specific language impairment. Am J Speech Lang Pathol.
175 Haber J, Norris M. (1983). The Texas Preschool Screening Inventory: a simple screening device for language and learning disorders. Child Health Care.
176 Hadley PA. (2006). Assessing the emergence of grammar in toddlers at risk for specific language impairment. Semin Speech Lang.
177 Hagberg BS, Miniscalco C, Gillberg C. (2010). Clinic attenders with autism or attention-deficit/hyperactivity disorder: cognitive profile at school age and its relationship to preschool indicators of language delay. Res Dev Disabil.
178 Hall AJ, Maw AR, Steer CD. (2009). Developmental outcomes in early compared with delayed surgery for glue ear up to age 7 years: a randomised controlled trial. Clin Otolaryngol.
179 Hall NE, Segarra VR. (2007). Predicting academic performance in children with language impairment: the role of parent report. J Commun Disord.
180 Hannus S, Kauppila T, Pitkäniemi J, et al. (2013). Use of language tests when identifying specific language impairment in primary health care. Folia Phoniatrica et Logopaedica.
181 Harris MN, Voigt RG, Barbaresi WJ, et al. (2013). ADHD and learning disabilities in former late preterm infants: a population-based birth cohort. Pediatrics.
182 Harty M, Alant E, Uys CJ. (2007). Maternal self-efficacy and maternal perception of child language competence in pre-school children with a communication disability. Child Care Health Dev.
183 Hassink JM, Leonard LB. (2010). Within-treatment factors as predictors of outcomes following conversational recasting. Am J Speech Lang Pathol.
184 Hatcher PJ, Hulme C, Miles JN, et al. (2006). Efficacy of small group reading intervention for beginning readers with reading-delay: a randomised controlled trial. J Child Psychol Psychiatry.
185 Hay I, Elias G, Fielding-Barnsley R, et al. (2007). Language delays, reading delays, and learning difficulties: interactive elements requiring multidimensional programming. J Learn Disabil.
186 Helland T, Plante E, Hugdahl K. (2011). Predicting dyslexia at age 11 from a risk index questionnaire at age 5. Dyslexia.
187 Heo KH, Squires J. (2012). Cultural adaptation of a parent completed social emotional screening instrument for young children: Ages and stages questionnaire-social emotional. Early Hum Dev.
188 Hesketh A, Dima E, Nelson V. (2007). Teaching phoneme awareness to pre-literate children with speech disorder: a randomized controlled trial. Int J Lang Commun Disord.
189 Hetzroni OE. (2004). AAC and literacy. Disabil Rehabil.
190 Hillen T, Gafson L. (2014). Statutory health assessments for pre-school foster children fail to screen accurately for mental health disorders. Clin Child Psychol Psychiatry.
191 Hix-Small H, Marks K, Squires J, et al. (2007). Impact of implementing developmental screening at 12 and 24 months in a pediatric practice. Pediatrics.
192 Hodge T, Downie J. (2004). Together we are heard: effectiveness of daily ‘language’ groups in a community preschool. Nurs Health Sci.
193 Holm A, Farrier F, Dodd B. (2008). Phonological awareness, reading accuracy and spelling ability of children with inconsistent phonological disorder. Int J Lang Commun Disord.
194 Hornman J, Kerstjens JM, de Winter AF, et al. (2013). Validity and internal consistency of the Ages and Stages Questionnaire 60-month version and the effect of three scoring methods. Early Hum Dev.
195 Horowitz L, Jansson L, Ljungberg T, et al. (2006). Interaction before conflict and conflict resolution in pre-school boys with language impairment. Int J Lang Commun Disord.
196 Howlin P. (2006). Augmentative and Alternative Communication Systems for Children with Autism. Charman T, Stone W, editors. Social & communication development in autism spectrum disorders: Early identification, diagnosis, & intervention.
197 Hughes CW, Melson AG. (2008). Child and adolescent measures for diagnosis and screening. Rush AJ, First MB, Blacker D, editors. Handbook of psychiatric measures.
198 Hustad KC, Keppner K, Schanz A, et al. (2008). Augmentative and alternative communication for preschool children: intervention goals and use of technology. Semin Speech Lang.
199 Hwa-Froelich DA, Matsuo H. (2005). Vietnamese children and language-based processing tasks. Lang Speech Hear Serv Sch.
200 Hyde ML. (2005). Newborn hearing screening programs: overview. J Otolaryngol.
201 Illerbrun D, Haines L, Greenough P. (1985). Language Identification Screening Test for Kindergarten: a comparison with four screening and three diagnostic language tests. Lang Speech Hear Serv Schools.
202 Isotani SM, Azevedo MF, Chiari BM, et al. (2009). Expressive language of two year-old pre-term and full-term children. Pro Fono.
203 Jackson J, Kornrich R, Safranek S. (2011). Clinical inquiries. How should you evaluate a toddler for speech delay?. J Fam Pract.
204 Jee SH, Szilagyi M, Ovenshire C, et al. (2010). Improved detection of developmental delays among young children in foster care. Pediatrics.
205 Jessup B, Ward E, Cahill L, et al. (2008). Teacher identification of speech and language impairment in kindergarten students using the Kindergarten Development Check. Int J Speech Lang Pathol.
206 Jimenez JE, Rodriguez C, Crespo P, et al. (2010). Implementation of Response to Intervention (RtI) Model in Spain: an example of a collaboration between Canarian universities and the department of education of the Canary Islands. Psicothema.
207 Joffe VL, Black E. (2012). Social, emotional, and behavioral functioning of secondary school students with low academic and language performance: perspectives from students, teachers, and parents. Lang Speech Hear Serv Sch.
208 Johnson CA, Weston AD, Bain BA. (2004). An objective and time-efficient method for determining severity of childhood speech delay. Am J Speech Lang Pathol.
209 Johnson CJ, Beitchman JH, Brownlie EB. (2010). Twenty-year follow-up of children with and without speech-language impairments: Family, educational, occupational, and quality of life outcomes. Am J Speech Lang Pathol.
210 Jordan R. (2005). Managing autism and Asperger’s syndrome in current educational provision. Pediatr Rehabil.
211 Justice LM, Bowles RP, Pence Turnbull KL, et al. (2009). School readiness among children with varying histories of language difficulties. Dev Psychol.
212 Justice LM, Petscher Y, Schatschneider C, et al. (2011). Peer effects in preschool classrooms: is children’s language growth associated with their classmates’ skills?. Child Dev.
213 Justice LM, Skibbe LE, McGinty AS, et al. (2011). Feasibility, efficacy, and social validity of home-based storybook reading intervention for children with language impairment. J Speech Lang Hear Res.
214 Kaderavek JN, Justice LM. (2004). Embedded-explicit emergent literacy intervention II: goal selection and implementation in the early childhood classroom. Lang Speech Hear Serv Sch.
215 Kapalková S, Polišenská K, Vicenová Z. (2013). Non-word repetition performance in Slovak-speaking children with and without SLI: novel scoring methods. Int J Lang Commun Disord.
216 Kapci EG, Kucuker S, Uslu RI. (2010). How applicable are Ages and Stages Questionnaires for use with Turkish children?. Topics in Early Childhood Special Education.
217 Kasper J, Kreis J, Scheibler F, et al. (2011). Population-based screening of children for specific speech and language impairment in Germany: a systematic review. Folia Phoniatr Logop.
218 Katz LA, Maag A, Fallon KA, et al. (2010). What makes a caseload (un)manageable? School-based speech-language pathologists speak. Lang Speech Hear Serv Sch.
219 Keegstra AL, Knijff WA, Post WJ, et al. (2007). Children with language problems in a speech and hearing clinic: background variables and extent of language problems. Int J Pediatr Otorhinolaryngol.
220 Kelley E, Paul JJ, Fein D, et al. (2006). Residual language deficits in optimal outcome children with a history of autism. J Autism Dev Disord.
221 Ketelaars MP, Cuperus J, Jansonius K, et al. (2010). Pragmatic language impairment and associated behavioural problems. Int J Lang Commun Disord.
222 Khan NZ, Muslima H, Shilpi AB, et al. (2013). Validation of a home-based neurodevelopmental screening tool for under 2-year-old children in Bangladesh. Child Care Health Dev.
223 King S, Laplante DP. (2005). The effects of prenatal maternal stress on children’s cognitive development: Project Ice Storm. Stress.
224 King TM, Rosenberg LA, Fuddy L, et al. (2005). Prevalence and early identification of language delays among at-risk three year olds. J Dev Behav Pediatr.
225 Kirk C, Gillon GT. (2007). Longitudinal effects of phonological awareness intervention on morphological awareness in children with speech impairment. Lang Speech Hear Serv Sch.
226 Klein PS, Tzuriel D. (1986). Preschoolers type of temperament as predictor of potential difficulties in cognitive functioning. Isr J Psychiatry Relat Sci.
227 Klein-Tasman BP, Mervis CB, Lord C, et al. (2007). Socio-communicative deficits in young children with Williams syndrome: Performance on the Autism Diagnostic Observation Schedule. Child Neuropsychol.
228 Kloth S, Janssen P, Kraaimaat F, et al. (1995). Communicative behavior of mothers of stuttering and nonstuttering high-risk children prior to the onset of stuttering. J Fluency Disord.
229 Koushik S, Hewat S, Shenker RC, et al. (2011). North-American Lidcombe Program file audit: replication and meta-analysis. Int J Speech Lang Pathol.
230 Kucuker S, Kapci EG, Uslu RI. (2011). Evaluation of the Turkish version of the ‘Ages and Stages Questionnaires: Social-Emotional’ in identifying children with social-emotional problems. Infants Young Child.
231 Lamont J, Girolametto L, Johnson CJ, et al. (2011). Emergent Literacy Skills of Preschoolers with Language Disorders: Monolingual English versus Dual Language Learners. Canadian Journal of Speech-Language Pathology & Audiology.
232 Laplante DP, Brunet A, Schmitz N, et al. (2008). Project Ice Storm: prenatal maternal stress affects cognitive and linguistic functioning in 5 1/2-year-old children. J Am Acad Child Adolesc Psychiatry.
233 Lattermann C, Euler HA, Neumann K. (2008). A randomized control trial to investigate the impact of the Lidcombe Program on early stuttering in German-speaking preschoolers. J Fluency Disord.
234 Law J, Boyle J, Harris F, et al. (1998). Screening for primary speech and language delay: a systematic review of the literature. Int J Lang Commun Disord.
235 Law J, Boyle J, Harris F, et al. (1998). Screening for speech and language delay: a systematic review of the literature. Health Technol Assess.
236 Law J, Boyle J, Harris F, et al. (2000). Prevalence and natural history of primary speech and language delay: findings from a systematic review of the literature. Int J Lang Commun Disord.
237 Law J, Dockrell J, Williams K, et al. (2004). Comparing specialist early years provision for speech and language impaired children with mainstream nursery provision in the UK -- an application of the Early Childhood Environment Rating Scale (ECERS). Child Care Health Dev.
238 Law J, Garrett Z, Nye C. (2003). Speech and language therapy interventions for children with primary speech and language delay or disorder. Cochrane Database Syst Rev.
239 Law J, Kot A, Barnett G. (1999). A comparison of two methods for providing intervention to three year old children with expressive/receptive language impairment.
240 Laws G, Bates G, Feuerstein M, et al. (2012). Peer acceptance of children with language and communication impairments in a mainstream primary school: Associations with type of language difficulty, problem behaviours and a change in placement organization. Child Lang Teach Ther.
241 Leitão S, Fletcher J. (2004). Literacy outcomes for students with speech impairment: Long-term follow-up. Int J Lang Commun Disord.
242 Leonard LB, Deevy P, Fey ME, et al. (2013). Sentence comprehension in specific language impairment: a task designed to distinguish between cognitive capacity and syntactic complexity. J Speech Lang Hear Res.
243 Leppert ML, Shank TP, Shapiro BK, et al. (1998). The capute scales: CAT/CLAMS-A pediatric assessment tool for the early detection of mental retardation and communicative disorders. Ment Retard Dev Disabil Res Rev.
244 Lerna A, Esposito D, Conson M, et al. (2012). Social-communicative effects of the Picture Exchange Communication System (PECS) in autism spectrum disorders. Int J Lang Commun Disord.
245 Lewis BA, Kirchner HL, Short EJ, et al. (2007). Prenatal cocaine and tobacco effects on children’s language trajectories. Pediatrics.
246 Limbos MM, Joyce DP. (2011). Comparison of the ASQ and PEDS in screening for developmental delay in children presenting for primary care. J Dev Behav Pediatr.
247 Linan-Thompson S. (2010). Response to instruction, English language learners and disproportionate representation: the role of assessment. Psicothema.
248 Lipka O, Siegel LS. (2010). The improvement of reading skills of L1 and ESL children using a Response to Intervention (RtI) Model. Psicothema.
249 Lung FW, Shu BC, Chiang TL, et al. (2008). Efficient developmental screening instrument for 6- and 18-month-old children in the Taiwan Birth Cohort Pilot Study. Acta Paediatr.
250 Lunkenheimer ES, Dishion TJ, Shaw DS, et al. (2008). Collateral benefits of the Family Check-Up on early childhood school readiness: indirect effects of parents’ positive behavior support. Dev Psychol.
251 Luu TM, Vohr BR, Allan W, et al. (2011). Evidence for catch-up in cognition and receptive vocabulary among adolescents born very preterm. Pediatrics.
252 Lyytinen H, Ahonen T, Eklund K, et al. (2004). Early development of children at familial risk for dyslexia--follow-up from birth to school age. Dyslexia.
253 Lyytinen H, Ahonen T, Eklund K, et al. (2001). Developmental pathways of children with and without familial risk for dyslexia during the first years of life. Dev Neuropsychol.
254 Lyytinen H, Erskine J, Kujala J, et al. (2009). In search of a science-based application: a learning tool for reading acquisition. Scand J Psychol.
255 Lyytinen P, Eklund K, Lyytinen H. (2005). Language development and literacy skills in late-talking toddlers with and without familial risk for dyslexia. Ann Dyslexia.
256 Macharey G, von Suchodoletz W. (2008). Perceived stigmatization of children with speech-language impairment and their parents. Folia Phoniatr Logop.
257 Macias MM, Saylor CF, Greer MK, et al. (1998). Infant screening: the usefulness of the Bayley Infant Neurodevelopmental Screener and the Clinical Adaptive Test/Clinical Linguistic Auditory Milestone Scale. J Dev Behav Pediatr.
258 Magnusson M, Sundelin C, Westerlund M. (2006). Identification of health problems at 18 months of age--a task for physicians or child health nurses?. Child Care Health Dev.
259 Marino BS, Lipkin PH, Newburger JW, et al. (2012). Neurodevelopmental outcomes in children with congenital heart disease: evaluation and management: a scientific statement from the American Heart Association. Circulation.
260 Markiewicz K, Pachalska M. (2007). Diagnosis of severe developmental disorders in children under three years of age. Med Sci Monit.
261 Marks K, Hix-Small H, Clark K, et al. (2009). Lowering developmental screening thresholds and raising quality improvement for preterm children. Pediatrics.
262 Martin AJ, Darlow BA, Salt A, et al. (2013). Performance of the Parent Report of Children’s Abilities-Revised (PARCA-R) versus the Bayley Scales of Infant Development III. Arch Dis Child.
263 Martin-Ruiz ML, Duboy MA, de la Cruz IP. (2013). Deployment and validation of a smart system for screening of language disorders in primary care. Sensors (Basel).
264 Massa J, Gomes H, Tartter V, et al. (2008). Concordance rates between parent and teacher clinical evaluation of Language Fundamentals Observational Rating Scale. Int J Lang Commun Disord.
265 Matheny N, Panagos J. (1978). Comparing the effects of articulation and syntax programmes on syntax and articulation improvement. Language Speech and Hearing Services in Schools.
266 Matthews-Somerville RC, Cress CJ. (2005). Parent Perceptions of Communication Behaviors at Formally Assessed Stage Transitions in Young Children at Risk for Being Nonspeaking. Commun Disord Q.
267 McCormack J, Harrison LJ, McLeod S, et al. (2011). A nationally representative study of the association between communication impairment at 4–5 years and children’s life activities at 7–9 years. J Speech Lang Hear Res.
268 McIntosh B, Dodd BJ. (2008). Two-year-olds’ phonological acquisition: normative data. Int J Speech Lang Pathol.
269 McKean K, Phillips B, Thompson A. (2012). A family-centred model of care in paediatric speech-language pathology. Int J Speech Lang Pathol.
270 McLeod S, Harrison LJ, McCormack J. (2012). The Intelligibility in Context Scale: Validity and Reliability of a Subjective Rating Measure. J Speech Lang Hear Res.
271 McLeod S, McCormack J. (2007). Application of the ICF and ICF-Children and Youth in children with speech impairment. Semin Speech Lang.
272 McPhillips M, Jordan-Black JA. (2007). The effect of social disadvantage on motor development in young children: a comparative study. J Child Psychol Psychiatry.
273 McQuiston S, Kloczko N. (2011). Speech and language development: monitoring process and problems. Pediatr Rev.
274 Merrell AW, Plante E. (1997). Norm-referenced test interpretation in the diagnostic process. Lang Speech Hear Ser Schools.
275 Millard SK, Cook FM. (2010). Working with young children who stutter: raising our game. Semin Speech Lang.
276 Millard SK, Nicholas A, Cook FM. (2008). Is parent-child interaction therapy effective in reducing stuttering?. J Speech Lang Hear Res.
277 Miniscalco C, Nygren G, Hagberg B, et al. (2006). Neuropsychiatric and neurodevelopmental outcome of children at age 6 and 7 years who screened positive for language problems at 30 months. Dev Med Child Neurol.
278 Miniscalco C, Westerlund M, Lohmander A. (2005). Language skills at age 6 years in Swedish children screened for language delay at 2(1/2) years of age. Acta Paediatr.
279 Mirrett PL, Bailey DB, Roberts JE, et al. (2004). Developmental screening and detection of developmental delays in infants and toddlers with fragile X syndrome. J Dev Behav Pediatr.
280 Moats L. (2004). Relevance of neuroscience to effective education for students with reading and other learning disabilities. J Child Neurol.
281 Moricke E, Swinkels SH, Beuker KT, et al. (2010). Predictive value of subclinical autistic traits at age 14–15 months for behavioural and cognitive problems at age 3–5 years. Eur Child Adolesc Psychiatry.
282 Morris SR. (2010). Clinical application of the mean babbling level and syllable structure level. Lang Speech Hear Serv Sch.
283 Mortimer J, Rvachew S. (2010). A longitudinal investigation of morpho-syntax in children with speech sound disorders. J Commun Disord.
284 Mouridsen SE, Hauschild K. (2009). A longitudinal study of personality disorders in individuals with and without a history of developmental language disorder. Logopedics Phoniatrics Vocology.
285 Munsell KL. (2007). A screening battery for identifying at-risk infants: Prediction of outcome on Bayley Scales of Infant/Todder Development-III. US: ProQuest Information & Learning.
286 Murray E, McCabe P, Ballard KJ. (2012). A comparison of two treatments for childhood apraxia of speech: methods and treatment protocol for a parallel group randomised control trial. BMC Pediatr.
287 Nair MK, Nair GS, George B, et al. (2013). Development and validation of Trivandrum Development Screening Chart for children aged 0–6 years [TDSC (0–6)]. Indian J Pediatr.
288 Nathani S, Oller DK, Neal AR. (2007). On the robustness of vocal development: an examination of infants with moderate-to-severe hearing loss and additional risk factors. J Speech Lang Hear Res.
289 Nelson HD, Bougatsos C, Nygren P. (2008). Universal newborn hearing screening: systematic review to update the 2001 US Preventive Services Task Force Recommendation. Pediatrics.
290 Noordenbos MW, Segers E, Serniclaes W, et al. (2012). Allophonic mode of speech perception in Dutch children at risk for dyslexia: a longitudinal study. Res Dev Disabil.
291 Oakenfull S, McGregor T, Ramtin F, et al. (2001). Re: WILSTAAR. Int J Lang Commun Disord.
292 O’Brian S, Iverach L, Jones M, et al. (2013). Effectiveness of the Lidcombe Program for early stuttering in Australian community clinics. Int J Speech Lang Pathol.
293 O’Connor M, Arnott W, McIntosh B, et al. (2009). Phonological awareness and language intervention in preschoolers from low socio-economic backgrounds: a longitudinal investigation. Br J Dev Psychol.
294 Oetting JB, Cleveland LH. (2006). The clinical utility of nonword repetition for children living in the rural south of the US. Clin Linguist Phon.
295 Oetting JB, Newkirk BL, Hartfield LR, et al. (2010). Index of productive syntax for children who speak African American English. Lang Speech Hear Ser Schools.
296 O’Hare AE. (2009). Wayward words and watchful waiting: should clinicians be more proactive for the preschooler with uncomplicated expressive language delay?. Arch Dis Child.
297 Oliver B, Dale PS, Plomin R. (2004). Verbal and nonverbal predictors of early language problems: an analysis of twins in early childhood back to infancy. J Child Lang.
298 Onslow M, Yaruss JS. (2007). Differing perspectives on what to do with a stuttering preschooler and why. Am J Speech Lang Pathol.
299 Pankratz ME, Plante E, Vance R, et al. (2007). The diagnostic and predictive validity of the Renfrew Bus Story. Lang Speech Hear Serv Sch.
300 Paradis J. (2005). Grammatical morphology in children learning English as a second language: implications of similarities with specific language impairment. Lang Speech Hear Serv Sch.
301 Patterson JL, Rodríguez BL, Dale PS. (2013). Response to Dynamic Language Tasks Among Typically Developing Latino Preschool Children With Bilingual Experience. Am J Speech Lang Pathol.
302 Paul R, Roth FP. (2011). Characterizing and predicting outcomes of communication delays in infants and toddlers: implications for clinical practice. Lang Speech Hear Serv Sch.
303 Peadon E, Rhys-Jones B, Bower C, et al. (2009). Systematic review of interventions for children with Fetal Alcohol Spectrum Disorders. BMC Pediatr.
304 Pearce WM, James DG, McCormack PF. (2010). A comparison of oral narratives in children with specific language and non-specific language impairment. Clin Linguist Phon.
305 Pennington L. (2010). Measuring communication outcomes. Dev Med Child Neurol.
306 Pennington L, Miller N, Robson S. (2009). Speech therapy for children with dysarthria acquired before three years of age. Cochrane Database Syst Rev.
307 Perona K, Plante E, Vance R. (2005). Diagnostic accuracy of the Structured Photographic Expressive Language Test: Third Edition (SPELT-3). Lang Speech Hear Ser Schools.
308 Pesco D, O’Neill DK. (2012). Predicting later language outcomes from the Language Use Inventory. J Speech Lang Hear Res.
309 Peter B, Button L, Stoel-Gammon C, et al. (2013). Deficits in sequential processing manifest in motor and linguistic tasks in a multigenerational family with childhood apraxia of speech. Clin Linguist Phon.
310 Peters SA, Grievink EH, van Bon WH, et al. (1997). The contribution of risk factors to the effect of early otitis media with effusion on later language, reading, and spelling. Dev Med Child Neurol.
311 Peterson RL, Pennington BF, Shriberg LD, et al. (2009). What influences literacy outcome in children with speech sound disorder?. J Speech Lang Hear Res.
312 Phillips BM, Lonigan CJ, Wyatt MA. (2009). Predictive validity of the get ready to read! Screener: concurrent and long-term relations with reading-related skills. J Learn Disabil.
313 Pickett E, Pullara O, O’Grady J, et al. (2009). Speech acquisition in older nonverbal individuals with autism: a review of features, methods, and prognosis. Cogn Behav Neurol.
314 Pickstone C, Goldbart J, Marshall J, et al. (2009). A systematic review of environmental interventions to improve child language outcomes for children with or at risk of primary language impairment. J Res Spec Educat Needs.
315 Pihko E, Mickos A, Kujala T, et al. (2007). Group intervention changes brain activity in bilingual language-impaired children. Cereb Cortex.
316 Plante E, Vance R. (1995). Diagnostic accuracy of two tests of preschool language. Am J Speech Lang Pathol.
317 Pollock KE, Price JR. (2005). Phonological skills of children adopted from China: implications for assessment. Semin Speech Lang.
318 Prathanee B, Purdy SC, Thinkhamrop B, et al. (2009). Early language delay and predictive factors in children aged 2 years. J Med Assoc Thai.
319 Price J, Roberts J, Vandergrift N, et al. (2007). Language comprehension in boys with fragile X syndrome and boys with Down syndrome. J Intellect Disabil Res.
320 Puolakanaho A, Ahonen T, Aro M, et al. (2007). Very early phonological and language skills: estimating individual risk of reading disability. J Child Psychol Psychiatry.
321 Puolakanaho A, Ahonen T, Aro M, et al. (2008). Developmental links of very early phonological and language skills to second grade reading outcomes: strong to accuracy but only minor to fluency. J Learn Disabil.
322 Qi CH, Kaiser AP. (2004). Problem behaviors of low-income children with language delays: an observation study. J Speech Lang Hear Res.
323 Quigg TC, Mahajerin A, Sullivan PD, et al. (2013). Ages and Stages Questionnaires-3 Developmental Screening of Infants and Young Children With Cancer. J Pediatr Oncol Nurs.
324 Quintero I, Hernández S, Verche E, et al. (2013). Disfunción ejecutiva en el Trastorno Específico del Lenguaje. = Executive dysfunction in Specific Language Impairment. Revista de Logopedia, Foniatría y Audiología.
325 Randall D, Reynell J, Curwen M. (1974). A study of language development in a sample of 3 year old children. Br J Disord Commun.
326 Rannard A, Lyons C, Glenn S. (2005). Parent concerns and professional responses: the case of specific language impairment. Br J Gen Pract.
327 Reading S, Richie C. (2007). Documenting changes in communication behaviours using a Structured Observation System. Child Lang Teach Ther.
328 Redmond SM. (2005). Differentiating SLI from ADHD using children’s sentence recall and production of past tense morphology. Clin Linguist Phon.
329 Reid J, Donaldson ML. (1996). The effectiveness of therapy for child phonological disorder: the Metaphon approach. MA, editor. Child Language.
330 Rescorla L. (2005). Age 13 language and reading outcomes in late-talking toddlers. J Speech Lang Hear Res.
331 Rescorla L. (2009). Age 17 language and reading outcomes in late-talking toddlers: support for a dimensional perspective on language delay. J Speech Lang Hear Res.
332 Rescorla L. (2011). Late talkers: do good predictors of outcome exist?. Dev Disabil Res Rev.
333 Rescorla L, Ross GS, McClure S. (2007). Language delay and behavioral/emotional problems in toddlers: findings from two developmental clinics. J Speech Lang Hear Res.
334 Roberts MY, Kaiser AP. (2011). The effectiveness of parent-implemented language interventions: a meta-analysis. Am J Speech Lang Pathol.
335 Romski M, Sevcik RA, Adamson LB, et al. (2010). Randomized comparison of augmented and nonaugmented language interventions for toddlers with developmental delays and their parents. J Speech Lang Hear Res.
336 Ross B, Cress CJ. (2006). Comparison of standardized assessments for cognitive and receptive communication skills in young children with complex communication needs. AAC: Augmentative & Alternative Communication.
337 Rousseau I, Packman A, Onslow M, et al. (2007). An investigation of language and phonological development and the responsiveness of preschool age children to the Lidcombe Program. J Commun Disord.
338 Ruscello DM, Cartwright LR, Haines KB, et al. (1993). The use of different service delivery models for children with phonological disorders. J Commun Disord.
339 Russ S, Halfon N. (2005). Early identification of language delays--are we there yet?. J Dev Behav Pediatr.
340 Rvachew S, Bernhardt BM. (2010). Clinical implications of dynamic systems theory for phonological development. Am J Speech Lang Pathol.
341 Rvachew S, Nowak M. (2001). The effect of target-selection strategy on phonological learning. J Speech Lang Hear Res.
342 Ryan-Krause P, Meadows-Oliver M, Sadler L, et al. (2009). Developmental status of children of teen mothers: contrasting objective assessments with maternal reports. Journal of Pediatric Healthcare.
343 Saltuklaroglu T, Kalinowski J. (2005). How effective is therapy for childhood stuttering? Dissecting and reinterpreting the evidence in light of spontaneous recovery rates. Int J Lang Commun Disord.
344 Samson JF, Lesaux NK. (2009). Language-minority learners in special education: rates and predictors of identification for services. J Learn Disabil.
345 Scheffler F, Vogel D, Astern R, et al. (2007). Screening for communication and cognitive disorders in infants and toddlers. Pediatr Nurs.
346 Scherer NJ, D’Antonio LL. (1995). Parent questionnaire for screening early language development in children with cleft palate. Cleft Palate Craniofac J.
347 Schirmer CR, Portuguez MW, Nunes ML. (2006). Clinical assessment of language development in children at age 3 years that were born preterm. Arq Neuropsiquiatr.
348 Schlosser RW. (2004). Goal attainment scaling as a clinical measurement technique in communication disorders: A critical review. J Commun Disord.
349 Schum RL. (2007). Language screening in the pediatric office setting. Pediatr Clin North Am.
350 Segers E, Verhoeven L. (2004). Computer-supported phonological awareness intervention for kindergarten children with specific language impairment. Lang Speech Hear Serv Sch.
351 Sevcik RA. (2006). Comprehension: An overlooked component in augmented language development. Disability and Rehabilitation: An International, Multidisciplinary Journal.
352 Sevcik RA, Barton-Hulsey A, Romski M. (2008). Early intervention, AAC, and transition to school for young children with significant spoken communication disorders and their families. Semin Speech Lang.
353 Shafer VL, Sussman E. (2011). Predicting the future: ERP markers of language risk in infancy. Clin Neurophysiol.
354 Share DL. (2008). Orthographic learning, phonological recoding, and self-teaching. Adv Child Dev Behav.
355 Sheldrick RC, Neger EN, Perrin EC. (2012). Concerns about development, behavior, and learning among parents seeking pediatric care. J Dev Behav Pediatr.
356 Shetty P. (2012). Speech and language delay in children: a review and the role of a pediatric dentist. J Indian Soc Pedod Prev Dent.
357 Shevell MI, Majnemer A, Webster RI, et al. (2005). Outcomes at school age of preschool children with developmental language impairment. Pediatr Neurol.
358 Shong SY, Cheng ST. (2009). Development of a screening instrument for early language delay in Hong Kong Chinese: a preliminary study. J Genet Psychol.
359 Sices L, Stancin T, Kirchner HL, et al. (2009). PEDS and ASQ developmental screening tests may not identify the same children. Pediatrics.
360 Sices L, Taylor HG, Freebairn L, et al. (2007). Relationship between speech-sound disorders and early literacy skills in preschool-age children: impact of comorbid language impairment. J Dev Behav Pediatr.
361 Sidhu M, Malhi P, Jerath J. (2010). Multiple risks and early language development. Indian J Pediatr.
362 Sigman M, McGovern CW. (2005). Improvement in cognitive and language skills from preschool to adolescence in autism. J Autism Dev Disord.
363 Simms MD. (2007). Language disorders in children: classification and clinical syndromes. Pediatr Clin North Am.
364 Singhania R, Sonksen P. (2004). The Indian picture puzzle test - a developmental test designed and standardised for Indian children. Indian J Pediatr.
365 Sittner Bridges M, Catts HW. (2011). The Use of a Dynamic Screening of Phonological Awareness to Predict Risk for Reading Disabilities in Kindergarten Children. J Learn Disabil.
366 Skovgaard AM, Olsen EM, Christiansen E, et al. (2008). Predictors (0–10 months) of psychopathology at age 1 1/2 years--A general population study in the Copenhagen Child Cohort CCC 2000. Journal of Child Psychology and Psychiatry.
367 Slott M, Vach W, Bleses D. (2008). Evaluation of methods used to assess language development of 3–4-year-old Danish children. Logoped Phoniatr Vocol.
368 Smit-Glaude SW, van Strien JW, Licht R, et al. (2005). Neuropsychological intervention in kindergarten children with subtyped risks of reading retardation. Ann Dyslexia.
369 Smith-Lock KM, Leitao S, Lambert L, et al. (2013). Effective intervention for expressive grammar in children with specific language impairment. Int J Lang Commun Disord.
370 Snowling MJ, Bishop DV, Stothard SE, et al. (2006). Psychosocial outcomes at 15 years of children with a preschool history of speech-language impairment. J Child Psychol Psychiatry.
371 Snowling MJ, Hulme C. (2012). Interventions for children’s language and literacy difficulties. Int J Lang Commun Disord.
372 Sohr-Preston SL, Scaramella LV. (2006). Implications of timing of maternal depressive symptoms for early cognitive and language development. Clin Child Fam Psychol Rev.
373 Spaulding TJ, Hosmer S, Schechtman C. (2013). Investigating the interchangeability and diagnostic utility of the PPVT-III and PPVT-IV for children with and without SLI. Int J Speech Lang Pathol.
374 Spaulding TJ, Plante E, Farinella KA. (2006). Eligibility criteria for language impairment: is the low end of normal always appropriate?. Lang Speech Hear Serv Sch.
375 Spek IL, Weisglas-Kuperus N. (2012). Language Functions in Preterm-Born Children: A Systematic Review and Meta-analysis. Pediatrics.
376 St James-Roberts I, Alston E. (2006). Attention development in 10-month-old infants selected by the WILSTAAR screen for pre-language difficulties. J Child Psychol Psychiatry.
377 St Pourcain B, Mandy WP, Heron J, et al. (2011). Links between co-occurring social-communication and hyperactive-inattentive trait trajectories. J Am Acad Child Adolesc Psychiatry.
378 Stern LM, Connell TM, Lee M, et al. (1995). The Adelaide preschool language unit: results of follow-up. J Paediatr Child Health.
379 Stevenson J, Richman N. (1976). The prevalence of language delay in a population of three-year-old children and its association with general retardation. Dev Med Child Neurol.
380 Stock CD, Fisher PA. (2006). Language delays among foster children: implications for policy and practice. Child Welfare.
381 Stockman IJ. (2008). Toward validation of a minimal competence phonetic core for african american children. J Speech Lang Hear Res.
382 Stoel-Gammon C, Williams AL. (2013). Early phonological development: creating an assessment test. Clin Linguist Phon.
383 Stokes SF, Klee T. (2009). The diagnostic accuracy of a new test of early nonword repetition for differentiating late talking and typically developing children. J Speech Lang Hear Res.
384 Suggate SP. (2010). Why what we teach depends on when: grade and reading intervention modality moderate effect size. Dev Psychol.
385 Tervo RC. (2006). Identifying patterns of developmental delays can help diagnose neurodevelopmental disorders. Clin Pediatr (Phila).
386 Thomas-Stonell N, Oddson B, Robertson B, et al. (2009). Predicted and observed outcomes in preschool children following speech and language treatment: parent and clinician perspectives. J Commun Disord.
387 Thomas-Stonell N, Oddson B, Robertson B, et al. (2013). Validation of the Focus on the Outcomes of Communication under Six outcome measure. Dev Med Child Neurol.
388 Thomas-Stonell N, Oddson B, Robertson B, et al. (2013). Validation of the Focus on the Outcomes of Communication under Six outcome measure. Dev Med Child Neurol.
389 Thordardottir E, Kehayia E, Mazer B, et al. (2011). Sensitivity and specificity of French language and processing measures for the identification of primary language impairment at age 5. J Speech Lang Hear Res.
390 Tjus T, Heimann M, Nelson K. (2004). Reading acquisition by implementing a multimedia intervention strategy for fifty children with autism or other learning and communication disabilities. Journal of Cognitive and Behavioral Psychotherapies.
391 To T, Guttmann A, Dick PT, et al. (2004). Risk markers for poor developmental attainment in young children: results from a longitudinal national survey. Arch Pediatr Adolesc Med.
392 Tomblin JB, Zhang X, Buckwalter P, et al. (2000). The association of reading disability, behavioral disorders, and language impairment among second-grade children. J Child Psychol Psychiatry.
393 Toohill BJ, McLeod S, McCormack J. (2012). Effect of dialect on identification and severity of speech impairment in Indigenous Australian children. Clin Linguist Phon.
394 Toth K, Dawson G, Meltzoff AN, et al. (2007). Early social, imitation, play, and language abilities of young non-autistic siblings of children with autism. J Autism Dev Disord.
395 Trajkovski N, Andrews C, Onslow M, et al. (2011). A phase II trial of the Westmead Program: syllable-timed speech treatment for pre-school children who stutter. Int J Speech Lang Pathol.
396 Turnbull KP, Anthony AB, Justice L, et al. (2009). Preschoolers’ exposure to language stimulation in classrooms serving at-risk children: The contribution of group size and activity context. Early Education and Development.
397 Valtonen R, Ahonen T, Lyytinen P, et al. (2004). Co-occurrence of developmental delays in a screening study of 4-year-old Finnish children. Dev Med Child Neurol.
398 van der Leij A, van Bergen E, van Zuijen T, et al. (2013). Precursors of developmental dyslexia: an overview of the longitudinal Dutch Dyslexia Programme study. Dyslexia.
399 van der Lely HK, Payne E, McClelland A. (2011). An investigation to validate the grammar and phonology screening (GAPS) test to identify children with specific language impairment. PLoS One.
400 van Kleeck A, Vander Woude J, Hammett L. (2006). Fostering literal and inferential language skills in Head Start preschoolers with language impairment using scripted book-sharing discussions. Am J Speech Lang Pathol.
401 van Otterloo SG, van der Leij A. (2009). Dutch home-based pre-reading intervention with children at familial risk of dyslexia. Ann Dyslexia.
402 Vandereet J, Maes B, Lembrechts D, et al. (2010). Predicting expressive vocabulary acquisition in children with intellectual disabilities: a 2-year longitudinal study. J Speech Lang Hear Res.
403 Vandewalle E, Boets B, Ghesquiere P, et al. (2012). Development of phonological processing skills in children with specific language impairment with and without literacy delay: a 3-year longitudinal study. J Speech Lang Hear Res.
404 Venker CE, McDuffie A, Ellis Weismer S, et al. (2012). Increasing verbal responsiveness in parents of children with autism:a pilot study. Autism.
405 Ventola P, Kleinman J, Pandey J, et al. (2007). Differentiating between autism spectrum disorders and other developmental disabilities in children who failed a screening instrument for ASD. J Autism Dev Disord.
406 Voigt RG, Llorente AM, Jensen CL, et al. (2007). Comparison of the validity of direct pediatric developmental evaluation versus developmental screening by parent report. Clin Pediatr (Phila).
407 Waite MC, Theodoros DG, Russell TG, et al. (2010). Internet-based telehealth assessment of language using the CELF-4. Lang Speech Hear Serv Sch.
408 Waite MC, Theodoros DG, Russell TG, et al. (2012). Assessing children’s speech intelligibility and oral structures, and functions via an Internet-based telehealth system. J Telemed Telecare.
409 Wake M, Gerner B, Gallagher S. (2005). Does parents’ evaluation of developmental status at school entry predict language, achievement, and quality of life 2 years later?. Ambul Pediatr.
410 Wake M, Levickis P, Tobin S, et al. (2012). Improving outcomes of preschool language delay in the community: protocol for the Language for Learning randomised controlled trial. BMC Pediatr.
411 Wankoff LS. (2011). Warning signs in the development of speech, language, and communication: when to refer to a speech-language pathologist. J Child Adolesc Psychiatr Nurs.
412 Washington JA, Craig HK. (2004). A language screening protocol for use with young African American children in urban settings. Am J Speech Lang Pathol.
413 Washington KN, Warr-Leeper G, Thomas-Stonell N. (2011). Exploring the outcomes of a novel computer-assisted treatment program targeting expressive-grammar deficits in preschoolers with SLI. J Commun Disord.
414 Webster RI, Majnemer A, Platt RW, et al. (2004). The predictive value of a preschool diagnosis of developmental language impairment. Neurology.
415 Weir E, Bianchet S. (2004). Developmental dysfluency: early intervention is key. CMAJ.
416 Weiss AL. (2004). Why we should consider pragmatics when planning treatment for children who stutter. Lang Speech Hear Serv Sch.
417 Wellman RL, Lewis BA, Freebairn LA, et al. (2011). Narrative ability of children with speech sound disorders and the prediction of later literacy skills. Lang Speech Hear Serv Sch.
418 Westerlund M. (2004). Identifying children at risk for language impairment: screening of communication at 18 months. Acta Paediatr.
419 Westerlund M, Lagerberg D. (2008). Expressive vocabulary in 18-month-old children in relation to demographic factors, mother and child characteristics, communication style and shared reading. Child Care Health Dev.
420 Westerveld MF, Gillon GT, Boyd L. (2012). Evaluating the clinical utility of the Profile of Oral Narrative Ability for 4-year-old children. Int J Speech Lang Pathol.
421 Whitehouse AJ, Robinson M, Zubrick SR. (2011). Late talking and the risk for psychosocial problems during childhood and adolescence. Pediatrics.
422 Whitworth A, Daves C, Stokes S, et al. (1993). Identification of communication impairments in preschoolers: a comparison of parent and teachers success. Aust J Hum Commun Disord.
423 Wijedasa D. (2012). Developmental screening in context: Adaptation and standardization of the Denver Developmental Screening Test-II (DDST-II) for Sri Lankan children. Child Care Health Dev.
424 Wilcox LD, Anderson RT. (1998). Distinguishing between phonological difference and disorder in children who speak African-American vernacular English: an experimental testing instrument. J Commun Disord.
425 Wilcox MJ, Kouri TA, Caswell SB. (1991). Early language intervention: a comparison of classroom and individual treatment. Am J Speech-Lang Path.
426 Williams C. (2006). Teacher judgements of the language skills of children in the early years of schooling. Child Lang Teach Ther.
427 Wilson SB, Lonigan CJ. (2009). An evaluation of two emergent literacy screening tools for preschool children. Ann Dyslexia.
428 Wilson SB, Lonigan CJ. (2010). Identifying preschool children at risk of later reading difficulties: evaluation of two emergent literacy screening tools. J Learn Disabil.
429 Wink M, Rosanowski F, Hoppe U, et al. (2007). Subjective burden in mothers of speech-impaired children. Folia Phoniatr Logop.
430 Wong AM, Klee T, Stokes SF, et al. (2010). Differentiating Cantonese-speaking preschool children with and without SLI using MLU and lexical diversity (D). J Speech Lang Hear Res.
431 Yoder PJ, Molfese D, Gardner E. (2011). Initial mean length of utterance predicts the relative efficacy of two grammatical treatments in preschoolers with specific language impairment. J Speech Lang Hear Res.
432 Yoon G, Kramer J, Zanko A, et al. (2006). Speech and language delay are early manifestations of juvenile-onset Huntington disease. Neurology.
433 Young AR, Beitchman JH, Johnson C, et al. (2002). Young adult academic outcomes in a longitudinal sample of early identified language impaired and control children. J Child Psychol Psychiatry.
434 Yu JW, Buka SL, McCormick MC, et al. (2006). Behavioral problems and the effects of early intervention on eight-year-old children with learning disabilities. Matern Child Health J.
435 Yurchak SH. (2004). The moderating influence of parental enculturation on the relationship between socioeconomic risk factors and outcomes for Native American preschool children. US: ProQuest Information & Learning.
436 Zakopoulou V, Anagnostopoulou A, Christodoulides P, et al. (2011). An interpretative model of early indicators of specific developmental dyslexia in preschool age: a comparative presentation of three studies in Greece. Res Dev Disabil.