# Appendix A Search Strategy

## Speech Language Evidence 2004 Forward Searches

| Search String | Results
#1 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) | 15523
#5 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 1246
| OVERARCHING EVIDENCE
#6 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Review; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 95
#16 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Controlled Clinical Trial; Guideline; Practice Guideline; Meta-Analysis; Multicenter Study; Randomized Controlled Trial; Publication date from 2004/01/01; English; Preschool Child: 2–5 years; Infant: birth-23 months | 55
#23 | Search ”Epidemiologic Studies”[Mesh] Filters: Publication date from 2004/01/01; English; Preschool Child: 2–5 years; Infant: birth-23 months | 92332
#24 | Search (#16 AND #23) Filters: Publication date from 2004/01/01; English; Preschool Child: 2–5 years; Infant: birth-23 months | 24
| SCREENING
#25 | Search ((“Psychological Tests”[Mesh]) OR “Diagnostic Techniques and Procedures”[Mesh]) OR “Mass Screening”[Mesh] Filters: Publication date from 2004/01/01; English; Preschool Child: 2–5 years; Infant: birth-23 months | 106030
#26 | Search (#1 AND #25) Filters: Publication date from 2004/01/01; English; Preschool Child: 2–5 years; Infant: birth-23 months | 797
#27 | Search (#1 AND #25) Filters: Review; Publication date from 2004/01/01; English; Preschool Child: 2–5 years; Infant: birth-23 months | 34
#28 | Search (#1 AND #25) Filters: Review; Publication date from 2004/01/01; English; Infant: birth-23 months | 18
#30 | Search (#1 AND #25) Filters: Review; Publication date from 2004/01/01; English; Preschool Child: 2–5 years | 31
#32 | Search ”Risk”[Mesh] Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 37645
#33 | Search (#5 AND #32) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 165
#34 | Search ((((“Primary Health Care”[Mesh]) OR “Physicians, Family”[Mesh]) OR “Pediatrics”[Mesh] OR primary care OR family physicians OR pediatrician) OR “Child Health Services”[Mesh]) OR “Preventive Health Services”[Mesh]Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 29572
#35 | Search (#5 AND #34) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 206
#39 | Search ((“Sensitivity and Specificity”[Mesh]) OR “Diagnostic Errors”[Mesh]) OR “Diagnosis, Differential”[Mesh] Filters: English; Infant: birth-23 months; Preschool Child: 2–5 years | 55512
#40 | Search (#5 AND #39) Filters: English; Infant: birth-23 months; Preschool Child: 2–5 years | 180
| ADVERSE EFFECTS
#45 | Search ”Communication Disorders”[Mesh] Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 2828
#50 | Search (((((“Diagnostic Errors”[Mesh]) OR “Stress, Physiological”[Mesh]) OR “Life Change Events”[Mesh]) OR “Prejudice”[Mesh]) OR “Stereotyping”[Mesh]) OR “Self Concept”[Mesh] OR adverse effect OR harm OR stigma | 529148
#55 | Search (#45 AND #50) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 115
#56 | Search (#45 AND #50) Filters: Review; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 8
#62 | Search (#45 AND #50) Filters: Controlled Clinical Trial; Meta-Analysis; Multicenter Study; Randomized Controlled Trial; Guideline; Practice Guideline; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 5
#63 | Search (#56 OR #62) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 12
#65 | Search (#23 AND #51) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 41
| INTERVENTIONS/OUTCOMES
#68 | Search (“Communication Disorders/drug therapy”[Mesh] OR “Communication Disorders/nursing”[Mesh] OR “Communication Disorders/prevention and control”[Mesh] OR “Communication Disorders/rehabilitation”[Mesh] OR “Communication Disorders/surgery”[Mesh] OR “Communication Disorders/therapy”[Mesh]) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 718
#69 | Search ((((((((“Cost of Illness”[Mesh]) OR “Quality of Life”[Mesh]) OR “Employment”[Mesh]) OR “Psychology, Industrial”[Mesh]) OR “Family Relations”[Mesh]) OR “Family”[Mesh]) OR “Interpersonal Relations”[Mesh]) OR (“Educational Status”[Mesh] OR “Educational Measurement”[Mesh])) OR “Motivation”[Mesh] Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 29636
#70 | Search (#68 AND #69) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 207
#71 | Search (((“Outcome and Process Assessment (Health Care)”[Mesh]) OR “Comparative Study” [Publication Type]) OR (“Evaluation Studies” [Publication Type] OR “Evaluation Studies as Topic”[Mesh])) OR “Epidemiologic Studies”[Mesh] Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 132829
#72 | Search (#68 AND #71) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 399
#79 | Search (#70 OR #72) Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Multicenter Study; Practice Guideline; Randomized Controlled Trial; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 99
#85 | Search (#70 OR #72) Filters: Review; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 43
| COSTS
#86 | Search ((“Costs and Cost Analysis”[Mesh] OR “Economics”[Mesh])) Filters:Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 6647
#98 | Search (#69 OR #86) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 34506
#99 | Search (#68 AND #98) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 215
#105 | Search (#68 AND #98) Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Multicenter Study; Practice Guideline; Randomized Controlled Trial; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 35
#106 | Search (#68 AND #98) Filters: Review; Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 24
#107 | Search (#99 AND #23) Filters: Publication date from 2004/01/01; English; Infant: birth-23 months; Preschool Child: 2–5 years | 69

Total Unduplicated PubMed = 740

Cochrane = 6 = 6 new

PsycInfo = 182 = 173 new

CINAHL = 142 = 136 new

Instruments = 147 = 137 new

Total Unduplicated Database = 1074

## Search – July 20, 2013

| Search String | Results
#1 | Search ((((((Ages and Stages Questionnaire[Title/Abstract])) OR Battelle Developmental Inventory Screening Test[Title/Abstract]) OR Clinical Adaptive Test[Title/Abstract]) OR (Clinical Linguistic and Auditory Milestone Scale[Title/Abstract])) OR Denver Developmental Screening Test[Title/Abstract]) OR Early Language Milestone Scale[Title/Abstract] | 314
#2 | Search ((((((Ages and Stages Questionnaire[Title/Abstract])) OR Battelle Developmental Inventory Screening Test[Title/Abstract]) OR Clinical Adaptive Test[Title/Abstract]) OR (Clinical Linguistic and Auditory Milestone Scale[Title/Abstract])) OR Denver Developmental Screening Test[Title/Abstract]) OR Early Language Milestone Scale[Title/Abstract] Filters: Publication date from 2013/03/01 | 11
#3 | Search ((((((Ages and Stages Questionnaire[Title/Abstract])) OR Battelle Developmental Inventory Screening Test[Title/Abstract]) OR Clinical Adaptive Test[Title/Abstract]) OR (Clinical Linguistic and Auditory Milestone Scale[Title/Abstract])) OR Denver Developmental Screening Test[Title/Abstract]) OR Early Language Milestone Scale[Title/Abstract] Filters: Publication date from 2013/04/01 | 10
#4 | Search ((((Fluharty Preschool Speech[Title/Abstract]) OR Infant-Toddler Checklist[Title/Abstract]) OR Language Development Survey[Title/Abstract]) OR McArthur-Bates Communicative Development Inventory[Title/Abstract]) OR WILSTAAR[Title/Abstract] Filters: Publication date from 2013/04/01 | 4
#5 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01 | 10
#6 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01; Infant: 1–23 months | 2
#7 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 3
#8 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 1
#9 | Search ((“Psychological Tests”[Mesh]) OR “Diagnostic Techniques and Procedures”[Mesh]) OR “Mass Screening”[Mesh] Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 227
#10 | Search (#7 AND #9) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 2
#11 | Search ”Risk”[Mesh] Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 116
#12 | Search (#7 AND #11) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#13 | Search (#7 AND #11) Schema: all Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#14 | Search ((((“Primary Health Care”[Mesh]) OR “Physicians, Family”[Mesh]) OR “Pediatrics”[Mesh] OR primary care OR family physicians OR pediatrician) OR “Child Health Services”[Mesh]) OR “Preventive Health Services”[Mesh] Filters:Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 87
#15 | Search (#7 AND #14) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#16 | Search (#7 AND #14) Schema: all Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#17 | Search ((“Sensitivity and Specificity”[Mesh]) OR “Diagnostic Errors”[Mesh]) OR “Diagnosis, Differential”[Mesh] Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 46
#18 | Search (#7 AND #17) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#19 | Search (#7 AND #17) Schema: all Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#20 | Search ”Communication Disorders”[Mesh] Filters: Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 7
#21 | Search ”Communication Disorders”[Mesh] Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 1
#22 | Search (“Communication Disorders/drug therapy”[Mesh] OR “Communication Disorders/nursing”[Mesh] OR “Communication Disorders/prevention and control”[Mesh] OR “Communication Disorders/rehabilitation”[Mesh] OR “Communication Disorders/surgery”[Mesh] OR “Communication Disorders/therapy”[Mesh]) Filters:Publication date from 2013/04/01; Infant: 1–23 months; Preschool Child: 2–5 years | 3
#23 | Search (“Communication Disorders/drug therapy”[Mesh] OR “Communication Disorders/nursing”[Mesh] OR “Communication Disorders/prevention and control”[Mesh] OR “Communication Disorders/rehabilitation”[Mesh] OR “Communication Disorders/surgery”[Mesh] OR “Communication Disorders/therapy”[Mesh]) Filters:Publication date from 2013/04/01; English; Infant: 1–23 months; Preschool Child: 2–5 years | 3
#24 | Search ((“Costs and Cost Analysis”[Mesh] OR “Economics”[Mesh])) Filters:Publication date from 2013/04/01; English; Infant: 1–23 months; Preschool Child: 2–5 years | 19
#25 | Search (#23 AND #24) Filters: Publication date from 2013/04/01; English; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#26 | Search (#23 AND #24) Schema: all Filters: Publication date from 2013/04/01; English; Infant: 1–23 months; Preschool Child: 2–5 years | 0

PubMed Total Citations = 19 = 11 new

Cochrane = 0

PsycInfo = 10 = 4 new

CINAHL = 11 = 1 new

Instruments = 9

Total NEW Database = 14

Instruments that were searched by name across databases:

- Ages and Stages Questionnaire—3rd Edition,
- Battelle Developmental Inventory Screening Test—2nd edition,
- Clinical Adaptive Test/Clinical Linguistic and Auditory Milestone Scale,
- Denver Developmental Screening Test II,
- Early Language Milestone Scale,
- Fluharty Preschool Speech and Language Screening Test,
- Infant-Toddler Checklist,
- The Language Development Survey,
- McArthur-Bates Communicative Development Inventory, and
- Ward Infant Language Screening Test, Assessment, Acceleration, and Remediation (WILSTAAR).

## Search – July 2014

| Search String | Results
#1 | Search ((((((Ages and Stages Questionnaire[Title/Abstract])) OR Battelle Developmental Inventory Screening Test[Title/Abstract]) OR Clinical Adaptive Test[Title/Abstract]) OR (Clinical Linguistic and Auditory Milestone Scale[Title/Abstract])) OR Denver Developmental Screening Test[Title/Abstract]) OR Early Language Milestone Scale[Title/Abstract] | 345
#2 | Search (((((Fluharty Preschool Speech[Title/Abstract]) OR Infant-Toddler Checklist[Title/Abstract]) OR Language Development Survey[Title/Abstract]) OR McArthur-Bates Communicative Development Inventory[Title/Abstract]) OR WILSTAAR[Title/Abstract] | 53
#3 | Search (#1 OR #2) | 398
#4 | Search (#1 OR #2) Filters: Publication date from 2013/04/01 | 53
#5 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01 | 421
#6 | Search (“Communication Disorders/classification” [Mesh] OR “Communication Disorders/diagnosis”[Mesh]) | 16177
#7 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01; Infant: 1–23 months | 35
#8 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month | 39
#9 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months | 39
#10 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 102
#12 | Search ((“Psychological Tests”[Mesh]) OR “Diagnostic Techniques and Procedures”[Mesh]) OR “Mass Screening”[Mesh] | 5667363
#13 | Search (#10 AND #12) Filters: Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 64
#14 | Search (#10 AND #12) | 64
#15 | Search (“Communication Disorders/classification”[Mesh] OR “Communication Disorders/diagnosis”[Mesh]) Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 9
#16 | Search “Risk”[Mesh] Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 375
#17 | Search “Risk”[Mesh] | 820783
#18 | Search (#10 AND #17) Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 1
#19 | Search (#10 AND #17) | 16
#20 | Search ((((“Primary Health Care”[Mesh]) OR “Physicians, Family”[Mesh]) OR “Pediatrics”[Mesh] OR primary care OR family physicians OR pediatrician) OR “Child Health Services”[Mesh]) OR “Preventive Health Services”[Mesh] Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 419
#21 | Search ((((“Primary Health Care”[Mesh]) OR “Physicians, Family”[Mesh]) OR “Pediatrics”[Mesh] OR primary care OR family physicians OR pediatrician) OR “Child Health Services”[Mesh]) OR “Preventive Health Services”[Mesh] | 703870
#22 | Search (#10 AND #21) Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 0
#23 | Search (#10 AND #21) Schema: all Filters: Review; Publication date from 2013/04/01; Infant: 1–23 months; Newborn: birth-1 month; Infant: birth-23 months; Preschool Child: 2–5 years | 0
#24 | Search (#10 AND #21) | 14
#25 | Search (((“Sensitivity and Specificity”[Mesh]) OR “Diagnostic Errors”[Mesh]) OR “Diagnosis, Differential”[Mesh]) | 837185
#26 | Search (#10 AND #25) | 23
#27 | Search “Communication Disorders”[Mesh] | 52319
#28 | Search “Communication Disorders”[Mesh] Filters: Newborn: birth-1 month | 1383
#29 | Search “Communication Disorders”[Mesh] Filters: Newborn: birth-1 month; Infant: birth-23 months | 3861
#30 | Search “Communication Disorders”[Mesh] Filters: Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months | 3861
#31 | Search “Communication Disorders”[Mesh] Filters: Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 10964
#32 | Search “Communication Disorders”[Mesh] Filters: Publication date from 2013/04/01; Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 263
#33 | Search “Communication Disorders”[Mesh] Filters: Review; Publication date from 2013/04/01; Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 18
#35 | Search (“Communication Disorders/drug therapy”[Mesh] OR “Communication Disorders/nursing”[Mesh] OR “Communication Disorders/prevention and control”[Mesh] OR “Communication Disorders/rehabilitation”[Mesh] OR “Communication Disorders/surgery”[Mesh] OR “Communication Disorders/therapy”[Mesh]) | 13469
#36 | Search ((“Costs and Cost Analysis”[Mesh] OR “Economics”[Mesh])) Filters:Review; Publication date from 2013/04/01; Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 54
#37 | Search ((“Costs and Cost Analysis”[Mesh] OR “Economics”[Mesh])) | 487743
#38 | Search ((“Costs and Cost Analysis”[Mesh] OR “Economics”[Mesh])) Filters:Publication date from 2013/04/01; Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 773
#39 | Search (#35 AND #38) Filters: Publication date from 2013/04/01; Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#40 | Search (#35 AND #38) Schema: all Filters: Publication date from 2013/04/01; Newborn: birth-1 month; Infant: birth-23 months; Infant: 1–23 months; Preschool Child: 2–5 years | 0
#41 | Search (#35 AND #38) | 0

PubMed Total Citations = 147 = 135 New

Cochrane = 1

PsycInfo = 29= 23

CINAHL = 59 = 20 New

Instruments = 54 = 11 New

Total NEW Database = 190

Instruments that were searched by name across databases:

- Ages and Stages Questionnaire—3rd Edition,
- Battelle Developmental Inventory Screening Test—2nd edition,
- Clinical Adaptive Test/Clinical Linguistic and Auditory Milestone Scale,
- Denver Developmental Screening Test II,
- Early Language Milestone Scale,
- Fluharty Preschool Speech and Language Screening Test,
- Infant-Toddler Checklist,
- The Language Development Survey,
- McArthur-Bates Communicative Development Inventory, and
- Ward Infant Language Screening Test, Assessment, Acceleration, and Remediation (WILSTAAR).

## Grey Literature Searches

### 4/30/2013 ClinicalTrials.Gov

(communication OR language) AND (therapy OR development) | “communication disorders” | Child (76 records)

Communicative development inventory = 32

- Ages and Stages Questionnaire—3rd Edition = 0
- Battelle Developmental Inventory Screening Test—2nd edition = 0
- Clinical Adaptive Test/Clinical Linguistic and Auditory Milestone Scale = 0
- Denver Developmental Screening Test II = 3
- Early Language Milestone Scale = 0
- Fluharty Preschool Speech and Language Screening Test = 0
- Infant-Toddler Checklist = 0
- The Language Development Survey = 1
- McArthur-Bates Communicative Development Inventory = 0
- Ward Infant Language Screening Test, Assessment, Acceleration, and Remediation (WILSTAAR) = 0

### 7/20/2014 Clinical Trials.gov

(communication OR language) AND (therapy OR development) | “communication disorders” | Child (34 records)

Communicative development inventory = 10

- Ages and Stages Questionnaire—3rd Edition = 0
- Battelle Developmental Inventory Screening Test—2nd edition = 0
- Clinical Adaptive Test/Clinical Linguistic and Auditory Milestone Scale = 0
- Denver Developmental Screening Test II = 0
- Early Language Milestone Scale = 0
- Fluharty Preschool Speech and Language Screening Test = 0
- Infant-Toddler Checklist = 0
- The Language Development Survey = 0
- McArthur-Bates Communicative Development Inventory = 0
- Ward Infant Language Screening Test, Assessment, Acceleration, and Remediation (WILSTAAR) = 0

Appendix A Table 1 Inclusion/Exclusion Criteria

| Included | Excluded
Populations | KQs 1–4: Children age 5 years or younger who are representative of a population seen in a primary care setting KQs 5–7: Children age 6 years or younger who are representative of a population seen in a primary care or similar setting identified with speech or language delay or disorder. Treatment studies must focus on treatment of children who were screened and/or diagnosed according to the specified age criteria. | - Screening for or treatment of children with comorbid developmental disorder (e.g., hearing impairment, developmental or neurological/neurogenetic impairment) identified prior to speech and language diagnostic procedure
Interventions: Screening | All instruments and procedures that are applicable for use in children age 5 years or younger:; - ≤10 minutes to administer by a primary care provider or to be interpreted in a primary care setting; - >10 minutes if completed by a parent or trained examiner and interpreted by the clinician; - Instruments specifically for speech and language; - General developmental instruments with a separate component for speech and/or language skills | - Instruments not designed for use in children age 5 years or younger; - Tools that take >10 minutes to administer by a primary care provider; - Tools that require a professional to administer, score, or interpret; - General developmental screening instruments that do not have a separate component for speech and/or language skills
Interventions: Treatment | - All therapeutic interventions designed to improve speech or language in children delivered at any age, as long as diagnosis occurs when child is age 6 years or younger.; ○ Therapists may be speech-language pathologists or other clinicians, parents, or teachers; - Therapeutic settings include group and individual sessions offered in a clinical locale, school, or home | Therapeutic interventions delivered to children who are diagnosed after age 6 years
Comparisons | KQs 1, 3: Screened vs. unscreened KQ 2: Different subpopulations (e.g., by age, risk factors) KQ 4: Screening vs. surveillance; surveillance vs. no activity KQs 5–7: Intervention vs. no intervention | - Single group design with no comparator (KQs 1, 3, 5–7); - Treatment or screening comparisons