# Acknowledgements

This systematic evidence review was prepared for the Agency for Healthcare Research and Quality (contract #290-97-0018, task order no. 2) to be used by the U.S. Preventive Services Task Force. Task Force members Janet Allen, PhD, RN, and Steven Teutsch, MD, MPH, served as liaisons. Oregon Health & Science University, Evidence-based Practice Center staff who contributed to this project included Peggy Nygren, MA, research associate, and Patty Davies, MA, librarian.