# References

1 Nelson HD, Helfand M. Screening for Postmenopausal Osteoporosis. Systematic Evidence Review. Rockville, MD: Agency for Heathcare Research and Quality; 2001 (forthcoming).
2 Kanis JA. Assessment of fracture risk and its application to screening for postmenopausal osteoporosis: synopsis of a WHO report. Osteoporos Int. 1994;4:368-381. [pmid: 7696835].
3 Looker AC, Orwoll ES, Johnston CC Jr,, et al. Prevalence of low femoral bone density in older US adults from NHANES III. J Bone Miner Res. 1997;12:1761-1768. [pmid: 9383679].
4 Looker AC, Wahner HW, Dunn WL, et al. Updated data on proximal femur bone mineral levels of US adults. Osteoporos Int. 1998;8:468-489. [pmid: 9850356].
5 Melton LJ. How many women have osteoporosis now?. J Bone Miner Res. 1995;10:175-177. [pmid: 7754796].
6 National Osteoporosis Foundation. Osteoporosis: Review of the evidence for prevention, diagnosis, and treatment and cost-effectiveness analysis. Osteoporos Int. 1998;Suppl 4:S7-S88.
7 Heaney RP. Bone mass, bone loss, and osteoporosis prophylaxis. Ann Intern Med. 1998;128:313-314. [pmid: 9471936].
8 Farmer ME, White LR, Brody JA, Bailey KR. Race and sex differences in hip fracture incidence. Am J Public Health. 1984;74:1374-1380. [pmid: 6507690]. [pmcid: 1652702].
9 Melton LJ, Amadio PC, Crowson CS, O'Fallon WM. Long-term trends in the incidence of distal forearm fractures. Osteoporos Int. 1998;8:341-348. [pmid: 10024904].
10 Melton LJ III, Kan SH, Frye MA, Wahner HW, O'Fallon WM, Riggs BL. Epidemiology of vertebral fractures in women. Am J Epidemiol. 1989;129:1000-1011. [pmid: 2784934].
11 Khovidhunkit W, Shoback DM. Clinical effects of raloxifene hydrochloride in women. Ann Intern Med. 1999;130:431-439. [pmid: 10068418].
12 Tugwell P, Wells G, Shea B, et al. Hormone replacement therapy for osteoporosis in postmenopausal women (Protocol for Cochrane Review). In: The Cochrane Library: Oxford: Update Software; 2000:125.
13 Torgerson D, Bell-Syer S. Hormone replacement therapy and prevention of nonvertebral fractures: A meta-analysis of randomized trials. JAMA. 2001;285:2891-2897. [pmid: 11401611].
14 Slavin R. Best practice synthesis: An alternative to meta-analytic and traditional reviews. Educ Res. 1986;15:5-11.
15 Keating NL, Cleary PD, Rossi AS, Zaslavsky AM, Ayanian JZ. Use of hormone replacement therapy by postmenopausal women in the United States. Ann Intern Med. 1999;130:545-553. [pmid: 10189323].
16 Matthews KA, Kuller LH, Wing RR, Meilahn EN, Plantinga P. Prior to use of estrogen replacement therapy, are users healthier than nonusers?. Am J Epidemiol. 1996;143:971-978. [pmid: 8629615].
17 Folsom AR, Mink PJ, Sellers TA, Hong CP, Zheng W, Potter JD. Hormonal replacement therapy and morbidity and mortality in a prospective study of postmenopausal women. Am J Public Health. 1995;85:1128-1132. [pmid: 7625511]. [pmcid: 1615815].
18 Derby CA, Hume AL, Barbour MM, McPhillips JB, Lasater TM, Carleton RA. Correlates of postmenopausal estrogen use and trends through the 1980s in two southeastern New England communities. Am J Epidemiol. 1993;137:1125-1135. [pmid: 8317442].
19 Barrett-Connor E. Postmenopausal estrogen and prevention bias. Ann Intern Med. 1991;115:455-456. [pmid: 1872493].
20 Cauley JA, Seeley DG, Browner WS, et al. Estrogen replacement therapy and mortality among older women. The Study of Osteoporotic Fractures. Arch Intern Med. 1997;157:2181-2187. [pmid: 9342994].
21 Grodstein F, Stampfer MJ, Colditz GA, et al. Postmenopausal hormone therapy and mortality. N Engl J Med. 1997;336:1769-1775. [pmid: 9187066].
22 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(suppl 3):21-35. [pmid: 11306229].
23 Wells B, Shea P, Tugwell J, Peterson V, Welch A, Cranney A. Cochrane systematic review data presented at the NIH Consensus Development Conference on Osteoporosis. Bethesda, MD: National Institutes of Health; 2000.
24 Recker RR, Davies KM, Dowd RM, Heaney RP. The effect of low-dose continuous estrogen and progesterone therapy with calcium and vitamin D on bone in elderly women. A randomized, controlled trial. Ann Intern Med. 1999;130:897-904. [pmid: 10375338].
25 The Writing Group for the PEPI trial. Effects of hormone therapy on bone mineral density: results from the postmenopausal estrogen/progestin interventions (PEPI) trial. JAMA. 1996;276:1389-1396. [pmid: 8892713].
26 Ravn P, Bidstrup M, Wasnich RD, et al. Alendronate and estrogen-progestin in the long-term prevention of bone loss: four-year results from the early postmenopausal intervention cohort study. A randomized, controlled trial. Ann Intern Med. 1999;131:935-942. [pmid: 10610644].
27 Lufkin EG, Wahner HW, O'Fallon WM, et al. Treatment of postmenopausal osteoporosis with transdermal estrogen. Ann Intern Med. 1992;117:1-9. [pmid: 1534476].
28 Wimalawansa SJ. A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med. 1998;104:219-226. [pmid: 9552083].
29 Komulainen MH, Kroger H, Tuppurainen MT, et al. HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women; a 5 year randomized trial. Maturitas. 1998;31:45-54. [pmid: 10091204].
30 Mosekilde L, Beck-Nielsen H, Sorensen OH, et al. Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women—results of the Danish Osteoporosis Prevention Study. Maturitas. 2000;36:181-193. [pmid: 11063900].
31 Cauley J, Black D, Barrett-Connor E, et al. Effects of hormone replacement therapy on clinical fractures and height loss: the Heart and Estrogen/progestin Replacement Study (HERS). Am J Med. 2001;110:442-450. [pmid: 11331055].
32 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998;280:605-613. [pmid: 9718051].
33 Cooper C, Melton L. Vertebral fractures: How large is the silent epidemic. BMJ. 1992;304:793-794. [pmid: 1392705]. [pmcid: 1881670].
34 Kiel DP, Felson DT, Anderson JJ, Wilson PW, Moskowitz MA. Hip fracture and the use of estrogens in postmenopausal women. The Framingham Study. N Engl J Med. 1987;317:1169-1174. [pmid: 3657888].
35 Naessen T, Persson I, Adami HO, Bergstrom R, Bergkvist L. Hormone replacement therapy and the risk for first hip fracture. A prospective, population-based cohort study. Ann Intern Med. 1990;113:95-103. [pmid: 2360759].
36 Grodstein F, Stampfer MJ, Falkeborn M, Naessen T, Persson I. Postmenopausal hormone therapy and risk of cardiovascular disease and hip fracture in a cohort of Swedish women. Epidemiology. 1999;10:476-480. [pmid: 10468418].
37 Maxim P, Ettinger B, Spitalny GM. Fracture protection provided by long-term estrogen treatment. Osteoporos Int. 1995;5:23-29. [pmid: 7703620].
38 Cauley JA, Seeley DG, Ensrud K, Ettinger B, Black D, Cummings SR. Estrogen replacement therapy and fractures in older women. Study of Osteoporotic Fractures Research Group. Ann Intern Med. 1995;122:9-16. [pmid: 7985914].
39 Hoidrup S, Gronbaek M, Gottschau A, Lauritzen JB, Schroll M. Alcohol intake, beverage preference, and risk of hip fracture in men and women. Copenhagen Centre for Prospective Population Studies. Am J Epidemiol. 1999;149:993-1001. [pmid: 10355374].
40 Nelson H, Harris E, Cauley J, et al. Osteoporosis and fractures are common in older postmenopausal women using estrogen (abstract). Bone. 1998;23:56.
41 Lufkin EG, Whitaker MD, Nickelsen T, et al. Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res. 1998;13:1747-1754. [pmid: 9797484].
42 Meunier PJ, Vignot E, Garnero P, et al. Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group [published erratum appears in Osteoporos Int. 1999;10(5):433]Osteoporos Int. 1999; 10:330–336.
43 Ettinger B, Black DM, Mitlak BH, et al. Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA. 1999;282:637-645. [pmid: 10517716].
44 Prestwood KM, Gunness M, Muchmore DB, Lu Y, Wong M, Raisz LG. A comparison of the effects of raloxifene and estrogen on bone in postmenopausal women. J Clin Endocrinol Metab. 2000;85:2197-2202. [pmid: 10852452].
45 Delmas PD. Hormone replacement therapy in the prevention and treatment of osteoporosis. Osteoporos Int. 1997;7:S3-7. [pmid: 9205638].
46 Grey AB, Stapleton JP, Evans MC, Tatnell MA, Ames RW, Reid IR. The effect of the antiestrogen tamoxifen on bone mineral density in normal late postmenopausal women. Am J Med. 1995;99:636-641. [pmid: 7503087].
47 Powles TJ, Hickish T, Kanis JA, Tidy A, Ashley S. Effect of tamoxifen on bone mineral density measured by dual-energy x-ray absorptiometry in healthy premenopausal and postmenopausal women. J Clin Oncol. 1996;14:78-84. [pmid: 8558225].
48 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90:1371-1388. [pmid: 9747868].