# Discussion

## Conclusions

Table 7 summarizes the type and quality of evidence for each of the 4 key questions. For bone density outcomes, randomized controlled trials consistently indicated improved bone density with estrogen use. These findings were similar between prevention and treatment trials, opposed and unopposed regimens, oral and transdermal forms of estrogen, and types of progestins. Most studies support a dose-response effect, and higher doses of estrogen and longer duration of use tend to be associated with greater benefit on bone density. This is not true with all studies, however, and significant bone density effects have been demonstrated with lower doses of estrogen. Estrogen appears to have a stronger effect on bone density than raloxifene, and the effect of tamoxifen is much weaker than either.

Table 7. Summary of Evidence

Key Questions | Evidence Codes* | Quality of Evidence**
Arrow 1
Does HRT improve or stabilize bone density? | I | Good: many good-quality RCTs of HRT and bone density are consistent and demonstrate benefit; limited by short duration of trials, BMD is an intermediate outcome.
Does postmenopausal use of SERMs improve or stabilize bone density? | I | Few trials available but are good-quality; larger studies with at least 2-year follow-up indicate benefit; limited by short duration and small numbers of trials; BMD is an intermediate outcome.
Arrow 2
Does HRT prevent fractures? | I, II-2 | RCTs: only 5 studies available that are limited methodologically; lack of hip fracture outcomes.
| | Cohort studies: Good: several good-quality cohort studies are consistent and demonstrate benefit; limited by healthy user bias.
Does postmenopausal use of SERMS prevent fractures? | I | One large good-quality RCT demonstrates benefit for vertebral fractures, one small RCT shows no benefit; limited by short duration of trials and small numbers of trials. No studies yet address hip fracture outcomes.

* Study Design Categories

I: Randomized, controlled trials

II-1: Controlled trials without randomization

II-2: Cohort or case-control analytic studies

II-3: Multiple time series, dramatic uncontrolled experiments

III: Opinions of respected authorities, descriptive epidemiology

** Quality of evidence ratings based on criteria developed by the U.S. Preventive Services Task Force (Harris, 2001) ^22^

For fracture outcomes, 5 randomized controlled trials ^27–31^ of estrogen were identified and none met criteria to be ranked as a good-quality study. A primary prevention trial indicated a significant decrease in risk of nonvertebral fractures in 1 of 2 estrogen arms. ^29^ None of the other trials indicated a significant risk reduction with estrogen, but all had important methodologic limitations. A recent meta-analysis of 22 trials of estrogen, many with unpublished data, reported an overall 27% reduction in nonvertebral fractures (RR, 0.73; 95% CI, 0.56–0.94). ^13^ Six good-quality cohort studies ^34–39^ were identified, and 3 of 4 studies reported 20% to 35% reductions in adjusted relative risks for hip fractures among ever users. ^34–36^

In randomized controlled trials, raloxifene increased bone density at lumbar spine, hip, and wrist sites, and tamoxifen modestly increased bone density at the hip and spine, although results were inconsistent between studies. The largest trial of raloxifene reported a protective effect for vertebral fractures (RR, 0.59; 95% CI, 0.05–0.70), but not for nonvertebral fractures. ^43^ A large trial of tamoxifen indicated no statistically significant fracture benefit. ^48^

## Limitations of the Literature

Although randomized controlled trials are available for all of the key questions, they are limited in important ways. Except for trials of estrogen and bone density, there are very few trials available upon which to make treatment decisions, and the results are sometimes conflicting. This is particularly true for studies of estrogen and fracture outcomes. Fracture benefits would be expected from randomized controlled trials based on results reported in the cohort studies supporting a 20% to 35% reduction in fractures, and on randomized controlled trials consistently demonstrating improved bone density at lumbar spine, hip, and wrist sites. Although an intermediate outcome, bone density is an important risk factor for fracture. Too few trials with fracture outcomes have been performed, however, and they have not been sufficiently large or long enough to measure a treatment effect. The largest trial ^31^ was designed as a secondary prevention trial for cardiac disease, did not monitor for asymptomatic incident vertebral fractures, and did not provide information on osteoporotic confounders to assure comparability of treatment groups.

The MORE study of raloxifene, however, provides good evidence of benefit for vertebral fractures. ^43^ It is possible that similar effects for estrogen could be detected if subjected to a study as large and comprehensive as the MORE trial. The tamoxifen trial did not measure vertebral fracture outcomes as precisely as the MORE trial, was designed as a breast cancer prevention study, and could have missed a potential effect. ^48^

## Future Research

Additional trials are needed to more accurately weigh the benefits and harms of HRT. Results of the Women's Health Initiative will add this type of information. As SERMs and other estrogen-like agents are developed, direct comparisons with estrogen in addition to placebo during trials will be important. Careful monitoring and reporting of adverse events would contribute additional knowledge of the consequences of HRT use.

Many gaps exist in current understanding of estrogen's effect on bone. It is not clear how age effects the impact of estrogen, and it would be valuable to know if it is as effective in an 80-year-old woman as in a 50-year-old woman. Similarly, understanding the optimal duration of effect would allow targeting of estrogen use to specific times of a woman's life. Despite the overall effect on increasing bone density described in treatment trials, some women do not experience this benefit. These women could be spared prolonged estrogen exposure if adequately identified. There is also little understanding of potential harms of long-term HRT on bone.