# Results

## Arrow 1: Does hormone replacement therapy improve or stabilize bone density?

Many randomized controlled trials have been published indicating that estrogen, alone or in combination with progestin, improves bone density or prevents bone density loss compared to placebo. An unpublished Cochrane systematic review reported combined results of 57 randomized controlled trials at the NIH Consensus Development Conference on Osteoporosis in 2000. ^23^ Eligible studies included randomized controlled trials enrolling postmenopausal women for more than one year in duration that compared HRT with placebo or calcium/vitamin D use. Studies were identified from MEDLINE (1966 to December 1998) and the Cochrane Library Controlled Clinical Trials Register. Additional methodology is described elsewhere. ^12^ The Cochrane systematic review and meta-analysis met USPSTF criteria for high quality (comprehensive sources, standard appraisal, valid conclusions, recent and relevant).

The trials reported in the Cochrane systematic review are summarized in Table 2 with results expressed as weighted mean differences, calculated by using percent change from baseline and standard deviations. Combining 18 two-year prevention studies of opposed and unopposed HRT regimens, the increase in bone density at the lumbar spine was 6.98% (95% CI, 5.53–8.43). The 8 studies measuring femoral neck bone density indicated an increase of 4.07% (95% CI, 3.30–4.84), and the 14 studies measuring forearm bone density indicated an increase of 4.53% (95% CI, 3.68–5.36).

Table 2. Combined Results of Randomized Controlled Trials of HRT with Bone Density Outcomes*

BMD Site | Types of studies | Number of studies | Weighted Mean Difference (95% CI)**
Lumbar spine (1-year) | Treatment and prevention opposed and unopposed | 25 | 5.39 (4.24–6.46)
Lumbar spine (2-years) | Treatment and prevention opposed and unopposed | 21 | 6.76 (5.63–7.89)
Femoral neck (1-year) | Treatment and prevention opposed and unopposed | 7 | 2.50 (1.16–3.83)
Femoral neck (2-years) | Treatment and prevention opposed and unopposed | 9 | 4.12 (3.45–4.80)
Lumbar spine | 2-year prevention opposed and unopposed | 18 | 6.98 (5.53–8.43)
Femoral neck | 2-year prevention opposed and unopposed | 8 | 4.07 (3.30–4.84)
Forearm | 2-year prevention opposed and unopposed | 14 | 4.53 (3.68–5.36)

* Data from a Cochrane systematic review presented at the NIH Consensus Development Conference on Osteoporosis, March 2000, 23

** Weighted mean difference is calculated by using percent change from baseline and standard deviations.

Note: CI indicates confidence interval

Results were similar when comparing prevention to treatment trials, opposed to unopposed HRT regimens, transdermal estrogen to oral estradiol and oral conjugated estrogen, and types of progestins. Results differed, however, with different doses and duration of estrogen use. Use of usual doses (eg 0.625 mg of conjugated estrogen) resulted in larger increases at lumbar, femoral neck, and forearm sites than use of lower doses (0.3 mg). Two-year trials resulted in larger increases than one-year trials. The effect of using calcium and vitamin D in these trials rather than true placebo was not separately analyzed. Also, the proportion of nonresponders in these trials was not reported.

A randomized controlled trial ^24^ published in 1999 and not included in the Cochrane review found that a continuous low-dose HRT regimen given over 3.5 years resulted in increased bone density of the spine (mean percent change, 3.23; 95% CI, 1.64–4.82), nonsignificant increased bone density of the femoral neck (mean percent change, 1.79; 95% CI, 0.56–2.98), and no increase or decrease at the radius (P<0.01 compared with placebo who lost bone density). These results, using conjugated equine estrogen (0.3 mg/day) and oral medroxyprogesterone (2.5 mg/day) combined with calcium and vitamin D, are similar to the results of the Postmenopausal Estrogen/Progestin Interventions (PEPI) trial ^25^ that used a higher dose of estrogen (0.625 mg/day), various progestin regimens, and no calcium and vitamin D supplementation. The patients in these studies differed however. Women in PEPI were younger (aged 45 to 64 years) than those enrolled in this trial (age over 65, mean age 73), and had a wide range of T-scores, while women in this trial had T-scores of -1.226 or lower. Among subjects in the PEPI trial, older women and women with low initial bone density gained the most bone density with HRT use.

Another randomized controlled trial ^26^ published in 1999 compared women aged 45 to 59 years, most not osteoporotic, who took alendronate, HRT, or placebo for 4-years. Two different doses of alendronate (5 mg/day and 2.5 mg/day) and 2 different forms of HRT (a cyclic regimen of 2 mg of estradiol with 1 mg/day of norethisterone and a continuous regimen of 0.625 mg of conjugated equine estrogen with 5.0 mg of medroxyprogesterone) were used. Bone density decreased at all skeletal sites in the placebo group and increased or stayed the same at all sites except the forearm for the alendronate groups with the larger dose, demonstrating more benefit. Both HRT regimens resulted in statistically significantly greater increases in bone density at the spine, similar increases at the hip, and was significantly more effective in maintaining bone mass at the forearm than treatment with 5 mg of alendronate per day. A 5 mg dose of alendronate represents the dose used for prevention, 10 mg is used for treatment.

### Summary

- Many randomized controlled trials have been conducted of HRT and bone density outcomes, and results consistently indicate improved bone density. These findings are similar between prevention and treatment trials, opposed and unopposed regimens, oral and transdermal forms of estrogen, and types of progestins.
- A meta-analysis of HRT randomized controlled trials indicated a better effect on bone density with usual compared to low dose regimens. However, a recent trial indicated similar results for a low dose regimen as previously reported for usual dose regimens, although patient populations differed between studies.
- A recent trial comparing bone density outcomes of HRT with alendronate found more benefit with HRT.

## Arrow 2: Does hormone replacement therapy prevent osteoporotic fractures?

### Randomized controlled trials

A recent meta-analysis of 22 trials of estrogen reported an overall 27% reduction in nonvertebral fractures (RR, 0.73; 95% CI, 0.56–0.94). ^13^ Although the meta-analysis met USPSTF criteria for a good-quality rating, several trials included in the meta-analysis did not meet inclusion criteria for our review because they used unpublished data, did not verify fractures radiographically, included traumatic fractures, or included women who were hospitalized or had secondary causes of osteoporosis. Five randomized controlled trials of estrogen with vertebral or nonvertebral fracture outcomes met our inclusion criteria (Table 3). ^27–31^

Table 3. Randomized Controlled Trials of HRT with Fracture Outcomes

Author/year | N | Duration (years) | Population | Drug/dose | Assessment of fracture | Relative risk (95% CI) for fractures | | Other | USPSTF Quality Rating*
| | | | | | Vertebral | Nonvertebral
Lufkin, 1992 ^27^ | 78 | 1 | Age 47 to 75 years with 1 or more vertebral fractures enrolled at the Mayo Clinic, Minnesota. | Cyclic transdermal patch with 0.1 mg estradiol / 10 mg oral medroxyprogesterone compared to placebo. | At least 1 of 3 measurements on lateral x-ray of spine was decreased by more than 15% compared with baseline. | 0.39 (0.16–0.95) | NA | Results are nonsignificant when expressing them as the number of patients experiencing new vertebral fractures (7 in HRT group, 12 placebo) rather than number of fractures per person-years. | Fair: 77% follow-up in HRT group, 82% placebo; inappropriate analysis.
Wimalawansa, 1998 ^28^ | 36 | 4 | Women with mean age 65 years attending metabolic bone disease outpatient clinics with established osteoporosis. | Cyclic premarin 0.625 mg/day with norgestrel 150 micorg/12 days each month compared with placebo; all subjects received calcium and vitamin D. | Reduction of 20% or more on 1 of 3 measurements with reduction of 15% or more in area in a previously unaffected vertebra on lateral x-ray of spine compared to baseline. | HRT: 33.3/1,000 patient-yrs; calcium/vitamin D: 89.3/1,000 patient-yrs; no difference between groups | NA | Two treatment arms (etidronate and etidronate/HRT) are not included in this table; 2 fractures in HRT group, 5 in calcium/vitamin D. | Poor: 83% follow-up in HRT group, 77% calcium/vitamin D; inappropriate analysis; under powered for fracture outcomes.
Komulainen, 1998 ^29^ | 464 | 4.3 | Early postmenopausal women without osteoporosis, a subgroup of the Kuopio Osteoporosis Study (n=13,100) based in Finland. | 1. Sequential estradiol (2 mg/day) / cyproiterone acetate (1 mg/day) | New, symptomatic radiographically defined nonvertebral fractures. | NA | HRT alone: 0.29 (0.10–0.90); HRT & vitamin D: 0.44 (0.17–1.15) | Relative risk adjusted for baseline bone density and prior fractures; numbers of fractures include: HRT 4, HRT/vitamin D 8, vitamin D 10, placebo 17. | Fair: 79% completed study; randomized open trial.
| | | | 2. Vitamin D (300 IU/day)
| | | | 3. HRT & vitamin D
| | | | 4. Placebo
Cauley, 2001 ^31^ | 2,763 | 4.1 | Heart and Estrogen/progestin Replacement Study (HERS), postmenopausal women with coronary disease under 80 years (mean 67 years) with an intact uterus, fractures were a secondary outcome. | Continuous combined regimen of 0.625 mg/day conjugated equine estrogen with 2.5 mg/day medroxyprogesterone or placebo. | New fractures were reviewed by coordinating center physicians blinded to treatment assignment. | NA | Any fracture: 0.95 (0.75–1.21); Hip fracture: 1.10 ((0.49–2.50) | 130 fractures in the HRT group (12 hip); 138 in placebo (11 hip). | Fair: fractures are secondary outcomes, inclusion criteria was based on cardiac risk, not known if treatment groups have comparably distributed osteoporosis risk factors; asymptomatic vertebral fractures not included.
Mosekilde, 2000 ^30^ | 1,006 | 5 | Postmenopausal Danish women ages 45 to 52 years recruited by mailed questionnaire. | Sequential estradiol (1–2 mg/day) with norethisterone acetate (1 mg/day for 10 days each month); continuous estradiol (2 mg/day) if hysterectomy; or nonuse. | Not well described. | 2.0 (0.62–6.49) | All: 0.82 (0.53–1.29); forearm: 0.40 (0.16–1.01); other: 0.96 (0.57–1.64) | | Poor

* See appendix 2 for quality criteria

Note: CI indicates confidence interval

Two trials ^27,^ ^28^ evaluated the effect of HRT on preventing vertebral fractures in women with pre-existing osteoporosis. A trial of 78 postmenopausal women age 47 to 75 years with one or more pre-existing vertebral fractures recorded incident vertebral fractures. ^27^ The treatment group was provided with a cyclic regimen of transdermal estrogen and progesterone for one year and was compared to an untreated placebo group. The estrogen group experienced 8 new vertebral fractures in 7 women, while the placebo group had 20 fractures in 12 women. Despite a lower vertebral fracture rate in the estrogen group (RR, 0.39; CI, 0.16–0.95), the number of women experiencing new vertebral fractures was not significantly different between groups. A smaller trial of 4 years duration comparing 18 women using a cyclic oral estrogen regimen to 18 women in a comparison group found no significant difference in vertebral fractures. ^28^

Three trials ^29–31^ reported nonvertebral fracture outcomes. A primary prevention trial enrolled a subgroup of a large prospective osteoporosis study based in Finland. ^29^ In this study, 464 early postmenopausal women without osteoporosis were randomly assigned to one of four groups: cyclic oral estradiol with progestin, vitamin D alone, estradiol with progestin and vitamin D, or placebo. New, symptomatic, radiographically confirmed nonvertebral fractures were recorded during a mean 4.3 years of follow-up. The risk for fracture was significantly lower for the estrogen/progestin alone group (RR, 0.29; 95% CI, 0.10–0.90), but not for the estrogen/progestin and vitamin D group, or the vitamin D alone group, compared to placebo when adjusted for baseline bone density and prior fractures. Another primary prevention trial ^30^ randomized 1,006 early postmenopausal women in Denmark to oral estradiol/norethisterone or placebo. After 5 years, the relative risk for all types of fractures was 0.82 (95% CI, 0.53–1.29), and for forearm fractures 0.40 (95% CI, 0.16–1.01). ^30^

The Heart and Estrogen/progestin Replacement Study (HERS) is a secondary prevention trial of the effects of estrogen on cardiovascular outcomes. ^32^ This study enrolled 2,763 postmenopausal women with pre-existing coronary disease under 80 years old (mean 66.7 years). A subgroup of women underwent bone densitometry, and 15% of them had osteoporosis. Fractures at various sites were secondary outcomes. The treatment group was given a continuous combined regimen of conjugated estrogen with medroxyprogesterone per day and compared with an equal-sized placebo group. After 4 years, this study found no difference between groups for all fractures combined, or hip, wrist, spine, or other types of fractures specifically. ^31^

These trials did not meet USPSTF criteria to be ranked as good-quality studies because they did not assemble or maintain comparable groups, ^30,^ ^31^ were not blinded, ^29,^ ^30^ were small, ^27–29^ or used inappropriate analyses. ^27,^ ^28^ The largest trial, HERS, did not monitor for asymptomatic incident vertebral fractures, potentially missing as many as 2 out of 3 of vertebral fractures that would be diagnosed solely by radiographic morphometric criteria. ^33^ Although asymptomatic fractures may not be as important to patients as symptomatic fractures, patients with nontraumatic vertebral fractures meet diagnostic criteria for osteoporosis and are usually identified as such in trials.

### Cohort studies

Several good-quality cohort studies that enrolled thousands of postmenopausal women and reported fracture outcomes have been published. These studies included more women, often recruited from community-based populations, and followed them for longer periods of time than the randomized controlled trials. In general, these studies determined estrogen use at baseline by interviewing subjects or reviewing prescription data. Use was usually defined as current, past, or ever use, and nonuse. However, type of HRT regimen including doses, concurrent use of progestins, and duration was not reported in all studies. Subjects were then followed over several years while investigators collected data on incident fractures. Fracture occurrence was determined by asking subjects directly or by reviewing hospital admission databases. In all studies included in this review, fractures were confirmed radiographically. Additional data was also collected, such as age, weight, history of previous fractures, and other known risk factors, in order to adjust for confounders and to examine subgroups. Most cohort studies adjusted for measurable confounders and reported adjusted results, although an important disadvantage of cohort studies is the inability to control for healthy user bias. Other studies have found that estrogen users are healthier and have healthier lifestyles ^19^ which may influence health outcomes.

Table 4 outlines 6 good-quality cohort studies ^34–39^ and the reported relative risks for hip fracture for each study based on ever or current use of estrogens. These studies include data from the Framingham Heart Study ^34^ ; pharmacy, questionnaire, and inpatient registry information from the Uppsala health care region in Sweden ^35,^ ^36^ ; pharmacy and chart records from Kaiser ^37^ ; the Study of Osteoporotic Fractures (SOF) ^38^ ; and the Copenhagen Center for Prospective Population Studies. ^39^ All studies, except the Kaiser study, include several thousand postmenopausal women. Follow-up times ranged from 4.5 years in SOF to up to 32 years in the Framingham study.

Table 4. Cohort Studies of HRT with Hip Fracture Outcomes

Author/year | Exposure | N | Duration | Population | Assessment of fracture | RR (95% CI) for fractures | | Other | USPSTF Quality Rating*
| | | | | | Hip | Other Fractures
Ever Use
Kiel, 1987 ^34^ | Ever user | 2,873 | Up to 32 years | Women in the Framingham Heart Study. | Hip fractures confirmed by hospital discharge summary, review of hospital admission diagnoses, subject interview, and/or routine contact during study asking about hospitalizations. | 0.63 (0.42–0.95) | | Results adjusted for age, weight, age at menopause, smoking, alcohol consumption; 28 fractures for users, 135 for non users; taking estrogen within 4 years of menopause also protected against fracture. | Good
Naessen, 1990 ^35^ | Ever user | 23,246 | 5.7 years | All women age 35 and older (mean age 53.7 years) who received noncontraceptive estrogens from 1977-80 compared to nonusers based on prescription data in the Uppsala health care region in Sweden. | Follow-up through 1983 for hospital admissions for first hip fracture. | 0.79 (0.68–0.93) | | Observed number of cases was compared with that expected based on incidence rates in the background population; type of estrogen, age at and period of the first recorded prescription, and follow-up period were included in multivariate model; for those taking more potent estrogens RR=0.37 (0.13–0.79). | Good
Maxim, 1995 ^37^ | Ever user for at least 5 years | 490 | Approx. 25 years | Retrospective review of computerized pharmacy records at Kaiser of postmenopausal women who began using estrogen between 1968-1971 and used it regularly for at least 5 years (n=245) compared with age matched nonusers. | Nontraumatic fractures based on x-ray reports and chart review. | 1.31 (0.55–3.12) | wrist 0.44 (0.23–0.84); vertebral 0.60 (0.36–0.99) | Results adjusted for age at menopause, body mass index, smoking. | Good
Grodstein, 1999 ^36^ | Ever user | 9,236 | 8 years | Women in the Uppsala health care region in Sweden who had received at least one prescription for postmenopausal hormones from 1977-1980 and responded to a mailed questionnaire about estrogen use in 1987-88 (response rate 66%). | National Swedish Inpatient Registry to confirm hip fractures. | 0.65 (0.45–0.95) | | Results adjusted for age; best results found for those using estrogen for 7 or more years. | Good: although few confounders considered
Current Use
Kiel, 1987 ^34^ | Current user | 2,873 | Up to 32 years | Women in the Framingham Heart Study. | Hip fractures confirmed by hospital discharge summary, review of hospital admission diagnoses, subject interview, and/or routine contact during study asking about hospitalizations. | 0.34 (0.11–1.09) | | Defined as use within 2 years; adjusted for age, weight, age at menopause, smoking, alcohol consumption; 3 fractures for users, 135 for nonusers. | Good
Cauley, 1995 ^38^ | Current user | 9,704 | 4.5 years | Women in the Study of Osteoporotic Fractures (community dwelling, ambulatory women age 65 and above, predominantly white); mean age at baseline 72 years. | Incident fractures validated by radiographic report. | 0.60 (0.36–1.02) | wrist: 0.39 (0.24–0.64); all nonvertebral: 0.66 (0.54–0.80) | Adjusted for multiple confounders (age, physical activity, calcium intake, body mass index, surgical menopause, health status, use of thiazide diuretics, poor cognition, alcohol intake, recent fall, use of sedatives or anxiolytics, smoking, thyroid supplements); estrogen use was most effective in preventing hip fracture for those over 75 years old and current users who started within 5 years of menopause, previous use had no effect; number of fractures for current users included 134 hip, 200 wrist, 824 total nonvertebral. | Good
Hoidrup, 1999 ^39^ | Current user | 6,159 | Approx. 7 years | Postmenopausal women from the Copenhagen Center for Prospective Population Studies, Denmark; mean age at baseline 55 for users, 60 for nonusers. | National Register of Hospital Discharges and review of hospital records for hip fracture. | 0.71 (0.50–1.01) | | Adjusted for multiple confounders (age, body mass index, physical activity, smoking, alcohol intake, cohabitation, marital status, school education, age at menopause, and parity); 326 hip fractures for nonusers, 37 for current users. | Good

Note: CI indicates confidence interval

* See appendix 2 for quality criteria; few studies reported loss to follow-up or cross-over.

Three of the 4 studies of ever users of HRT reported significantly reduced adjusted relative risks for hip fractures ranging from 0.63 to 0.79. ^34–36^ These studies also noted that those taking more potent forms of estrogen had even better risk reduction, ^35^ the best results were found among those using estrogen for 7 or more years, ^36^ and taking estrogen within 4 years of menopause was protective. ^34^ No studies reported effects of progestins specifically. The only study not reporting a reduced relative risk for hip fracture was much smaller in size than the others, and reported significantly reduced relative risks for wrist and vertebral fractures. ^37^ Hip fractures are less frequent outcomes than wrist or vertebral fractures in this relatively younger cohort.

The 3 studies of effects for current estrogen users, a subgroup of ever users, reported nonsignificant reduced relative risks for hip fracture. ^34,^ ^38,^ ^39^ Although data from the Copenhagen Center for Prospective Population Studies included over 6,000 women and followed them for 7 years, current users had a mean age of only 55 years at baseline and accrued only 37 fractures. Incident hip fracture rates for all user groups would be expected to rise as this cohort ages.

The Study of Osteoporotic Fractures is primarily designed to prospectively measure fracture outcomes in a cohort of 9,704 community-dwelling postmenopausal women residing in 4 areas of the U.S. Although the effect of HRT on hip fracture outcomes was not statistically significant after 4.5 years of follow-up, SOF reported significant risk reduction for wrist (RR, 0.39; 95% CI, 0.24–0.64) and all nonvertebral fractures (RR, 0.66; 95% CI, 0.54–0.80) after adjustment for several other variables. ^38^ Subgroup analyses within SOF also indicated that estrogen was most effective in preventing hip fractures for those over 75 years old, and for current users who started estrogen within 5 years of menopause. Previous use of estrogen, however, had no effect on fracture outcomes, implying a transient protective effect. Additional data from SOF expands the follow-up time to 10 years. These results indicate that current users have significantly reduced probabilities of hip, wrist, and nonvertebral fractures at 10 years compared to never users in age and weight adjusted models. ^40^

### Summary

- Only 5 randomized controlled trials report the effects of HRT on fracture outcomes, and they are methodologically limited.
- Good-quality cohort studies indicate 20% to 35% reduction in relative risks for hip fracture and reduced risks for other types of fractures. Subgroup analyses indicate that certain users may have additional benefits such as older women, long-term users, and those who initiate use at or near menopause.
- Cohort studies of estrogen users, even when well-designed and controlled for measurable confounders, are subject to healthy user bias making it difficult to determine if beneficial effects are due to HRT or bias.

## Arrow 1: Does postmenopausal use of SERMs improve or stabilize bone density?

Five randomized controlled trials ^41–45^ reporting the effect of raloxifene on bone density have been published (Table 5). Three studies were rated good ^41–43^ and 2 were rated fair. ^44,^ ^45^

Table 5. Randomized Controlled Trials of SERMs with Bone Density Outcomes

Author/year | N | Duration | Population | Drug/dose | Significant Increases in BMD (mean % from baseline)* | | | Other | USPSTF Quality Rating**
| | | | | Lumbar spine | Hip | Wrist
Raloxifene
Prestwood, 2000 ^44^ | 51 | 6 months | Postmenopausal women age 55 to 85 with low bone density in Connecticut. | Raloxifene 60 mg/day compared to conjugated equine estrogen (0.625 mg/day). | 1.3 | femoral neck 3.0; trochanter 4.0; Ward's triangle 5.0 | | Numbers estimated from graph; estrogen had a greater effect than raloxifene for lumbar spine. | Fair: estrogen group had more dropouts than raloxifene group (23% vs 4%); follow up shorter than other trials, significance of bone density changes after only 6 months questionable.
Lufkin, 1998 ^41^ | 143 | 1 year | Postmenopausal women age 45 to 75 (mean age 68 years) with at least 1 prevalent vertebral fracture and low BMD, recruited at the Mayo Clinic, Minnesota and Arizona. | Raloxifene 60 or 120 mg/day or placebo; all received calcuim and vitamin D. | NS | 1.7 (60 mg); NS (120 mg) | 2.9 (60 mg); 2.5 (120 mg) | 120 mg dose did not significantly increase bone density at the total hip. | Good: 9% dropped out of study.
Delmas, 1997 ^45^ | 601 | 2 years | Postmenopausal women age 45 to 60 (mean age 55 years) recruited from the community in Europe and UK with a range of BMD values. | Raloxifene 30, 60, or 150 mg/day or placebo; all received calcium. | 1.6 (60 mg) | total hip 1.6 (60 mg); femoral neck 1.2 (60 mg) | | All raloxifene doses resulted in significant increases; higher doses generally had more effect although this was not seen at the hip; placebo group lost bone at all sites and comparisons with placebo rather than baseline indicate greater effect; increases in bone density in the lumbar spine and hip were similar regardless of initial BMD. | Fair: 25% of subjects dropped out of the study although there were no differences among therapy groups with respect to the number who dropped out.
Meunier, 1999 ^42^ | 129 | 2 years | Postmenopausal women age 50 to 75 years (mean age 60 years) with low bone density, a third had prior nonvertebral fractures, recruited at 8 clinic sites in France. | Raloxifene 60 or 150 mg/day compared to placebo; all received calcium and vitamin D. | 3.3 (60 and 150 mg combined) | trochanter 3.0 (combined); femoral neck 2.1 (60 mg); total hip 1.6 (60 mg), 2.4 (150 mg) | | Mean % differences compared to placebo, pooled results for both doses unless indicated. | Good: 16% dropped out of study.
Ettinger, 1999 ^43^ | 7,705 | 3 years | Multiple Outcomes of Raloxifene Evaluation (MORE) study of women aged 31 to 80 years (mean 67 years) in 25 countries who had been postmenopausal for at least 2 years and met WHO criteria for osteoporosis. | Raloxifene 60 or 120 mg/day or placebo; all received calcium and vitamin D. | 2.6 (60 mg); 2.7 (120 mg) | femoral neck 2.1 (60 mg); 2.4 (120 mg) | | Bone density of hip peaked at 24 months, spinal density remained constant between 2 and 3 years; 24% of subjects had adverse effects regardless of treatment group. | Good: 18% of placebo, 17% of treatment groups dropped out at 2 years; 25% of placebo and 22% of treatment groups at 3 years.
Tamoxifen
Grey, 1995 ^46^ | 57 | 2 years | Postmenopausal women with mean age 58 to 60, not with low bone density or breast cancer, in New Zealand. | Tamoxifen 20 mg/day compared to placebo. | 1.4 | proximal femur NS | | Effect of tamoxifen was maximal after 1 year. | Poor: intention-to-treat analysis not used; 19% dropout rate.
Powles, 1996 ^47^ | 54 | 3 years | Postmenopausal women (mean agse 57 to 59) enrolled in a breast cancer prevention trial in the UK. | Tamoxifen 20 mg/day compared to placebo. | NS | hip 1.8 | | Expressed as mean annual %; numbers estimated from graph. | Poor: high dropout rates, 28% after 2 years, 48% after 3 years.

* Meunier, 1999 expressed this as mean % difference compared to placebo rather than baseline.

** See appendix 2 for quality criteria

Note: BMD indicates bone mass density; NS, not significant.

Note: BMD indicate bone mass density

The largest study, the Multiple Outcomes of Raloxifene Evaluation (MORE) study, included 7,705 postmenopausal women aged 31 to 80 years (mean age 67 years) and followed them for 3 years. ^43^ These women met WHO criteria for osteoporosis based on low bone density or presence of vertebral fractures. Two doses of raloxifene (60 or 120 mg/day) were compared with placebo, and all subjects received calcium and vitamin D. Both raloxifene treatment groups experienced significant increases in bone density, with the largest gains reported as 2.4% at the femoral neck and 2.7% at the lumbar spine for the 120 mg dose. It is important to note that 60 mg of raloxifene is the FDA approved dose.

A smaller randomized controlled trial of one year duration also evaluated the effects of raloxifene. ^41^ The trial included 143 postmenopausal women, mean age 68 years, with at least one prevalent vertebral fracture and low bone density. Two doses of raloxifene (60 and 120 mg/day) were compared to placebo, and all groups took calcium and vitamin D. Results included significant increases at the total hip (1.7% for 60 mg dose) and radius (2.9% for 60 mg, 2.5% for 120 mg), and nonsignificant increases in the lumbar spine.

Another trial of 601 postmenopausal women recruited from the community in Europe and the United Kingdom with a range of initial bone densities also compared various doses of raloxifene (30, 60, or 150 mg/day) with placebo. ^45^ After 2 years, there were significant increases in bone density with the 60 mg/day dose at the lumbar spine (1.6%), hip (1.6%), and femoral neck (1.2%). All of the raloxifene doses resulted in significant increases, although the higher doses generally had more effect. Two other small studies also reported gains at the lumbar spine and hip. ^42,^ ^44^ One of these trials compared raloxifene with conjugated equine estrogen and noted higher gains at the lumbar spine for the estrogen group. ^44^ Some of these raloxifene trials, however, had dropout rates exceeding 20%. ^43–45^

Only 2 small randomized controlled trials ^46,^ ^47^ of postmenopausal women without breast cancer reported effects of tamoxifen on bone density (Table 5). One reported a 1.4% increase at the lumbar spine ^46^ and the other 1.8% at the hip. ^47^ These studies were limited by either high dropout rates ^47^ or lack of intention-to-treat analysis ^46^ and were rated poor.

### Summary

- The 2 larger randomized controlled trials of raloxifene indicated significant increases in bone density at the lumbar spine, hip, and wrist. These ranged from 2.1% in the femoral neck to 2.7% in the spine measured from baseline after 3 years of treatment in the MORE study. The smaller randomized controlled trials reported increases in most of the sites tested.
- Randomized controlled trials of tamoxifen reported modest, inconsistent increases in bone density at the spine and hip, however these trials have important methodologic limitations.

## Arrow 2: Does postmenopausal use of SERMs prevent osteoporotic fractures?

Two good-quality randomized controlled trials of raloxifene with fracture outcomes have been published (Table 6). The MORE study, ^43^ described above, evaluated incident vertebral fractures using radiographic criteria at the 24- and 36- month visits and at other times if new symptoms of vertebral fractures developed. Nonvertebral fractures were determined by interviewing subjects at 6-month visits. After 3 years of treatment, women in the raloxifene group had a significantly reduced risk for vertebral fractures compared with women in the placebo group (RR, 0.59; 95% CI, 0.50–0.70). The risk for nonvertebral fractures was not significantly reduced.

Table 6. Randomized Controlled Trials of SERMs with Fracture Outcomes

Author/year | N | Duration | Population | Drug/dose | Assessment of fracture | RR (95% CI) for fractures | | Other | USPSTF Quality Rating*
| | | | | | Vertebral | Nonvertebral
Raloxifene
Lufkin, 1998 ^41^ | 143 | 1 year | Postmenopausal women age 45 to 75 (mean age 68 years) with at least 1 prevalent vertebral fracture and low BMD, recruited at the Mayo Clinic, Minnesota and Arizona. | Raloxifene 60 or 120 mg/day or placebo; all received calcium and vitamin D. | Vertebral fractures determined by lateral spine x-rays with incident fractures defined as 15% or more decrease in vertebral height at specific points. | 1.15 (0.75–1.75) | 0.51 (0.12–2.16) | No differences with dose; when vertebral fracture criteria changed to 30% or more reduction in vertebral height, fracture reduction was significant (P=0.047; RR not given). | Good: 9% dropped out of study.
Ettinger, 1999 ^43^ | 7,705 | 3 years | Multiple Outcomes of Raloxifene Evaluation (MORE) study of women aged 31 to 80 years (mean 67 years) in 25 countries who had been postmenopausal for at least 2 years and met WHO criteria for osteoporosis; 2 treatment groups studied 1.) BMD t-score <-2.5; 2.) low BMD and previous vertebral or other fracture. | Raloxifene 60 or 120 mg/day or placebo; all received calcium and vitamin D. | Incident vertebral fractures determined radiographically as a 20% reduction in vertebral height at 24- and 36-month visits and if new symptoms; nonvertebral fractures determined by interview at 6-month visits. | 0.59 (0.05–0.70) | 0.91 (0.79–1.06) | Results similar for both doses except for significantly fewer vertebral fractures for subgroup 2 (with pre-existing fractures) who took 120 mg compared with 60 mg. | Good: 18% of placebo and 17% of treatment groups dropped out at 2 years; 25% of placebo and 22% of treatment groups at 3 years.
Tamoxifen
Fisher, 1998 ^48^ | 13,388 | 5 years | Women enrolled in National Surgical Adjuvant Breast and Bowel Project Breast Cancer Prevention Trial (P-1), high risk for breast cancer, age 35 and over (61% age 50 and over), in U.S. and Canada; fractures were secondary outcome measures. | Tamoxifen 20 mg/day or placebo. | Radiographically confirmed incident fractures of hip, wrist, and vertebra (criteria for vertebral fracture not provided). | 0.74 (0.41–1.32) | Hip: 0.55 (0.25–1.15); Colles' 0.61 (0.29–1.23) | All fractures RR= 0.81 (0.63–1.05); overall reduction greater in women 50 or older at entry RR= 0.79 (0.60–1.05). | Fair: fractures are secondary endpoints, inclusion criteria was based on breast cancer risk, not known if treatment groups have comparably distributed osteoporosis risk factors; vertebral fractures diagnosed only if reported by patient, asymptomatic fractures would be missed; 74% followed for more than 3 years, 37% for more than 5 years.

Note: BMD indicates bone mass density; CI, confidence interval; WHO, World Health Organization

* See appendix 2 for quality criteria.

A smaller randomized controlled trial, ^41^ also described above, evaluated the effects of raloxifene after one year of use and found no significant reductions in risk for vertebral or nonvertebral fractures in the treatment groups compared to the control group. When the outcomes were re-analyzed using more stringent radiographic criteria for vertebral fractures (30% or more reduction in vertebral height rather than 15%), there were significantly fewer vertebral fractures among raloxifene users than placebo (P=0.047; RR not given). These results were not calculated using the fracture criteria of the MORE study ^43^ (20% or more reduction of vertebral height), precluding direct comparison of the 2 studies.

Women enrolled in the National Surgical Adjuvant Breast and Bowel Project Breast Cancer Prevention Trial (P-1) ^48^ of tamoxifen were also monitored for fractures, although this was a secondary outcome. In this study, 13,388 women were randomized to tamoxifen or placebo and followed for 5 years. Incident fractures of the hip, wrist, and spine were confirmed by x-rays. Relative risks for total fractures, hip, wrist, and spine were not significantly reduced. This study, however, has important methodologic limitations and was rated fair. Since this trial was designed to determine tamoxifen's role in breast cancer prevention, the inclusion criteria were based on breast cancer risk not osteoporosis risk. As such, it is not known if the treatment and placebo groups have comparably distributed osteoporosis risk factors. These were not controlled for in the analysis and could have biased the results. Also, vertebral fractures were diagnosed only if reported by participants who may have missed asymptomatic fractures. Undercounting of fractures would compromise estimation of relative risks.

### Summary

- The largest trial of raloxifene, the MORE study, reported a protective effect for vertebral fractures, but not for nonvertebral fractures.
- The subgroup of women in this study with low bone density and pre-existing fractures demonstrated additional benefit with the 120 mg/day dose compared to the 60 mg/day dose.
- A smaller trial with short duration of follow-up indicated no fracture benefit when using less stringent vertebral fracture criteria, but some benefit when using more stringent criteria (15% compared to 30% or more loss of vertebral height).
- A large trial of tamoxifen, designed for breast cancer prevention indicated no statistically significant effect.