# Methods

## Literature Search Strategy

We searched MEDLINE, HealthSTAR, and Cochrane Library databases for papers published between 1994 and May 2001 using the search strategies shown in Appendix 1. Separate searches were conducted to identify randomized controlled trials for estrogen and SERMs. Additional articles were obtained from reference lists of relevant papers including all studies of estrogen pre-dating the electronic search. Studies of raloxifene and tamoxifen, for purposes other than cancer treatment, were present only in the recent literature. A single reader reviewed all English abstracts. We also report the results of 2 recently conducted meta-analyses of HRT and bone density, ^12^ and HRT and fractures. ^13^ Only published studies were included in evidence tables; abstracts and other unpublished works were cited in the text if particularly pertinent.

## Inclusion/Exclusion Criteria

In order to identify the most important studies for inclusion in this review, we used a “best evidence” approach. ^14^ We first examined randomized, double-blind, placebo-controlled trials of estrogen, with and without progestins, and SERMs and fracture outcomes. Because very few such trials have been published, we next examined randomized controlled trials with bone density outcomes. However, these studies were limited because they report intermediate outcomes (bone density), provide only short-term exposure to treatment (1 to 4 years), and enroll subjects often using narrowly defined entry criteria that limit generalizability.

Cohort studies provide additional information about long-term estrogen use and fractures not yet available from randomized controlled trials. Therefore, we also included good-quality cohort studies of estrogen use and fractures acknowledging that these studies are subject to healthy user bias. Other studies have found that estrogen users are healthier, have healthier lifestyles and better mortality, and are more highly educated than nonusers. ^15–21^ Nonetheless, a random sample of U.S. women aged 50 to 74 years old recently found that 38% currently use estrogen, ^15^ and we felt that cohort studies may provide information useful to this high proportion of users in the population. Case-control and cross-sectional studies were excluded. Table 1 outlines the type and number of studies we reviewed for each key question.

Table 1. Key Questions and Types of Studies Cited

| Type of Study
Key Questions | RCT | Cohort
HRT
Does HRT improve or stabilize bone density? | 57
Does HRT prevent fractures? | 5 | 6
SERMs
Does postmenopausal use of SERMs improve or stabilize bone density? | 7
Does postmenopausal use of SERMs prevent fractures? | 3

Note: RCT indicates randomized controlled trial; SERMs, selective estrogen receptor modulators

Studies were included in this review if they enrolled postmenopausal women without secondary causes of osteoporosis; described the number of subjects and setting; and described characteristics of treatment and placebo groups including age, type of HRT, and duration of use. Study design factors that we recorded included exclusion/inclusion criteria, method of allocation, and compliance and follow-up rates. We abstracted comparable information from the cohort studies comparing HRT users and nonusers with the addition of how exposure status was determined. In both randomized controlled trials and cohort studies, we recorded the bone measurement tests that were used, how bone density or fracture outcomes were measured, and fracture rates or bone density outcomes of users and nonusers. All fractures had to be radiographically verified. The most adjusted values were recorded, and pertinent sub-group analyses were noted. Any trends in duration, currency of use, or dosage were also noted.

## Literature Synthesis

We applied quality criteria developed by the methods workgroup for the USPSTF (Appendix 2). ^22^ Most studies included in this report achieved a rating of good. The most common reason for a study not receiving a good rating was follow-up rates falling below 80%.