# Introduction

In this paper, we systematically review the medical literature and evaluate data on the use of hormone replacement therapy (HRT) to prevent osteoporosis in healthy postmenopausal women. Specifically, we focus on the effects of estrogen, with and without progestins, on fracture and bone density outcomes. We also review studies of selective estrogen receptor modulators (SERMs) because of their emerging role in preventing osteoporosis. This report is part of a larger project on the risks and benefits of HRT prepared for the U.S. Preventive Services Task Force (USPSTF) to assist them in making recommendations. A separate systematic evidence review on screening for osteoporosis contains more detailed information about other aspects of osteoporosis prevention. ^1^

The term osteoporosis describes both a process of decreasing bone density as well as the clinical outcome of fracture. Bone density can be measured by a number of techniques and at a number of anatomical sites, although the measures most often used in studies are dual energy x-ray absorptiometry (DXA) of the hip, spine, heel, or wrist. A World Health Organization (WHO) working group proposed that osteoporosis should be diagnosed when bone mineral density (BMD) is 2.5 standard deviations below the mean for healthy young adult women at the spine, hip, or wrist, or when a history of an atraumatic fracture is present. ^2^ The working group also proposed that low bone mass, or osteopenia, be diagnosed when bone density is between 1.0 to 2.5 standard deviations below the young healthy mean. The number of standard deviation units above or below the young healthy mean is called the T-score. This measure is often used in eligibility criteria for treatment trials and is used clinically to diagnose osteoporosis.

## Burden of Suffering/Epidemiology

Osteoporosis affects a large proportion of American women over the age of 50. Estimates of rates of prevalence depend on the instrument used to measure bone density and on the characteristics, including ethnicity, of the population studied. The third National Health and Nutrition Examination Survey (NHANES III) reports prevalence rates for osteoporosis by race, adjusted for age and for census undercount estimates from 1990 and 1993. ^3,^ ^4^ From these data, an estimated 12 million (41%) white women over age 50 met WHO criterion described above for osteopenia and 5 million (15%) met WHO criterion for osteoporosis. The prevalence of osteoporosis in Hispanic women is similar to white women, while rates in black women are approximately half that of the other groups (8%).

The prevalence of osteoporosis increases with age for all sites measured. By the WHO definition, up to 70% of women over age 80 have osteoporosis based on low measurements at the spine, hip or wrist. ^5^ Age is an important factor in the relationship between bone density and the absolute risk of fracture. An increase in age of 13 years increases the risk of hip fracture by the same amount as a one standard deviation decrease in bone density. ^6^ Older women have a much higher fracture rate than younger women with the same bone density because of increasing risk from other factors such as bone quality and tendency to fall. ^7^

Women with osteoporosis are more likely to have fractures, and demographic trends for hip fracture parallel those for osteoporosis. Hip fracture incidence in white women rises from 50 per 100,000 women at age 50 to 237 per 100,000 women at age 65. ^6^ White women are generally 2 to 3 times more likely than non-white women to suffer a hip fracture. ^8^ Wrist fracture incidence tends to increase at earlier ages than hip fractures, with 268 per 100,000 women at age 45 to 54. ^9^ Sixteen percent of postmenopausal women have osteoporosis of the lumbar spine, ^5^ and, among white women, 5% of 50-year-olds and 25% of 80-year-olds have had at least one vertebral fracture. ^10^

## Healthcare Interventions

Estrogen has important effects on bone and estrogen deficiency is considered to be a major factor leading to bone loss in postmenopausal women. Estrogen inhibits bone loss by reducing bone resorption. Bone density decreases steadily after menopause, and supplementation with exogenous estrogen during the peri- and postmenopausal periods has been a common primary preventive approach.

A new class of agents, the SERMs, was developed in an effort to find a treatment for breast cancer and osteoporosis. ^11^ The advantage of SERMs is that they bind to estrogen receptors competing with endogenous estrogens and may either activate or block estrogen action allowing tissue-selective effects. Raloxifene, for example, has estrogen-agonistic effects on bone and lipids, and estrogen-antagonistic effects on the breast and uterus ^11^ and may be preferred by women at increased risk for breast cancer. Raloxifene has been approved for treatment of osteoporosis. Tamoxifen, a different kind of SERM primarily used for breast cancer prevention and treatment, is included in this review for completeness. It has not been approved for treatment of osteoporosis.

## Prior Recommendations

The previous USPSTF thought that the evidence on the effects of HRT for improving or preserving bone density was good based on results of retrospective studies and a few clinical trials. Data on fracture reduction was based on epidemiologic and nonrandomized clinical trials, and the risk of hip fracture reduction was estimated as 25% among women who had used estrogens.

## Analytic Frameworks and Key Questions

The analytic frameworks in Figures 1 and 2 show the target populations, interventions, and health outcome measures we examined for the overall question of the benefits and risks of postmenopausal HRT. Other benefits and risks of HRT are addressed in separate reports and will not be considered here. Arrows 1 and 2 in Figure 1 correspond to issues of HRT and osteoporosis specifically covered in this report. Key questions relating to the numbered arrows in the analytic framework guided our literature review. These include:

Figure 1. Benefits of Hormone Replacement Therapy

Figure 2. Adverse Effects of Hormone Replacement Therapy

Arrow 1: Does hormone replacement therapy improve or stabilize bone density?

Does postmenopausal use of SERMs improve or stabilize bone density?

Arrow 2: Does hormone replacement therapy prevent osteoporotic fractures?

Does postmenopausal use of SERMs prevent osteoporotic fractures?

We were concerned with HRT as a primary preventive measure, and therefore focused on the use of either estrogen alone or estrogen combined with progestins in healthy, postmenopausal women without known secondary causes of osteoporosis. However, because osteoporosis is defined by both low bone density and fracture occurrence, we included studies of women with known low bone density. Results for HRT and SERMs are presented separately.