# Appendix 1

## Appendix 1a: Search Strategy for Hormone Replacement Therapy with Bone Density or Fracture Outcomes

The topic of HRT and osteoporosis and fractures was searched in the MEDLINE database including 1994 to May 2001.

1. exp hormone replacement therapy
  estrogen replacement therapy
2. hormone replacement.tw. (text word taken from title and abstract of article)
3. estrogen replacement.tw.
4. exp estrogens/ad,tu (ad = administration & dosage; tu = therapeutic use)
  equilenin estrogens, catechol
  equilin estrogens, conjugated
  estradiol estrogens, non-steroidal
  estriol estrone
5. exp estrogens, synthetic/ad,tu
  estrogens, non-steroidal epimestrol
  chlorotrianisene ethinyl estradiol
  coumestrol mestranol
  dienestrol quinestrol
  diethylstilbestrol hexestrol
  zearalenone zeranol
6. 1 or 2 or 3 or 4 or 5
7. exp osteoporosis
  osteoporosis, postmenopausal
8. exp fractures
  femoral fractures fractures, closed
  fractures, comminuted fractures, malunited
  fractures, open fractures, spontaneous
  fractures, stress fractures, ununited
  humeral fractures radius fractures
  rib fractures shoulder fractures
  skull fractures spinal fractures
  tibial fractures ulna fractures
9. fracture$.tw.
10. bone density
11. 7 or 8 or 9 or 10
12. 6 and 11
13. limit 12 to human
14. limit 13 to english language
15. looked at english abstracts of foreign articles

## Appendix 1b: Search Strategy for Randomized Controlled Trials of Estrogen and SERMs

The topic of randomized controlled trials of estrogen with bone density or fracture outcomes was searched in the MEDLINE database including 1994 to May 2001. A similar search was also conducted for the SERMs raloxifene and tamoxifen.

### Estrogen

1. exp hormone replacement therapy
  estrogen replacement therapy
2. hormone replacement.tw. (text word taken from title and abstract of article)
3. estrogen replacement.tw.
4. exp estrogens/ad,tu (ad = administration & dosage; tu = therapeutic use)
  equilenin estrogens, catechol
  equilin estrogens, conjugated
  estradiol estrogens, non-steroidal
  estriol estrone
5. exp estrogens, synthetic/ad,tu
  estrogens, non-steroidal epimestrol
  chlorotrianisene ethinyl estradiol
  coumestrol mestranol
  dienestrol quinestrol
  diethylstilbestrol hexestrol
  zearalenone zeranol
6. 1 or 2 or 3 or 4 or 5
7. limit 6 to randomized controlled trials (check for document type)
8. randomized controlled trials
9. randomized.tw.
10. 8 or 9
11. 6 and 10
12. 7 or 11
13. limit 12 to human
14. limit 13 to english language
15. looked at english abstracts of foreign articles

### Tamoxifen and raloxifene

1. (tamoxifen or raloxifene).mp.
2. Bone density/ or “bone density”.mp
3. exp osteoporosis/ or “osteoporosis”.mp
4. exp fractures/ or fracture$.mp.
5. exp hormone replacement therapy
6. estrogen replacement.mp.
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7
9. limit 8 to (human and english language)
10. exp breast neoplasms/
11. 9 not 10
12. from 11 keep 1–145