# REFERENCES

1 U.S. Preventive Services Task Force. Prevention of falls in community-dwelling older adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(3):197-204. [pmid: 22868837].
2 U.S. Preventive Services Task Force. Vitamin D and Calcium Supplementation to Prevent Cancer and Osteoporotic Fractures in Adults: Draft Recommendation Statement. Rockville, MD. U.S. Preventive Services Task Force. 2012.
3 U.S. Preventive Services Task Force. Vitamin D and calcium supplementation to prevent fractures in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;158(9):691-6. [pmid: 23440163].
4 U.S. Preventive Services Task Force. Vitamin, mineral, and multivitamin supplements for the primary prevention of cardiovascular disease and cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;160(8):558-64. [pmid: 24566474].
5 Looker AC, Johnson CL, Lacher DA, et al. Vitamin D Status: United States, 2001-2006. Hyattsville, MD. Centers for Disease Control and Prevention. 2011.
6 Holick MF. Vitamin D deficiency. N Engl J Med. 2007;357(3):266-81. [pmid: 17634462].
7 Christakos S, DeLuca H. Minireview: vitamin D: is there a role in extraskeletal health?. Endocrinology. 2011;152(8):2930-36. [pmid: 21673104].
8 Holick MF. Optimal vitamin D status for the prevention and treatment of osteoporosis. Drugs Aging. 2007;24(12):1017-29. [pmid: 18020534].
9 Powe CE, Evans MK, Wenger J, et al. Vitamin D-binding protein and vitamin D status of black Americans and white Americans. N Engl J Med. 2013;369(21):1991-2000. [pmid: 24256378].
10 Fraser WD, Milan AM. Vitamin D assays: past and present debates, difficulties, and developments. Calcif Tissue Int. 2013;92(2):118-27. [pmid: 23314742].
11 Carter GD. Accuracy of 25-hydroxyvitamin D assays: confronting the issues. Curr Drug Targets. 2011;12(1):19-28. [pmid: 20795940].
12 Institute of Medicine. 2011 Dietary Reference Intakes for Calcium and Vitamin D. Washington, DC. National Academies Press. 2011.
13 Holick MF, Binkley NC, Bischoff-Ferrari HA, et al. Evaluation, treatment, and prevention of vitamin D deficiency: an Endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2011;96(7):1911-30. [pmid: 21646368].
14 Holmes EW, Garbincius J, McKenna KM. Analytical variability among methods for the measurement of 25-hydroxyvitamin D: still adding to the noise. Am J Clin Pathol. 2013;140(4):550-60. [pmid: 24045553].
15 Lai JK, Lucas RM, Banks E, et al. Variability in vitamin D assays impairs clinical assessment of vitamin D status. Intern Med J. 2012;42(1):43-50. [pmid: 21395958].
16 Bedner M, Lippa KA, Tai SS. An assessment of 25-hydroxyvitamin D measurements in comparability studies conducted by the Vitamin D Metabolites Quality Assurance Program. Clin Chim Acta. 2013;426:6-11. [pmid: 23978484].
17 Cashman KD, Kiely M, Kinsella M, et al. Evaluation of Vitamin D Standardization Program protocols for standardizing serum 25-hydroxyvitamin D data: a case study of the program's potential for national nutrition and health surveys. Am J Clin Nutr. 2013;97(6):1235-42. [pmid: 23615829].
18 Wagner D, Hanwell HE, Vieth R. An evaluation of automated methods for measurement of serum 25-hydroxyvitamin D. Clin Biochem. 2009;42(15):1549-56. [pmid: 19631201].
19 Binkley N, Krueger DC, Morgan S, et al. Current status of clinical 25-hydroxyvitamin D measurement: an assessment of between-laboratory agreement. Clin Chim Acta. 2010;411(23-24):1976-82. [pmid: 20713030].
20 Moon HW, Cho JH, Hur M, et al. Comparison of four current 25-hydroxyvitamin D assays. Clin Biochem. 2012;45(4-5):326-30. [pmid: 22244986].
21 Granado Lorencio F, Blanco-Navarro I, Perez-Sacrsitan B. Critical evaluation of assays for vitamin D status. Curr Opin Clin Nutr Metab Care. 2013;16(6):734-40. [pmid: 24100666].
22 Malabanan A, Veronikis I, Holick M. Redefining vitamin D insufficiency. Lancet. 1998;351(9105):805-6. [pmid: 9519960].
23 Chapuy M, Schott A, Garnero P, et al. Healthy elderly French women living at home have secondary hyperparathyroidism and high bone turnover in winter: EPIDOS Study Group. Clin Endocrinol Metab. 1996;81:1129-33.
24 Holick M, Siris E, Binkley N, et al. Prevalence of vitamin D inadequacy among postmenopausal North American women receiving osteoporosis therapy. J Clin Epidemiol Metab. 2005;90:3215-24.
25 Thomas M, Lloyd-Jones D, Thadhani R, et al. Hypovitaminosis D in medical inpatients. N Engl J Med. 1998;338(12):777-83. [pmid: 9504937].
26 Heaney R, Dowell M, Hale C, et al. Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. Am Coll Nutr. 2003;22:142-6.
27 Hansen K, Jones A, Lindstrom M, et al. Vitamin D insufficiency: disease or no disease?. J Bone Miner Res. 2008;23:1052-60. [pmid: 18302509].
28 Bischoff-Ferrari H. Vitamin D: what is an adequate vitamin D level and how much supplementation is necessary?. Best Pract Res Clin Rheumatol. 2009;23(6):789-95. [pmid: 19945690].
29 Rosen CJ, Adams JS, Bikle DD, et al. The nonskeletal effects of vitamin D: an Endocrine Society scientific statement. Endocr Rev. 2012;33(3):456-92. [pmid: 22596255].
30 Ross AC, Manson JE, Abrams SA, et al. The 2011 report on dietary reference intakes for calcium and vitamin D from the Institute of Medicine: what clinicians need to know. J Clin Endocrinol Metab. 2011;96(1):53-8. [pmid: 21118827].
31 Vieth R. What is the optimal vitamin D status for health?. Prog Biophys Mol Biol. 2006;(92):26. [pmid: 16766239].
32 National Osteoporosis Foundation. Clinician's Guide to Prevention and Treatment of Osteoporosis. Accessed at http://nof.org/files/nof/public/content/file/344/upload/159.pdf. 12 November 2014.
33 International Osteoporosis Foundation. International Osteoporosis Foundation Statement of New IOM Dietary Reference Intakes for Calcium and Vitamin D. Accessed at http://www.iofbonehealth.org/iof-statement-new-iom-dietary-reference-intakes-calcium-and-vitamin-d. 12 November 2014.
34 Dawson-Hughes B, Mithal A, Bonjour JP, et al. IOF position statement: vitamin D recommendations for older adults. Osteoporos Int. 2010;21(7):1151-4. [pmid: 20422154].
35 Taylor CL, Carriquiry AL, Bailey RL, et al. Appropriateness of the probability approach with a nutrient status biomarker to assess population inadequacy: a study using vitamin D. Am J Clin Nutr. 2013;97(1):72-8. [pmid: 23097269].
36 Ginde AA, Liu MC, Camargo CA Jr. Demographic differences and trends of Vitamin D insufficiency in the US population, 1988-2004. Arch Intern Med. 2009;169(6):626-32. [pmid: 19307527].
37 McCullough ML, Weinstein SJ, Freedman DM, et al. Correlates of circulating 25-hydroxyvitamin D: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):21-35. [pmid: 20562191].
38 Orwoll E, Nielson CM, Marshall LM, et al. Vitamin D deficiency in older men. J Clin Endocrinol Metab. 2009;94(4):1214-22. [pmid: 19174492].
39 Forrest KY, Stuhldreher WL. Prevalence and correlates of vitamin D deficiency in US adults. Nutr Res. 2011;31(1):48-54. [pmid: 21310306].
40 Jacques PF, Felson DT, Tucker KL, et al. Plasma 25-hydroxyvitamin D and its determinants in an elderly population sample. Am J Clin Nutr. 1997;66(4):929-36. [pmid: 9322570].
41 Millen AE, Wactawski-Wende J, Pettinger M, et al. Predictors of serum 25-hydroxyvitamin D concentrations among postmenopausal women: the Women's Health Initiative Calcium plus Vitamin D clinical trial. Am J Clin Nutr. 2010;91(5):1324-35. [pmid: 20219959].
42 Looker AC, Pfeiffer CM, Lacher DA, et al. Serum 25-hydroxyvitamin D status of the US population: 1988-1994 compared with 2000-2004. Am J Clin Nutr. 2008;88(6):1519-27. [pmid: 19064511].
43 Bhan A, Rao A, Rao D. Osteomalacia as a result of vitamin D deficiency. Endocrinol Metab Clin North Am. 2010;39(2):321. [pmid: 20511054].
44 Chung M, Balk EM, Brendel M, et al. Vitamin D and Calcium: Systematic Review of Health Outcomes. Evidence Report/Technology Assessment No. 183. AHRQ Publication No. 09-E015. Rockville, MD. Agency for Healthcare Research and Quality. 2009. Accessed at http://www.ahrq.gov/downloads/pub/evidence/pdf/vitadcal/vitadcal.pdf. 12 November 2014.
45 Theodoratou E, Tzoulaki I, Zgaga L, et al. Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014;348.
46 Cauley JA, Danielson ME, Boudreau R, et al. Serum 25-hydroxyvitamin D and clinical fracture risk in a multiethnic cohort of women: the Women's Health Initiative (WHI). J Bone Miner Res. 2011;26(10):2378-88. [pmid: 21710614].
47 Barbour KE, Houston DK, Cummings SR, et al. Calciotropic hormones and the risk of hip and nonspine fractures in older adults: the health ABC study. J Bone Miner Res. 2012;27(5):1177-85. [pmid: 22228250].
48 Scragg R, Holdaway I, Singh V, et al. Serum 25-hydroxyvitamin D3 levels decreased in impaired glucose tolerance and diabetes mellitus. Diabetes Res Clin Pract. 1995;27(3):181-8. [pmid: 7555599].
49 Ford ES, Ajani UA, McGuire LC, et al. Concentrations of serum Vitamin D and the metabolic syndrome among U.S. adults. Diabetes Care. 2005;28(5):1228-30. [pmid: 15855599].
50 Jenab M, Bueno-de-Mesquita HB, Ferrari P, et al. Association between pre-diagnostic circulating vitamin D concentration and risk of colorectal cancer in European populations: a nested case-control study. BMJ. 2010;340:b5500. [pmid: 20093284].
51 Garland CF, Gorham ED, Mohr SB, et al. Vitamin D for cancer prevention: global perspective. Ann Epidemiol. 2009;19(7):468-83. [pmid: 19523595].
52 Wu K, Feskanich D, Fuchs CS, et al. A nested case control study of plasma 25-hydroxyvitamin D concentrations and risk of colorectal cancer. J Natl Cancer Inst. 2007;99(14):1120-9. [pmid: 17623801].
53 Kim DH, Sabour S, Sagar UN, et al. Prevalence of hypovitaminosis D in cardiovascular diseases (from the National Health and Nutrition Examination Survey 2001 to 2004). Am J Cardiol. 2008;102(11):1540-4. [pmid: 19026311].
54 Semba RD, Houston DK, Bandinelli S, et al. Relationship of 25-hydroxyvitamin D with all-cause and cardiovascular disease mortality in older community-dwelling adults. Eur J Clin Nutr. 2010;64(2):203-9. [pmid: 19953106].
55 Cranney A, Horsley T, O'Donnell S, et al. Effectiveness and safety of vitamin D in relation to bone health. Evid Rep Technol Assess. 2007;(158):1-235.
56 Menant JC, Close JCT, Delbaere K, et al. Relationships between serum vitamin D levels, neuromuscular and neuropsychological function and falls in older men and women. Osteoporos Int. 2012;23(3):981-9. [pmid: 21523392].
57 Faulkner KA, Cauley JA, Zmuda JM, et al. Higher 1,25-dihydroxyvitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporos Int. 2006;17(9):1318-28. [pmid: 16788853].
58 Autier P, Boniol M, Pizot C, et al. Vitamin D status and ill health: a systematic review. Lancet Diabetes Endocrinol. 2014;2(1):76-89. [pmid: 24622671].
59 Sohl E, van Schoor NM, de Jongh RT, et al. Vitamin D status is associated with functional limitations and functional decline in older individuals. J Clin Endocrinol Metab. 2013;98(9):E1483-90. [pmid: 23864700].
60 Houston DK, Tooze JA, Davis CC, et al. Serum 25-hydroxyvitamin D and physical function in older adults: the Cardiovascular Health Study All Stars. J Am Geriatr Soc. 2011;59(10):1793-801. [pmid: 22091492].
61 Houston DK, Neiberg RH, Tooze JA, et al. Low 25-hydroxyvitamin D predicts the onset of mobility limitation and disability in community-dwelling older adults: the Health ABC Study. J Gerontol A Biol Sci Med Sci. 2013;68(2):181-7. [pmid: 22573914].
62 Houston DK, Tooze JA, Neiberg RH, et al. 25-hydroxyvitamin D status and change in physical performance and strength in older adults. Am J Epidemiol. 2012;176(11):1025-34. [pmid: 23118104].
63 Sohl E, de Jongh RT, Heijboer AC, et al. Vitamin D status is associated with physical performance: the results of three independent cohorts. Osteoporos Int. 2013;24(1):187-96. [pmid: 22961566].
64 Pittas AG, Chung M, Trikalinos T, et al. Systematic review: vitamin D and cardiometabolic outcomes. Ann Intern Med. 2010;152(5):307-14. [pmid: 20194237].
65 Wang L, Song Y, Manson JE, et al. Circulating 25-hydroxy-vitamin D and risk of cardiovascular disease: a meta-analysis of prospective studies. Circ Cardiovasc Qual Outcomes. 2012;5(6):819-29. [pmid: 23149428].
66 Brondum-Jacobsen P, Benn M, Jensen GB, et al. 25-hydroxyvitamin D levels and risk of ischemic heart disease, myocardial infarction, and early death: population-based study and meta-analyses of 18 and 17 studies. Arterioscler Thromb Vasc Biol. 2012;32(11):2794-802. [pmid: 22936341].
67 Sun Q, Pan A, Hu FB, et al. 25-Hydroxyvitamin D levels and the risk of stroke: a prospective study and meta-analysis. Stroke. 2012;43(6):1470-7. [pmid: 22442173].
68 Robinson-Cohen C, Hoofnagle AN, Ix JH, et al. Racial differences in the association of serum 25-hydroxyvitamin D concentration with coronary heart disease events. JAMA. 2013;310(2):179-88. [pmid: 23839752].
69 Michos ED, Reis JP, Post WS, et al. 25-Hydroxyvitamin D deficiency is associated with fatal stroke among whites but not blacks: the NHANES-III linked mortality files. Nutrition. 2012;28(4):367-71. [pmid: 22261577].
70 Chung M, Lee J, Terasawa T, et al. Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;155(12):827-38. [pmid: 22184690].
71 Yin L, Raum E, Haug U, et al. Meta-analysis of longitudinal studies: serum vitamin D and prostate cancer risk. Cancer Epidemiol. 2009;33(6):435-45. [pmid: 19939760].
72 Gandini S, Boniol M, Haukka J, et al. Meta-analysis of observational studies of serum 25-hydroxyvitamin D levels and colorectal, breast and prostate cancer and colorectal adenoma. Int J Cancer. 2011;128(6):1414-24. [pmid: 20473927].
73 Yin L, Grandi N, Raum E, et al. Meta-analysis: serum vitamin D and breast cancer risk. Eur J Cancer. 2010;46(12):2196-205. [pmid: 20456946].
74 Eliassen AH, Spiegelman D, Hollis BW, et al. Plasma 25-hydroxyvitamin D and risk of breast cancer in the Nurses' Health Study II. Breast Cancer Res. 2011;13(3):R50. [pmid: 21569367].
75 Grant WB. Relation between prediagnostic serum 25-hydroxyvitamin D level and incidence of breast, colorectal, and other cancers. J Photochem Photobiol B. 2010;101(2):130-6. [pmid: 20570169].
76 Lee JE, Li H, Chan AT, et al. Circulating levels of vitamin D and colon and rectal cancer: the Physicians' Health Study and a meta-analysis of prospective studies. Cancer Prev Res. 2011;4(5):735-43.
77 Gorham ED, Garland CF, Garland FC, et al. Optimal vitamin D status for colorectal cancer prevention: a quantitative meta analysis. Am J Prev Med. 2007;32(3):210-6. [pmid: 17296473].
78 International Agency for Research on Cancer. Vitamin D and Cancer. Lyon, France. International Agency for Research on Cancer. 2008.
79 Mattila C, Knekt P, Mannisto S, et al. Serum 25-hydroxyvitamin D concentration and subsequent risk of type 2 diabetes. Diabetes Care. 2007;30(10):2569-70. [pmid: 17626891].
80 Knekt P, Laaksonen M, Mattila C, et al. Serum vitamin D and subsequent occurrence of type 2 diabetes. Epidemiology. 2008;19(5):666-71. [pmid: 18496468].
81 Gonzalez-Molero I, Rojo-Martinez G, Morcillo S, et al. Vitamin D and incidence of diabetes: a prospective cohort study. Clin Nutr. 2012;31(4):571-3. [pmid: 22204964].
82 Pittas AG, Sun Q, Manson JE, et al. Plasma 25-hydroxyvitamin D concentration and risk of incident type 2 diabetes in women. Diabetes Care. 2010;33(9):2021-3. [pmid: 20805275].
83 Song Y, Wang L, Pittas AG, et al. Blood 25-hydroxy vitamin D levels and incident type 2 diabetes: a meta-analysis of prospective studies. Diabetes Care. 2013;36(5):1422-8. [pmid: 23613602].
84 Tsur A, Feldman BS, Feldhammer I, et al. Decreased serum concentrations of 25-hydroxycholecalciferol are associated with increased risk of progression to impaired fasting glucose and diabetes. Diabetes Care. 2013;36(5):1361-7. [pmid: 23393216].
85 Schottker B, Herder C, Rothenbacher D, et al. Serum 25-hydroxyvitamin D levels and incident diabetes mellitus type 2: a competing risk analysis in a large population-based cohort of older adults. Eur J Epidemiol. 2013;28(3):267-75. [pmid: 23354985].
86 Husemoen LL, Skaaby T, Thuesen BH, et al. Serum 25(OH)D and incident type 2 diabetes: a cohort study. Eur J Clin Nutr. 2012;66(12):1309-14. [pmid: 23031851].
87 Forouhi NG, Ye Z, Rickard AP, et al. Circulating 25-hydroxyvitamin D concentration and the risk of type 2 diabetes: results from the European Prospective Investigation into Cancer (EPIC)-Norfolk cohort and updated meta-analysis of prospective studies. Diabetologia. 2012;55(8):2173-82. [pmid: 22526608].
88 Milaneschi Y, Shardell M, Corsi AM, et al. Serum 25-hydroxyvitamin D and depressive symptoms in older women and men. J Clin Endocrinol Metab. 2010;95(7):3225-33. [pmid: 20444911].
89 Maddock J, Berry DJ, Geoffroy MC, et al. Vitamin D and common mental disorders in mid-life: cross-sectional and prospective findings. Clin Nutr. 2013;32(5):758-64. [pmid: 23395104].
90 Llewellyn DJ, Lang IA, Langa KM, et al. Vitamin D and risk of cognitive decline in elderly persons. Arch Intern Med. 2010;170(13):1135-41. [pmid: 20625021].
91 Slinin Y, Paudel M, Taylor BC, et al. Association between serum 25(OH) vitamin D and the risk of cognitive decline in older women. J Gerontol A Biol Sci Med Sci. 2012;67(10):1092-8. [pmid: 22454371].
92 Slinin Y, Paudel ML, Taylor BC, et al. 25-Hydroxyvitamin D levels and cognitive performance and decline in elderly men. Neurology. 2010;74(1):33-41. [pmid: 19940271].
93 Chowdhury R, Kunutsor S, Vitezova A, et al. Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014;348.
94 Durup D, Jorgensen HL, Christensen J, et al. A reverse J-shaped association of all-cause mortality with serum 25-hydroxyvitamin D in general practice: the CopD study. J Clin Endocrinol Metab. 2012;97(8):2644-52. [pmid: 22573406].
95 Sempos CT, Durazo-Arvizu RA, Dawson-Hughes B, et al. Is there a reverse J-shaped association between 25-hydroxyvitamin D and all-cause mortality? Results from the U.S. nationally representative NHANES. J Clin Endocrinol Metab. 2013;98(7):3001-9. [pmid: 23666975].
96 Dror Y, Giveon SM, Hoshen M, et al. Vitamin D levels for preventing acute coronary syndrome and mortality: evidence of a nonlinear association. J Clin Endocrinol Metab. 2013;98(5):2160-7. [pmid: 23533239].
97 Zittermann A, Iodice S, Pilz S, et al. Vitamin D deficiency and mortality risk in the general population: a meta-analysis of prospective cohort studies. Am J Clin Nutr. 2012;95(1):91-100. [pmid: 22170374].
98 Signorello LB, Han X, Cai Q, et al. A prospective study of serum 25-hydroxyvitamin D levels and mortality among African Americans and non-African Americans. Am J Epidemiol. 2013;177(2):171-9. [pmid: 23125439].
99 Schottker B, Haug U, Schomburg L, et al. Strong associations of 25-hydroxyvitamin D concentrations with all-cause, cardiovascular, cancer, and respiratory disease mortality in a large cohort study. Am J Clin Nutr. 2013;97(4):782-93. [pmid: 23446902].
100 Johansson H, Oden A, Kanis J, et al. Low serum vitamin D is associated with increased mortality in elderly men: MrOS Sweden. Osteoporos Int. 2012;23(3):991-9. [pmid: 22008880].
101 Virtanen JK, Nurmi T, Voutilainen S, et al. Association of serum 25-hydroxyvitamin D with the risk of death in a general older population in Finland. Eur J Nutr. 2011;50(5):305-12. [pmid: 20976461].
102 Wong YY, McCaul KA, Yeap BB, et al. Low vitamin D status is an independent predictor of increased frailty and all-cause mortality in older men: the Health in Men Study. J Clin Endocrinol Metab. 2013;98(9):3821-8. [pmid: 23788685].
103 Tomson J, Emberson J, Hill M, et al. Vitamin D and risk of death from vascular and non-vascular causes in the Whitehall study and meta-analyses of 12,000 deaths. Eur Heart J. 2013;34(18):1365-74. [pmid: 23257953].
104 Kritchevsky SB, Tooze JA, Neiberg RH, et al. 25-Hydroxyvitamin D, parathyroid hormone, and mortality in black and white older adults: the health ABC study. J Clin Endocrinol Metab. 2012;97(11):4156-65. [pmid: 22942386].
105 Linos E, Keiser E, Kanzler M, et al. Sun protective behaviors and vitamin D levels in the US population: NHANES 2003-2006. Cancer Causes Control. 2012;23(1):133-40. [pmid: 22045154].
106 Matsuoka LY, Ide L, Wortsman J, et al. Sunscreens suppress cutaneous vitamin D3 synthesis. J Clin Endocrinol Metab. 1987;64(6):1165-8. [pmid: 3033008].
107 Norval M, Wulf HC. Does chronic sunscreen use reduce vitamin D production to insufficient levels?. Br J Dermatol. 2009;161(4):732-6. [pmid: 19663879].
108 Faurschou A, Beyer DM, Schmedes A, et al. The relation between sunscreen layer thickness and vitamin D production after ultraviolet B exposure: a randomized clinical trial. Br J Dermatol. 2012;167(2):391-5. [pmid: 22512875].
109 Samuel L, Borrell LN. The effect of body mass index on optimal vitamin D status in U.S. adults: the National Health and Nutrition Examination Survey 2001-2006. Ann Epidemiol. 2013;23(7):409-14. [pmid: 23790345].
110 Giovannucci E, Liu Y, Rimm EB, et al. Prospective study of predictors of vitamin D status and cancer incidence and mortality in men. J Natl Cancer Inst. 2006;98(7):451-9. [pmid: 16595781].
111 Wang TJ, Zhang F, Richards JB, et al. Common genetic determinants of vitamin D insufficiency: a genome-wide association study. Lancet. 2010;376(9736):180-8. [pmid: 20541252].
112 Hanley DA, Cranney A, Jones G, et al. Vitamin D in adult health and disease: a review and guideline statement from Osteoporosis Canada. CMAJ. 2010;182(12):E610-8. [pmid: 20624868].
113 McKee J. Studies find patients have low levels of vitamin D. AAOS Now. Nov. 2014;8:11.
114 Tripkovic L, Lambert H, Hart K, et al. Comparison of vitamin D2 and vitamin D3 supplementation in raising serum 25-hydroxyvitamin D status: a systematic review and meta-analysis. Am J Clin Nutr. 2012;95(6):1357-64. [pmid: 22552031].
115 Lehmann U, Hirche F, Stangl GI, et al. Bioavailability of vitamin D2 and D3 in healthy volunteers, a randomised placebo-controlled trial. J Clin Endocrinol Metab. 2013;98(11):4339-45. [pmid: 24001747].
116 Holick MF, Biancuzzo RM, Chen TC, et al. Vitamin D2 is as effective as vitamin D3 in maintaining circulating concentrations of 25-hydroxyvitamin D. J Clin Endocrinol Metab. 2008;93(3):677-81. [pmid: 18089691].
117 Biancuzzo RM, Clarke N, Reitz RE, et al. Serum concentrations of 1,25-dihydroxyvitamin D2 and 1,25-dihydroxyvitamin D3 in response to vitamin D2 and vitamin D3 supplementation. J Clin Endocrinol Metab. 2013;98(3):973-9. [pmid: 23386645].
118 Rejnmark L, Avenell A, Masud T, et al. Vitamin D with calcium reduces mortality: patient level pooled analysis of 70,528 patients from eight major vitamin D trials. J Clin Endocrinol Metab. 2012;97(8):2670-81. [pmid: 22605432].
119 DIPART (Vitamin D Individual Patient Analysis of Randomized Trials) Group. Patient level pooled analysis of 68 500 patients from seven major vitamin D fracture trials in US and Europe. Br Med J (Clin Res Ed). 2010;340:b5463.
120 Ooms ME, Roos JC, Bezemer PD, et al. Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. 1995;80(4):1052-8. [pmid: 7714065].
121 Grados F, Brazier M, Kamel S, et al. Prediction of bone mass density variation by bone remodeling markers in postmenopausal women with vitamin D insufficiency treated with calcium and vitamin D supplementation. J Clin Endocrinol Metab. 2003;88(11):5175-9. [pmid: 14602746].
122 Chapuy MC, Pamphile R, Paris E, et al. Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. 2002;13(3):257-64. [pmid: 11991447].
123 Orwoll ES, Oviatt SK, McClung MR, et al. The rate of bone mineral loss in normal men and the effects of calcium and cholecalciferol supplementation. Ann Intern Med. 1990;112(1):29-34. [pmid: 2152844].
124 Andersen R, Molgaard C, Skovgaard LT, et al. Effect of vitamin D supplementation on bone and vitamin D status among Pakistani immigrants in Denmark: a randomised double-blinded placebo-controlled intervention study. Br J Nutr. 2008;100(1):197-207. [pmid: 18208636].
125 Wamberg L, Pedersen SB, Richelsen B, et al. The effect of high-dose vitamin D supplementation on calciotropic hormones and bone mineral density in obese subjects with low levels of circulating 25-hydroxyvitamin D: results from a randomized controlled study. Calcif Tissue Int. 2013;93(1):69-77. [pmid: 23591713].
126 Nieves JW, Cosman F, Grubert E, et al. Skeletal effects of vitamin D supplementation in postmenopausal black women. Calcif Tissue Int. 2012;91(5):316-24. [pmid: 22923289].
127 Janssen HC, Samson MM, Verhaar HJ. Muscle strength and mobility in vitamin D-insufficient female geriatric patients: a randomized controlled trial on vitamin D and calcium supplementation. Aging Clin. 2010;22(1):78-84.
128 Honkanen R, Alhava E, Parviainen M, et al. The necessity and safety of calcium and vitamin D in the elderly. J Am Geriatr Soc. 1990;38(8):862-6. [pmid: 2387950].
129 Bischoff-Ferrari HA, Conzelmann M, Stahelin HB, et al. Is fall prevention by vitamin D mediated by a change in postural or dynamic balance?. Osteoporos Int. 2006;17(5):656-63. [pmid: 16508700].
130 Gupta R, Sharma U, Gupta N, et al. Effect of cholecalciferol and calcium supplementation on muscle strength and energy metabolism in vitamin D-deficient Asian Indians: a randomized, controlled trial. Clin Endocrinol. 2010;73(4):445-51.
131 Close GL, Russell J, Cobley JN, et al. Assessment of vitamin D concentration in non-supplemented professional athletes and healthy adults during the winter months in the UK: implications for skeletal muscle function. J Sports Sci. 2013;31(4):344-53. [pmid: 23083379].
132 Knutsen KV, Madar AA, Lagerlov P, et al. Does vitamin D improve muscle strength in adults? A randomized, double-blind, placebo-controlled trial among ethnic minorities in Norway. J Clin Endocrinol Metab. 2014;99(1):194-202. [pmid: 24248184].
133 Wamberg L, Kampmann U, Stodkilde-Jorgensen H, et al. Effects of vitamin D supplementation on body fat accumulation, inflammation, and metabolic risk factors in obese adults with low vitamin D levels: results from a randomized trial. Eur J Intern Med. 2013;24(7):644-9. [pmid: 23566943].
134 Andersen R, Brot C, Mejborn H, et al. Vitamin D supplementation does not affect serum lipids and lipoproteins in Pakistani immigrants. Eur J Clin Nutr. 2009;63(9):1150-3. [pmid: 19352377].
135 Pfeifer M, Begerow B, Minne HW, et al. Effects of a short-term vitamin D(3) and calcium supplementation on blood pressure and parathyroid hormone levels in elderly women. J Clin Endocrinol Metab. 2001;86(4):1633-7. [pmid: 11297596].
136 Wood AD, Secombes KR, Thies F, et al. Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab. 2012;97(10):3557-68. [pmid: 22865902].
137 Simha V, Mahmood M, Ansari M, et al. Effect of vitamin D replacement on insulin sensitivity in subjects with vitamin D deficiency. J Investig Med. 2012;60(8):1214-8.
138 Margolis KL, Ray RM, Van Horn L, et al. Effect of calcium and vitamin D supplementation on blood pressure: the Women's Health Initiative Randomized Trial. Hypertension. 2008;52(5):847-55. [pmid: 18824662].
139 Jones G. Pharmacokinetics of vitamin D toxicity. Am J Clin Nutr. 2008;88(2):582S-6S. [pmid: 18689406].
140 Office of Dietary Supplements. Vitamin D: Fact Sheet for Health Professionals. Bethesda, MD. National Institutes of Health. 2014. Accessed at http://ods.od.nih.gov/factsheets/VitaminD-HealthProfessional/. 12 November 2014.
141 Rollins G. Vitamin D testing—what's the right answer? Labs grapple with confusing analytics, evidence. Clinical Laboratory News. 2009;35(7).
142 Stratton-Loeffler M, Lo J, Hui R, et al. Treatment of vitamin D deficiency within a large integrated health care delivery system. J Manag Care Pharm. 2012;18(7):497-505. [pmid: 22971203].
143 Gahche J, Bailey R, Burt V, et al. Dietary supplement use among U.S. adults has increased since NHANES III (1988-1994). NCHS Data Brief. 2011;(61):1-8. [pmid: 21592424].
144 Gordon NP, Caan BJ, Asgari MM. Variation in vitamin D supplementation among adults in a multi-race/ethnic health plan population, 2008. Nutr J. 2012;11:104. [pmid: 23231734].
145 American Society for Clinical Pathology. Five Things Physicians and Patients Should Question. Chicago. American Society for Clinical Pathology. 2013. Accessed at http://www.choosingwisely.org/doctor-patient-lists/american-society-for-clinical-pathology/. 12 November 2014.
146 Jackson RD, LaCroix AZ, Cauley JA, et al. The Women's Health Initiative calcium-vitamin D trial: overview and baseline characteristics of participants. Ann Epidemiol. 2003;13(9 Suppl):S98-106. [pmid: 14575942].
147 Glerup H, Mikkelsen K, Poulsen L, et al. Hypovitaminosis D myopathy without biochemical signs of osteomalacic bone involvement. Calcif Tissue Int. 2000;66(6):419-24. [pmid: 10821877].
148 Plotnikoff GA, Quigley JM. Prevalence of severe hypovitaminosis D in patients with persistent, nonspecific musculoskeletal pain. Mayo Clin Proc. 2003;78(12):1463-70. [pmid: 14661675].
149 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. 12 November 2014.
150 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996;15(6):619-29. [pmid: 8731004].
151 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
152 LaCroix AZ, Kotchen J, Anderson G, et al. Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women's Health Initiative calcium-vitamin D randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2009;64(5):559-67. [pmid: 19221190].
153 Kärkkäinen M, Tuppurainen M, Salovaara K, et al. Effect of calcium and vitamin D supplementation on bone mineral density in women aged 65-71 years: a 3-year randomized population-based trial (OSTPRE-FPS). Osteoporos Int. 2010;21(12):2047-55. [pmid: 20204604].
154 Krieg MA, Jacquet AF, Bremgartner M, et al. Effect of supplementation with vitamin D3 and calcium on quantitative ultrasound of bone in elderly institutionalized women: a longitudinal study. Osteoporos Int. 1999;9(6):483-8. [pmid: 10624454].
155 Lips P, Binkley N, Pfeifer M, et al. Once-weekly dose of 8400 IU vitamin D(3) compared with placebo: effects on neuromuscular function and tolerability in older adults with vitamin D insufficiency. Am J Clin Nutr. 2010;91(4):985-91. [pmid: 20130093].
156 Gallagher JC, Sai A, Templin T, et al. Dose response to vitamin D supplementation in postmenopausal women: a randomized trial. Ann Intern Med. 2012;156(6):425-37. [pmid: 22431675].
157 Brazier M, Grados F, Kamel S, et al. Clinical and laboratory safety of one year's use of a combination calcium + vitamin D tablet in ambulatory elderly women with vitamin D insufficiency: results of a multicenter, randomized, double-blind, placebo-controlled study. Clin Ther. 2005;27(12):1885-93. [pmid: 16507374].
158 Grimnes G, Figenschau Y, Almas B, et al. Vitamin D, insulin secretion, sensitivity, and lipids: results from a case-control study and a randomized controlled trial using hyperglycemic clamp technique. Diabetes. 2011;60(11):2748-57. [pmid: 21911741].
159 Gallagher JC, Jindal PS, Smith LM. Vitamin D supplementation in young white and African American women. J Bone Miner Res. 2014;29(1):173-81. [pmid: 23761326].
160 Gallagher JC, Peacock M, Yalamanchili V, et al. Effects of vitamin D supplementation in older African American women. J Clin Endocrinol Metab. 2013;98(3):1137-46. [pmid: 23386641].
161 Lips P, Graafmans WC, Ooms ME, et al. Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med. 1996;124(4):400-6. [pmid: 8554248].
162 Pfeifer M, Begerow B, Minne HW, et al. Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000;15(6):1113-8. [pmid: 10841179].
163 Pfeifer M, Begerow B, Minne HW, et al. Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009;20(2):315-22. [pmid: 18629569].
164 Jackson RD, LaCroix AZ, Gass M, et al. Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 2006;354(7):669-83. [pmid: 16481635].
165 Bischoff HA, Stahelin HB, Dick W, et al. Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. J Bone Miner Res. 2003;18(2):343-51. [pmid: 12568412].
166 Kärkkäinen MK, Tuppurainen M, Salovaara K, et al. Does daily vitamin D 800 IU and calcium 1000 mg supplementation decrease the risk of falling in ambulatory women aged 65-71 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas. 2010;65(4):359-65. [pmid: 20060665].
167 Chlebowski RT, Johnson KC, Kooperberg C, et al. Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. 2008;100(22):1581-91. [pmid: 19001601].
168 Wactawski-Wende J, Kotchen JM, Anderson GL, et al. Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006;354(7):684-96. [pmid: 16481636].
169 De Boer IH, Tinker LF, Connelly S, et al. Calcium plus vitamin D supplementation and the risk of incident diabetes in the Women's Health Initiative. Diabetes Care. 2008;31(4):701-7. [pmid: 18235052].
170 Arvold DS, Odean MJ, Dornfeld MP, et al. Correlation of symptoms with vitamin D deficiency and symptom response to cholecalciferol treatment: a randomized controlled trial. Endocr Pract. 2009;15(3):203-12. [pmid: 19364687].
171 Kjaergaard M, Waterloo K, Wang CE, et al. Effect of vitamin D supplement on depression scores in people with low levels of serum 25-hydroxyvitamin D: nested case-control study and randomised clinical trial. Br J Psychiatry. 2012;201(5):360-8. [pmid: 22790678].
172 Williams DA, Arnold LM. Measures of fibromyalgia: Fibromyalgia Impact Questionnaire (FIQ), Brief Pain Inventory (BPI), Multidimensional Fatigue Inventory (MFI-20), Medical Outcomes Study (MOS) Sleep Scale, and Multiple Ability Self-Report Questionnaire (MASQ). Arthritis Care Res. 2011;63(S11):S86-S97.
173 Freiberger E, de Vreede P, Schoene D, et al. Performance-based physical function in older community-dwelling persons: a systematic review of instruments. Age Ageing. 2012;41(6):712-21. [pmid: 22885845].
174 Aloia JF, Patel M, Dimaano R, et al. Vitamin D intake to attain a desired serum 25-hydroxyvitamin D concentration. Am J Clin Nutr. 2008;87(6):1952-8. [pmid: 18541590].
175 Aloia JF, Talwar SA, Pollack S, et al. A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. 2005;165(14):1618-23. [pmid: 16043680].
176 Harris SS, Dawson-Hughes B, Perrone GA. Plasma 25-hydroxyvitamin D responses of younger and older men to three weeks of supplementation with 1800 IU/day of vitamin D. J Am Coll Nutr. 1999;18(5):470-4. [pmid: 10511329].
177 Talwar SA, Aloia JF, Pollack S, et al. Dose response to vitamin D supplementation among postmenopausal African American women. Am J Clin Nutr. 2007;86(6):1657-62. [pmid: 18065583].
178 Berlin T, Emtestam L, Bjorkhem I. Studies on the relationship between vitamin D3 status and urinary excretion of calcium in healthy subjects: effects of increased levels of 25-hydroxyvitamin D3. Scand J Clin Lab Invest. 1986;46(8):723-9. [pmid: 3026026].
179 Martineau AR, Wilkinson RJ, Wilkinson KA, et al. A single dose of vitamin D enhances immunity to mycobacteria. Am J Respir Crit Care Med. 2007;176(2):208-13. [pmid: 17463418].
180 Fortmann SP, Burda BU, Senger CA, et al. Vitamin and mineral supplements in the primary prevention of cardiovascular disease and cancer: an updated systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;159(12):824-34. [pmid: 24217421].
181 Michael YL, Whitlock EP, Lin JS, et al. Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(12):815-25. [pmid: 21173416].
182 Lappe JM, Travers-Gustafson D, Davies KM, et al. Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. 2007;85(6):1586-91. [pmid: 17556697].
183 Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005;365(9471):1621-8. [pmid: 15885294].
184 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. Br Med J (Clin Res Ed). 2003;326(7387):469.
185 Wallace RB, Wactawski-Wende J, O'sullivan MJ, et al. Urinary tract stone occurrence in the Women's Health Initiative (WHI) randomized clinical trial of calcium and vitamin D supplements. Am J Clin Nutr. 2011;94(1):270-7. [pmid: 21525191].
186 Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(02):138-44. [pmid: 22559755].
187 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005;58(8):769-76. [pmid: 16086467].
188 Ott SM, Chesnut CH 3rd. Calcitriol treatment is not effective in postmenopausal osteoporosis. Ann Intern Med. 1989;110(4):267-74. [pmid: 2913914].
189 Orwoll ES, McClung MR, Oviatt SK, et al. Histomorphometric effects of calcium or calcium plus 25-hydroxyvitamin D3 therapy in senile osteoporosis. J Bone Miner Res. 1989;4(1):81-8. [pmid: 2718782].
190 Mastaglia SR, Mautalen CA, Parisi MS, et al. Vitamin D2 dose required to rapidly increase 25OHD levels in osteoporotic women. Eur J Clin Nutr. 2006;60(5):681-7. [pmid: 16391587].
191 Bischoff-Ferrari HA, Dawson-Hughes B, Platz A, et al. Effect of high-dosage cholecalciferol and extended physiotherapy on complications after hip fracture: a randomized controlled trial. Arch Intern Med. 2010;170(9):813-20. [pmid: 20458090].
192 Prince RL, Austin N, Devine A, et al. Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 2008;168(1):103-8. [pmid: 18195202].
193 Zhu K, Bruce D, Austin N, et al. Randomized controlled trial of the effects of calcium with or without vitamin D on bone structure and bone-related chemistry in elderly women with vitamin D insufficiency. J Bone Miner Res. 2008;23(8):1343-8. [pmid: 18410225].
194 Latham NK, Anderson CS, Lee A, et al. A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc. 2003;51(3):291-9. [pmid: 12588571].
195 Gloth FM 3rd, Smith CE, Hollis BW, et al. Functional improvement with vitamin D replenishment in a cohort of frail, vitamin D-deficient older people. J Am Geriatr Soc. 1995;43(11):1269-71. [pmid: 7594162].
196 Corless D, Dawson E, Fraser F, et al. Do vitamin D supplements improve the physical capabilities of elderly hospital patients?. Age Ageing. 1985;14(2):76-84. [pmid: 4003187].
197 Davidson MB, Duran P, Lee ML, et al. High-dose vitamin D supplementation in people with prediabetes and hypovitaminosis D. Diabetes Care. 2013;36(2):260-6. [pmid: 23033239].
198 Witham MD, Crighton LJ, Gillespie ND, et al. The effects of vitamin D supplementation on physical function and quality of life in older patients with heart failure: a randomized controlled trial. Circ Heart Fail. 2010;3(2):195-201. [pmid: 20103775].
199 Schleithoff SS, Zittermann A, Tenderich G, et al. Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial. Am J Clin Nutr. 2006;83(4):754-9. [pmid: 16600924].
200 Martineau AR, Timms PM, Bothamley GH, et al. High-dose vitamin D(3) during intensive-phase antimicrobial treatment of pulmonary tuberculosis: a double-blind randomised controlled trial. Lancet. 2011;377(9761):242-50. [pmid: 21215445].
201 Manson JE, Bassuk SS, Lee IM, et al. The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 2012;33(1):159-71. [pmid: 21986389].