# DISCUSSION

## Summary of Review Findings

The findings of this report are summarized in Table 5. We did not find any studies that directly examined whether screening for vitamin D deficiency resulted in improved health outcomes or harms. While the evidence on the effects of vitamin D treatment in populations with low 25(OH)D levels was available, it had limitations. For example, we identified only two good-quality studies,156,171 relatively few trials evaluated clinical outcomes, and many studies reported few events or were otherwise underpowered to evaluate clinical outcomes. Additionally, studies were mostly conducted in white women, and factors that may influence risk for deficiency, such as BMI and UV light exposure, were often not reported. No study specifically evaluated effects of treatment in participants with screen-detected vitamin D deficiency.

Table 5 Summary of Evidence

Number and Type of Studies | Overall Quality | Limitations | Consistency | Applicability | Summary of Findings
Key Question 1. Is there direct evidence that screening for vitamin D deficiency results in improved health outcomes? Key Question 1a. Are there differences in screening efficacy between patient subgroups (subgroups defined by risk factors for vitamin D deficiency, such as age ≥65 years, sex, race/ethnicity, body mass index, ultraviolet light exposure, and institutionalized status)?
No studies | NA | NA | NA | NA | NA
Key Question 2. What are the harms of screening?
No studies | NA | NA | NA | NA | NA
Key Question 3. Does treatment of vitamin D deficiency with vitamin D lead to improved health outcomes?
17 studies RCTs, nested case-control studies | Fair | Few studies addressed each outcome; many studies reported few events or were underpowered; variability in baseline 25(OH)D levels, doses of vitamin D treatment, use of calcium cosupplementation, and length of followup | Moderate | Studies mostly conducted in older white U.S. or European women | - Vitamin D treatment (with or without calcium) was associated with a decreased risk for mortality (11 studies; pooled RR, 0.83 [95% CI, 0.70 to 0.99]); risk reduction limited to studies of older, institutionalized persons (3 trials; pooled RR, 0.72 [95% CI, 0.56 to 0.94]); - Vitamin D treatment was not associated with decreased risk for falling (5 studies; pooled RR, 0.84 [95% CI, 0.69 to 1.02]), but was associated with a lower rate of falls per individual (pooled rate ratio, 0.66 [95% CI, 0.50 to 0.88]); - Vitamin D treatment was not associated with a decreased fracture risk (5 studies; pooled RR, 0.98 [95% CI, 0.82 to 1.16]); - Limited (≤2 studies) data on cancer risk, type 2 diabetes risk, psychosocial functioning, disability, and physical functioning, but generally no associations with vitamin D treatment were seen
Key Question 3a. Are there differences in efficacy between patient subgroups (subgroups defined by risk factors for vitamin D deficiency, such as age ≥65 years, sex, race/ethnicity, body mass index, ultraviolet light exposure, and institutionalized status)?
No studies | NA | NA | NA | NA | NA
Key Question 4. What are the adverse effects of treatment of vitamin D deficiency with vitamin D?
24 studies^*^ RCTs, cohorts | Fair | Few studies prespecified harms outcomes; studies were not designed to address harms; variability in baseline 25(OH)D levels, doses of vitamin D treatment, use of calcium cosupplementation, and length of followup | High | Only 7 studies were conducted in the U.S. and only 3 of these U.S. studies reported populations having a significant percentage of nonwhite participants | Vitamin D treatment (with or without calcium) was not associated with increased adverse events
Key Question 4a. Are there differences in adverse effects between patient subgroups (subgroups defined by risk factors for vitamin D deficiency such as age ≥65 years, sex, race/ethnicity, body mass index, ultraviolet light exposure, and institutionalized status)?
No studies | NA | NA | NA | NA | NA

* Includes two poor-quality trials.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized, controlled trial; RR = risk ratio.

Of 11 studies that examined the association between vitamin D_3_ treatment and mortality, only a nested case-control analysis within the WHI CaD trial152 was designed to assess mortality risk associated with vitamin D_3_ supplementation. While no individual study found that vitamin D_3_ treatment was associated with decreased risk for mortality versus control conditions, the number of deaths in most studies was low. When results were pooled, however, vitamin D_3_ treatment was associated with a slight but significant decrease in risk for mortality in persons with 25(OH)D levels of 30 ng/mL or less. Benefits were no longer seen when we excluded trials of institutionalized persons (8 studies; RR, 0.93 [95% CI, 0.73 to 1.18]). Some,58,93 but not all,45 recent systematic reviews that included studies of persons with and without deficiency have concluded that supplementation in older persons (mainly women) seems to slightly reduce all-cause mortality.

Vitamin D treatment was associated with a nonsignificant reduction in the risk for experiencing one or more falls and a significantly reduced overall burden of falls, as measured by the number of falls per individual. Four trials examined both risk for falling and rate of falls per person.162,163, 165,166 Risk estimates were similar in three of these trials.162,163,166 In the fourth trial, the rate ratio for falls per person (primary outcome of this trial) was lower than the risk for experiencing at least one fall (0.46 [95% CI, 0.28 to 0.76] and 0.75 [95% CI, 0.41 to 1.37], respectively).165 This trial was conducted in an institutionalized population with a high comorbidity burden, and its results could account for the potential discrepancy between the pooled falls outcome estimates.

Vitamin D_3_ treatment was not associated with decreased risk for fracture in vitamin D–deficient persons. Data were limited (≤2 studies) on its effect on cancer risk, type 2 diabetes risk, psychosocial functioning, disability, and physical functioning in persons with 25(OH)D levels of 30 ng/mL or less. We did not find that baseline 25(OH)D level, vitamin D dosage, or duration of followup influenced results. No trials evaluating how vitamin D treatment affected risk for cardiovascular disease or immune disease met inclusion criteria. Recent (2014) systematic reviews that included studies of persons with and without deficiency concluded that vitamin D supplementation did not favorably affect the health outcomes of cardiovascular disease, diabetes, cancer, falls, or fracture outcomes.45,58

Vitamin D (D_3_ or D_2_) treatment did not appear to be associated with harms, although few trials were designed to specifically address harms, and adverse event reporting was often suboptimal. Given the variability of the 25(OH)D assay, there is the potential for misclassification that could lead to unnecessary vitamin D treatment and mislabeling. Most misclassification, however, is likely to occur near the cutoff for sufficiency, so individuals with very low or very high 25(OH)D levels were probably classified correctly.

Our findings are generally consistent with previous evidence reviews for the USPSTF of vitamin D supplementation in populations not known to be deficient. A 2013 evidence review conducted by Fortmann and colleagues180 included three trials on the effects of vitamin D supplementation (with or without calcium) on mortality in noninstitutionalized populations. We excluded all of these trials from our review because they did not measure 25(OH)D levels in all participants at baseline. None of the three trials found that vitamin D supplementation (with or without calcium) was associated with decreased mortality risk. The USPSTF concluded that the evidence on the effects of vitamin D supplementation (alone or with other vitamins) on mortality risk was insufficient to make a recommendation.

A 2011 systematic review and meta-analysis by Chung and colleagues70 examined 16 studies of the association between vitamin D supplementation (with or without calcium) and fracture risk. Because the review did not require that populations be vitamin D deficient, we excluded 12 of these studies from our review. Chung and colleagues concluded that vitamin D combined with calcium (but not vitamin D alone) could reduce fracture risk, particularly in institutionalized elderly persons.70 The USPSTF recommended against low-dose supplementation with vitamin D (≤400 IU) and calcium (≤1,000 mg) to reduce fracture risk in noninstitutionalized populations and concluded that the evidence on the effects of higher doses was insufficient to make a recommendation.3

A 2010 systematic review by Michael and colleagues181 examined nine trials evaluating the association between vitamin D supplementation (without or without calcium) and fall risk. We excluded six of these trials because they did not examine a known deficient population or examined persons at high risk for falls. We included three studies not in the previous review, two because they were published after that review136,166 and one165 because the population was institutionalized and the 2010 review examined only noninstitutionalized populations. Michael and colleagues concluded that vitamin D supplementation (with or without calcium) was associated with a reduced risk for falling. The USPSTF recommended that vitamin D supplementation be given to community-dwelling adults age 65 years or older who are at increased risk for falls, regardless of 25(OH)D status.1

Two systematic reviews (in 2011 and 2013) examined whether vitamin D supplementation with or without calcium was associated with cancer risk.70,180 The four trials included in these prior systematic reviews were excluded from our review because the study populations, including that from the full WHI CaD trial, were not known to have low 25(OH)D levels.146,182-184 The authors of the most recent systematic review concluded that vitamin D and/or calcium supplementation showed no overall effect on cancer.180 The USPSTF concluded that the evidence was insufficient to make a recommendation.

Previous systematic reviews on the effects of vitamin D and calcium supplementation on fractures, falls, and cancer in general populations (not selected for deficiency) found that adverse event rates were generally low in both treatment and placebo groups.70,180,181 The systematic reviews noted that the WHI CaD trial found a significantly increased risk for harm: a 17-percent increased risk for kidney stones in persons randomized to supplementation with 400 IU of vitamin D and 1,000 mg calcium per day (participants were also allowed to take up to 1,000 IU of vitamin D and 1,000 mg calcium per day on their own). We did not include this evidence, however, because the reviews derived harms data from persons with unknown vitamin D status. Harms were not reported for the subgroup with 25(OH)D levels from the WHI case-control analyses.185

## Limitations of Review Methods

We excluded non–English-language articles, which could result in language bias. Some studies, however, have found empirical evidence that restricting systematic reviews of noncomplementary medicine intervention to English-language studies has little effect on the conclusions.186,187 We did not search for studies published only as abstracts and could not formally assess for publication bias with graphical or statistical methods because we identified only small numbers of studies for each key question. We included the WHI nested case-control studies in the pooled trials, as the event rates were low enough (≤11%) that the ORs could be expected to estimate the rate ratio. In sensitivity analyses, results were unchanged when we excluded the WHI case-control analyses and when we calculated ORs for all of the studies before pooling. Some pooled analyses were based on small numbers of studies or were characterized by the presence of statistical heterogeneity. Stratification further reduced the number of studies in the pooled analyses. In such cases, CIs may be too narrow. As a result, these results should be interpreted cautiously. We also conducted sensitivity analyses based on the profile likelihood method, which did not affect conclusions.

For key questions 3 and 4, our goal was to examine the effects of vitamin D treatment in populations similar to those that would be identified through a screening program. Therefore, we did not include studies that targeted populations for which vitamin D might be considered a treatment option or with particular medical conditions, even if the participants had low 25(OH)D levels. Based on these criteria, we excluded trials that required participants to have osteoporosis or osteopenia (4 studies),188-191 risk factors for falls (5 studies),194-196 prediabetes (1 study),197 heart failure (2 studies),198,199 or tuberculosis (1 study).200 The findings from these studies of selected populations were similar to our overall results. Vitamin D treatment did not reduce risk for experiencing a compression fracture in vitamin D–deficient persons with a history of a compression fracture.188 The effects of vitamin D treatment on fall risk and functional status or physical performance were mixed. Vitamin D treatment did not reduce fall risk in persons with vitamin D deficiency who had recently suffered a hip fracture191 or who had one or more health problems or functional limitations at admission to a geriatric rehabilitation center;194 however, vitamin D treatment reduced falls in vitamin D–deficient populations with a history of falls.192 Although community-dwelling homebound persons experienced an improvement in functional status with vitamin D treatment,195 long-term inpatients and those in a rehabilitation center with health problems or functional limitations did not experience an improvement in physical functioning or the ability to complete activities of daily living with vitamin D treatment.194,196 In one trial, risk for diabetes was not reduced when vitamin D treatment was given to persons with prediabetes who had low 25(OH)D levels.197

## Limitations in the Evidence

We identified no direct evidence on the effect of vitamin D screening on health outcomes. The evidence on clinical outcomes associated with vitamin D treatment in deficient populations was relatively limited. Data on adverse events was not highly reliable because most trials were not designed to assess harms and had suboptimal adverse event reporting. No study examined the effects of vitamin D treatment according to subgroups defined by race, age, or sex. In fact, few studies were conducted in populations other than white females of European descent. While we attempted to examine age and institutionalized status through sensitivity analyses, such sensitivity analyses are not as strong as subgroup analyses within studies. No study specifically evaluated the effect of treatment for screen-detected vitamin D deficiency, potentially limiting applicability to screening settings. There was variability in baseline 25(OH)D levels, the dosages used, the use of calcium cosupplementation, and duration of followup, all of which could have contributed to heterogeneity.

The effects of variability in vitamin D assays were difficult to assess, given the lack of a reference standard with which to estimate sensitivity, specificity, and other diagnostic parameters. In general, differential classification due to assay variability is likely to affect persons close to the threshold used to define vitamin D deficiency. In studies of treatment of vitamin D deficiency, the expected effect of misclassification would be to attenuate estimates of treatment benefit, as some persons who are not vitamin D deficient would be classified and treated as such. These persons would therefore be subject to unnecessary treatment and any associated harms.

For the WHI CaD trial, the largest trial, we included only the results of the nested case-control studies in which 25(OH)D levels were measured. Statistical power was limited for many of these stratified analyses. The results for the overall WHI CaD trial, however, were similar to those for the nested case-control studies; vitamin D supplementation did not significantly reduce risk for death, colorectal or breast cancer, or fractures.146,152,164,167-169 We were not able to include harm outcomes from the WHI CaD trial because they were not stratified by 25(OH)D status. The WHI CaD trial found an increased risk for kidney stones in women with unknown 25(OH)D status who were randomized to vitamin D and calcium supplementation.

## Emerging Issues and Next Steps

A trial of vitamin D screening in a diverse population would be the ideal way to answer the question of whether vitamin D screening leads to benefits or harms. Before such a trial can be conducted, however, the best method for measuring and defining vitamin D deficiency needs to be determined. A recent study noted that while total 25(OH)D levels were lower in blacks than whites, the level of bioavailable 25(OH)D was similar.115 However, this is only one study, and the results require replication. This study highlights the need for ongoing research to examine the most accurate way to measure vitamin D deficiency, especially in nonwhite populations.

In addition, there is a lack of consensus on what level of 25(OH)D (<20 vs. <30 ng/mL) defines deficiency. While the IOM contends that 25(OH)D concentrations of at least 20 ng/mL30 are optimal, other expert bodies, including the Endocrine Society, National Osteoporosis Foundation, and International Osteoporosis Foundation, recommend 25(OH)D levels of greater than 30 ng/mL.13,31-34 Our survey of the literature on the association between 25(OH)D levels and outcomes (Appendix A1) found that data are still lacking about the levels associated with various health outcomes. Therefore, we stratified the results for key questions 3 and 4 according to the level of 25(OH)D in the population of study (<20 vs. ≤30 ng/mL). We did not find a clear difference in outcomes by baseline 25(OH)D level.

## Relevance for Priority Populations

Certain patient subgroups appear to be at increased risk for vitamin D deficiency, including those with low UV light exposure, high BMI, and dark skin pigmentation. In addition, beneficial effects of vitamin D treatment on mortality and falls risk were primarily observed in older (e.g., age >70 years) and/or institutionalized populations that were mainly female. Determining whether screening these high-risk populations for vitamin D deficiency would result in benefit or harm remains a critical issue. No screening studies have been conducted, however, and few trials have examined the benefits and harms of vitamin D treatment in these patient subgroups.

## Future Research

Future trials of vitamin D treatment should measure 25(OH)D levels and be powered to examine effects in deficient subgroups. Trials of clinical outcomes should be adequately powered and of sufficient length to detect clinically important effects. Future trials should focus on persons at higher risk and those in understudied groups. Researchers should use state-of-the-science assay methods that have acceptable performance characteristics, are comparable to currently available reference standards, and are conducted in laboratories participating in quality assurance programs. Future studies should examine vitamin D treatment alone and vitamin D treatment combined with calcium to separate the beneficial and harmful effects of these two nutrients.

An ongoing trial, the Vitamin D and Omega-3 Trial, is designed to address many of these issues.201 This large randomized, double-blind, placebo-controlled trial examines the effects of 5 years of supplementation with 2,000 IU per day of vitamin D_3_ for the primary prevention of cancer and cardiovascular disease in a multiethnic population of 20,000 U.S. men age 50 years or older and women age 55 years or older. The researchers estimate that about 16,000 participants will have baseline 25(OH)D levels measured. Results are expected in 2017.

## Conclusions

In conclusion, no study directly examined the benefits and harms of screening for vitamin D deficiency. Treatment of vitamin D deficiency with vitamin D may be associated with decreased risk for mortality in institutionalized elderly persons and a reduction in the average number of falls. More research is needed to reduce assay variability, determine appropriate thresholds for vitamin D deficiency, clarify the effects of screening, define the subsequent treatment, and identify the subpopulations most likely to benefit.