# RESULTS

## Key Question 1 Is There Direct Evidence That Screening for Vitamin D Deficiency Results in Improved Health Outcomes?

We found no study that addressed this key question.

## Key Question 2 What Are the Harms of Screening?

We found no study that addressed this key question.

## Key Question 3 Does Treatment of Vitamin D Deficiency With Vitamin D Lead to Improved Health Outcomes?

### Summary

Eleven studies examined the effect of vitamin D treatment on mortality,120,122,152-160 five examined fractures,122,161-164 six examined falls,122,136,162,163,165,166 one examined cancer,167,168 two examined type 2 diabetes,136,169 two examined psychosocial functioning and disability,170,171 and one examined physical functioning.155 While vitamin D treatment was associated with decreased risk for mortality compared with placebo/no treatment (pooled RR, 0.83 [95% CI, 0.70 to 0.99]; I^2^=0%; 11 studies), these studies were not designed to assess mortality.120,122,152-160 Additionally, the benefits of vitamin D treatment were confined to trials of elderly institutionalized participants with high mortality rates.120,122,154 The reduction was no longer significantly reduced when we examined only noninstitutionalized populations (RR, 0.93 [95% CI, 0.73 to 1.18]; I^2^=0%; 8 studies).152,153,155-158 Vitamin D treatment was not associated with decreased risk for fracture (pooled RR, 0.98 [95% CI, 0.82 to 1.16]; I^2^=32%; 5 studies).122,161-164 Falls data were mixed: while vitamin D treatment was not associated with decreased risk for experiencing a fall (pooled RR, 0.84 [95% CI, 0.69 to 1.02]; I^2^=70%; 5 trials),122,162,163,165,166 our primary fall endpoint, vitamin D treatment was associated with a decreased number of falls per individual (pooled rate ratio, 0.66 [95% CI, 0.50 to 0.88]; I^2^=65%; 5 trials).136,162,163,165,166 We found limited data (≤2 studies) on the effect of vitamin D treatment on cancer risk, type 2 diabetes risk, psychosocial functioning, disability, and physical functioning.

### Evidence

We identified 16 trials and one nested case-control study that evaluated the effects of vitamin D treatment (with or without calcium) on health outcomes in vitamin D–deficient populations (Table 2 and Appendixes C1 and C2). Seven of these studies were conducted in populations in which at least 90 percent of participants had 25(OH)D levels of less than 20 ng/mL122,155,157-160,162 and 10 in populations in which at least 90 percent of participants had levels of 30 ng/mL or less (but at least 10% had levels of ≥20 ng/mL).120,136,152-154,156,161,163-171 Eleven studies examined the effect of vitamin D treatment on mortality,120,122,152-160 five examined effects on fracture,122,161-164 six examined effects on falls,122,136,162,163,165,166 one examined effects on cancer,167,168 two examined effects on type 2 diabetes,136,169 two examined effects on psychosocial functioning and disability,170,171 and one examined effects on physical functioning.155 The mean age of the participants ranged from 37 to 85 years, and 40 to 100 percent were female. Mean BMIs ranged from 24 to 36 kg/m^2^. The included studies were population-based or were conducted within outpatient clinics, academic institutions, and nursing or residential homes for the elderly (considered institutionalized) in the United States or Europe. UV light exposure was not well quantified in any study. Only six136,146,152,156, 159,160,164,167-170 of 17 studies reported race. One study comprised 100 percent African Americans.160 In the remaining studies reporting race, 83 to 100 percent of participants were white. Studies examined vitamin D_3_ at dosages ranging from 400 to 4,800 IU per day to 8,400 to 50,000 IU per week. Five studies examined vitamin D_3_ treatment coadministered with calcium (1,000 to 1,200 mg per day) and 12 examined vitamin D_3_ treatment alone. Study duration ranged from 2 months to 7 years. To measure 25(OH)D levels in participants, four studies used competitive protein binding,120,122,154,157,161 eight used immunoassay methods,146,153,156,159,160,162,163,165,166 one used HPLC,155 and four used LC-MS/MS.136,158,170,171 Two trials used laboratories that were participating in an external accuracy-based testing system (DEQAS).155,156

Table 2 Studies of Effectiveness of Vitamin D Treatment

Author, Year Quality | Country | Population Characteristics^*^ | 25(OH)D Level at Baseline (ng/mL)^*,†^ (Vitamin D vs. Control) | 25(OH)D Level at Followup (ng/mL)^*,†^ (Vitamin D vs. Control) | Interventions | Duration^*^ | Clinical Health Outcomes Reported
25(OH)D level <20 ng/mL^‡^
Brazier et al, 2005^157^ Fair | France | Analyzed: 191 Age (years): 74.6 Female: 100% Comorbidities: NR History of falls: NR Institutionalized: 0% | 7 vs. 7 | Median: 29 vs. 11 | [underlined: Vitamin D (n=95):] 800 IU vitamin D_3_ and 1000 mg calcium daily [underlined: Control (n=97):] Placebo | 12 months | Mortality
Chapuy et al, 2002^122^ Fair | France | Analyzed: 583 Age (years): 85 Female: 100% Comorbidities: NR History of falls: 16.1% Use of walking device: 40.7% Institutionalized: 100% | 9 vs. 9 | ∼33 vs. 5 (from figure); p=0.0001 for change from baseline for vitamin D group only | [underlined: Vitamin D (n=393):] 800 IU of vitamin D_3_ and 1200 mg calcium daily [underlined: Control (n=190):] Placebo | 24 months | Fractures (primary outcome) Fallers Mortality
Gallagher et al, 2013^160^ Fair | United States | Analyzed: 110 Age (years): 67 Female: 100% BMI (kg/m^2^): 32.7 Comorbidities: NR History of falls: NR Institutionalized: NR | Placebo: 14 Vitamin D 800 IU: 14 1600 IU: 13 2400 IU: 14 4800 IU: 14 NR for 400, 3600, or 4000 IU groups | 97.5% (from figure) of those using vitamin D 800 IU reached serum 25(OH)D >20 ng/mL; p<0.05 vs. placebo for all vitamin D groups | [underlined: Vitamin D:] 400, 800, 1600, 2400, 3200, 4000, or 4800 IU of vitamin D_3_ daily [underlined: Control:] Placebo All participants supplemented to maintain total calcium intake of 1200 to1400 mg/day | 12 months | Mortality^§^
Gallagher et al, 2014^159^ Fair | United States | Analyzed: 198 Age (years): 37 Female: 100% BMI (kg/m^2^): 30.2 Comorbidities: NR History of falls: NR Institutionalized: NR | Placebo: 13 Vitamin D 400 IU: 13 800 IU: 14 1600 IU: 13 2400 IU: 14 | 97.5% (from figure) of white women using vitamin D 400 IU reached serum 25(OH)D >20 ng/mL; 97.5% of black women using vitamin D 800 to 1600 IU reached serum 25(OH)D >20 ng/mL | [underlined: Vitamin D:] 400, 800, 1600, or 2400 IU of vitamin D_3_ daily [underlined: Control:] Placebo All participants supplemented to maintain total calcium intake of 1000 to 1200 mg/day | 12 months | Mortality^§^
Grimnes et al, 2011^158^ Fair | Norway | Analyzed: 104 Age (years): 52.1 (51.5 vs. 52.7) Female: 49.1% (45% vs. 51%) BMI (kg/m^2^): 26.5 (27.2 vs. 26.3) History of falls: NR Institutionalized: 0% | 17 vs. 16 | 57 vs. 17 | [underlined: Vitamin D (n=51):] 40,000 IU of vitamin D_3_ weekly [underlined: Control (n=52):] Placebo | 6 months | Mortality
Lips et al, 2010^155^ Fair | The Netherlands, Germany, United States | Analyzed: 213 for SPPB; 226 for mortality Age (years): 78 Female: NR BMI (kg/m^2^): 27.8^†^ Comorbidities: NR History of falls: NR Use of walking device: 15% Institutionalized: 14% | 14 vs. 14 | 26 vs. 12; p<0.001 | [underlined: Vitamin D (n=114):] 8400 IU of Vitamin D_3_ weekly [underlined: Control (n=112):] Placebo Those with daily calcium intake <1000 mg were also given 500 mg calcium | 16 weeks | Physical functioning Mortality
Pfeifer et al, 2000^162^ Fair | Germany | Analyzed: 137 Age (years): 74.8^†^ Female: 100% BMI (kg/m^2^): 25.5^†^ Comorbidities: 39% cardiovascular; 12% central nervous, neurological; <1% psychiatric; 22% musculoskeletal History of falls: NR Use of walking device: NR Institutionalized: 0% | 10 vs. 10 | 26 vs. 17; p<0.001 | [underlined: Vitamin D (n=70):] 800 IU of vitamin D_3_ and 1200 mg of calcium daily [underlined: Control (n=67):] 1200 mg of calcium daily | 8 weeks treatment; 1 year followup | Falls Fallers Fractures
25(OH)D level ≤30 ng/mL^‖^
Arvold et al, 2009^170^ Fair | United States | Analyzed: 90 Age (years): 58.8^†^ Female: 40% BMI: NR Comorbidities: NR History of falls: NR Use of walking device: NR Institutionalized: 0% | 18 vs. 18 | 45 vs. 22 | [underlined: Vitamin D (n=48):] 50,000 IU of vitamin D_3_ weekly [underlined: Control (n=42)]: Placebo | 8 weeks | Psychosocial functioning Disability
Bischoff et al, 2003^165^ Fair | Switzerland | Analyzed: 122 Age (years): 85 Female: 100% BMI (kg/m^2^): 24.7 Comorbidities: 30.3% hypertension, 15.6% stroke, 50.0% myocardial infarction or congestive heart failure, 12.3% anemia, 14.8% diabetes, 8.2% chronic obstructive pulmonary disease, 16.4% peptic ulcer disease, 24.6% depression, 9.0% malnutrition, 4.1% obesity, 54.9% dementia, 54.1% fracture at any site History of falls: 34% Use of walking device: 60% Institutionalized: 100% | Median, 12 vs. 12 | Median, 26 vs. 11; p<0.001 | [underlined: Vitamin D (n=62):] 800 IU of vitamin D_3_ and 1200 mg of calcium daily [underlined: Control (n=60):] 1200 mg calcium daily | 6 weeks pre-treatment; 12 weeks treatment | Falls (primary outcome) Fallers
Gallagher et al, 2012^156^ Good | United States | Analyzed: 163 Age (years): 67 Female: 100% BMI (kg/m^2^): 30.2 Comorbidities: NR History of falls: NR Institutionalized: NR | Placebo: 15 Vitamin D 400 IU: 15 800 IU: 16 1600 IU: 15 2400 IU: 15 3200 IU: 16 4000 IU: 15 4800 IU: 16 | 97.5% (from figure) of those using vitamin D 600 IU reached serum 25(OH)D >20 ng/mL; p<0.05 vs. placebo for all vitamin D groups | [underlined: Vitamin D (n=142):] Either 400, 800, 1600, 2400, 3200, 4000, or 4800 IU of vitamin D_3_ daily [underlined: Control (n=21):] Placebo All participants supplemented to maintain total calcium intake of 1200 to 1400 mg/day | Median, 12 months | Mortality
Kärkkäinen et al, 2010^166^ Kärkkäinen et al, 2010^153^ Fair | Finland | Analyzed: 593 Age (years): 67.4^†^ Female: 100% BMI (kg/m^2^): 27.5^†^ Comorbidities: NR History of falls: NR Ambulatory: 100% Institutionalized: NR | 20 vs. 20 | 30 vs. 22 | [underlined: Vitamin D (n=290][underlined: ¶ and 287]^**^[underlined: ):] 800 IU of vitamin D_3_ and 1000 mg of calcium daily [underlined: Control (n=313][underlined: ¶ and 306]^**^[underlined: ):] No treatment | 3 years | Falls (primary outcome) Fallers Mortality
Kjaergaard et al, 2012^171^ Good | Norway | Analyzed: 230 (per protocol) Age (years): 53.4^†^ Female: 56% BMI (kg/m^2^): 27.7^†^ Comorbidities: NR History of falls: NR Institutionalized: NR | 19 vs. 19 | 59 vs. 21 | [underlined: Vitamin D (n=120):] 20,000 IU of vitamin D_3_ weekly [underlined: Control (n=110):] Placebo | 6 months | Psychosocial functioning (primary outcome)
Krieg et al, 1999^154^ Fair | Switzerland | Analyzed: 248 Age (years): 84.5^†^ Female: 100% BMI (kg/m^2^): 24.7^†^ History of falls: NR Institutionalized: 100% | 12 vs. 12 | 27 vs. 6 | [underlined: Vitamin D (n=124):] 880 IU of vitamin D_3_ and 1000 mg calcium daily [underlined: Control (n=124):] No supplementation | 2 years | Mortality
Lips et al, 1996^161^ Ooms et al, 1995^120^ Fair | The Netherlands | Analyzed: 270 for fracture; 348 for mortality Age (years): 80.4^†^ Female: 100% BMI (kg/m^2^): 28.3^†^ Comorbidities: NR History of falls: NR Use of walking device: NR Institutionalized: 100%^††^ | Median, 11 vs. 10 | Median, 25 vs. 9 (at 1 year) | [underlined: Vitamin D (n=177):] 400 IU of vitamin D_3_ daily [underlined: Control (n=171):] Placebo | 3 to 3.5 years, maximum 4 years | Fractures (primary outcome) Mortality
Pfeifer et al, 2009^163^ Fair | Austria and Germany | Analyzed: 242 Age (years): 76.5 Female: 74.5% BMI (kg/m^2^): 27.3 Comorbidities: NR History of falls: NR Ambulatory: 100% Institutionalized: 0% | 22 vs. 22 | Month 12: 34 vs. 23 Month 20: 19 vs. 15 | [underlined: Vitamin D (n=122):] 800 IU of vitamin D_3_ and 1000 mg of calcium daily [underlined: Control (n=120):] 1000 mg of calcium daily | 12 month treatment; 8 months post-treatment | Falls (primary outcome) Fallers Fractures
Wood et al, 2012^136^ Fair | United Kingdom | Analyzed: 305 Age (years): 63.8^†^ Female: 100% BMI (kg/m^2^): 26.7^†^ History of falls: NR Institutionalized: NR | Vitamin D 400 IU vs. 1000 IU vs. control: 13 vs. 13 vs. 14 | Vitamin D 400 IU vs. 1000 IU vs. control: 26 vs. 30 vs. 13 | [underlined: Vitamin D (n=102 and 101):] 400 or 1000 IU of vitamin D_3_ daily [underlined: Control (n=102):] Placebo | 12 months treatment; 1 month followup | Falls Type 2 diabetes
WHI Calcium with Vitamin D Trial Fair Associated case-control studies with outcome reported: Jackson et al, 2006^164^ (for fractures) Wactawski-Wende et al, 2006^168^ (for colorectal cancer) Chlebowski et al, 2008^167^ (for breast cancer) de Boer et al, 2008^169^ (for diabetes) LaCroix et al, 2009^152^ (for mortality) | United States | Analyzed: 36,282 [underlined: Case-control studies] Fractures: 1491 cases/controls Colorectal cancer: 612 cases/controls Breast cancer: 895 cases/controls Diabetes: 192 cases/2905 controls Mortality: 323 cases/1962 controls [underlined: Entire trial characteristics] Age (years): 62 Female: 100% BMI (kg/m^2^): 29 Race: 83.1% white; 9.1% black; 4.2% Hispanic; 0.42% American Indian or Native American; 2.0% Asian or Pacific Islander; 1.2% unknown or not identified Comorbidities: 35% with previous fracture; 67% with no falls, 20% with 1 fall, 9.0% with 2 falls, 4.0% with >3 falls in past 12 months [underlined: Case-control characteristics] NR | Entire trial: NR [underlined: Case-control studies] Fractures: <24 Colorectal cancer: <23 Breast cancer: <27 Diabetes: <24 Mortality: <21 | Entire trial: After 2 years, in random sample of 1.2% of participants, vitamin D levels were 28% higher (9 ng/mL) in vitamin D vs. placebo group Case-control studies: NR | Vitamin D: 400 IU of vitamin D_3_ + 1000 mg calcium daily Control: Placebo [underlined: Number analyzed in case-control studies per intervention (vitamin D vs. control)] Fractures: 266 vs. 285 Colorectal cancer: 237 vs. 222 Breast cancer: 909 vs. 722 Diabetes: 1118 vs. 1187 Mortality: 675 vs. 678 | 7 years | Fractures Mortality Type 2 diabetes Cancer

* Reported as means, unless otherwise noted.

† Calculated.

‡ ≥90% of study participants had 25(OH)D levels <20 ng/mL.

§ As per author correspondence.

‖ ≥90% of study participants had 25(OH)D levels ≤30 ng/ml, with ≥10% with 25(OH)D levels ≥20 ng/mL.

¶ For mortality outcomes.

** For falls/fallers outcomes.

†† Received care, but not as much as in a nursing home.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; BMI = body mass index; NR = not reported; SPPB = Short Physical Performance Battery.

Two trials were rated good quality156,171 and 15 were rated fair quality120,122,127,136,146,153-155,157-167, 170 (Appendix C3). Methodological shortcomings in the fair-quality studies frequently included the unclear use of adequate randomization and allocation concealment methods and/or masking of outcome assessors, providers, or participants. Some studies also reported high attrition (>20%).

The WHI CaD trial was the largest study (N=36,282).146,152,164,167-169 The results of the overall trial were not included in this evidence review because baseline levels of 25(OH)D were not measured in all participants. Instead, we included the results reported for the subset of trial participants with low 25(OH)D levels, reported in several case-control studies. We quality rated the overall trial because the case-control studies were based on women originally randomized to the main WHI CaD trial (Table 2 and Appendixes C2 and C3). We rated this trial as fair quality, primarily because of a potential lack of intervention fidelity. Participants in both intervention groups were allowed off-protocol supplementation of up to 600 IU per day of vitamin D initially and up to 1,000 IU per day from 1999 onward. Six years into the trial, off-protocol vitamin D use was reported by 52 percent of participants.167 Despite this finding, those assigned to vitamin D supplementation had a 28-percent higher 25(OH)D level than those taking placebo in a random subsample of 1.2 percent of the study population at the end of year 2.^164^ The baseline characteristics of the cases and controls in the WHI CaD subanalyses were also not provided, although study intervention and placebo participants had similar baseline characteristics in the overall trial.

#### Effects of Vitamin D Treatment on Mortality

One good-quality trial, nine fair-quality trials, and one fair-quality nested case-control study examined the effect of vitamin D_3_ treatment on mortality in vitamin D–deficient populations (N=4,126).120,122,154,155,157,161 Five studies were conducted in populations with a mean age older than 70 years,120,122,154,155,157,161 three trials specifically focused on older (age >80 years) women in nursing or elderly homes,120,122,154 and one trial specifically focused on younger (age ≥45 years) women.159 No study had death as a primary outcome.

No individual study reported a statistically significant reduction in mortality in participants randomized to vitamin D_3_ treatment (dosage of 400 IU per day to 40,000 IU per week, with or without calcium) compared with placebo, calcium alone, or no treatment. The estimates in some trials were extremely imprecise, however, because of very few events.153,155-160 In four studies that reported at least 10 events, RR estimates ranged from 0.51 to 0.90.^120,122,152,154^ When data were combined for all studies, vitamin D_3_ treatment (with or without calcium) was associated with decreased risk for mortality versus placebo/no treatment (pooled RR, 0.83 [95% CI, 0.70 to 0.99]; I^2^=0%; Figure 2). Studies reported an absolute risk difference that ranged from a reduction of 6 percentage points to an increase of 2 percentage points with vitamin D_3_ treatment (with or without calcium) versus placebo/no treatment.

Figure 2 Meta-Analysis of Effects of Vitamin D Treatment on Mortality

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

‡ Included an institutionalized population.

§ This is a nested case-control study from the Women's Health Initiative Calcium with Vitamin D Trial.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 2 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on mortality. The figure shows that none of the included studies reporting on mortality demonstrates a statistically significant effect on mortality on its own. The figure also shows that when data from all 11 studies reporting on mortality are combined, treatment with vitamin D3 was associated with a decreased risk of mortality versus placebo or no treatment.

These results should be interpreted with caution. While the CI was very close to 1, mortality was not the primary outcome in any study and was usually not a prespecified outcome. In addition, in the only good-quality trial, a U.S. vitamin D treatment dose-response trial of 400 to 4,800 IU per day of vitamin D_3_ treatment in 163 vitamin D–deficient (≤20 ng/mL) white postmenopausal women with a mean age of 67 years, no deaths were observed in any group after 12 months.156 The largest study (n=2,185), a case-control study nested within the WHI CaD trial, also found no association between randomization to 400 IU per day of vitamin D_3_ with 1,000 mg per day of calcium versus placebo and risk for mortality after 7 years in vitamin D–deficient (<21 ng/mL) postmenopausal women in the United States.152 The two trials with the RR that most suggested a possible benefit of vitamin D treatment on mortality (0.75 [95% CI, 0.54 to 1.05]122 and 0.51 [95% CI, 0.25 to 1.02]120) examined the effects of 400 to 800 IU per day of vitamin D_3_ treatment (with or without calcium) in older (mean age, 80 to 85 years) vitamin D–deficient (≤30 ng/mL) institutionalized European women who experienced high mortality rates (9% to 20%) during followup.120,122 When we analyzed trials of institutionalized and noninstitutionalized persons separately, the risk reduction was limited to studies of older institutionalized persons (pooled RR, 0.72 [95% CI, 0.56 to 0.94]; I^2^=0%; 3 trials; Figure 3); absolute risk reductions ranged from 4 to 6 percentage points.120,122,154 The reduction was no longer significantly reduced when we examined only noninstitutionalized populations (RR, 0.93 [95% CI, 0.73 to 1.18]; I^2^=0%; 8 studies; Figure 3).152,153,155-158 In sensitivity analyses, the reduction in mortality occurred only when studies with more than 12 months duration were pooled and in studies whose population had a mean age older than 70 years. Stratification by baseline 25(OH)D level (<20 vs. ≤30 ng/mL), treatment regimen (vitamin D treatment alone vs. with calcium), or vitamin D dosage (≤400 vs. >400 IU per day) did not affect risk estimates. Excluding the WHI case-control study and pooling ORs instead of RRs did not affect findings.

Figure 3 Meta-Analysis of Effects of Vitamin D Treatment on Mortality by Institutionalized Status

* This is a nested case-control study from the Women's Health Initiative Calcium with Vitamin D Trial.

Abbreviation: CI = confidence interval.

Figure 3 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on mortality when separated by institutionalized status. The figure shows that when 3 studies reporting mortality outcomes in an institutionalized population are combined there is a mortality benefit for use of vitamin D versus placebo or no treatment. Pooling the remaining 8 studies that had noninstitutionalized patients does not show a mortality benefit for vitamin D treatment versus placebo or no treatment.

#### Effects of Vitamin D Treatment on Fracture Risk

Four fair-quality trials and one nested case-control study examined the effects of 2 months to 7 years of treatment with 400 to 800 IU per day of vitamin D_3_ (with or without calcium) on risk for any type of fracture in ambulatory and institutionalized vitamin D–deficient persons (94% women) with mean ages of 62 to 85 years (N=3,551).122,161-164 No individual study reported a statistically significant reduction in fracture risk in those randomized to vitamin D_3_ treatment versus placebo, and the pooled estimate was close to 1 (pooled RR, 0.98 [95% CI, 0.82 to 1.16]; I^2^=32%; Figure 4). This includes the largest study, which was a case-control analysis nested within the WHI CaD trial.164 Stratifying studies by institutionalized status, baseline 25(OH)D level (<20 vs. ≤30 ng/mL), treatment regimen (vitamin D treatment alone vs. with calcium), vitamin D dosage (≤400 vs. >400 IU per day), study duration (≤12 vs. >12 months), and mean age of population (≤70 vs. >70 years) resulted in similar findings of no effect and did not decrease heterogeneity. Neither exclusion of the WHI case-control study nor examination of pooled ORs affected findings.

Figure 4 Meta-Analysis of Effects of Vitamin D Treatment on Any Type of Fracture Risk

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† Included an institutionalized population.

‡ ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

§ This is a nested case-control study from the Women's Health Initiative Calcium with Vitamin D Trial.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 4 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on any type of fracture risk. The figure shows that no study reported a reduction in fracture risk for patients on vitamin D versus placebo or no treatment. The figure shows that when all studies of fracture risk are combined there is no statistical benefit on fractures in those treated with vitamin D versus placebo.

In three trials and one nested case-control study that reported data separately (N=1,619),122,161,162, 164 there was no significant reduction in hip fracture risk with vitamin D_3_ treatment versus placebo in any individual study, and the pooled estimate was close to 1 (pooled RR, 0.96 [95% CI, 0.72 to 1.29]; I^2^=46%; Figure 5). Considering only noninstitutionalized populations did not affect the null findings. Stratification by baseline 25(OH)D level, dosage, study duration, age, and treatment regimen did not change findings and did not decrease heterogeneity. The trial most suggestive of a possible benefit of vitamin D treatment on hip fracture risk was conducted in older institutionalized European women given 800 IU per day of vitamin D_3_ with calcium over 24 months and had a population whose baseline 25(OH)D level was less than 20 ng/mL (RR, 0.62 [95% CI, 0.36 to 1.07]).122

Figure 5 Meta-Analysis of Effects of Vitamin D Treatment on Hip Fracture Risk

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† Included an institutionalized population.

‡ ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

§ This is a nested case-control study from the Women's Health Initiative Calcium with Vitamin D Trial.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 5 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on hip fracture risk. The figure shows that no study showed a statistically significant reduction in hip fracture risk for vitamin D treatment versus placebo. The figure shows that when the 4 studies of hip fracture risk are combined there is no statistical benefit on fractures in those treated with vitamin D versus placebo.

#### Effects of Vitamin D Treatment on Fall Risk

Five fair-quality trials examined the effects of 2 to 36 months of 800 IU per day of vitamin D_3_ treatment (with or without calcium) compared with placebo, no treatment, or calcium alone on the risk for experiencing at least one fall (N=1,677; Table 3).122,162,163,165,166 Although trials did not specifically recruit participants for being at high risk for frailty or because of prior falls, the studies included persons who may have been at risk for falls based on older age (mean age, >70 years),122,162,163,165 institutionalized status,122,165 mobility problems,122,165 or multiple comorbid conditions.122,162,165 In two studies that reported how many patients had prior falls in the past 3 to 6 months, the proportions were 16 and 34 percent.122,165 While the overall summary RR indicated no statistically significant effect on risk for experiencing at least one fall in participants given vitamin D_3_ treatment versus the control intervention (pooled RR, 0.84 [95% CI, 0.69 to 1.02]; Figure 6), heterogeneity was high (I^2^=70%). Trials reported an absolute risk difference that ranged from a reduction of 22 percentage points to an increase of 2 percentage points with vitamin D_3_ treatment (with or without calcium) versus placebo/no treatment.

Table 3 Studies Examining the Association Between Vitamin D Treatment and Falls

Study, Setting, Age^*^ | Fall Risk | Intervention | IRR (95% CI) for Falls per Person | RR (95% CI) for Risk for Falling | Primary Outcome of Study
Bischoff et al, 2003^165^ Institutionalized Age: 85 | 34% with falls 6 weeks prior; 30% of CG fell over 3 months | Vitamin D | 0.46 (0.28 to 0.76) | 0.75 (0.41 to 1.37) | Number of falls per person
Chapuy et al, 2002^122^ Institutionalized Age: 85 | 16% with falls 3 months prior; 62% of CG fell over 24 months | Vitamin D + calcium | NR | 1.03 (0.90 to 1.18) | Fractures
Kärkkäinen et al, 2010^166^ Noninstitutionalized Age: 67 | Fall history NR; 67% of CG fell over 36 months | Vitamin D + calcium | 0.87 (0.77 to 1.00) | 0.93 (0.83 to 1.05) | Occurrence of falls
Pfeifer et al, 2000^162^ Noninstitutionalized Age: 75 | Fall history NR; 28% of CG fell over 12 months | Vitamin D | 0.54 (0.28 to 1.02) | 0.55 (0.29 to 1.08) | Body sway; biochemical measures of bone
Pfeifer et al, 2009^163^ Noninstitutionalized Age: 77 | Fall history NR; 63% of CG fell over 20 months | Vitamin D | 0.63 (0.49 to 0.80) | 0.64 (0.50 to 0.83) | Occurrence of falls
Wood et al, 2012^136^ Noninstitutionalized Age: 64 | Fall history NR; 3 falls among 227 in CG | Vitamin D | 0.67 (0.11 to 4.57) | NR | Reported as adverse event

* Mean age (in years) of study population.

Abbreviations: CG = control group; CI = confidence interval; IRR = incidence rate ratio; NR = not reported; RR = risk ratio.

Figure 6 Meta-Analysis of Effects of Vitamin D Treatment on Falls Risk

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† Included an institutionalized population.

‡ ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

§ The calculated risk ratio is different than the one reported by the study.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 6 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on risk of falls. The figure shows that 1 of the 5 included studies reporting risk for falls showed a statistically significant effect of vitamin D treatment on risk for falls when compared with placebo. The figure shows that when the 5 studies of fall risk are combined there is no statistically significant effect of vitamin D treatment on risk for falls when compared with placebo. The figure also shows that there is a high level of heterogeneity in this meta-analysis.

The only trial that reported a statistically significant effect on risk for falls was a German trial conducted in an ambulatory population (75% women) with 25(OH)D levels of 30 ng/mL or less and a mean age of 77 years (n=242).163 This trial reported that 12 months of 800 IU per day of vitamin D_3_ treatment was associated with a 36-percent reduction in the risk for having at least one fall over 20 months (RR, 0.64 [95% CI, 0.50 to 0.83]), which was the trial's primary outcome. When we stratified trials by institutionalized status, the RRs did not change and heterogeneity remained high. Similarly, stratification of trials according to baseline 25(OH)D level, vitamin D dosage, study duration, and age did not reduce heterogeneity and resulted in similar estimates. Heterogeneity was reduced to zero, however, when we excluded the two trials of cosupplementation with vitamin D and calcium122,166 in order to separately examine the three trials of vitamin D_3_ treatment alone, and there was a significant reduction in risk for experiencing at least one fall (RR, 0.65 [95% CI, 0.52 to 0.81]; I^2^=0%).162,163,165

Five fair-quality trials examined the effect of 400 to 1,000 IU per day of vitamin D_3_ treatment (with or without calcium) on the number of falls per individual (N=1,399, Table 3).136,162,163,165, 166 When the five trials were pooled, vitamin D treatment was associated with a significant reduction in the number of falls per individual compared with placebo (pooled rate ratio, 0.66 [95% CI, 0.50 to 0.88]; I^2^=65%; Figure 7). Although there was statistical heterogeneity, all estimates favored vitamin D treatment. The trial populations were European, mostly female (88%), and had mean ages of 64 to 85 years. Only one trial studied institutionalized persons.165 Excluding this trial did not affect the risk estimate. Stratification by baseline 25(OH)D level, study duration, and age did not change findings and did not decrease heterogeneity. Excluding the one trial that coadministered calcium with vitamin D did not change findings but decreased heterogeneity. Our findings did not change when the analysis was re-run using the profile likelihood random effects model.

Figure 7 Meta-Analysis of Effects of Vitamin D Treatment on the Number of Falls per Person

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

‡ Included an institutionalized population.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval; PY = person-year.

Figure 7 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on the number of falls per individual. The figure shows that 3 of the 5 studies reporting on number of falls per individual reported that vitamin D treatment was associated with a decreased risk of falls per individual when compared with placebo. The figure shows that when the 5 trials reporting on number of falls per individual were pooled vitamin D treatment was associated with a significant reduction in the number of falls per individual compared with placebo.

Four trials examined both risk for falling and rate of falls per person.162,163,165,166 In three of these trials, the risk estimates were similar.162,163,166 In the fourth trial, the rate ratio for falls per person (primary outcome of this trial) was lower than the risk for experiencing at least one fall (0.46 [95% CI, 0.28 to 0.76] and 0.75 [95% CI, 0.41 to 1.37], respectively).165 This trial, conducted in an institutionalized population with a high comorbidity burden, used nurses to record falls, while other trials relied on self-report or did not report how falls were recorded. This trial also had a shorter duration than the other trials (12 weeks vs. ≥12 months). The one trial that examined only risk for falls (not rate of falls) reported no reduced risk for falls in those given vitamin D_3_ treatment with calcium versus placebo (RR, 1.03 [95% CI, 0.90 to 1.18]).122 This trial's primary outcome was risk for fractures, and the method of recording falls was not described. The trial examining only rate of falls (not risk for falls) was conducted in a younger (mean age, 64 years) population in which falls were collected as part of adverse event reporting; few falls were recorded during followup, leading to wide CIs.136

#### Effect of Vitamin D Treatment on Cancer Risk

Effects of 7 years of treatment with 400 IU per day of vitamin D_3_ and calcium on risk for breast cancer (n=909 cases) and colorectal cancer (n=237 cases) in women with low 25(OH)D levels were examined in case-control studies nested within the WHI CaD trial.167,168 Compared with placebo, treatment with vitamin D_3_ and calcium was not associated with a decreased risk for colorectal or breast cancer in women with 25(OH)D levels in the deficiency range (OR, 1.15 [95% CI, 0.58 to 2.27] for <23 vs. ≥23 ng/mL for colorectal cancer and adjusted OR, 0.89 [95% CI, 0.58 to 1.36] for <27 vs. ≥27 ng/mL for breast cancer).167,168

#### Effect of Vitamin D Treatment on Type 2 Diabetes Risk

One fair-quality trial (n=305)136 and one case-control study nested within the WHI CaD trial (n=192 cases)169 examined the effects of treatment with 400 to 1,000 IU per day of vitamin D_3_ (with or without calcium) for 1 to 7 years in mostly (>83%) white, vitamin D–deficient (<30 ng/mL) women with mean ages of 62 to 64 years. Neither study found that vitamin D treatment was associated with reduced risk for developing type 2 diabetes, and the summary RR was close to 1 (pooled RR, 0.93 [95% CI, 0.68 to 1.27]; I^2^=0%; Figure 8).

Figure 8 Meta-Analysis of Effects of Vitamin D Treatment on Type 2 Diabetes Risk

* ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

† This is a nested case-control study from the Women's Health Initiative Calcium with Vitamin D Trial.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 8 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on type 2 diabetes risk. The figure shows that when data from the 2 included studies reporting on type 2 diabetes risk are combined there is no association between treatment with vitamin D and risk for type 2 diabetes compared with placebo.

#### Effect of Vitamin D Treatment on Psychosocial Functioning and Disability

One good-quality trial examined the effect of 20,000 IU per week of vitamin D_3_ for 6 months on depression and anxiety as measured by the Beck Depression Inventory, the Montgomery-Åsberg Depression Rating Scale, and the Hospital Anxiety and Depression Scale. In vitamin D–deficient (<22 ng/mL) healthy persons (56% female) with a mean age of 53 years,171 there was no difference after 6 months of treatment on any scale (Table 2 and Appendix C1). There were also no significant differences between treatment groups in change from baseline when stratifying by sex, age, BMI, 25(OH)D level at baseline, or smoking status.

One small fair-quality trial (n=90) examined the effect of eight weekly doses of 50,000 IU of vitamin D_3_ on psychosocial functioning and disability as measured by the Fibromyalgia Impact Questionnaire.172 In vitamin D–deficient (<25 ng/mL) healthy persons (40% female) with a mean age of 59 years,170 those randomized to vitamin D_3_ treatment showed improvement in their overall score after 8 weeks (Table 2 and Appendix C1). Individuals in the placebo group, on the other hand, experienced worsening scores (mean difference from baseline on scale from 0 to 100, −3.7 vs. +1.9; p<0.03 for difference between groups). Despite this result, however, vitamin D_3_ treatment did not beneficially affect scores on the depression or work interference subscales compared with placebo.

#### Effect of Vitamin D Treatment on Physical Functioning

One fair-quality trial (n=213) examined the effect of 16 weekly doses of 8,400 IU of vitamin D_3_ on physical functioning in U.S. and European populations with an average age of 78 years.155 Compared with placebo, vitamin D_3_ treatment did not result in greater improvement on the Short Physical Performance Battery, a validated measure of lower extremity functioning.173

#### Effect of Vitamin D Treatment in Patient Subgroups

None of the included trials were designed or powered to evaluate potential subgroup effects based on age or institutionalized status. Data suggesting benefits of vitamin D treatment on mortality were limited to trials of institutionalized European women.120,122,154 While studies that examined fall risk with vitamin D treatment did not include participants chosen for being at high risk for falls, baseline characteristics indicate that most of the participants were older (>70 years) and many may have had risk factors for falls. No included studies were designed to evaluate differential effects of vitamin D treatment on clinical outcomes based on factors such as sex, race, BMI, or UV light exposure.

## Key Question 4 What Are the Adverse Effects of Treatment of Vitamin D Deficiency With Vitamin D?

### Summary

Data on the adverse events of treatment of vitamin D deficiency with vitamin D (with or without calcium) are limited. Trials were generally not designed to address harms, and prespecified outcomes rarely included assessment of harms. In the included trials, there was no evidence that treatment with 400 to 7,000 IU per day or 8,400 to 54,000 IU per week of vitamin D_3_ or D_2_ (with or without calcium) resulted in more total adverse events, serious adverse events, withdrawals due to adverse events, hypercalcemia, kidney stones, or gastrointestinal symptoms compared with control intervention over 6 weeks to 4 years.

### Evidence

We identified 24 trials that examined adverse events associated with vitamin D treatment (with or without calcium) in vitamin D–deficient (<20 or ≤30 ng/mL) populations (N=4,471; Table 4 and Appendix C1). The mean age of participants ranged from 31 to 85 years. Seven trials were conducted in the United States,156,159,160,170,174-177 16 were conducted in Europe,115,120,122,125,127,128, 132,133,136,153,154,157,158,165,171,178,179 and one was conducted in both the United States and Europe.155 These trials examined vitamin D_3_ treatment (21 trials),120,122,125,127, 128,132,133,136,153-160,165,170,171,174, 175,177,178 vitamin D_2_ treatment (2 trials),176,179 or both (1 trial)115 and examined dosages ranging from 400 to 7,000 IU per day to 8,400 to 54,000 IU per week. Nineteen trials evaluated the effects of vitamin D treatment alone and five evaluated the effects of vitamin D treatment with calcium (1,000 to 1,200 mg per day). Trials were from 6 weeks to 4 years in duration.

Table 4 Studies of Harms of Vitamin D Treatment

Author, Year Quality | Country | Population Characteristics^*^ | 25(OH)D Level at Baseline (ng/mL):^*,†^ Vitamin D vs. Control | 25(OH)D Level at Followup (ng/mL):^*,†^ Vitamin D vs. Control | Interventions | Duration^*^ | Adverse Events or Harms Reported
25(OH)D level <20 ng/mL^‡^
Brazier et al, 2005^157^ Fair | France | Analyzed: 191 Age (years): 74.6 (74.2 vs. 75.0) Female: 100% Comorbidities: NR History of falls: NR Institutionalized: 0% | 7 vs. 7 | Median, 29 vs. 11 | [underlined: Vitamin D (n=95):] 800 IU vitamin D_3_ and 1000 mg calcium daily [underlined: Control (n=97):] Placebo | 12 months | Total AEs Withdrawal due to AEs Serious AEs Any AE Hypercalcemia Gastrointestinal AEs Osteomuscular AEs Nervous system AEs Metabolic/nutritional AEs
Chapuy et al, 2002^122^ Fair | France | Analyzed: 583 Age (years): 85 Female: 100% Comorbidities: NR History of falls: 16.1% Use of walking device: 40.7% Institutionalized: 100% | 9.2 vs. 9.2 | ∼ 33 vs. 5 (from figure); p=0.0001 for change from baseline for vitamin D group only | [underlined: Vitamin D (n=393):] 800 IU of vitamin D_3_ and 1200 mg calcium daily [underlined: Control (n=190):] Placebo | 24 months | Withdrawal due to AEs (NR by group) Hypercalcemia Kidney stones Hypercalciuria Gastrointestinal AEs
Gallagher et al, 2013^160^ Fair | United States | Analyzed: 110 Age (years): 67 Female: 100% BMI (kg/m^2^): 32.7 Comorbidities: NR History of falls: NR Institutionalized: NR | Placebo: 14 Vitamin D^§^ 800 IU: 14 1600 IU: 13 2400 IU: 14 4800 IU: 14 | 97.5% (from figure) of those using vitamin D 800 IU reached serum 25(OH)D >20 ng/mL; p<0.05 vs. placebo for all vitamin D groups | [underlined: Vitamin D:] 400, 800, 1600, 2400, 3200, 4000, or 4800 IU of vitamin D_3_ daily [underlined: Control:] Placebo All participants supplemented to maintain total calcium intake of 1200 to 1400 mg/day | 12 months | Withdrawal due to AEs^‖^ Serious AEs Hypercalcemia
Gallagher et al, 2014^159^ Fair | United States | Analyzed: 198 Age (years): 37 Female: 100% BMI (kg/m^2^): 30.2 Comorbidities: NR History of falls: NR Institutionalized: NR | Placebo: 13 Vitamin D 400 IU: 13 800 IU: 14 1600 IU: 13 2400 IU: 14 | 97.5% (from figure) of white women using vitamin D 400 IU reached serum 25(OH)D >20 ng/mL; 97.5% of black women using vitamin D 800 to 1600 IU reached serum 25(OH)D >20 ng/mL | [underlined: Vitamin D:] 400, 800, 1600, or 2400 IU of vitamin D_3_ daily [underlined: Control:] Placebo All participants supplemented to maintain total calcium intake of 1000 to 1200 mg/day | 12 months | Serious AEs (NR by group) Hypercalcemia Kidney stones
Grimnes et al, 2011^158^ Fair | Norway | Analyzed: 104 Age (years): 52.1 (51.5 vs. 52.7) Female: 49.1% (45% vs. 51%) BMI (kg/m^2^): 26.5 (27.2 vs. 26.3) History of falls: NR Institutionalized: 0% | 17 vs. 16 | 57 vs. 17 | [underlined: Vitamin D (n=51):] 40,000 IU vitamin D_3_ weekly [underlined: Control (n=52):] Placebo | 6 months | Total AEs Hypercalcemia Kidney stones
Janssen et al, 2010^127^ Fair | The Netherlands | Analyzed: 70 Age (years): 80.8^†^ Female: 100% BMI (kg/m^2^): 26.4^†^ Comorbidities: 2.4^†^ Medications used: 5.0^†^ History of falls: NR Institutionalized: 100%^‡^ | 13 vs. 14 | 31 vs. 17 | [underlined: Vitamin D (n=28)]: 400 IU of vitamin D_3_ and 500 mg of calcium daily [underlined: Control (n=31):] Placebo and calcium 500 mg daily | 6 months | Withdrawals Any AE
Knutsen et al, 2014^132^ Fair | Norway | Analyzed: 215 Age (years): 37.3^†^ Female: 73% BMI (kg/m^2^): 27.4^†^ Comorbidities: NR History of falls: NR Institutionalized: NR | 11 vs. 11 | 19 vs. 10 | [underlined: Vitamin D (n=169):] 25 or 10 μg of vitamin D_3_ daily [underlined: Control (n=82):] Placebo | 16 weeks | Total AEs
Lips et al, 2010^155^ Fair | The Netherlands Germany United States | Analyzed: 226 Age (years): 78 Female: NR BMI (kg/m^2^): 27.8^†^ Comorbidities: NR History of falls: NR Use of walking device: 15% Institutionalized: 14% | 14 vs. 14 | 26 vs. 12; p<0.001 | [underlined: Vitamin D (n=114):] 8400 IU of vitamin D_3_ weekly [underlined: Control (n=112):] Placebo Those with daily calcium intake <1000 mg were also given 500 mg calcium | 16 weeks | Withdrawal due to AEs Serious AEs Any AE Kidney stones Hypercalcemia (data not shown)
Wamberg et al, 2013^125^ Wamberg et al, 2013^133^ Fair | Denmark | Analyzed: 43 Age (years): 40.5 Female: 71% BMI (kg/m^2^): 35.8%^†^ Sedentary: 35%^†^ Lightly active: 48%^†^ Moderately active: 17%^†^ Comorbidities: 2% (1/55) on lipid-lowering meds, 5% (3/55) on antihypertension meds History of falls: NR Institutionalized: NR | 14 vs. 14 | 44 vs. 19 | [underlined: Vitamin D (n=22):] 7000 IU of vitamin D_3_ daily [underlined: Control (n=21):] Placebo | 26 weeks | Total AEs Hypercalcemia
25(OH)D level ≤30 ng/mL
Aloia et al, 2008^174^ Fair | United States | Analyzed: 138 Age (years): 47.2^†^ Female: 81% History of falls: NR Institutionalized: NR | 19 | >30 ng/mL achieved by virtually all in active group; also increased by 8 ng/mL in placebo group because of seasonal change | [underlined: Vitamin D (n=65):] Dosage of vitamin D_3_ depended on 25(OH)D concentration; mean dose, 3440 IU [underlined: Control (n=73):] Placebo | 6 months | Hypercalcemia Hypercalcuria
Arvold et al, 2009^170^ Fair | United States | Analyzed: 100 Age (years): 58.8^†^ Female: 40% BMI: NR Comorbidities: NR History of falls: NR Use of walking device: NR Institutionalized: 0% | 18 vs. 18 | 45 vs. 22 | [underlined: Vitamin D (n=48):] 50,000 IU vitamin D_3_ weekly [underlined: Control (n=42)]: Placebo | 8 weeks | Any AE
Berlin et al, 1986^178^ Poor | Sweden | Analyzed: 24 Age (years): 31 (range, 22 to 47) Female: 0% History of falls: NR Institutionalized: NR | 15 vs. 15 | 49 vs. 19 | [underlined: Vitamin D (n=12):] 54,000 IU of vitamin D_3_ weekly [underlined: Control (n=12):] No treatment | NR; implies 2 months | Any AE
Bischoff et al, 2003^165^ Fair | Switzerland | Analyzed: 122 Age (years): 85 Female: 100% BMI (kg/m^2^): 24.7 Comorbidities: 30.3% hypertension, 15.6% stroke, 50.0% myocardial infarction or congestive heart failure, 12.3% anemia, 14.8% diabetes, 8.2% chronic obstructive pulmonary disease, 16.4% peptic ulcer disease, 24.6% depression, 9.0% malnutrition, 4.1% obesity, 54.9% dementia, 54.1% fracture at any site History of falls: 34% Use of walking device: 60% Institutionalized: 100% | Median, 12 vs. 12 | Median, 26 vs. 11; p<0.001 | [underlined: Vitamin D (n=62):] 800 IU of vitamin D_3_ and 1200 mg of calcium daily [underlined: Control (n=60):] 1200 mg calcium daily | 6 weeks pre-treatment 12 weeks treatment | Hypercalcemia Withdrawals Gastrointestinal AEs
Gallagher et al, 2012^156^ Good | United States | Analyzed: 163 Age (years): 67 Female: 100% BMI (kg/m^2^): 30.2 Comorbidities: NR History of falls: NR Institutionalized: NR | Placebo: 15 Vitamin D 400 IU: 15 800 IU: 16 1600 IU: 15 2400 IU: 15 3200 IU: 16 4000 IU: 15 4800 IU: 16 | 97.5% (from figure) of those using vitamin D 600 IU per day had serum 25(OH)D >20 ng/mL; p<0.05 vs. placebo for all vitamin D groups | [underlined: Vitamin D (n=235)]: Either 400, 800, 1600, 2400, 3200, 4000, or 4800 IU of vitamin D_3_ daily [underlined: Control (n=38):] Placebo All participants supplemented to maintain total calcium intake of 1200 to 1400 mg daily | Median, 12 months | Withdrawal due to AEs Any AE Serious AEs Kidney stones Hypercalcemia
Harris et al, 1999^176^ Poor | United States | Analyzed: 20 Age (years): 31 (range, 22 to 47) Female: 0% Comorbidities: NR History of falls: NR Institutionalized: NR | Younger men: 13 vs. 17 Older men: 16 vs. 16 | Younger men: 25 vs. 13 Older men: 19 vs. 15 | [underlined: Vitamin D (n=11):] 1800 IU of vitamin D_2_ daily [underlined: Control (n=7):] No treatment | 3 weeks | Any AE
Honkanen et al, 1990^128^ Fair | Finland | Analyzed: 126 [underlined: Home patients] Age (years): 69.5^†^ Female: 100% Weight (kg): 69.5^†^ Comorbidities: NR History of falls: NR [underlined: Hospital inpatients (52%)] Age (years): 82.5^†^ Female: 100% Weight (kg): 61.8^†^ Comorbidities: NR History of falls: NR | Home patients: 17 vs. 15 Hospital inpatients: 10 vs. 10 | Home patients: 32 vs. 9 Hospital inpatients: 26 vs. 4 | [underlined: Vitamin D (n=63):] 1800 IU of vitamin D_3_ and 1.558 g of calcium daily [underlined: Control (n=63):] No treatment | 11 weeks | Hypercalcemia Kidney stones
Kärkkäinen et al, 2010^153^ Fair | Finland | Analyzed: 603 Age (years): 67.4^†^ (67.4 vs. 67.4) Female: 100% BMI (kg/m^2^): 27.4^†^ (27.5 vs. 27.4) History of falls: NR Institutionalized: NR | 20 vs. 20 | 30 vs. 22 | [underlined: Vitamin D (n=290):] 800 IU of vitamin D_3_ and 1000 mg calcium daily [underlined: Control (n=313):] No treatment | 3 years | Withdrawal due to AE
Kjaergaard et al, 2012^171^ Good | Norway | Analyzed: 230 (per protocol) Age (years): 53.4^†^ Female: 56% BMI (kg/m^2^): 27.7^†^ Comorbidities: NR History of falls: NR Institutionalized: NR | 19 vs. 19 | 59 vs. 21 | [underlined: Vitamin D (n=120):] 20,000 IU of vitamin D_3_ weekly [underlined: Control (n=110):] Placebo | 6 months | Total AEs Gastrointestinal AEs Respiratory AEs Dermatological AEs Musculoskeletal AEs Urogenital AEs Circulatory AEs Neurological AEs Endocrinological AEs Other organ AEs Hypercalcemia
Krieg et al, 1999^154^ Fair | Switzerland | Analyzed: 248 Age (years): 84.5^†^ Female: 100% BMI (kg/m^2^): 24.7^†^ History of falls: NR Institutionalized: 100% | 12 vs. 12 | 27 vs. 6 | [underlined: Vitamin D (n=124):] 880 IU of vitamin D_3_ and 1000 mg calcium daily [underlined: Control (n=124):] No treatment | 2 years | Withdrawal due to AE
Lehmann et al, 2013^115^ Fair | Norway | Analyzed: 119 Age (years): 33.8^†^ Female: 63.5% BMI (kg/m^2^): 23.8^†^ History of falls: NR Institutionalized: NR | Overall (vitamin D_2_ vs. vitamin D_3_ vs. control): 16 (15 vs. 18 vs. 16) | Vitamin D_2_ vs. vitamin D_3_ vs. control: 27 vs. 36 vs. 13 | [underlined: Vitamin D (n=47, 46):] 2000 IU of either vitamin D_2_ or D_3_ daily [underlined: Control(n=19):] Placebo | 8 weeks | Any AE Hypercalcemia
Martineau et al, 2007^179^ Fair | United Kingdom | Analyzed: 192^††^ Median age (years): 33.7^†^ Female: 51.2%^†^ History of falls: NR Institutionalized: NR | 14 vs. NR | 27 vs. NR | [underlined: Vitamin D (n=96):] Single dose of 100,000 IU vitamin D_2_ [underlined: Control (n=96):] Placebo | 6 weeks | Any AE Hypercalcemia
Ooms et al, 1995^120^ Fair | The Netherlands | Analyzed: 348 Age (years): 80.4^†^ Female: 100% BMI (kg/m^2^): 28.3^†^ Comorbidities: NR History of falls: NR Use of walking device: NR Institutionalized: 100%^**^ | Median, 11 vs. 10 | Median, 25 vs. 9 (at 1 year) | [underlined: Vitamin D (n=177):] 400 IU of vitamin D_3_ daily [underlined: Control (n=171):] Placebo | 3 to 3.5 years, maximum 4 years | Any AE Hypercalcemia
Talwar et al, 2007^177^ Aloia et al, 2005^175^ Fair | United States | Analyzed: 208 Age (years): 60.5^†^ Female: 100% BMI (kg/m^2^): 29 vs. 30 History of falls: NR Institutionalized: NR | 19 vs. 17 | 35 vs. 18 | [underlined: Vitamin D (n=104):] 800 IU of vitamin D_3_ daily for first 24 months, increased to 2000 IU daily [underlined: Control (n=104):] Placebo Supplements given to maintain total daily intake of 1200 to 1500 mg calcium | 36 months | Total AEs (NR by group) Serious AEs Hypercalcemia Hypercalcuria Kidney stones
Wood et al, 2012^136^ Fair | United Kingdom | Analyzed: 305 Age (years): 63.8^†^ Female: 100% BMI (kg/m^2^): 26.7^†^ History of falls: NR Institutionalized: NR | Vitamin D 400 IU vs. 1000 IU vs. control: 13 vs. 13 vs. 14 | Vitamin D 400 IU vs. 1000 IU vs. control: 26 vs. 30 vs. 13 | [underlined: Vitamin D (n=102, 101):] 400 or 1000 IU of vitamin D_3_ daily [underlined: Control (n=102):] Placebo | 12 months treatment; 1 month followup | Total AEs Serious AEs Hypercalcemia Gastrointestinal AEs Osteomuscular AEs

* Reported as mean, unless otherwise noted.

† Calculated.

‡ ≥90% of study participants had 25(OH)D levels <20 ng/mL.

§ NR for 400, 3600, or 4000 IU groups.

‖ As per author correspondence.

¶ ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

** Received care, but not as much as in a nursing home.

†† Population characteristics only reported for those who finished study (n=131).

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; AE = adverse event; BMI = body mass index; NR = not reported.

Two trials were rated good quality156,171 and 20 were rated fair quality.115,120,122,125,127,128,132,133,136, 153-155,157-160,165,170,174,175,177,179 We excluded two poor-quality studies from the synthesis of the results176,178 (Appendix C2). Methodological shortcomings in the poor- and fair-quality trials included unclear randomization procedure; inadequate or unclear masking of assessors, providers, and/or participants; high attrition; and/or no clear statement that adverse events were a prespecified outcome.

#### Effects of Vitamin D Treatment on Adverse Events

One good-quality and six fair-quality trials reported on total adverse events in participants being treated with 400 to 7,000 IU per day or 20,000 to 40,000 IU per week of vitamin D_3_ or D_2_ for 6 to 36 months (Table 4 and Appendix C1; N=1,296).125,132,133,136,157,158,171,175,177 No trial reported significantly more total adverse events in the intervention group compared with the control group.

One good-quality and six fair-quality trials examined the effect of 400 to 4,800 IU per day or 8,400 IU per week of vitamin D_3_ treatment (with or without calcium) on serious adverse events in vitamin D–deficient white U.S. or European women with mean ages of 37 to 78 years (N=1,401).136,155-157, 159,160,175,177 No trial reported a significantly increased risk for serious adverse events. The summary RR did not indicate a significantly increased risk for serious adverse events in participants given vitamin D treatment compared with placebo (pooled RR, 1.17 [95% CI, 0.74 to 1.84]; I^2^=0%; Figure 9).

Figure 9 Meta-Analysis of Effects of Vitamin D Treatment on Serious Adverse Events

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 9 is a forest plot displaying the results of a meta-analysis of the effects of vitamin D treatment on serious adverse events The figure shows that no individual study associated vitamin D treatment with serious adverse events when compared with placebo. When data from the 6 studies are pooled there is no association between vitamin D treatment and serious adverse effects.

Five trials (one good and four fair quality) compared withdrawals due to adverse events in white U.S. and European women randomized to 400 to 4,800 IU per day or 8,400 IU per week of vitamin D_3_ treatment (with or without calcium) compared with placebo or no vitamin D treatment (N=938).154-157,160 Withdrawals were not significantly increased in the intervention group compared with the control group in any trial, although the number of withdrawals was low (29 out of 568 vs. 23 out of 370). A fair-quality trial conducted in elderly institutionalized women in Europe reported the biggest difference in withdrawals between the intervention and control groups, but the estimate was very imprecise (7 vs. 0; RR, 15.00 [95% CI, 0.87 to 259.82]).154 Withdrawals were due to gastrointestinal symptoms (n=6) or hypercalcemia (n=1). When data from the five trials were combined, there was no significantly increased risk for withdrawals due to adverse events (pooled RR, 0.90 [95% CI, 0.36 to 2.24]; I^2^=32%; Figure 10).

Figure 10 Meta-Analysis of Effects of Vitamin D Treatment on Withdrawals Due to Adverse Events

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

‡ Included an institutionalized population.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 10 is a forest plot displaying results of a meta-analysis of the effects of vitamin D treatment on withdrawals due to adverse events. The figure shows that none of the 5 included studies show an association between vitamin D treatment and withdrawals due to adverse events when compared with placebo. The figure shows that when data from all studies are pooled there is no association between vitamin D treatment and withdrawals due to adverse events when compared with placebo.

Two good-quality and 15 fair-quality trials examined the effects of treatment with 400 to 7,000 IU per day to 8,400 to 40,000 IU per week of vitamin D_3_ or D_2_ (with or without calcium) on risk for hypercalcemia in white, black, and South Asian participants in the United States and United Kingdom with mean ages of 34 to 85 years.115,120,122,125,128,133,136,155-160,165,171,174,175,177,179 Fifteen trials detected hypercalcemia by monitoring levels during followup. In three trials, hypercalcemia was defined as calcium levels of 10.8 mg/dL or greater.156,157,160 One trial defined hypercalcemia as levels of 10.6 mg/dL or greater,174 while two trials defined it as levels greater than 10.2 mg/dL.158,159 The remaining trials did not report how hypercalcemia was detected or defined.115,120,122,125,128,133,136,155,165,171,175,177,179 No individual study reported a significantly higher incidence of hypercalcemia in the intervention group compared with the control group, although the number of events was small, and seven trials reported no cases.115,125,128,133,158,165,174,179 The nine trials with at least one participant with hypercalcemia measured calcium as part of followup.120,122,136,156,157,159,160,171,175,177 Hypercalcemia in these trials was described as being mild, reversible, or due to an unrelated underlying illness uncovered by vitamin D treatment. One study reported that the incidence of hypercalcemia did not differ between treatment groups, although these data were not provided.155 Overall, in trials that provided data and reported at least one case of hypercalcemia, 32 (1.7%) of 1,939 persons randomized to vitamin D treatment (with or without calcium) were found to have hypercalcemia versus 16 (1.3%) out of 1,233 controls (pooled RR, 1.05 [95% CI, 0.57 to 1.94]; I^2^=0%; Figure 11).

Figure 11 Meta-Analysis of Effects of Vitamin D Treatment on Hypercalcemia

* ≥90% of study participants had 25(OH)D levels <20 ng/mL.

† Included an institutionalized population.

‡ ≥90% of study participants had 25(OH)D levels ≤30 ng/mL, with ≥10% with 25(OH)D levels ≥20 ng/mL.

Abbreviations: 25(OH)D = 25-hydroxyvitamin D; CI = confidence interval.

Figure 11 is a forest plot displaying the results of a meta-analysis of effects of vitamin D treatment on hypercalcemia. The figure shows that none of the 16 included studies reporting hypercalcemia showed an association between vitamin D treatment and hypercalcemia when compared with placebo. The figure also shows that when data from the 16 studies are pooled there is no association between vitamin D treatment and hypercalcemia when compared with placebo.

No kidney stones were reported in any participants in seven trials reporting this outcome (Table 4 and Appendix C1).122,128,155,156,158,159,175,177 Five fair-quality trials found no significant differences in the risk for gastrointestinal symptoms in intervention compared with control participants (Table 4 and Appendix C1).122,136,157,165,171 Five trials reported no adverse events in any study participants, regardless of group allocation.115,170,176,178,179

#### Effect of Vitamin D Treatment on Adverse Events in Patient Subgroups

In three trials that included nonwhite participants, adverse events were not increased in the vitamin D treatment group compared with placebo, but adverse events were not stratified by race. Few trials enrolled both men and women. No study evaluated risk for adverse events stratified by sex. No data were available to determine risk for adverse events according to BMI or UV light exposure.