# METHODS

## Key Questions and Analytic Framework

The USPSTF, with input from AHRQ, set the scope and developed the key questions for this review. Based on this work, we created an analytic framework including key questions and the patient populations, interventions, and outcomes reviewed (Figure 1). Key question 1 focuses on direct evidence on the effectiveness of screening for vitamin D deficiency in improving future health outcomes (e.g., mortality reduction, morbidity from selected conditions, physical and emotional functioning) compared with not screening. Such direct evidence on the effectiveness of screening interventions may be limited. Therefore, the remainder of the analytic framework (key questions 2 through 4) evaluates the chain of indirect evidence needed to link screening with improvements in important health outcomes. Links in the chain of indirect evidence include the effectiveness of vitamin D treatment in reducing the incidence of future health outcomes and the harms associated with screening and treatment in persons with vitamin D deficiency. It is implicit in the indirect chain of evidence that, in order to understand benefits and harms of screening, it is not sufficient to identify individuals who are vitamin D deficient. Instead, it is necessary to show that there are effective treatments for those identified with vitamin D deficiency, which are addressed in key questions 1 and 3. Key questions 1a, 3a, and 4a address how the effectiveness of screening and treatment varies in different subgroups.

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts the pathway that asymptomatic adults may experience during screening for vitamin D deficiency. The figure shows that adults who undergo screening for vitamin D deficiency may be identified as being vitamin D deficient or experience adverse effects related to screening. The figure shows the next steps in the pathway for those who are vitamin D deficient, is receiving treatment for vitamin D deficiency and adverse effects related to treatment. The pathway shows outcomes of interest after screening and treatment to be decreased morbidity from selected conditions, reduced disability, improved psychosocial functioning, and reduced mortality.

### Key Questions

1. Is there direct evidence that screening for vitamin D deficiency results in improved health outcomes?
  a. Are there differences in screening efficacy between patient subgroups (subgroups defined by risk factors for vitamin D deficiency, such as age 65 years or older, sex, race/ethnicity, BMI, UV light exposure, and institutionalized status)?
2. What are the harms of screening (e.g., risk from procedure, false-positive or false-negative results)?
3. Does treatment of vitamin D deficiency with vitamin D lead to improved health outcomes?
  a. Are there differences in efficacy between patient subgroups (subgroups defined by risk factors for vitamin D deficiency, such as age, sex, race/ethnicity, BMI, UV light exposure, and institutionalized status)?
4. What are the adverse effects of treatment of vitamin D deficiency with vitamin D?
  a. Are there differences in adverse effects between patient subgroups (subgroups defined by risk factors for vitamin D deficiency, such as age 65 years or older, sex, race/ethnicity, BMI, UV light exposure, and institutionalized status)?

We accepted different definitions of vitamin D deficiency as long as at least 90 percent of participants had a baseline 25(OH)D level of 30 ng/mL or less, based on the uncertainties about what level defines deficiency. However, we examined data stratified by 25(OH)D cutoff levels. For the purposes of this report, the term “vitamin D deficient” refers to populations in which at least 90 percent of individuals have 25(OH)D levels of 30 ng/mL or less.

### Contextual Questions

The USPSTF also requested three contextual questions to help inform the report. Contextual questions are not reviewed using systematic review methodology. Instead, they focus on evidence from large high-quality epidemiological and clinical studies. These contextual questions are addressed in the Introduction in the sections on Etiology and Natural History, Risk Factors, and Rationale for Screening and Screening Strategies and in more detail in Appendixes A1–A3.

The contextual questions are:

1. What is the association between serum 25(OH)D levels and health outcomes?
2. What are the risk factors associated with vitamin D deficiency?
3. What is the effect of vitamin D treatment (with or without calcium) on intermediate outcomes (e.g., blood pressure, bone mineral density, glucose tolerance, lipid levels)?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through August 2014) and Ovid MEDLINE® (through the third week of August 2014) for relevant studies and systematic reviews. Search strategies are shown in Appendix B1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated potential studies against inclusion and exclusion criteria developed for each key question (Appendix B2). Articles were selected for full-text review if they evaluated the benefits or harms of screening versus no screening or vitamin D treatment versus no treatment for our target population (see section below). We evaluated only English-language articles and excluded studies published only as abstracts. We also excluded studies of nonhuman subjects. All included studies reported original data. To evaluate the benefits of vitamin D screening, we included systematic reviews and randomized, controlled trials (RCTs). We also included case-control studies nested within an RCT, such as the large Women's Health Initiative (WHI) Calcium-Vitamin D (CaD) trial.146 For evaluation of harms, we included systematic reviews, RCTs, and cohort or case-control studies. Studies had to be conducted in or relevant to primary care settings. While we included studies of persons in institutional settings, we performed stratified analyses in which they were examined separately from studies of community-dwelling persons.

Our target population was vitamin D–deficient adults (age ≥18 years) in countries generalizable to the United States. As a result, we included only studies conducted in the United States, Canada, Europe, and Australia. For key question 1, we included studies of screening for vitamin D deficiency if they enrolled a healthy asymptomatic study population (persons neither known to have vitamin D deficiency nor selected for testing for evaluation of a medical condition associated with vitamin D deficiency); described the study population (e.g., number screened, sex, age range, and setting); and reported health outcomes or harms (e.g., labeling or effects of subsequent treatments). We could not assess sensitivity, specificity, or related measures of diagnostic accuracy (e.g., false-positives or false-negatives) due to assay variability and the absence of a recognized reference standard for vitamin D status. For key question 3, we included studies of treatment of vitamin D deficiency if they examined vitamin D–deficient persons identified through screening, if participants were not selected on the basis of having symptoms or signs of vitamin D deficiency, and if they were not being treated with vitamin D for a specific health condition (e.g., low bone mineral density, prior fracture, prior falls). While our review targeted asymptomatic persons, most studies did not report the presence of symptoms, and symptoms of vitamin D deficiency are nonspecific and may be relatively common.147,148 Therefore, we did not require that studies screen for symptoms of deficiency or exclude all patients with conditions associated with deficiency (e.g., studies of older patients might have included some persons who had osteoporosis or who had fallen in the past and were not excluded as long as the study did not purposely select patients with these conditions). We did not examine studies that targeted populations with signs of vitamin D deficiency (e.g., osteoporosis, history of nontraumatic fracture, or history of falls) or with medical conditions that increase risk for deficiency (e.g., liver, kidney, or malabsorptive disease) because screening for vitamin D deficiency and its treatment would be considered medical management of these conditions.

We accepted variable definitions of vitamin D deficiency as long as at least 90 percent of the participants had baseline 25(OH)D levels of 30 ng/mL or less. In addition, we included studies that did not specifically define their population as being vitamin D deficient as long as at least 90 percent of participants had baseline 25(OH)D levels of 30 ng/mL or less identified through screening. For the purposes of this report, the term “vitamin D deficient” refers to populations in which at least 90 percent of individuals have 25(OH)D levels of 30 ng/mL or less. For studies that did not restrict enrollment to persons with 25(OH)D levels of 30 ng/mL or less, we used the mean 25(OH)D level plus the standard deviation multiplied by 1.282 to approximate the 90th percentile and determine whether this level was at or below the 30 ng/mL threshold. To account for variability in the 25(OH)D level that constitutes deficiency, we stratified studies according to whether at least 90 percent of persons had levels less than 20 ng/mL (“<20 ng/mL” in this report) or at least 90 percent had levels less than 30 ng/mL with at least 10 percent greater than 20 ng/mL (“≤30 ng/mL” in this report). We converted 25(OH)D levels reported as nmol/L to ng/mL (1 nmol/L = 0.4 ng/mL). We included interventions of vitamin D treatment (with or without calcium) if they compared vitamin D treatment with placebo, calcium alone, or no treatment. Interventions were considered to be of vitamin D alone if they examined vitamin D treatment compared with placebo or no treatment, or if they examined vitamin D and calcium compared with calcium alone. Included studies described the study population (e.g., number screened, sex, age range, setting, and baseline 25(OH)D level), had a treatment period of at least 8 weeks for beneficial outcomes, and reported clinical health outcomes (see Appendix B2).

The selection of literature is summarized in the literature flow diagram (Appendix B3). Appendix B4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. Two investigators independently applied USPSTF criteria149 to rate the quality of each study as good, fair, or poor (Appendix B5). Poor-quality studies with a “fatal flaw” (or flaws) were excluded from the synthesis of the results. We resolved discrepancies through a consensus process. We considered the following factors to determine applicability: setting and generalizability of the setting to screening and primary care, enrollment criteria and whether they resulted in a highly selected population, use of run-in and washout periods, and similarity of testing and interventions to current clinical practices.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (good, fair, poor) using USPSTF methods. This assessment was based on the number, quality, and size of studies as well as the consistency of results between studies and the directness of evidence.149

We conducted meta-analyses to calculate summary risk ratios (RRs) for clinical outcomes (decreased mortality and decreased morbidity from fractures, falls, and diabetes) and harms (withdrawals due to adverse events, serious adverse events, and hypercalcemia) of treatment with vitamin D and/or calcium versus placebo, no treatment, or only calcium. We used the DerSimonian-Laird random effects model with Review Manager Version 5.2 (The Cochrane Collaboration, Copenhagen, Denmark) to conduct these analyses. Analyses for clinical outcomes used data on total study duration (including time following discontinuation of vitamin D treatment). For number of falls per person, we calculated rate ratios based on reported data and assumed mean equal length of followup between treatment groups if not reported. Rate ratios were combined using DerSimonian-Laird random effects models in the primary analyses. For all outcomes with substantial between-study heterogeneity, we conducted sensitivity analyses using profile likelihood random effects models.150 For number of falls per person, one study reported an adjusted rate ratio and we conducted a sensitivity analysis to assess the effect of the adjusted rate ratio on the summary rate ratio. Rate ratio analysis using the profile likelihood model were conducted with StataIC 12.0 (StataCorp LP, College Station, TX).

We assessed statistical heterogeneity using the standard chi-squared test and I^2^ statistic.151 For all analyses, we stratified results by serum baseline 25(OH)D level. We performed additional analyses in which trials were stratified by institutionalized status, treatment regimen (vitamin D alone or combined with calcium), vitamin D dose (≤400 vs. >400 IU per day), study duration (≤12 vs. >12 months), and participant mean age (≤70 vs. >70 years).

Several analyses included nested case-control studies from the WHI. We performed sensitivity analyses restricted to RCTs, excluding the results of the WHI subanalyses. For analyses that included results from nested case-control studies from WHI, we also performed sensitivity analyses using the odds ratio (OR) rather than the RR.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners (Appendix B6).

## Response to Public Comments

This systematic review was posted for public comment from June 24 to July 21, 2014. The systematic review team reviewed and considered relevant comments. No comments identified missing studies that met inclusion criteria or errors in the evidence reviewed, resulting in no changes to the findings or the conclusion of this report.