# INTRODUCTION

## Purpose of Review

The U.S. Preventive Services Task Force (USPSTF) will use this report to develop a recommendation statement on screening for vitamin D deficiency in asymptomatic adults. While the USPSTF has not previously issued recommendations on screening for vitamin D deficiency, it has issued several recommendation statements on the effects of vitamin D supplementation on the prevention of adverse health outcomes (e.g., falls, fractures, cancer, and cardiovascular disease) in populations of persons who were not necessarily vitamin D deficient (i.e., they included general populations who may or may not have been deficient).1-4

## Condition Definition

Vitamin D is a term used to refer to a group of fat-soluble compounds that play a significant role in calcium homeostasis and bone metabolism.5 Vitamin D is a unique vitamin in that it is acquired through synthesis in the skin after sun exposure in addition to through consuming food.6 Once synthesized, vitamin D is stored in adipocytes (fat cells) and is available for conversion to its active form, 1,25-dihydroxyvitamin D [1,25(OH)_2_D]. In addition to its effects on calcium and bone homeostasis, vitamin D potentially affects many other cellular regulatory functions.7

Vitamin D deficiency is determined by measuring serum 25-hydroxyvitamin D [25(OH)D] concentrations. The major circulating form of vitamin D is 25(OH)D, which is considered the best indicator of vitamin D status.6 Measurement of the active form of vitamin D, 1,25(OH)_2_D, is generally not performed in routine clinical practice because it does not accurately reflect vitamin D status. This is because vitamin D deficiency leads to elevated parathyroid hormone, which stimulates 1,25(OH)_2_D production in the kidneys, even when blood levels of vitamin D are low.8 While measurement of levels of vitamin D–binding protein (the major carrier protein for vitamin D) in conjunction with total 25(OH)D could possibly be a useful method for estimating bioavailable 25(OH)D,9 more research is needed on methods for measuring and interpreting bioavailable 25(OH)D. Measuring vitamin D–binding protein is not part of current standard clinical practice.

25(OH)D assays can be subject to variability (like all clinical assays). Multiple methodologies are available commercially and for research purposes to measure 25(OH)D. The first method developed to measure 25(OH)D used competitive protein–binding methodology. Because of the multiple limitations of this method, it has been supplanted by immunoassay methods as well as high-performance liquid chromatography (HPLC) and the combination of HPLC and mass spectrometry (LC-MS/MS).10 The sensitivity and specificity of different assays are not available because there is not yet an internationally recognized, commutable vitamin D reference material.11 Studies have produced evidence of intermethod and interlaboratory variability of 10 to 20 percent, however, which could limit the ability to precisely define an individual's vitamin D status using 25(OH)D levels.12-16 In studies comparing how different assays would classify a person's deficiency status, 4 to 32 percent of the samples would have been considered either deficient or not deficient depending on the assay used.17-20 The greatest risk for differential classification occurred when an individual's measured levels were close to defined cutoffs (i.e., those with very high and low levels were unlikely to be classified differently depending on the assay used).16,19

Several ongoing programs are currently working to decrease assay variability. In 2009, the National Institute of Standards and Technology (NIST) produced standard reference material for 25(OH)D, which represents the first step in standardizing its measurement. While this reference material has improved the accuracy of LC-MS/MS analyses, it has been less helpful in standardizing immunoassays.10,11 In 2010, the Vitamin D Standardization Program (VDSP) was established to promote 25(OH)D measurements that are accurate and comparable over time, at differing locations, and using different laboratory procedures. VDSP is an international effort conducted by the National Institutes of Health (NIH) Office of Dietary Supplements, in collaboration with the Centers for Disease Control and Prevention; National Center for Environmental Health; NIST; and the Belgian Laboratory for Analytical Chemistry, Faculty of Pharmaceutical Sciences, Ghent. VDSP developed protocols for standardizing procedures for measuring 25(OH)D in the National Health and Nutrition Examination Survey (NHANES). These protocols, however, are not yet available for commercial use or other research laboratories. Until these protocols are available, several external accuracy-based testing systems can be used, such as those of the NIST-NIH Vitamin D Metabolites Quality Assurance Program, the College of American Pathologists, and the Vitamin D External Quality Assurance Scheme (DEQAS). These schemes are similar to those used in other areas of clinical chemistry and can lead to decreased variability.21 DEQAS,12 for example, has acted as an early warning system to alert commercial kit manufacturers when they need to modify their products and procedures or when they need to withdraw kits.12

The level of 25(OH)D used to define vitamin D deficiency has varied over the previous two decades. There is no consensus on optimal 25(OH)D concentrations. To determine sufficiency cutoff levels, researchers have examined the level of 25(OH)D associated with maximal suppression of parathyroid hormone,12,22-25 maximum calcium absorption,26,27 and reduced fracture risk.28 In fact, the actual requirements for bone health likely reflect a distribution of values rather than a specific cutpoint. This is problematic for the purposes of diagnosing deficiency because clinicians require a specific cutpoint to make a diagnosis. While experts generally agree that levels lower than 20 ng/mL (50 nmol/L) may place an individual at risk relative to bone health, disagreement exists about whether goal 25(OH)D levels should be higher than 20 ng/mL for skeletal health29 (Table 1).

Table 1 Summary of Current Opinions About Defining Vitamin D Deficiency and Association Between 25(OH)D Cutoff Levels and Health Outcomes

25(OH)D Cutoff | Expert and Professional Body Opinions About Cutoff Levels | Association Between 25(OH)D Level and Health Outcomes | Subgroup Differences for the Association
<20 ng/mL | Widely used by researchers and available guidelines as indicative of deficiency | Levels >20 ng/mL have been associated with decreased risk for fractures, cardiovascular disease, colorectal cancer, diabetes, depressed mood, cognitive decline, and mortality | - Association with fracture and cardiovascular disease not seen in blacks; - Mortality association seen in blacks; - Association with falls has been seen in studies of institutionalized elderly populations; - Limited data that association with cognition may be stronger in women
20−30 ng/mL | Debate about whether 25(OH)D levels in this range represent deficiency | - Levels >24 ng/mL associated with decreased cardiovascular disease risk; - Levels >30 ng/mL associated with decreased mortality and colorectal cancer risk; - Levels >30 ng/mL have mixed association with decreased fracture risk | - Association with cardiovascular disease not seen in blacks; - Mortality association seen in blacks
>30−40 ng/mL | General agreement that 25(OH)D levels in this range do not represent deficiency; however, some recommend targeting 25(OH)D to this range because of potential variability in laboratory testing | Levels up to 35−40 ng/mL may be associated with decreased risk for mortality and colorectal cancer | No data available
>50 ng/mL | Debate about whether 25(OH)D levels above this range are associated with adverse health outcomes | Possible U-shaped association between vitamin D level and risk for mortality and pancreatic cancer | No data available
>200 ng/mL | 25(OH)D levels above this range are considered to be toxic | No data available | No data available

Note: For consistency throughout the report, we converted 25(OH)D levels reported as nmol/L to ng/mL (1 nmol/L = 0.4 ng/mL).

Abbreviation: 25(OH)D = 25-hydroxyvitamin D.

In 2011, the Institute of Medicine (IOM) concluded that 20 ng/mL was the level necessary for good bone health for practically all individuals.30 Other groups suggest that 25(OH)D levels should be greater than 30 ng/mL (75 nmol/L), particularly in older adults. These groups include the Endocrine Society, National Osteoporosis Foundation, and International Osteoporosis Foundation.13,31-34 The Endocrine Society suggests that, because of variability in laboratory measurements of 25(OH)D, targeting a higher 25(OH)D level than the goal level (such as 40 ng/mL [100 nmol/L]) better ensures that all persons meet goal levels.13 The IOM concluded, however, that there may be a potential U-shaped relationship between 25(OH)D and some outcomes with potential risks (e.g., mortality, cardiovascular disease, selected cancers, falls) at levels higher than 50 ng/mL (125 nmol/L).30 Experts agree that optimal serum 25(OH)D concentrations for extraskeletal health have not been established.13,30 For this report, the term “vitamin D deficient” refers to study participants who have been diagnosed with vitamin D deficiency, regardless of the study's cutoff (as long as it was ≤30 ng/mL).

## Prevalence and Burden of Disease

The prevalence of vitamin D deficiency varies based on how deficiency is defined (<20 vs. ≤30 ng/mL). According to NHANES data, 8 percent of the population were at risk for very low 25(OH)D levels (<12 ng/mL) from 2001 to 2006, and about 25 percent were at risk for deficiency, as defined by serum 25(OH)D levels of 12 to 20 ng/mL.5 The IOM has recently developed a statistical procedure to derive group prevalence estimates of nutritional inadequacy. According to this statistical model, 19 percent of the population is at risk for vitamin D deficiency as defined by the IOM.35 Data on the prevalence of 25(OH)D levels of less than 30 ng/mL come from a 2009 study using 2001 to 2004 NHANES data, which was not corrected for assay drift per instructions from the National Center for Health Statistics to do so. Between 2001 and 2004, 77 percent of noninstitutionalized U.S. participants had 25(OH)D levels below 30 ng/mL.36

When total 25(OH)D levels are used to define deficiency, blacks have a twofold to ninefold greater risk for deficiency and Hispanics a twofold to threefold greater risk for deficiency compared with whites.37-39 Additionally, one recent study found that black Americans not only had lower total 25(OH)D levels compared with white Americans, they also had lower vitamin D–binding protein levels.9 This resulted in similar concentrations of estimated bioavailable 25(OH)D between blacks and whites. More research is needed to determine whether total versus bioavailable 25(OH)D levels are a better indication of a state of deficiency and how they correlate with clinical health outcomes (e.g., bone density and fracture risk), especially in nonwhite populations.

Cross-sectional studies have reported inconsistent findings on the association between older age and prevalence of vitamin D deficiency, although there may be an increased risk in persons age 85 years or older.37-41 While some studies reported that females had greater risk for deficiency,37, 40 not all studies confirmed this finding.39

In NHANES, mean 25(OH)D levels were lower in 2000 to 2004 than in 1988 to 1994.^42^ Most of the differences in 25(OH)D levels between these time periods appear to be an artifact of assay changes rather than an actual decline in serum 25(OH)D levels. In an adult subgroup from NHANES, however, changes in body mass index (BMI), milk intake, and sun protection appeared to contribute to a small but real decline in vitamin D status.42

## Etiology and Natural History

Vitamin D is synthesized in the skin under the influence of ultraviolet (UV) rays in sunlight and is also obtained from dietary sources and supplements. In the United States, the primary dietary sources of vitamin D are fortified foods such as milk, milk products, fortified orange juice, and cereals, as well as supplements. Naturally occurring foods that contain vitamin D include fatty fish, egg yolk, and mushrooms that have been exposed to sunlight or UV radiation. In healthy individuals, vitamin D deficiency most often results from either decreased dietary intake, reduced sun exposure, or reduced ability to produce vitamin D (e.g., due to increased skin pigmentation or aging, or a combination of these factors).6

Vitamin D has a variety of actions on calcium, phosphate, and bone metabolism. Low 25(OH)D concentrations are associated with impaired intestinal calcium and phosphate absorption, negative calcium balance, phosphaturia, and a compensatory rise in parathyroid hormone, which results in excessive bone resorption. Severe vitamin D deficiency causes a mineralization defect in the skeleton.6 In children, vitamin D deficiency results in skeletal deformities classically called “rickets.” In adults, severe vitamin D deficiency can result in osteomalacia, which is associated with decreased bone mineral density, diffuse bone and joint pain, muscle weakness, and difficulty walking.43

### Association Between 25(OH)D Levels and Health Outcomes

The association between 25(OH)D levels of 12 to 30 ng/mL and bone and other health outcomes is controversial (Table 1). In 2009, an Agency for Healthcare Research and Quality (AHRQ) report (not for the USPSTF) concluded that the evidence for an association between serum 25(OH)D concentrations and fracture risk was inconsistent.44 Prospective studies published since the 2009 review have generally shown that lower 25(OH)D levels were associated with increased fracture risk. A recent 2014 umbrella study of systematic reviews and meta-analyses of observational studies, however, concluded that evidence was suggestive only for nonvertebral fractures and that no conclusions could be reached about other fractures.45 Prospective studies finding an association have generally noted that fracture risk increases at 25(OH)D levels less than 20 ng/mL in persons of Caucasian or European descent. Low 25(OH)D levels may not be associated with increased fracture risk in nonwhites.46,47 Some have hypothesized that these findings could be due to the differences in vitamin D–binding protein and levels of bioavailable 25(OH)D among different races.

In addition to its role in calcium and bone homeostasis, vitamin D potentially regulates many other cellular functions. Most tissues in the body have vitamin D receptors, and 1,25(OH)_2_D influences genomic expression in many cells.7 Therefore, researchers have hypothesized possible links between low 25(OH)D levels and muscle function, cancer, and metabolic, immune, and cardiovascular systems.48-54

The 2009 AHRQ review concluded that there was fair evidence for an association between low serum 25(OH)D concentrations (<16 ng/mL) and increased risk for falls in institutionalized elderly persons.44,55 This association, however, has not been observed in community-dwelling elderly persons.56,57 Similarly, a 2014 umbrella analysis of systematic reviews and meta-analyses concluded that there was insufficient evidence to draw conclusions about the association between low levels and fall risk. The review concluded that evidence suggested that high 25(OH)D levels are linked to an increased rate of falls.45 Evidence on the association between 25(OH)D levels and decline in physical functioning is inconsistent.58-63

Although the 2009 AHRQ review concluded that evidence describing the association between 25(OH)D status and cardiovascular disease was inconsistent,44 more recent data, mostly from white or primarily white populations, suggest an inverse association between risk for cardiovascular disease and 25(OH)D levels.45,58,64-67 Several studies have suggested an association up to 24 ng/mL.64-67 This inverse association, however, has not been observed in black individuals.68,69

While low 25(OH)D levels have not been associated with increased risk for breast, prostate, or pancreatic cancer,45,58,70-74 studies suggest an association between 25(OH)D levels and risk for colorectal cancer,45 with each increase of 10 to 20 ng/mL up to a 25(OH)D level of 35 to 40 ng/mL associated with a 15- to 50-percent decreased risk.58,71,72,75-78

Lower 25(OH)D levels (<12 to 20 ng/mL) have been associated with an increased risk for diabetes45,58,79-87 and depressed mood.45,58,88,89 The 2014 umbrella analysis of systematic reviews and meta-analyses concluded that evidence suggested a decreased risk for cognitive decline in persons with high 25(OH)D levels.45,58 Risk may increase at levels below 10 to 20 ng/mL versus levels greater than 30 ng/mL.90,91 The association may vary by sex, with the effect being seen more in women.91,92

Two 2014 systematic reviews of 31 to 73 studies concluded that lower 25(OH)D levels were associated with a significantly increased risk for death.58,93 A 2014 umbrella review of 107 systematic reviews and 74 meta-analyses of observational studies, however, stated that there was not enough evidence to make conclusions about the association between vitamin D levels and mortality.45 Although previous studies have concluded that there may be a U-shaped association in which high and low 25(OH)D levels are associated with an increased risk for mortality,94-103 this was not observed in the recent meta-analyses. In studies that included a significant proportion of nonwhite populations, lower 25(OH)D levels were associated with decreased mortality risk in black and white individuals.98,104

More detailed information on the association between 25(OH)D levels and health outcomes is provided in Appendix A1.

## Risk Factors

Low dietary vitamin D intake and/or lack of vitamin D supplements are associated with a twofold to fivefold increased risk for vitamin D deficiency (<20 ng/mL).37-39 Little or no UV light exposure (e.g., due to winter season, high latitude, and sun avoidance) is also associated with an increased risk for vitamin D deficiency.37,38,40,41,105 While sunscreen reduces the skin's ability to produce vitamin D in response to UV light in controlled research settings,106 this association has not been found in population-based studies.105,107 This finding in population-based studies is likely due to incomplete application108 and/or because subjects who use sunscreen are more likely to be exposed to the sun for extended periods.78

Obesity is associated with an almost twofold increased risk for vitamin D deficiency.37-39,109 This finding is possibly due to sequestration of vitamin D in fat cells30 or lifestyle differences (e.g., lower physical activity levels or lower dietary vitamin D intake). Low levels of physical activity,37,38,41 education attainment,36 and health status39,105 are modestly associated with vitamin D deficiency in some studies. Differences in diet, supplement use, and UV light exposure, however, could be mediating factors.

A significant proportion of the variability in 25(OH)D levels does not appear to be explained by traditional risk factors, which appear to account for only 20 to 30 percent of the variation in 25(OH)D levels.41,110 Genetic factors, including genetic variants of vitamin D–metabolizing genes, may influence serum 25(OH)D concentrations.111

More detailed information on risk factors associated with vitamin D deficiency is detailed in Appendix A2.

## Rationale for Screening and Screening Strategies

Vitamin D deficiency might affect one fifth to three fourths of the population, depending on which cutoff is used.5,35,36,39 Despite this prevalence, many of those who have low 25(OH)D levels are unaware of their status. Screening could identify persons with deficiency prior to the development of adverse health outcomes associated with this condition, assuming thresholds for deficiency can be established. If interventions to increase 25(OH)D levels successfully decrease disease risk, screening may improve the health of individuals with low 25(OH)D levels. This potential benefit, however, would need to be weighed against the risks associated with misdiagnosis of vitamin D deficiency, given current assay variability and unclear cutoffs to define deficiency. The risk for misclassification could outweigh any benefits if there are harms resulting from treatment or if diagnosis of deficiency leads to anxiety or inaccurate labeling.

## Interventions and Treatment

For healthy individuals not known to be vitamin D deficient, the IOM recently revised the Recommended Dietary Allowance (RDA) for vitamin D to up to 600 IU per day for adults ages 18 to 70 years and 800 IU per day for adults older than age 70 years.30 Other expert bodies, however, suggest that the daily intake of vitamin D may need to be higher (e.g., 1,000 to 2,000 IU per day) to avoid vitamin D deficiency, especially in high-risk individuals.13,32-34,112,113

Vitamin D deficiency can be treated by increased dietary intake, vitamin treatment, and increased UV light exposure. UV light exposure is usually not recommended because of increased skin cancer risk. While few foods naturally contain vitamin D, several food products (e.g., milk, cereals) are available fortified with vitamin D. An AHRQ-commissioned evidence report (not for the USPSTF) that assessed the effect of vitamin D and calcium intake on various health outcomes concluded that there was good evidence that dietary intake of vitamin D increases serum 25(OH)D levels in adults.44

Primary care physicians often treat vitamin D deficiency with oral vitamin D treatment. There are two commonly available forms of vitamin D treatment: vitamin D_3_ (cholecalciferol) and vitamin D_2_ (ergocalciferol). A 2012 meta-analysis of seven randomized trials concluded that vitamin D3 treatment increased serum 25(OH)D more efficiently than vitamin D_2_ treatment.114 The trials in the meta-analysis, however, used varying doses, treatment time periods, and assays to measure 25(OH)D_2_ and 25(OH)D_3_. Interpreting these findings is challenging because between-study statistical heterogeneity was present and the observed difference was of uncertain clinical significance. A 2013 bioavailability study that was powered to examine the effects of vitamin D_2_ compared with D_3_ treatment concluded that vitamin D_3_ treatment was more effective in raising total 25(OH)D levels.115 The Endocrine Society suggests using either vitamin D_2_ or D_3_ treatment13 based on several studies showing that physiological doses of vitamin D_2_ are equally effective as vitamin D_3_ treatment at increasing and maintaining serum 25(OH)D levels and maintaining 1,25(OH)_2_D levels.116,117 The IOM does not differentiate between use of vitamin D_2_ or D_3_ supplements in its recommendations.30

There are multiple forms (e.g., tablet, gel capsule), dosages (e.g., 200 to 500,000 IU), and dosing regimens (e.g., daily, weekly, monthly, yearly) of vitamin D treatment. Increasing doses of vitamin D are associated with greater net change in 25(OH)D concentration, although these effects vary depending on study participants' serum 25(OH)D status (e.g., ≤16 vs. >16 ng/mL) at baseline and the duration of treatment (e.g., ≤3 vs. >3 months).44

The amount of vitamin D required to effectively treat vitamin D deficiency also likely depends on an individual's vitamin D absorptive capacity, capacity to convert vitamin D to 25(OH)D in the liver, and genetic determinants. These factors lead to many different dosages and dosage patterns being used clinically. The Endocrine Society, for example, recommends that adults with vitamin D deficiency (≤30 ng/mL) be treated with 50,000 IU of vitamin D once a week or 6,000 IU per day for 8 weeks, followed by maintenance therapy of 1,500 to 2,000 IU per day. In persons with obesity, the Endocrine Society recommends increasing the dose by twofold or threefold.13 The efficacy of this practice, however, has not been rigorously compared with daily, weekly, or monthly dosing. While optimal monitoring strategies during vitamin D treatment are also not well studied, most experts recommend measuring 25(OH)D levels after 2 to 4 months of high-dose therapy.

Vitamin D supplements are often given with oral calcium, which may affect health outcomes and harms. Meta-analyses have suggested possible differences in health outcomes, such as mortality and fractures, when studies were stratified according to whether calcium was or was not given with the vitamin D supplements.118,119

### Effect of Vitamin D Treatment on Intermediate Outcomes

In older white women with severe vitamin D deficiency (<12 ng/mL), vitamin D treatment (400 to 800 IU per day, with or without calcium) for 12 to 24 months was associated with less decline in hip and/or spine bone mineral density than placebo in some studies,120,121 but not all.122 Vitamin D treatment (1,000 to 5,700 IU per day) for 6 to 36 months did not improve bone mineral density compared with placebo in older men, postmenopausal black women, or younger mixed-sex populations.123-126

In older women, our included studies found no association between vitamin D treatment (400 to 1,800 IU per day, with or without calcium) and improved hand strength,127,128 leg strength,127 or balance after 11 to 24 weeks129 versus placebo. Young persons (mean age, 18 to 33 years) who were vitamin D deficient (<30 ng/mL) and given large (25,000 to >60,000 IU per week) doses of vitamin D had improvement on several strength measures compared with those given placebo,130, 131 but this improvement in strength was not seen in a third trial that used smaller doses (400 to 1,000 IU) of vitamin D.132

Studies found no association between vitamin D treatment (400 to 7,143 IU per day, with or without calcium) and improvement in lipid, glucose, and insulin levels or insulin sensitivity in persons without diabetes and with low 25(OH)D levels (<30 ng/mL).133-137

Although some studies reported that vitamin D treatment (800 to 4,000 IU per day) was associated with decreased systolic (but not diastolic) blood pressure compared with placebo,135, 138 a nested case-control study of postmenopausal women with vitamin D deficiency in the Women's Health Initiative (WHI) Calcium with Vitamin D (CaD) trial found no difference between vitamin D supplementation (400 IU per day with 1,000 mg calcium) and placebo in risk for incident hypertension over 7 years.138

More detailed information on the effect of vitamin D treatment on intermediate outcomes is presented in Appendix A3.

### Adverse Effects of Vitamin D Treatment

Laboratory signs of vitamin D toxicity may appear before symptoms are evident. These symptoms include hypercalcemia, hyperphosphatemia, suppressed parathyroid hormone, and hypercalciuria and can occur after less than 4 weeks of continuous excess ingestion. These symptoms are variable and, while often nonspecific, are mostly related to hypercalcemia and hypercalciuria.30 Mild hypercalcemia can result in constipation, fatigue, and depression. More severe hypercalcemia can cause polyuria, polydipsia, dehydration, anorexia, nausea, muscle weakness, arrhythmias, and mental status changes. Hypercalciuria can lead to increased risk for kidney stones. The toxicity level of vitamin D (most commonly defined as >200 ng/mL [500 nmol/L]) is well above the level considered to be sufficient.139,140 Acute toxicity has not been linked to vitamin D intake of less than 10,000 IU per day.30 The IOM recommends a tolerable upper intake level of vitamin D supplementation for adults of 4,000 IU per day in order to avoid 25(OH)D levels greater than 50 ng/mL, which may be associated with potential risks (e.g., increased mortality, cardiovascular disease risk, certain cancers, and falls).30 While the Endocrine Society recommends a maintenance regimen of 4,000 IU per day, it states that 10,000 IU per day may be needed to correct deficiency in persons at risk for deficiency or during treatment of deficiency.13

## Current Clinical Practice

While we identified no reliable data on screening rates for vitamin D deficiency, available data suggest that testing rates for vitamin D status are increasing in general. A 2009 email survey of readers of Clinical Laboratory News (a publication of the American Academy for Clinical Chemistry) found that more than 50 percent of respondents reported an increase of at least 50 percent in the volume of testing for 25(OH)D in their laboratories over the prior year, and 27 percent reported an increase of 100 percent. Testing for 1,25(OH)_2_D also increased over this period, which suggests possible clinician uncertainty regarding which tests to order to assess vitamin D status.141

While data regarding vitamin D treatment patterns are limited, these data also suggest increased use. In one large integrated health care delivery system (>3 million members), use of high-dose vitamin D (50,000 IU) increased nearly eightfold between 2007 and 2010.^142^ Use of over-the-counter supplemental vitamin D has also increased over the past decade. In 2003 to 2006, for example, NHANES data reported that 56 percent of women age 60 years or older took vitamin D in one or more dietary supplements, as did 45 percent of women ages 40 to 59 years and 33 percent of women ages 20 to 39 years. This represents a significant increase from 1999 to 2002.^143^ Vitamin D supplementation was lower in men than in women in the same age groups (44%, 38%, and 26%, respectively). In 2008, 60 percent of women and 46 percent of men age 50 years or older in a large integrated health system reported taking vitamin D in the form of dietary supplements, as did 76 percent of women and 47 percent of men ages 51 to 85 years. Rates of vitamin D supplement usage were generally lower among nonwhites.143,144

## Recommendations of Other Groups

In 2011, the Endocrine Society recommended screening for vitamin D deficiency in persons at risk for deficiency. These identified groups include persons with diseases that predispose them to deficiency, such as chronic renal disease and malabsorption syndromes; persons who use medications that increase the risk for deficiency, such as glucocorticosteroids and antiepileptics; and persons who belong to an at-risk population, such as obese persons, blacks, and Hispanics. The Endocrine Society did not recommend screening for vitamin D deficiency in persons who are not at risk for this condition, noting a lack of evidence demonstrating the benefit of population-level screening.13

The American Board of Internal Medicine Foundation's 2013 “Choosing Wisely” report on unnecessary medical tests included a statement from the American Society for Clinical Pathology that “vitamin D testing is generally unnecessary.” It also stated that “over-the-counter vitamin D supplements and summer sun exposure are sufficient for most otherwise healthy people.” However, the report also stated that “laboratory testing is appropriate in higher risk patients—those who are obese or have chronic kidney disease, for example—when results will be used to decide whether to order more aggressive therapy.”145

From 2009 to 2011, the IOM convened an expert panel to update the Recommended Dietary Allowance for vitamin D. The panel assessed data on health outcomes associated with calcium and vitamin D to determine dietary reference intakes for vitamin D for the U.S. population. While the IOM did not make statements about vitamin D screening, it concluded that most persons have an average serum 25(OH)D level above that needed for good bone health. Because national surveys show an average total intake of vitamin D that is below the recommended median requirement, the IOM concluded that sun exposure likely contributes meaningful amounts of vitamin D to the U.S. population and that “the majority of the population is meeting its needs for vitamin D.”12 The IOM noted, however, that some subgroups may be at an increased risk for getting too little vitamin D (e.g., those who are older and living in institutions or who have dark skin pigmentation).

While the USPSTF has not previously issued recommendations on screening for vitamin D deficiency, it has issued several recommendations on the effects of vitamin D supplementation on the prevention of adverse health outcomes (e.g., falls, fractures, cancer, and cardiovascular disease) in populations that are not necessarily vitamin D deficient (i.e., they included general populations that may or may not be deficient). In 2012, the USPSTF recommended vitamin D supplementation for community-dwelling adults age 65 years or older at increased risk for falls (i.e., history of falls and mobility problems) to prevent future falls (B recommendation).1 The USPSTF examined the effects of vitamin D and calcium on fracture risk and concluded that there was insufficient evidence to assess the benefits and harms of vitamin D and calcium supplementation for the primary prevention of fractures in premenopausal adults (I statement). In noninstitutionalized postmenopausal women, there was insufficient evidence to assess the benefits and harms of daily supplementation with greater than 400 IU of vitamin D_3_ and 1,000 mg of calcium (I statement). The USPSTF recommended against daily supplementation with 400 IU or less of vitamin D_3_ and 1,000 mg calcium for the primary prevention of fractures in this population (D recommendation).3

The USPSTF also recently issued a recommendation statement on multivitamin and single vitamin supplementation for the primary prevention of cardiovascular disease and cancer.4 The recommendation was based on a review that included studies of vitamin D as part of multivitamins, as well as vitamin D given as a single tablet to persons who were likely receiving adequate nutritional vitamin D. The USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of the use of vitamin D (alone or as part of a multivitamin) for the prevention of cardiovascular disease or cancer (I statement).